# Appendix A: Research Team, Expert Panel, Technical Advisory Panel, and Peer Reviewers

## Research Team

David H. Hickam, MD, MPH, Principal Investigator

Professor, Department of Medicine and Division of Medical Informatics and Outcomes Research

Oregon Health & Science University

Portland Veterans Affairs Medical Center

Portland, Oregon

Susan Severance, MPH

Project Coordinator

Division of Medical Informatics and Outcomes Research

Oregon Health & Science University

Portland, Oregon

Adrianne Feldstein, MD, MS

Clinical Investigator

Center for Health Research

Kaiser Permanente

Portland, Oregon

Paul Gorman, MD

Associate Professor, Division of Medical Informatics and Outcomes Research

Oregon Health & Science University

Portland, Oregon

Leslie Ray, PhD, RN

Assistant Professor, Community Health Care

Systems Research

School of Nursing

Oregon Health & Science University

Portland, Oregon

Sherrie Schuldheis, PhD, RN

Director of Nursing Research

Portland VA Medical Center

Portland, Oregon

Kathryn Pyle Krages, AMLS, MA

Administrator, Oregon Evidence-based Practice Center

Division of Medical Informatics & Outcomes Research

Oregon Health & Science University

Portland, Oregon

Patty Davies, MS

Reference Librarian

Oregon Health & Science University

Portland, Oregon

Susan Wingenfeld

EPC Program Coordinator

Division of Medical Informatics & Outcomes Research

Oregon Health & Science University

Portland, Oregon

William R. Hersh, MD

Associate Director Oregon Evidence-based Practice Center

Professor and Head, Division of Medical Informatics & Outcomes Research

Oregon Health & Science University

Portland, Oregon

Mark Helfand, MD, MPH

Director, Oregon Evidence-based Practice Center

Associate Professor, Medicine and Medical Informatics & Outcomes Research

Oregon Health & Science University

Portland, Oregon

## Expert Panel

Doug Bonacum, CSP, CIH

Vice President, Safety Management

Kaiser Permanente

Oakland, CA

Anthony Ciavarelli, EdD

Professor, School of Aviation Safety

Naval Postgraduate School

Salinas, CA

Martha S. Gerrity, MD, MPH, PhD, FACP

Associate Professor, Department of Medicine

Oregon Health & Science University

Portland Veterans Affairs Medical Center

Portland, OR

Michael A. Heumann, MPH

MA Manager

Environmental Occupational Epidemiology

Oregon Health Division

Portland, OR

Joseph Hurrell, PhD

Associate Director of Science

National Institute for Occupational Health and Safety

Centers for Disease Control and Prevention

Cincinnati, OH

Melvin Kohn, MD, MPH

State Epidemiologist and Assistant Administrator

Oregon Health Division

Portland, OR

Loukia Loukopoulos, PhD, Lt USNR

Research Scientist

Aerospace Human Factors Research Division

NASA Ames Research Center

Moffett Field, CA

P.J. Maddox, PhD, RN

Assistant Dean for Health Sciences and Director of the Office of Research

Center for Health Policy and Ethics

George Mason University

Fairfax, VA

Pamela H. Mitchell, PhD, CNRN, FAAN

Elizabeth S. Soule Professor and Associate Dean of Research

School of Nursing

University of Washington

Seattle, WA

Misha Pavel, PhD

Professor and Director of the Center for Information Technology

Oregon Graduate Institute of Science and Technology

Oregon Health & Science University

Beaverton, OR

Anne Sales, PhD, MSN

Research Scientist

HSR&D Center of Excellence

VA Puget Sound Health Care System

Tumwater, WA

Patricia F. Uris, PhD, RN

Program Administrator

Colorado State Board of Nursing

Denver, CO

Yan Xiao, PhD

Associate Professor of Anesthesiology and Information Systems

Director, Human Factors and Technology Research

University of Maryland

Baltimore, MD

## Technical Advisory Panel

Anthony Ciavarelli, EdD

Professor, School of Aviation Safety

Naval Postgraduate School

Salinas, CA

Joseph Hurrell, PhD

Associate Director of Science

National Institute for Occupational Health and Safety

Centers for Disease Control and Prevention

Cincinnati, OH

Eric Larson, MD

Associate Dean for Clinical Affairs and Professor of Medicine and Health Services

University of Washington

Medical Director

University of Washington Medical Center

Seattle, WA

Robert Petzel, MD

Upper Midwest Health Care Network

Acting Director Network 23

Department of Veterans Affairs

Minneapolis, MN

Anne Sales, PhD, MSN

Research Scientist

HSR&D Center of Excellence

VA Puget Sound Health Care System

Tumwater, WA

Kaveh Shojania, MD

Department of Medicine

University of California, San Francisco

San Francisco, CA

## Peer Reviewers

### Individuals

Doug Bonacum, CSP, CIH

Vice President, Safety Management

Kaiser Permanente

Oakland, CA

Pamela H. Mitchell, PhD, CNRN, FAAN

Elizabeth S. Soule Professor & Associate Dean of Research

School of Nursing

University of Washington

Seattle, WA

Deborah Nadzam, PhD

Senior Investigator

Quality Institute

The Cleveland Clinic Foundation

Cleveland, OH

Patricia F. Uris, PhD, RN

Program Administrator

Colorado State Board of Nursing

Denver, CO

Yan Xiao, PhD

Associate Professor of Anesthesiology and Information Systems

Director, Human Factors and Technology Research

University of Maryland

Baltimore, MD

### Organizations

[underlined: American Association of Colleges of Pharmacy]

Elizabeth A. Flynn, PhD

Associate Research Professor

Center for Pharmacy Operations & Designs

Auburn University

Artesia, NM

[underlined: American College of Clinical Pharmacy]

Nancy Kimel, RPh

Patient Safety Specialist

Performance Improvement

Missouri Baptist Medical Center

St. Louis, MO

[underlined: American Medical Association]

Heidi Bossley, MSN, MBA

Policy Analyst

Clinical Quality Improvement

Chicago, IL

[underlined: American Nurses Association]

Patricia S. Yoder-Wise, EdD, RN, CNAA, FAAN

First Vice President, ANA

Professor, School of Nursing

Texas Tech University Health Sciences Center

Lubbock, TX

[underlined: American Nurses Association]

Rose Marie Martin, BSN, RN, OCN

Director, ANA Board of Directors

James Cancer Hospital

Ohio State University

Galloway, OH

### Federal Agencies

[underlined: Agency for Healthcare Research and Quality]

David Atkins, MD, MPH

Chief Medical Officer

Center for Practice and Technology Assessment

Rockville, MD

[underlined: Agency for Healthcare Research and Quality]

Ronda G. Hughes, PhD, RN, MHS

Center for Primary Care Research

Rockville, MD

[underlined: Institute of Medicine]

Ann E. K. Page

Senior Program Officer

Board on HCS

Washington, DC

[underlined: Occupational Safety and Health Administration]

Sheila Brown Arbury, RN, MPH

Office of Occupational Health Nursing

Washington, DC