# Evidence Tables

Evidence Table 1. Studies Evaluating Short Stature Secondary to Medical Impairment Part I

Author, Year | Demographics | Inclusion Criteria | Exclusion Criteria | Disease/Condition Type (N) | Study Design (Duration)
Abbott 1982 82277019 | Location: US | Short stature due to growth hormone deficiency and/or other pituitary hormone deficiency | None | Isolated short stature | Prospective cross-sectional cohort
| Setting: In-patient
| Mean age: 11±3 y
| Age range: 4–18 y
| Mean height: ND
| Height range: 81–132 cm
| Male: 64%
| Race: White 82%, Black 18%
| Enrolled: ND
| Evaluated: 11
| Number of sites: 1
Angehrn 1979 80093987 | Location: Switzerland | Russell-Silver syndrome: | None | RSS | Prospective longitudinal cohort
| Setting: ND | Height < 2 SDS
| Mean age: 4±2.2 y | Low normal growth velocity
| Age range: ND | Low birth weight
| Mean height, SDS: -4.4±1.0 | Moderate bone age retardation
| Male: 80% | Small triangular face and skull of large appearance
| Race: ND
| Enrolled: ND
| Evaluated: 20
| Number of sites: 1
Frisch 1990 90350511 | Location: Austria | Isolated GH deficiency, or Multi-pituitary hormone deficiency | None | GH deficiency | Prospective cross-sectional
| Setting: Clinic
| Mean age: 12±3 y
| Age range: 6.8–15.7 y
| Mean height, SDS: -2.5±0.9
| Height range, SDS: -4.5 to -0.9
| Male: 67%
| Race: ND
| Enrolled: ND
| Evaluated: 23
| Number of sites: 1
Gordon 1984 84214634 Gordon 1982 82268405 | Location: US | [underlined: Cases] - Constitutional short stature <5^th^ percentile height | [underlined: Cases] - Abnormal GH studies | Isolated short stature | Prospective cross-sectional cohort
| Setting: Psychiatric history clinic | Skeletal maturation delayed > 13 months | Psychiatric history
| Mean age: | Height velocity < 4 cm/y | [underlined: Controls] - Psychiatric history
| Cases 10±2.2 y | [underlined: Controls] - Normal height
| Controls 10±21. y | Matched for age, IQ, SES and sex
| Age range:
| Case 6–12 y
| Control 6–12 y
| Mean height, SDS: <5^th^ percentile
| Male: 83%
| Race: ND
| Mean SES: 3.5 (Hollinghead)
| Enrolled: ND (23 controls)
| Evaluated: 24 (23)
| Number of sites: 1
Holmes 1986 Holmes 1985 86060101 | Location: US | Height < -2 SDS | Additional medical diagnoses (e.g., IDDM) | Isolated short stature: | Prospective longitudinal cohort
| Setting: Pediatric endocrinology clinic | Patients at pediatric endocrinology clinic | | GH deficiency (17) | (Mean 3.1 y Range 2.2–4.0 y)
| Mean age, initial: 12 y | | | Constitutional delay (21)
| Mean age, follow-up: 15 y | | | Turner syndrome (9)
| Age range: ND
| Mean height, SDS: < -2
| Male: ND
| Race: ND
| SES: Middle class 21%
| Enrolled: 76
| Evaluated: 47
| Number of sites: 1
Kranzler 2000 20102780 | Location: US | [underlined: Referred Cases] - Height < 5^th^ percentile | IQ < 75 | Isolated short stature | Prospective cross-sectional cohort
| Setting: Region | Pediatric endocrinology clinics (n=27) | Serious psychiatric or medical problem
| Mean age: 10±1.4 y | [underlined: Non-referred] - Identified in local public schools as shortest 10% of class (n=34) | English not primary language
| Age range: 6–12 y | [underlined: Controls] - Height in middle 50%
| Mean height, SDS: | At local public schools
| Referred -2.7±1.0
| Non-referred -1.7±0.5
| Controls +0.1±0.4
| Height range, SDS:
| Referred -4.5 to -1.3
| Non-referred -3.2 to -1.3
| Controls -0.7 to +0.7
| Male: 51%
| Race: ND
| Enrolled: ND
| Evaluated: 61 (29 controls)
| Number of sites: 2
Lai 1994 95243689 | Location: UK | Russell-Silver Syndrome (met 3 of 5 criteria) | None | RSS | Prospective cross-sectional
| Setting: Clinic | Age 6–12 y
| Mean age: 9±2 y
| Age range: ND
| Mean height, SDS: -2.2±1.5
| Male: 80%
| Race: White 95%; West Indian 5%
| SES: 80% Middle-class or higher
| Enrolled: 30
| Evaluated: 25
| Number of sites: 3
McCauley 1987 87161055 McCauley 1986 86141341 | Location: US | [underlined: Cases] - Turner syndrome | Verbal IQ < 79–80 | Turner syndrome (17) | Prospective cross-sectional cohort
| Setting: Pediatric endocrinology clinic | Followed at Endocrine and Genetics Clinics | | Isolated short stature (16)
| Mean age: | [underlined: Controls] - Girls with height < 5^th^ percentile from cause other than Turner syndrome
| Turner 13±2.4 y | Followed at Endocrine and Genetics Clinics
| SS 13±2.8 y
| Age range: ND
| Mean height:
| Turner 52±5.0 in
| SS 53±4.5 in
| Male: 0%
| Race: White 94%, Black 6%
| SES:41±16 (Hollingshead revised)
| Enrolled: 23 (22 controls with SS)
| Evaluated: 33 total
| Number of sites: 1
Meyer-Bahlburg 1978 78184456 | Location: US | Isolated growth hormone deficiency, or Multiple hormone deficiency | None | Isolated growth hormone deficiency (9 total) | Prospective cross-sectional cohort
| Setting: Pediatric endocrine clinic | | | Multiple hormone deficiency (13 total)
| Mean age:
| GH def 12 y
| Multi-hormone def 13 y
| Age range:
| GH def 4–18 y
| Multi-hormone def 6–18 y
| Mean height, SDS:
| GH def -3.6
| Multi-hormone def -3.9
| Height range, SDS:
| GH def -4.8 to -2.4
| Multi-hormone def -6.0 to -1.9
| Male: 73%
| Race: ND
| Enrolled: 29
| Evaluated: 22 (age ≤ 18 y; 29 total)
| Number of sites: 1
Pollitt 1964 | Location: US | Significant short stature thought to be due to growth hormone deficiency - either pan-hypopituitary or isolated | None | Isolated short stature | Prospective cross-sectional cohort
| Setting: Endocrine clinic | Pediatricians thought were well-adjusted psychologically and had cooperative parents
| Mean age: ND
| Age range: 3–16 y
| Mean height: ND
| Height range: 70–126 cm
| Male: 40%
| Race: ND
| Enrolled: ND
| Evaluated: 15
| Number of sites: 1
Robinson 1983 84052395 | Location: US | Monosomy X karyotype (45, X) and partial monosomy X | None | Turner Syndrome | Prospective cross-sectional cohort
| Setting: Region | | | Monosomy (6)
| Mean age: ND | | | Partial monosomy (3)
| Age range: 7–15 y
| Mean height: ND
| Male: 0%
| Race: ND
| Enrolled: 9
| Evaluated: 9
| Number of sites: ND
Ross 1997 97320537 | Location: US | Turner syndrome, confirmed by karyotyping | Estrogen treatment | Turner syndrome | Prospective cross-sectional cohort (derived from RCT of GH treatment)
| Setting: ND | Age ≥ and <12 y | Androgen treatment
| Mean age: 9.5 y
| Age range: ND
| Mean height: ND
| Male: 0%
| Race: 87% White
| SES: 47 (Hollingshead)
| Enrolled: ND
| Evaluated: 40
| Number of sites: 2
Rovet 1985 | Location: Canada | Height more than 2 SD below mean | History of familial short stature | Isolated short stature | Prospective cross-sectional
| Setting: Clinic
| Mean age: 14±1 y
| Age range: ND
| Mean height: 139±9 cm
| Male: 100%
| Race: ND
| Enrolled: 27
| Evaluated: 25
| Number of sites: 1
Siegel 1986 | Location: US | Idiopathic hypopituitarism | Deprivation dwarfism | Isolated short stature | Prospective cross-sectional cohort
| Setting: Endocrinology clinic | | Craniopharyngioma | GH def (28)
| Mean age: 12±2.3 y | | Age < 6 y | Multiple hormone def (14)
| Age range: 6–16 y | | IQ < 30
| Mean height, SDS: < -2
| Male: 71%
| Race: ND
| SES, Social position: High 5%, High average 21%, Average 31%, Low average 33%(14), Low 10%
| Enrolled: 53
| Evaluated: 42
| Number of sites: 2
Siegel 1994 | Location: US | [underlined: Cases] - Height < 3^rd^ percentile | Known mental impairment | Isolated short stature | Prospective cross-sectional cohort
| Setting: Endocrinology clinic | [underlined: Controls] - Normal height | Severe psychiatric | GH Def (87)
| Mean age: | | Chronic medical illness | Idiopathic SS (90)
| GHD 11±2.7 y | | Non-English speaking
| ISS 11±2.6 y
| Control 11±2.8 y+ | | Short stature secondary to systemic disease, tumor, or genetic abnormalities
| Age range: ND
| Mean height, SDS:
| GHD -2.7±0.6
| ISS -2.8±0.6
| Control +0.1±0.9
| Male: 75%
| Race: White 91%
| Enrolled: 177 (90 controls)
| Evaluated: 177 (90)
| Number of sites: 27
Siegel 1998 98356098 | Location: US | [underlined: Cases] - Girls with Turner syndrome, GH deficiency, or idiopathic short stature | Did not follow through with 3 y of GH therapy | Turner syndrome (22) | Prospective longitudinal cohort
| Setting: Clinic | [underlined: Controls] - Matched for age and socioeconomic status | | GH deficiency (13) | (3 y)
| Initial mean age: 10 y | | | Idiopathic short stature (12)
| Control 11 y
| Initial mean height:
| TS 120±13 cm
| GHD/ISS 125±12 cm
| Control 145±17 cm
| Male: 0%
| Race: ND
| Enrolled: 88 (Controls 67)
| Evaluated: 47 (25)
| Number of sites: ~27
Skuse 1997 Gilmour 1996 96408881 Skuse 1994 95252652 | Location: UK | [underlined: Cases] - Height < 5th percentile (< -2 SDS) | [underlined: Cases] - Bone age delayed > 2 y | Isolated short stature (15) | Prospective cross-sectional cohort
| Setting: Growth clinics | Height velocity over the last year above -1.5 SDS | Medical treatment for growth retardation | Russell-Silver syndrome (7)
| Mean age: | Age 6–11 y | Russell-Silver children who had IQ < 72
| Case 8±1.5 y | Prepubertal
| Control 9±1.4 y | [underlined: Controls] - From each case's school class, matched for age, sex, and SES
| Age range:
| Case 6–11 y
| Control 2–11 y
| Mean height, SDS:
| Case -2.5±0.3
| Control -0.3±1.1
| Male: 72%
| Race: ND
| SES (Parent profession): 59%
| advantaged/professional ; 14%
| clerical/craft; 14% manual
| Enrolled: 31 (25 controls)
| Evaluated: 22 (22)
| Number of sites: 2
Stathis 1999 20099119 | Location: Australia | [underlined: Cases] - Height < 3^rd^ percentile | PPVT-R score < 50 | Isolated short stature | Prospective cross-sectional cohort
| Setting: Region | Age 4–6 y | Cerebral palsy
| Mean age: 5.5 y | [underlined: Controls] - Height between 10^th^ and 90^th^ percentile | Other serious neurological disorder
| Age range: 4–6 y | Age 4–6 y
| Mean height: <3^rd^ percentile
| Male: 53%
| Race: ND
| Enrolled: ND
| Evaluated: 113 (3,178 controls)
| Number of sites: 1
Steinhausen 1976 77086274 | Location: Germany | [underlined: Cases] - Height < 3^rd^ percentile | None | Isolated short stature | Prospective cross-sectional cohort
| Setting: Inpatient | [underlined: Controls] - Age and sex matched from local schools with “normal” stature | | GH deficiency (16)
| Mean age: | | | Constitutional delay (16)
| SS 14±2.7 y
| Control 14±2.6 y
| Age range:
| SS 9–18 y
| Control 9–18 y
| Mean height, SDS: <3^rd^ percentile
| Male: 81%
| Race: ND
| SES: Lower class 59%, Middle class 41%
| Enrolled: ND
| Evaluated: 32 (32 controls)
| Number of sites: 1
Tanner 1975 75217260 | Location: UK | Russell-Silver syndrome | None | RSS | Unclear
| Setting: Growth disorder clinic | Height < -2 SDS
| Mean age: ND | Adjusted birth weight ≥ 2 SD below the mean of the Tanner-Thomson standard
| Age range: 1.4–10 y
| Mean height, SDS: -3.6
| Height range, SDS: -6.3 to -2.2
| Male: 56%
| Race: ND
| Enrolled: 39
| Evaluated: 39
| Number of sites: 1
Voss 1994 Voss 1991 92151680 Downie 1997 97159125 Downie 1996 96408882 | Location: UK | [underlined: Cases] - Height <3^rd^ percentile, starting school between 1985 and 1986 | [underlined: Cases] - Organic disease (e.g., Turner syndrome or celiac disease); Immigrant parents | Isolated short stature | Prospective longitudinal cohort (up to 9 y)
| Setting: Region | [underlined: Controls] - From same school class | [underlined: Controls] - None
| Mean age: ND | Height between 10^th^ and 90^th^ percentile
| Age range: Data at ages 5–6 y, 7–9 y, 11–13 y, mean 13 y (see comments) | Matched for age, sex and school class
| Mean height (age 5–6 y), SDS:
| Case -2.3±0.3
| Control +0.1±0.6
| Mean height (mean age 13, No GH): Case 139 cm
| Control 155 cm
| Male: 54%
| Race: ND
| SES: Class I/II 20%; Class III 49%; Class IV/V 31%; 25% unemployed fathers
| Enrolled: 140 (140 controls)
| Evaluated: 140 (140) (See comments)
| Number of sites: 1
Wilson 1986 | Location: US | National Health Examination Survey (NHES): | None | Isolated short stature | Prospective cross-sectional cohort
| Setting: ND | 1963-1965: 7,119 children 6–11 y
| Mean age: ND | 1966-1970: 6,768 adolescents 12–17 y
| Age range: 6–17 y
| Mean height, SDS: ND
| Male: ND
| Race: ND
| Enrolled: ND
| Evaluated: 6,768–7,119 (all heights)
| Number of sites: ND
Young-Hyman 1986 | Location: US | Children with SS who presented to endocrine clinics for evaluation | Chronic health problem | Isolated short stature | Prospective cross-sectional cohort
| Setting: Endocrine clinic | | Mental disability
| Mean age: 12 y
| Age range: ND
| Mean height, SDS: ND
| Male: 78%
| Race: ND
| SES: Upper middle class
| Enrolled: 27
| Evaluated: 27
| Number of sites: 1

Evidence Table 1. Studies Evaluating Short Stature Secondary to Medical Impairment Part II

Author, Year | Predictors | Predictor Measures | Outcomes | Outcome Measures
Abbott 1982 82277019 | Isolated short stature | ND | Cognitive/Academic | IQ (WISC)
| | | | Academic achievement (WRAT)
| | | | Visual-motor skills (Developmental Test of Visual-Motor Integration)
Angehrn 1979 80093987 | Russell-Silver syndrome | Height < -2 SDS, low normal growth velocity, low birth weight for gestational age, moderate bone age retardation, typical small triangular face, and large skull | Cognitive/Academic | IQ (ND)
| | | Psychomotor | Psychomotor development (Denver developmental screening test)
Frisch 1990 90350511 | Isolated short stature/GH deficiency | GH peak < 5 ng/ml in 2 stimulation tests | Cognitive/Academic | IQ (HAWIK & HAWIE, German version of Wechsler IQ test)
| Hypopituitary GH deficiency | | | Academic performance (Repetition of grade)
| | | Behavioral/Psychological | Personality structure tests (Freiburger Personality Questionnaire, Giessen Test)
| | | | Sociability, Social activity, Neuroticism (Hamburger Neuroticism-Extroversion Scales)
Gordon 1984 84214634 Gordon 1982 82268405 | Isolated short stature | Height < 5^th^ percentile | Cognitive | IQ (WISC-R)
| | | | Math, reading, comprehension (PIAT)
| | | Behavioral | School adjustment, Internalization (CBCL - Teacher)
Holmes 1986 | Isolated short stature: CGD (21) | Retarded bone age, growth velocity within 2 SD of normal for age, projected adult height normal | Cognitive/Academic | IQ (WISC-R)
Holmes 1985 86060101 | GHD (17) | Maximum GH ≤ 7 ng/ml on 9 samples
| TS (9) | ND
Kranzler 2000 20102780 | Isolated short stature | Referred: Height < 5^th^ percentile | Cognitive/Academic | Verbal and non-verbal intelligence (K-BIT)
| | Non-referred: Height < 10^th^ percentile of class | | Educational achievement (KTEA brief form)
| | | Behavioral | Adaptive and problem behaviors (BASC - Teacher)
Lai 1994 95243689 | Isolated short stature | Russell-Silver syndrome | Cognitive/Academic | IQ (WISC)
| | | | Reading comprehension (Neale Analysis of Reading Ability)
| | | | Arithmetic comprehension (ND)
| | | | Cognitive processing (Matching Familiar Figure Test)
| | | | Special educational needs
McCauley 1987 87161055 McCauley 1986 86141341 | Turner syndrome | Karyotype showing absence of all or part of an X chromosome | Cognitive | IQ (WISC)
| | | Behavioral | Behavior factor (Piers-Harris Scale - Children self-report)
| Isolated short stature | Height < 5^th^ percentile | Psychological | Depression (Children's Depression Inventory)
Meyer-Bahlburg 1978 78184456 | Isolated growth hormone deficiency, and multiple hormone deficiency | GH deficient or panhypopituitary | Cognitive | IQ (WISC)
Pollitt 1964 | Hypopituitary short stature | Panhypopituitary | Cognitive | IQ (WISC Scale for Children - age > 5 y)
| | Isolated GH deficiency
| | Turner syndrome
| | Primordial
| | Undiagnosed
Robinson 1983 84052395 | Turner Syndrome | 45, X monosomy or partial monosomy on karyotype from chromosomal exam of amniotic membrane | Cognitive | IQ (Wechsler Preschool and Primary Scale of Intelligence)
| | | | Language development (“A comprehensive speech and language evaluation”)
| | | Physical Development | Neuromuscular maturation (Bruininks-Oseretsky Test of Motor Proficiency)
Ross 1997 97320537 | Turner syndrome | Karyotype 45,X | Cognitive/Academic | IQ (WISC-R)
| | | | Academic achievement (WART - reading)
Rovet 1985 | Isolated short stature | SD from mean | Cognitive | IQ (WISC)
Siegel 1986 | Hypopituitary isolated short stature | GH secretion < 7 ng/dL, delayed bone age, growth < 4 cm in past year, height < -2 SDS or below the 3^rd^ percentile | Cognitive/Academic | IQ (WISC-R)
| | | | Academic achievement (WRAT)
| | | | Visual-motor integration skills (Bender Visual-Motor Gestalt Test: a significant visual-motor integration deficit was defined as if the developmental score was < 16^th^ percentile, and four or more errors were significant indicators of brain injury)
Siegel 1994 | Isolated short stature GH deficient Idiopathic short stature | Height < 3^rd^ percentile | Cognitive/Academic | IQ (Slosson Intelligence Test)
| | | | Academic achievement (WRAT - revised)
Siegel 1998 98356098 | Isolated short stature | Turner syndrome GHD/ISS | Cognitive/Academic | IQ (Slosson Intelligence Test)
| | | | Academic achievement (WRAT - revised)
Skuse 1997 Gilmour 1996 96408881 Skuse 1994 95252652 | Isolated short stature and Russell-Silver syndrome | Height < -2 SDS | Cognitive | IQ (WISC for children - version III)
| | | Behavioral | Competence and self-concept (Harter Self Perception Profile for Children, Harter Pictorial Scale of Perceived Competence and Social Acceptance for Young Children, CHIPS)
Stathis 1999 20099119 | Isolated short stature | Height < 3^rd^ percentile | Cognitive | Receptive vocabulary (PPVT-R, which correlates closely with intellectual ability)
Steinhausen 1976 77086274 | Isolated short stature | Height < 3^rd^ percentile GH deficiency or no endocrine disease | Cognitive/Academic | Primary mental abilities (LPS)
| | | | IQ (WISC)
| | | | Academic performance (Grade level for age)
| | | | School achievement (ND)
| | | Behavior | Extraversion and Neuroticism (Hamburg Neuroticism Extraversion Scale)
Tanner 1975 75217260 | Russell-Silver syndrome | Height < -2 SDS, adjusted birth weight< -2 SDS, no other obvious cause of short stature | Cognitive/Academic | IQ (ND)
| | | | Academic achievement (Grade repetition)
Voss 1994 Voss 1991 92151680 Downie 1997 97159125 Downie 1996 96408882 | Isolated short stature | Height < 3^rd^ percentile | Cognitive/Academic | IQ (Short form IQ scale of the British Ability Scales)
| | | | Attainment (Word reading and basic number skills scales of British Ability Scales)
| | | Behavioral | Behavioral problems (Rutter's Behavior Questionnaire - Teacher)
| | | | Locus of control (Nowicki and Strickland scale)
Wilson 1986 | Isolated short stature | Height < 5^th^ percentile | Cognitive/Academic | IQ (WISC)
| | | | Academic achievement (WRAT)
Young-Hyman 1986 | Isolated short stature | ND | Cognitive | IQ (WISC-R)
| | | | Visual-motor integration skills (Bender Visual-Motor Gestalt Test)

Evidence Table 1. Studies Evaluating Short Stature Secondary to Medical Impairment Part III

Author, Year | Associations found | Potential Biases | Comments
Abbott 1982 82277019 | Mean (SD) IQ of children with SS due to pituitary hormone deficiency (n=11) was Full Scale = 88 (17), Verbal = 89 (20), Performance = 89 (16), Reading = 88 (17), Spelling = 85 (14), and Arithmetic = 83 (15) | Compared to population norms | Study was government and hospital funded
| Mean (SD) WRAT scores for children with SS (n=11) were Reading = 88 (17), Spelling = 85 (14), and Math = 83 (15)
| Visual-Motor Integration skills were significantly below average among children with SS
Angehrn 1979 80093987 | Mean (range) IQ for children with SS due to RSS (n=9) was 91 (38 to 110); 3 subjects had low IQs of 85, 83, and 38; an additional 5 subjects were “probably of normal intelligence” | Incomplete testing | No data on funding source
| Of subjects with RSS, 3 of these children had microcephaly; 3 children had sub-normal IQ, 2 of whom had microcephaly | IQ test used not reported
| More than half of the psychomotor activities on the Denver developmental screening test occurred at an age > 90^th^percentile in subjects with RSS (n=14) | Incomplete and unclear reporting
| | Small sample size for IQ data
Frisch 1990 90350511 | The median (range) IQ of children with GHD (n=23) were Full Scale = 115 (68–131), Performance = 114 (61–136), Verbal = 104 (72–128); full score and performance IQ were significantly higher than population norms; verbal IQ was similar to population norms | Compared to population norms | No data on funding source
| Performance Behavior (zeal and school aversion) was similar in children with GHD (n=20) compared to population norms | Reporting incomplete
| Sociability in children with GHD (n=20) than population norms; Social activity in children with GHD was similar to population norms (No further data)
| Emotional Stability (including mood, control, depression) in children with GHD was similar to population norms (No further data)
| Delayed Schooling was more common in children with multiple pituitary hormone deficiencies and SS (33%) than normal population (2.1%)
Gordon 1984 84214634 Gordon 1982 82268405 | Mean (SD) IQ for children with SS due to constitutional delay (n=24) were total 108 (14), verbal 107 (16), and performance 108 (14). | Comparisons of cognitive function between short children and controls of questionable value since controls were matched for overall IQ | Study was government and private funded
| Mean (SD) scores on PIAT for children with SS (n=24) were math 103 (16), reading recognition 102 (11), and comprehension 102 (11); these were, similar to scores among children with normal stature who were matched by IQ (n=23): 103 (9.6), 102 (7.5), and 103 (10), respectively | No outline of the statistical analyses used in the paper; therefore, it is hard to evaluate the significance | There is no evidence that these behavior problems constitute a disability
| Mean (SD) teacher CBCL scores for children with SS (n=24) were total 31.2 (26.5) and for controls (n=23) 27.5 (27.6); conduct problem scores were 22.6 (4.3) and 24.1 (6.8), respectively; inattentive/passive 12.7 (4.8) and 12.1 (4.8), respectively; hyperactive 13.7 (5.9) and 11.9 (4.3), respectively; and socialization 14.7 (2.5) and 14.3 (3.0), respectively | | The subjects and controls were matched for IQ and had equal school performance
Holmes 1986 Holmes 1985 86060101 | Mean (SD) Verbal IQ in children with isolated SS (n=47) was 102 (13); among these children, those with GH deficiency (n=17) verbal IQ was 97 (13), those with constitutional delay (n=21), 104 (14) and those with TS (n=9), 103 (14); these were all similar to population norms | 40% non-participation rate | No data on funding source
| | Those declining participation more likely to have constitutional delay and to have received optimal treatment benefits
| | Study presented only partial data, focusing on significant results
| | IQ compared only to population norms
Kranzler 2000 20102780 | Mean (SD) IQ scores of referred children with SS (n=27) were Verbal = 101 (16), Matrices = 106 (14), and Composite = 103 (14); of non-referred children with SS (n=34) were Verbal = 104 (15), Matrices = 105 (14), and Composite = 105 (14); and of normal controls (n=29) were verbal = 110 (12), matrices = 110 (17), and composite = 112 (13); | Study of cognitive skills excluded children with low IQ | Study was government, privately and pharmaceutical funded
| Post hoc analysis found that referred short children had significantly lower Verbal IQ than normal controls; other comparisons were statistically similar | Definition of non-referred short children sample vague
| Mean (SD) composite and spelling Educational Achievement (KTEA) scores were similar for referred short children, 106 (18) and 105 (15), non-referred short children, 107 (19) and 104 (19); and, controls, 114 (17) and 102 (17). | Predominantly post hoc analyses
| Mean (SD) mathematics and reading KTEA scores were lower for referred short children, 107 (21) and 104 (15) and for non-referred short children, 105 (19) and 106 (18) than for controls, 121 (20) and 115 (18).
| Teacher ratings on BASC for Externalizing behavior, Internalizing behavior, School Problems composite, Behavior symptoms index and Adaptive Skills composite were each similar among referred short children, non-referred short children and normal controls
Lai 1994 95243689 | The mean (SD) IQ of children with RSS (n=25) were Full Scale = 86 (24), range 46–130, Verbal = 89 (23), range 52–141, and Performance = 84 (24), range 47–127; these were significantly lower than population norm, 100 (15) | Compared to population norms and controls from prior study | No data on funding source
| In children with RSS, larger Head Circumference was significantly associated with higher IQ (r=0.5–0.6)
| Reading Comprehension in children with RSS was delayed by a mean of 15.4 months; Arithmetic Competence was delayed by a mean of 7 months
| Cognitive Processing, measured by reaction time and error scores in children with RSS (n=22) was similar to normal controls from an earlier study (n=90)
| Special Education needs were necessary in 9 (36%) children with RSS, primarily in reading and language skills; 12 (48%) children received speech therapy
McCauley 1987 87161055 McCauley 1986 86141341 | Mean verbal and performance IQ (SD) for girls with TS (n=17) were 95 (11) and 91 (10), respectively; those IQ (SD) scores for girls with SS not due to TS (n=16) were 100 (12) and 108 (14), respectively. | Excluded children with low IQ | Study was hospital funded
| The difference in performance IQ between the groups was significant; however, both groups had verbal and performance IQ scores within 1 SD of the mean
| Girls with TS had significantly lower performance on arithmetic, digit span, picture completion, object assembly, and coding subscales than girls with SS; performance on other subscales were similar for the two groups
| Self-reported Piers-Harris behavior factor and Children's Depression Inventory scores were similar in girls with TS and girls with SS;
| “Although the TS children indicated low self-concept they did not endorse features of clinical depression.”
Meyer-Bahlburg 1978 78184456 | Mean IQ of children with isolated GHD (n=13) was 101, and of children with multiple hormone deficiency (n=9) was 102 | Compared to population norms | No data on funding source
| Patients with multiple hormone deficiencies have somewhat lower IQs than patients with isolated GHD, after controlling for SES
Pollitt 1964 | Mean (SD) IQ for children over age 5 with SS (n=13) were total 103 (16), verbal 103 (15), and performance 102 (16); | Compared to population norms | No data on funding source
| These IQ scores were not significantly different than normal IQ | | Descriptive study
Robinson 1983 84052395 | Mean (SD) IQ of girls with TS (n=9) were Full Scale = 87 (20), Verbal = 93 (25), and Performance = 83 (12). Siblings (n=17) had significantly higher Full Scale IQ = 111 (15) and Performance IQ = 107 (14), but similar Verbal IQ =113 (15). | Small sample | No data on funding source
| The TS girls were at non-significantly greater risk of developing Language Disorders than their unaffected siblings | Handwriting problems not defined
| | Methods and results not fully reported
| | Most analyses were done for all subjects (girls and boys with various sex chromosomal anomalies) together
Ross 1997 97320537 | Mean (SD) Full scale IQ in girls with TS with GH treatment (n=20) was 98 (14) and without GH (n=20) was 99 (15) | Indirectly compared to population norms | Study was government funded
| Mean (SD) Academic Achievement (WART) reading score in girls with TS with GH treatment (n=20) was 100 (14) and without GH treatment (n=20) was 97 (17), similar to population norms
Rovet 1985 | The mean IQ of boys with SS (n=25) were Verbal = 98, Performance = 102, and Full Scale = 101 | Compared to population norms | Study was hospital funded
Siegel 1986 | Mean (SD) IQ for children with hypopituitary SS (n=42) were verbal 94 (18), range 52 to 127, and performance 94 (16), range 49–123; Both the verbal and performance IQ were significantly below normal IQ | Compared to population norms | Study was hospital funded
| Mean (SD) WRAT scores for children with hypopituitary SS (n=42) were reading 96 (16.9), range 52 to 131, and math 85 (13.9), range 52–126; | Excluded children with severe mental retardation
| The WRAT reading score was in normal range, but the WRAT math score was significantly below the normal score (100)
| Significant visual-motor integration deficits occurred in 11 (26%) of children with hypopituitary SS (n=42), indicating “a significant number of hypopituitary youngsters have visual-motor integration problems.”
Siegel 1994 | Mean (SD) IQ for children with GHD (n=87) was 110 (16) for children with ISS (n=90) was 107 (19); compared to 116 (15) for control children (n=90); | Excluded children with “known mental impairment” | No data on funding source
| Significantly more GHD children (9%) and ISS children (18%) had IQs < 90, than control children (3%)
| Mean (SD) WRAT scores for children with GHD (n=87) were reading 103 (18), spelling 98 (17), and math 99 (17); for children with ISS (n=90) were reading 102 (18), spelling 98 (17), and math 96 (21); and for control children (n=90) were reading 105 (14), spelling 103 (14), and math 105 (16)
| Significantly more ISS children (22%) had a skill deficit in math (score < 80) compared to GHD (10%) and normal children (7%)
Siegel 1998 98356098 | The mean IQ of girls with TS (n=22) was 102 (11), and with GHD/ISS (n=25) was 105 (15); these were not significantly different than controls (n=25) with 109 (17). | CBCL completed by parent, typically mother | Study was pharmaceutical company funded
| Mean (SD) WRAT scores for children with TS (n=22) were reading 98 (15), spelling 95 (19), and math 90 (16); for children with GHD/ISS (n=25) were reading 105 (18), spelling 99 (21), and math 102 (22); and for control children (n=25) were reading 98 (16), spelling 100 (15), and math 99 (20). No significant differences among groups.
Skuse 1997 Gilmour 1996 96408881 Skuse 1994 95252652 | Mean (SD) IQ of children with SS (n=22) were Full Scale = 96 (19), Verbal = 95 (20), and Performance = 97 (17); for normal children (n=22), Full Scale = 107 (17), Verbal = 105 (17), and Performance = 108 (17); | Excluded Russell-Silver Syndrome children who had low IQ | Study was pharmaceutical funded
| Children with SS had statistically lower Full Scale IQ and Performance IQ than controls, but statistically similar Verbal IQ | Incomplete reporting of results.
| Conduct, Global, Physical, Athletic, Social, and Scholastic competencies measured by Teacher CBCL were similar among SS children (n=17) and controls | Teacher CBCL completed only on subset of subjects
Stathis 1999 20099119 | Mean receptive vocabulary score on PPVT-R test for boys with SS (n=60) was 92, which was significantly lower for normal height boys, 98 (n=1,660) | Study of correlation of PPVT-R score to height excluded those with score < 50 | No data on funding source
| Mean receptive vocabulary score on PPVT-R test for girls with SS (n=53) was 92, which was significantly lower for normal height girls, 95 (n=1,508) | | PPVT-R score was adjusted for maternal age, education, non-English speaking background, age at evaluation, maternal depression at birth and maternal height
Steinhausen 1976 77086274 | Mean IQ for children with SS (n=32) were total 103, verbal 102, and performance 103. | Not all of the psychological tests are published and validated; the one well-known test (WISC) was used without data in control group | No data on funding source
| Primary mental abilities on LPS intelligence test were significantly different among children with SS (n=32) and controls (n=32) for only 2 of 14 measures of intelligence; Spatial orientation was 4.7 for SS children and 6.2 for controls; Speed of closure was 4.4 for SS children and 5.3 for controls | Many comparisons with some statistical significance but questionable clinical significance; the intelligence (LPS) and personality (CPQ) variables are not well defined
| Grade level was appropriate in 59% of children with SS (n=17); Academic achievement was adequate in 48% of SS children | No statistical comparison was done for social and coping behavior; and, school performance; Average scores only
| Among children with short stature (n=32) mean extraversion and neuroticism scores on HANES were 11.4 and 12.9, respectively. These were similar to controls (11.6 and 15.6, respectively). | No outline of how the subset 17 kids were selected
| | School achievement not defined
Tanner 1975 75217260 | Mean (SD) IQ for children with SS due to RSS (n=11) was 103 (21), range 70–130 | IQ test not described and performed in only a sub-sample | No data on funding source
| Of subjects with RSS and head circumference < 3^rd^percentile (n=18), 83% were at “normal” schools, 17% were at schools for educationally subnormal children (“usually IQ < 80”);
| Of subjects with head circumference > 3^rd^percentile (n=19), all were at normal schools
Voss 1994 Voss 1991 92151680 Downie 1997 97159125 Downie 1996 96408882 | Mean (SD) IQ in children aged 7–9 y with SS (n=140)was 102 (15.2) and for controls with normal height (n=140), IQ was 104 (14.1); there was no significant difference between the two groups; there was also no significant difference in Verbal scales, Non-verbal scales, Speed of Information Processing, or Reading or Number Attainment, after controlling for SES | None noted | Studies were hospital and pharmaceutical funded
| Behavior Disturbance (total Teacher RBQ score > 9) occurred in 29% of children aged 7–9 y with SS (n=132), and in 21% of control children (n=132); the difference was not significant; | | Downie studies included subsets of subjects in Voss studies; one examined subjects treated with GH; one examined untreated subjects
| Hyperactivity (Activity subscale score ≥ 3) occurred in 16% of SS children compared to 8% of control children (p=0.003); | | Different sized subsets of subjects, at different ages, analyzed in different articles
| Mean (SD) Total Behavior scale score for children with SS was 6.2 (6.2), compared to 5.1 (6.5) for control children (NS)
| Conduct subscale score was 1.2 (2.3) for children with SS, compared to 1.0 (2.1) for control children (NS)
| Emotional subscale score was 1.2 (1.4) for children with SS, compared to 1.2 (1.7) for control children (NS)
| Activity subscale score was 1.7 (2.1)for children with SS, compared to 1.1 (1.6) for control children (NS after controlling for SES)
| Mean (SD) IQ in children aged 13 y with SS, not treated with GH, (n=84–106 for different tests) and controls (n=93–119), were 103 (17) and 109 (16), respectively (p=0.005);
| Reading Attainment of 44.3 (8.8) and 47.9 (8.5), respectively (p=0.002);
| Math Attainment of 40.2 (7.2) and 43.5 (9.2), respectively (p=0.003);
| Locus of Control score of 16.6 (5.0) and 14.3 (5.1), respectively (p=0.001), Behavior score of 6.8 (7.5) and 5.3 (6.8), respectively (NS);
| The statistical significance of these differences were reduced, but remained significant, after controlling for SES
Wilson 1986 | Mean IQ (WISC) for children with SS, aged 12–17 (N~350) was 92 | Prevalence and correlation data only | Study was government funded
| Mean IQ (WRAT) for children with SS, aged 12–17 (N~350) was 91 | Incomplete reporting
| Among children of all heights, aged 6–11 (n=7,119), both WISC and WRAT scores showed a significant but small correlation with height (r=0.18, WISC; r=0.17, WRAT)
| Among children of all heights, aged 12–17 (n=6,768), both WISC and WRAT scores showed a significant but small correlation with height (r=0.20, WISC; r=0.19, WRAT)
| “The association between height and IQ scores is less among the subjects with a high family income”
Young-Hyman 1986 | Mean (SD) IQ for children with SS (n=27) was 110 (16), range was 85 to 142 | How significance was defined for perceptual-motor skill test was not outlined in the paper | No data on funding source
| Mean (SD) perceptual-motor skill for children with SS (n=27) was significantly delayed at 9.2 y (1.2 y), compared to chronological age 11.8 y

Evidence Table 2. Studies Evaluating Short Stature Secondary to Skeletal Dysplasia Part I

Author, Year | Demographics | Inclusion Criteria | Exclusion Criteria | Disease / Condition Type | Study Design Mean Duration (Range)
Alston 1983 | Location: UK | [underlined: Cases] - Osteogenesis imperfecta | None reported | Osteogenesis imperfecta | Prospective cross-sectional cohort
| Setting: Brittle Bone Society, Health Authorities | [underlined: Controls] - Same school class or neighborhood as cases, matched for age, sex and social class
| Mean age: ND
| Age range: 5–16 y
| Mean height: ND
| Male: ND
| Race: ND
| Enrolled: 40 (40 controls)
| Evaluated: 40 (40)
| Number of sites: ND
Apajasalo 1998 98163312 | Location: Finland | [underlined: Cases] - Diagnosis of skeletal dysplasia | [underlined: Cases] - Incomplete questionnaires | Skeletal dysplasia | Prospective cross-sectional
| Setting: Clinic | Age 12–15 y | | Achondroplasia
| Mean age: ND | [underlined: Controls] - Age-matched Helsinki elementary school pupils who completed the HRQOL questionnaire | | Cartilage hair hypoplasia
| Age range: 12–15 y | Age 12–15 y | | Diastrophic dysplasia
| Mean height: ND
| Male: 42%
| Race: ND
| Enrolled: 21 (239 controls)
| Evaluated: 19 (239)
| Number of sites: 1
Bailey 1971 72080259 | Location: US | Diagnosis of achondroplasia | None reported | Achondroplasia | Retrospective cross-sectional
| Setting: Clinic
| Mean age: ND
| Age range: 3 days – 72 y
| Mean height: ND
| Male: 51%
| Race: ND
| Enrolled: ND
| Evaluated: 41 (no data on number < 21 y)
| Number of sites: 1
Benson 1978 79027354 | Location: US | Diagnosis of osteogenesis imperfecta from 1924 to 1974 | Spine X-ray films not available | Osteogenesis imperfecta | Retrospective longitudinal case series (Mean [Range] 5 [0–17] y)
| Setting: Shriner's Hospital
| Mean age: ND
| Initial age range: 1 mo – 16 y
| Mean height: ND
| Male: 44%
| Race: White 94%; Black 6%
| Enrolled: 143
| Evaluated: 126
| Number of sites: 1
Bleck 1981 82026195 | Location: US | Diagnosis of osteogenesis imperfecta: congenita or tarda | Death | Osteogenesis imperfecta | Prospective longitudinal cohort (Mean [Range] 4 [1–15] y)
| Setting: ND | | Too young to enable a satisfactory follow-up
| Initial mean age: 9y | | Moved out of the state
| Follow-up mean age: 13 y
| Initial age range: 3 mo – 21 y
| Follow-up age range: 4–26 y
| Mean height: ND
| Male: ND
| Race: ND
| Enrolled: 30
| Evaluated: 24
| Number of sites: ND
Brinkmann 1993 94091382 | Location: Germany | [underlined: Cases] - Clinical and radiographic diagnosis of achondroplasia | None reported | Achondroplasia | Prospective cross-sectional
| Setting: Clinic | [underlined: Controls] - Closest sibling;
| Mean age: 9 y | Other causes of short stature
| Age range: ND | Matched for age, sex and SES
| Mean height: ND | Normal height children, matched for age, sex and SES
| Male: 47%%
| Race: ND
| SES: Primarily middle-class
| Enrolled: 30 (90 controls)
| Evaluated: 30 (90)
| Number of sites: 1
Cox 1982 83016754 | Location: US | Medically diagnosed osteogenesis imperfecta, types I, III or IV | History of head injury | Osteogenesis imperfecta | Prospective cross-sectional cohort
| Setting: Dept of Communicative Disorders | | Prior surgery
| Mean age: 10 y | | Treatment for ear disease Noise exposure (For current review, excluded those age ≥ 18 y)
| Age range: 4–17 y
| Mean height: ND
| Male: 53%
| Race: ND
| Enrolled: 30
| Evaluated: 30 (15 met criteria for current review)
| Number of sites: 1
Daly 1996 96219608 | Location: UK | Patients registered at OI clinic who had been recently seen | No reply to the questionnaire | Osteogenesis imperfecta | Prospective cross-sectional cohort
| Setting: Osteogenesis imperfecta clinic
| Mean age: 7.4 y
| Age range: 3.5–16.3 y
| Mean height: ND
| Male: 49%
| Race: ND
| Enrolled: 59
| Evaluated: 51
| Number of sites: 1
Engelbert 1997 | Location: Netherlands | Diagnosis of osteogenesis imperfecta | Parents declined to participate | Osteogenesis imperfecta | Prospective cross-sectional cohort
Possible overlap with Engelbert 1998, Engelbert 1999 Engelbert 2000 Engelbert 2001 | Setting: Children's hospital | Visit source hospital = 1 per year
| Mean age:
| Type I OI: 7.3±3.5 y
| Type III OI: 6.5±2.9 y
| Type IV OI: 9.1±5.0 y
| Age range:
| Type I OI: 2–16 y
| Type III OI: 2–12 y
| Type IV OI: 1–17 y
| Mean height: ND
| Male: 54%
| Race: ND
| Enrolled: 68
| Evaluated: 61
| Number of sites: 1
Engelbert 1998 98366964 | Location: Netherlands | Children with osteogenesis imperfecta who regularly attended a referral center | None reported | Osteogenesis imperfecta | Prospective cross-sectional cohort
Possible overlap with Engelbert 1997, Engelbert 1999 Engelbert 2000 Engelbert 2001 | Setting: Children's hospital
| Mean age: 8 y
| Age range: 1–15 y
| Mean height, SDS:
| Type I OI -1.6±1.3
| Type III OI -8.0±2.0
| Type IV OI -2.8±1.7
| Male: 47%
| Race: ND
| Enrolled: 47
| Evaluated: 47
| Number of sites: 1
Engelbert 1999 99381568 | Location: Netherlands | Diagnosis of osteogenesis imperfecta | Intramedullary fixation surgery within 6 months | Osteogenesis imperfecta | Prospective longitudinal cohort (Mean [Range] 1.2 [0.7–1.8] y)
Possible overlap with Engelbert 1997, Engelbert 1998 Engelbert 2000 Engelbert 2001 | Setting: Children's hospital | | Any other disability or impairment
| Mean age: | | Parents' refusal in follow-up
| Initial: 7.3±3.8 y | | Unable to be reached
| Follow-up: 9.4±3.6 y | | Surgical interventions in the last half year of the study
| Age range:
| Initial: 1–15 y
| Follow-up: 3–17 y
| Mean height: ND
| Male: 50%
| Race: ND
| Enrolled: 54
| Evaluated: 44
| Number of sites: 1
Engelbert 2000 20429012 | Location: Netherlands | Diagnosis of osteogenesis imperfecta | Too young to expect walking | Osteogenesis imperfecta | Retrospective cross-sectional cohort
Possible overlap with Engelbert 1997, Engelbert 1998 Engelbert 1999 Engelbert 2001 | Setting: Children's hospital | Completed questionnaire
| Mean age: 11.2±5.2 y
| Type I OI: 10.8±5.8 y
| Type III OI: 9.4±2.9 y
| Type IV OI: 13±4.6 y
| Age range: 1–28 y
| Type I OI: 1–28 y
| Type III OI: 5–15 y
| Type IV OI: 4–20 y
| Mean height: ND
| Male: 45%
| Race: ND
| Enrolled: 98
| Evaluated: 70
| Number of sites: 1
Engelbert 2001 21334060 | Location: Netherlands | Diagnosis of osteogenesis imperfecta | None reported | Osteogenesis imperfecta | Prospective cross-sectional cohort
Possible overlap with Engelbert 1997, Engelbert 1998 Engelbert 1999 Engelbert 2000 | Setting: Hospital
| Mean age: 12.6±3.2 y
| Age range: 8–16 y
| Mean height: ND
| Male: 50%
| Race: ND
| Enrolled: 40
| Evaluated: 40
| Number of sites: 1
Falvo 1973 74013834 | Location: US | Diagnosis of osteogenesis imperfecta | None reported | Osteogenesis imperfecta | Unclear
| Setting: ND
| Mean age: 13.5 y
| Age range: 4–34 y
| Mean height: ND
| Male: 27%
| Race: ND
| Enrolled: ND
| Evaluated: 11
| Number of sites: 1
Fowler 1997 97356792 | Location: US | Diagnosis of achondroplasia | None reported | Achondroplasia | Prospective cross-sectional
Possible overlap with Pauli 1995 | Setting: Bone dysplasia clinic
| Mean age: ND
| Age range: 1–60 months
| Mean height: ND
| Male: 48%
| Race: White 88%, Black 2%, Hispanic 3%, Korean/Asian/Indian 5%
| Enrolled: 93
| Evaluated: 37
| Number of sites: 1
Pauli 1995 95193803 | Location: US | Clinical diagnosis of achondroplasia | None reported | Achondroplasia | Prospective longitudinal (N = 53) and cross-sectional (N = 22) cohorts
Possible overlap with Fowler 1997 | Setting: Bone clinic | | | | (To age > 1 y)
| Mean age: ND
| Age range: Infants, young children
| Mean height: ND
| Male: 52%
| Race: White 85%; Black 3%; Hispanic 4%; Korean 7%; Asian Indian 1%
| Enrolled: 75
| Evaluated: 75
| Number of sites: 1
Hecht 1991 92152267 | Location: US | Infants with clinical diagnosis of achondroplasia | None reported | Achondroplasia | Prospective cross-sectional cohort
| Setting: Clinic
| Mean age: 15±5 mo
| Age range: 8.5–26 mo
| Mean height: ND
| Male: 46%
| Race: ND
| Enrolled: 13
| Evaluated: 13
| Number of sites: ND
Hunter 1998 98299528 | Location: Multinational | [underlined: Cases] - Diagnosis of primary skeletal dysplasia | None reported | Skeletal dysplasia | Prospective cross-sectional
| Setting: Clinic | Age < 16–18 y old (by site)
| Mean age: ND | [underlined: Controls] - Unaffected siblings
| Age range: ND
| Mean height: ND
| Male: 49%
| Race: White 100%
| Enrolled: 55 (37 controls)
| Evaluated: 55 (37)
| Number of sites: 6
Kuurila 2000 20379515 | Location: Finland | Diagnosis of osteogenesis imperfecta | Insufficient cooperation | Osteogenesis imperfecta | Prospective cross-sectional cohort
| Setting: Dept of clinical genetics | Age 4–16 y | No audiometry performed
| Mean age: 10 y | | Moderate mental retardation.
| Age range: 4–16 y
| Mean height: ND
| Male: 42%
| Race: White
| Enrolled: 60
| Evaluated: 45
| Number of sites: 1
Norimatsu 1982 82163323 | Location: Japan | Osteogenesis imperfecta | None reported | Osteogenesis imperfecta (congenita and tarda) | Retrospective longitudinal case series
| Setting: Children's Hospital | Treated from 1959 to 1980 | | | (Mean [Range] 7.6 [1–20] y)
| Initial mean age: ND | Followed by spinal x-ray
| Follow-up mean age: 15.5 y
| Initial age range: 12 d – 14 y
| Follow-up age range: 4–28 y
| Mean height: ND
| Male: 68%
| Race: (Japanese)
| Enrolled: 30
| Evaluated: 22
| Number of sites: 1
Poussa 1991 92054945 | Location: Finland | Diagnoses of diastrophic dysplasia | None reported | Diastrophic dysplasia | Prospective longitudinal cohort 13.5 y
| Setting: Genetics and bone clinics | Age ≤ 20 y
| Mean age: ND
| Age range: 6–20 y
| Mean height: ND
| Male: ND
| Race: White
| Enrolled: 101
| Evaluated: 38
| Number of sites: 2
Reid 1988 89193370 | Location: US | Achondroplasia | Seen only in orthopedics clinic (not in genetics clinic) | Achondroplasia | Prospective longitudinal cohort 20–45 mo
Possible overlap with Stokes 1988 | Setting: Genetics clinic | Age < 7 y
| Mean age: ND | Seen in genetics clinic
| Age range: < 7 y
| Mean height: ND
| Male: ND
| Race: ND
| Enrolled: 62
| Evaluated: 26
| Number of sites: 1
Stokes 1988 88110722 | Location: US | Achondroplasia | Acute medical or surgical problems | Achondroplasia | Prospective cross-sectional cohort
Possible overlap with Reid 1988 | Setting: Hospital, genetics clinic, LPA convention | | Hypochondroplasia
| Mean age: ND | | Technically unsatisfactory spirometry
| Age range: ND | | Too young to cooperate with spirometry
| Mean height: ND
| Male: 50%
| Race: ND
| Enrolled: 102 (including adults)
| Evaluated: 24 children
| Number of sites: 1
Reite 1972 72182015 | Location: US | Children with “severe” osteogenesis imperfecta | None reported | Osteogenesis imperfecta | Retrospective cross-sectional
| Setting: Clinic
| Mean age: ND
| Age range: 6–17 y
| Mean height: ND
| Male: ND
| Race: ND
| Enrolled: ND Evaluated: 12
| Number of sites: 2
Rogers 1979 79200737 | Location: US | Diagnosis of skeletal dysplasia leading to short stature | Syndromes of low-birth-weight dwarfism | Skeletal dysplasia and achondroplasia | Prospective cross-sectional cohort
| Setting: Pediatric clinic research unit | | Multiple malformations
| Mean age: ND | | Mucolipidosis or mucopolysaccharidosis
| Age range: 5 mo – 15 y | | Cardiac arrest
| Mean height: ND
| Male: ND
| Race: ND
| Enrolled: 68 Evaluated: 68
| Number of sites: 1
Ruiz-Garcia 1997 97346439 | Location: Mexico | “Classical” achondroplasia diagnosed in Genetics Department | History of neurosurgical procedures | Achondroplasia | Prospective cross-sectional cohort
| Setting: Genetics clinic
| Mean age: 4.5 y
| Age range: 3 mo – 17 y
| Mean height: ND
| Male: 49%
| Race: ND
| Enrolled: 39
| Evaluated: 39
| Number of sites: 1
Shurka 1976 | Location: Israel | Dwarfism due to bone disease | (For current review, age ≥ 18 y) | Bone disease (External chondromatosis, Achondroplasia, Undefined) | Prospective cross-sectional cohort
| Setting: Pediatric endocrinology clinic
| Mean age: 15 y
| Age range: 9–17 y
| Mean height: 134 cm
| Height range: 104–157 cm
| Male: 46%
| Race: ND
| SES: Primarily average or high Enrolled: 12
| Evaluated: 11 (7 met criteria for current review)
| Number of sites: 1
Skeletal Dysplasia Group 1989 89192477 | Location: UK | Diagnosis of skeletal dysplasia | Osteogenesis imperfecta | Morquio disease | Retrospective cross-sectional case series
| Setting: Workgroup's registers | Adequate cervical spine films (Morquio disease: other disease sub-groups did not meet criteria for current review) | Sclerosing bone dysplasias or tumor-like disorders
| Mean age: ND | | Malformation syndromes
| Age range: 1–15 y
| Mean height: ND
| Male: 49%
| Race: ND
| Enrolled: 182
| Evaluated: 15 (children with Morquio disease)
| Number of sites: ND
Stewart 1989 90125184 | Location: Scotland | Diagnosed based on their history of spontaneous fractures. | None reported | Osteogenesis imperfecta | Prospective cross-sectional cohort
| Setting: Dep. Of medical genetics | Contacted via Brittle Bon Society.
| Mean age: ND | For current review, only children aged 10–19 were included
| Age range: 10–19 y
| Mean height: ND
| Male: 43% for the larger group
| Race: ND
| Enrolled: 56
| Evaluated: 56 (13 met criteria for current review)
| Number of sites: ND
Thompson 1999 99221075 | Location: US | [underlined: Cases] - clinical and radiographic diagnosis of ACH | Severe psychiatric disorder | Achondroplasia | Prospective cross-sectional cohort
| Setting: Genetics clinic | [underlined: Premature] [underlined: controls]- premature infants with hydrocephalus | Uncontrolled seizure
| Mean age: | [underlined: Normal controls] - normally developing children of average stature | Other neurological disorder
| Cases: 89 mo | [underlined: All] - IQ>69 | Child abuse
| Premature: 107 mo | | Sensory deficit
| Controls: 111 mo | | Unable to speak English
| Age range: ND
| Mean height: ND
| Male: 52%
| Race: White 74%, Black 6%, Hispanic 13%, Other 7%
| SES: Low 31%, Middle 19%, High 50%
| Enrolled: 16 (21 premature, 17 controls)
| Evaluated: 16 (21, 17)
| Number of sites: 1
Waters 1993 94029092 | Location: Australia | Patients with dysplasia (implied) | Refusal to participate | Achondroplasia | Prospective cross-sectional cohort
| Setting: Sleep lab and clinic
| Mean age: ND
| Age range: 1–31 y
| Mean height: ND
| Male: 50%
| Race: ND
| Enrolled: 20
| Evaluated: 20
| Number of sites: 1

Evidence Table 2. Studies Evaluating Short Stature Secondary to Skeletal Dysplasia Part II

Author, Year | Predictors | Predictor Measures / Definitions | Outcomes | Outcome Measures
Alston 1983 | Osteogenesis imperfecta | ND | Cognitive/Academic | Non-verbal intelligence (Raven's Matrices) Reading (Primary Reading Test, Wide Span Reading Test, or Gapadol Reading Test)
| | | | Spelling (Graded Word Spelling Test) Writing speed (Number of words written in 5 minutes)
| | | Motor function | Mobility (Walk vs wheelchair)
Apajasalo 1998 98163312 | Achondroplasia | Disproportionate short limbed short stature, characteristic facial features and joint and spine disorders | Physical development | Overall quality of life (Health related quality of life, 16 dimensions)
| Cartilage-hair hypoplasia | Congenital disproportionate short-limbed short stature, thin/sparse hair, defective immunity | | Mobility dimension
| Diastrophic Dysplasia | Severe physical handicap due to short-limbed short stature, progressive joint limitations, kyphoscoliosis, foot deformities | | Vision dimension
| | | | Hearing dimension
Bailey 197172080259 | Achondroplasia | ND | Motor function | Elbow flexion (Angle, Self-reported disability)
Benson 1978 79027354 | Osteogenesis imperfecta, mild | Thicker cortical bone with visible trabeculae, not severe osteoporosis of vertebrae | Motor function | Walking ability (Independent walkers, Walked with appliance, Sitter)
| Osteogenesis imperfecta, moderate | ND | | Scoliosis (spinal curvature on spine radiography)
| Osteogenesis imperfecta, severe | Thin osteoporotic long bones and severe osteoporosis of vertebrae
Bleck 1981 82026195 | Osteogenesis imperfecta congenita | Severe type | Physical development/Motor function | Independence (0 = No achievement possible
| Osteogenesis imperfecta tarda | ND | | 1 = Complete dependence
| | | | 2 = Partial dependence
| | | | 3 = Independence through technical help
| | | | 4 = Completely independent, but not normal in timing, effort expenditure, or external appearance
| | | | 5 = Normal activity)
| | | | Mobility efficiency (0 = None
| | | | 1 = Mobility not functional enough to be used
| | | | 2 = Moves about immediate surroundings
| | | | 3 = Travels in the community
| | | | 4 = Travel beyond the community Activities of daily living (ADL: 0 = No ADL possible
| | | | 1 = Meets own essential needs
| | | | 2 = Completes personal care
| | | | 3 = Household activity possible
| | | | 4 = Normal ADL)
| | | | Ambulation (0 = None
| | | | 1 = Walking possible but not functional enough to be useful
| | | | 2 = Household walker
| | | | 3 = Walk outside home but limited to neighborhood
| | | | 4 = Community walker)
Brinkmann 1993 94091382 | Achondroplasia | Short limbs and characteristic skull changes with macrocephaly | Cognitive | Cognitive Abilities Test, German version
| | | | Verbal component
| | | | Arithmetic component
| | | | Reasoning component
| | | Physical development | Motor development (Months to sit, stand, walk alone)
| | | Physical development | Delayed speech (parental report)
| | | Sensory | Hearing deficit (parental report)
| | | Pain | Limb, joint, back pain
Cox 1982 83016754 | Osteogenesis imperfecta | Idiopathic bone fragility, blue sclerae, hearing impairment | Sensory | Hearing loss (Pure tone thresholds > 30 dB hearing loss at 250–1,000 Hz and/or > 25 db hearing loss at 2,000–6,000 Hz)
Daly 1996 96219608 | Osteogenesis imperfecta Shapiro classification: | Fractures at birth, bones radiographically abnormal | Physical development/Motor function | Mobility (Wheelchair, Aided walker, Independent)
| Congenita A | | | Patterns of development (Abnormal arrested, Delayed arrested, Normal arrested, Delayed, Normal)
| Congenita B | Fractures at birth, bones radiographically normal
| Tarda A | First fracture by walking stage, bones narrow, osteopenic
| Tarda B | First fracture after walking, bones radiographically normal
| Osteogenesis imperfecta Sillence classification: | Autosomal dominant, normal stature, blue sclerae
| I A
| I B | IA plus dentinogenesis imperfecta
| III | Autosomal recessive, multiple fractures at birth, progressively deforming
| IV A | Autosomal dominant, bone fragility, normal sclerae
| IV B | IV A plus dentinogenesis imperfecta
Engelbert 1997 | Osteogenesis imperfecta | Classified according to Sillence method (see Daly 1996 , above) | Motor function | Self-care (Pediatric Evaluation of Disability Inventory, PEDI, range 0–100, median 50. Score scaled for children older than 7.5 years such that normal score=100)
| I, III and IV | | | Mobility (PEDI)
Engelbert 1998 98366964 | Osteogenesis imperfecta | Classified according to Sillence method (see Daly 1996, above) | Motor function | Scoliosis (Cobb angle > 40°)
| I, III and IV | | | Kyphosis (Cobb angle < 10° or > 40°)
Engelbert 1999 99381568 | Osteogenesis imperfecta | Classified according to Sillence method (see Daly 1996, above) | Motor function | Level of ambulation (Bleck classification)
| I, III and IV
Engelbert 2000 20429012 | Osteogenesis imperfecta | Classified according to Sillence method (see Daly 1996, above) | Motor function | Level of ambulation (Bleck classification)
| I, III and IV
Engelbert 2001 21334060 | Osteogenesis imperfecta | Classified according to Sillence method (see Daly 1996, above) | Motor function | Self-care (Pediatric Evaluation of Disability Inventory, PEDI, range 0–100. Score scaled for children older than 7.5 years such that normal score=100)
| I, III and IV | | | Mobility (PEDI)
| | | | Level of ambulation (Bleck classification)
| | | Motor function | Joint range of motion: arms, legs (0=normal, 4=maximally decreased)
| | | | Muscle strength: arms, legs (0=no muscle activity, 5=normal muscle strength)
Falvo 1973 74013834 | Osteogenesis imperfecta | Generalized osteoporosis, blue sclerae, dentinogenesis imperfecta, history of fracture | Pulmonary | Pulmonary function tests (Vital capacity (VC), Residual volume (RV), 1-second forced expiratory volume divided by forced vital capacity (FEV_1_/FVC))
| Mild | No noticeable deformity of long bones | | Arterial blood analysis (Oxygen partial pressure, carbon dioxide partial pressure)
| Moderate | Bowing of lower extremity long bones only
| Severe | Bowing of all long bones
Fowler 1997 97356792 | Achondroplasia | ND | Physical development | Motor development (Denver Developmental Screening Test: Months to sit, stand, walk alone)
Pauli 1995 95193803 | Achondroplasia | ND | Neurological | Neurological examination (Truncal tone, Limb tone, Arm strength, Leg strength)
| | | | Neurological history (Developmental delays, Asymmetry, Weakness, Sensory abnormality, Arching / opisthotonus, Clonus, Seizure, Apnea)
| | | Pulmonary | Polysomnography (Central apnea, Central hypopnea, Obstructive apnea)
Hecht 1991 92152267 | Achondroplasia | ND | Cognitive | Mental development index (Bayley Scales of Infant Development)
| | | | Psychomotor development index (Bayley)
| | | Pulmonary | Sleep apnea
Hunter 199898299528 | Chondrodysplasia | ND | Psychological | Depression (Beck Depression Inventories)
| | | | Anxiety (Speilberger State-Trait Anxiety Inventories)
Kuurila 2000 20379515 | Osteogenesis imperfecta | Classified according to Sillence method (see Daly 1996, above) | Sensory | Hearing loss (Pure tone < 20 dB, Conductive < 15 dB)
| I, III and IV
Norimatsu 1982 82163323 | Osteogenesis imperfecta | Per Falvo 1973 (see above) | Motor function | Walking ability (Wheelchair bound, ambulates with assistance)
| Mild, Moderate, Severe | | | Scoliosis (Mild <30°; Moderate 30°-50°; Severe > 50°, by Cobb's method)
Poussa 1991 92054945 | Diastrophic dysplasia | Short-limbed short stature, joint limitations, spinal and foot deformities, dysmorphic earlobes, cleft palate | Motor function | Scoliosis (>10° by Cobb's method)
Reid 1988 89193370 | Achondroplasia | ND | Pulmonary | Obstructive sleep apnea (>5 obstructive or >2 central apneas per hour)
| | | Neurological | Paresis (not defined)
Stokes 1988 88110722 | Achondroplasia | Rhizomelia, macrocephaly with midfacial hypoplasia, spinal canal narrowing | Pulmonary | Forced vital capacity
Reite 1972 72182015 | Osteogenesis imperfecta | ND | Cognitive | IQ (WISC)
Rogers 1979 79200737 | Achondroplasia | ND | Cognitive | IQ (Age< 2 y: Bayley Scales of Infant Development; Age 2–6 y: Stanford-Binet Intelligence Scale; Age 6–15 y: WISC)
| Other skeletal dysplasia | Multiple diagnoses
Ruiz-Garcia 1997 97346439 | Achondroplasia | Autosomal dominant, abnormally short stature, macrocephaly, rhizomelia | Neurological | Neurological examination (Quadriparesis, Weakness, Sensory deficit)
| | | | Compressive neural syndrome (craniocervical compression, lumbar compression)
| | | Hearing Loss | Brainstem auditory evoked response
Shurka 1976 | Skeletal dysplasia | External chondromatosis, achondroplasia, or undefined | Cognitive | IQ (WISC)
Skeletal Dysplasia Group 1989 89192477 | Morquio disease | ND | Neurological | Neurological complications (ND)
Stewart 1989 90125184 | Osteogenesis imperfecta | ND | Sensory | Hearing loss (Pure tone < 30 dB, conductive < 15 dB)
Thompson 1999 99221075 | Achondroplasia | ND | Cognitive | IQ (WISC-R)
| | | | Academic achievement (WRAT-R)
| | | Motor function | Gross motor arm and leg coordination (McCarthy Scales)
| | | Visual-motor skills | Motor-based design copying task (Beery Test of Visual Motor Integration)
| | | | Motor-free spatial matching task (Judgment of Line Orientation)
| | | | Fine motor skills
Waters 1993 94029092 | Achondroplasia | ND | Pulmonary | Sleep apnea (> 5 apneic episodes per hour)

Evidence Table 2. Studies Evaluating Short Stature Secondary to Skeletal Dysplasia Part III

Author, Year | Associations found | Potential Biases | Comments
Alston 1983 | In children with osteogenesis imperfecta (n=40) mean non-verbal intelligence (104), reading ability (100) and spelling ability (102) were similar to control children (n=40, 105, 102, 104, respectively). Writing speed was significantly slower (51 words in 5 minutes) compared to controls (61 words). | None noted | Study was privately funded
| Of children with osteogenesis imperfecta (n=40), 38% required wheelchair use.
Apajasalo 1998 98163312 | Among adolescents with skeletal dysplasia (n=19), overall quality of life (HRQOL=92) was significantly lower than in controls (n=239, 95) in univariate and multivariate analyses. | Few definitions of outcome measures | No data on funding source
| Among adolescents with skeletal dysplasias (n=19), the quality of life dimension mobility was significantly lower than for normal children. Children with diastrophic dysplasia and achondroplasia had mean scores of ~81 (from graph); those with cartilage-hair hypoplasia had a mean score of 100. | Reporting of analyses incomplete
| Those with skeletal dysplasia had similar scores to normal children for vision and hearing. Children with diastrophic dysplasia had mean scores of 94 for vision and 93 for hearing; those with achondroplasia had mean scores of 96 and 95, respectively; those with cartilage-hair hypoplasia had mean scores of 96 and 85, respectively.
| In the analysis of 16 dimensions of quality of life, there were no statistically significant differences among the different groups of children with skeletal dysplasia.
Bailey 1971 72080259 | Infants with achondroplasia, aged 0–2 years, had mean elbow flexion deformity of 11°, ranging from 5°–25°; Children, aged 3–12 years, had mean elbow flexion of 19°, ranging from 10°–40°; adolescents, aged 13–20 years, had mean elbow flexion of 23.5°, ranging from 0°–40°. | No data on actual disability due to limited joint movement specifically in children. | No data on funding source
| | Unknown number of subjects in relevant age ranges.
Benson 1978 79027354 | Among children with osteogenesis imperfecta (n=126) 48% were wheelchair bound (sitters), 25% walked with appliances, and 28% were independent walkers. | Incomplete data available. | No data on funding source
| Among those children with osteogenesis imperfecta who had spine radiography performed (n=103), 38% had straight spines, 7% had scoliosis between 0°–9°, 19% had scoliosis between 10°–19°, 14% had scoliosis between 20°–49°, 14% had scoliosis between 50°–79°, and 9% ≥ 80°. | Incomplete reporting
Bleck 1981 82026195 | Among children with osteogenesis imperfecta congenita, severe type (n=12), mean independence, mobility, activities of daily living, and ambulation scores after orthotic and mobility management were 2.6 (partial dependence-independence through technical help), 3.0 (travels in community), 2.5 (completes personal care-household activity possible), and 0.7 (no ambulation-walking possible but not functional), respectively. | No statistical analysis. | No data on funding source.
| Among children with osteogenesis imperfecta tarda (n=12), mean independence, mobility, activities of daily living, and ambulation scores after orthotic and mobility management were 3.4 (independence through technical help-completely independent but not normal), 3.8 (almost travel beyond community), 3.7 (almost normal activities of daily living), and 2.8 (almost walk outside home but limited to neighborhood), respectively. | | No statistical comparison.
Brinkmann 1993 94091382 | Among children with achondroplasia (n=30), mean Cognitive Abilities Scores were Total 48, Verbal 46, Arithmetic 49, and Reasoning 51. Compared to normal controls (n=30), Total (56), Verbal (54) and Arithmetic (55), children with achondroplasia had significantly lower scores; Reasoning scores (control 55) were not significantly different. Overall comparisons to siblings (n=30) and other short children (n=30) were similar. | Limited statistical analyses. | Study was government funded
| Children with achondroplasia (n=30) were able to sit alone at a median of 12 months (compared to 7 months for normal controls, n=30), according to parental reports, to stand alone at 14 months (10 months), and to walk alone at 18 months (12 months). Siblings (n=30) and short controls (n=30) had motor development similar to other controls. No statistical analysis reported. | No data on sibling controls for factors that were reported by parents.
| Among children with achondroplasia (n=27) 63% were reported by their parents to have hearing deficits, compared to 18% of short controls (n=28) and 19% of normal controls (n=27).
| Among children with achondroplasia (n=27) 41% were reported by their parents to have delayed speech development, compared to 14% of short controls (n=28) and 7% of normal controls (n=27).
| Among children with achondroplasia (n=30) limb, joint or back pain was present by parental report in 80%, compared to 43% of short controls (n=30) and 10% of normal controls (n=30).
Cox 1982 83016754 | Of children with osteogenesis imperfecta (n=15) 33% had hearing loss | All subjects from 5 families with history of osteogenesis imperfecta. | Study was university funded
| | Limited data on hearing function
Daly 1996 96219608 | Among children with osteogenesis imperfecta classified by Shapiro as congenita B (n=31) 19% had abnormal arrested development, 19% had delayed arrested development, 29% had normal arrested development, 29% had delayed development, and 3% had normal development. Among these children, 87% were wheelchair bound and 13% were independent walkers. | Only a parental questionnaire | No data on funding source
| Among children with osteogenesis imperfecta tarda A (n=15) none had abnormal arrested development, 27% had delayed arrested development, 7% had normal arrested development, 20% had delayed development, and 47% had normal development. Among these children, 27% were wheelchair bound, 13% were aided walkers, and 60% were independent walkers. | No statistical analysis.
| Too few children had osteogenesis congenita A (n=1) or tarda B (n=4) for analysis. | Definitions of development unclear
| Among (the same sample of) children with osteogenesis imperfecta classified by Sillence as Type I (n=15) none had abnormal arrested or delayed arrested development, 7% had normal arrested development, 27% had delayed development, and 67% had normal development. Among these children, 7% were aided walkers and 93% were independent walkers.
| Among children with osteogenesis imperfecta Type III (n=29) 21% had abnormal arrested development, 34% had delayed arrested development, 28% had normal arrested development, 17% had delayed development, and none had normal development. Among these children, 97% were wheelchair bound and 3% were independent walkers.
| Among children with osteogenesis imperfecta Type IV (n=7) none had abnormal arrested development, 14% had delayed arrested development, 14% had normal arrested development, 43% had delayed development, and 29 had normal development. Among these children, 57% were wheelchair bound, 14% were aided walkers and 29% were independent walkers.
Engelbert 1997 | Among children aged ≤ 7.5 years with osteogenesis imperfecta Type I (n=16) mean Self-care Functional Skills score on PEDI (normal median 50) was 39 and mean Mobility score was 31. Among children with Type III (n=8) mean Self-care score was 31 and Mobility score was 5. Among children with Type IV (n=6) mean Self-care score was 37 and Mobility was 48. | Interpretation of scales difficult due to different norms used and unclear description of scales | No data on funding source
| Among children aged > 7.5 years with osteogenesis imperfecta Type I (n=16) mean Self-care Functional Skills score on PEDI (normal = 100) was 100 and mean Mobility score was 100. Among children with Type III (n=6) mean Self-care score was 70 and mean Mobility was 41. Among children with Type IV (n=9) mean Self-care score was 93 and Mobility was 62. | No explicit comparison to normal children
| | Unclear how much overlap in sample with other Engelbert papers.
Engelbert 1998 98366964 | Among children with osteogenesis imperfecta scoliosis > 10° was present in 12% of those with Type I (n=17), 63% with Type III (n=16), and 71% with Type IV (n=14). | No comparison with normal controls | No data on funding source
| Among children with osteogenesis imperfecta kyphosis < 10° was present in 6% of those with Type I (n=17), 38% with Type III (n=16), and 14% with Type IV (n=14). | Unclear how much overlap in sample with other Engelbert papers.
| Among children with osteogenesis imperfecta kyphosis > 40° was present in 6% of those with Type I (n=17), 38% with Type III (n=16), and 14% with Type IV (n=14).
Engelbert 1999 99381568 | At follow-up, of children with osteogenesis imperfecta Type I (n=19) 53% were community walkers, 26% were neighborhood walkers, 16% were household walkers, and 5% were exercise walkers. | No children with recent intramedullary fixation surgery or other disability or impairments. | No data on funding source
| Of children with Type III (n=13) 31% were household walkers, 8% were exercise walkers, 38% were bottom shufflers, 15% could sit unsupported, and 8% could only sit supported. | PEDI scale scores reported for small to very small samples of children. Appears to be earlier subset of data reported earlier in Engelbert 1997. Not analyzed here.
| Of children with Type IV (n=10) 10% were community walkers, 10% were neighborhood walkers, 10% were household walkers, 40% were exercise walkers, 20% could weight bear on feet, and 10% were bottom shufflers. | Unclear how much overlap in sample with other Engelbert papers.
Engelbert 2000 20429012 | At follow-up, of children with osteogenesis imperfecta Type I (n=41) 59% were community walkers without aides, 5% were community walkers with aides, 10% were neighborhood walkers without aides, 12% were household walkers without aides, 7% were household walkers with aides, and 7% were therapy walkers with aides. | Unclear how much overlap in sample with other Engelbert papers. | No data on funding source.
| Of children with Type III (n=11) 9% were neighborhood walkers with aides, 27% were household walkers with aides, 19% were therapy walkers with aides, and 45% were non-walkers. | No comparison with normal children
| Of children with Type IV (n=18) 28% were community walkers without aides, 11% were community walkers with aides, 6% were neighborhood walkers with aides, 11% were household walkers with aides, 22% were therapy walkers with aides, and 22% were non-walkers.
Engelbert 2001 21334060 | Among children aged > 8 years with osteogenesis imperfecta Type I (n=17) mean Self-care Functional Skills score on PEDI (normal = 100) was 100 and mean Mobility score was 92. Among children with Type III (n=11) mean Self-care score was 81 and mean Mobility was 55. Among children with Type IV (n=12) mean Self-care score was 100 and Mobility was 67. | Unclear how much overlap in sample with other Engelbert papers, especially those with PEDI analyses (1997 and 1999) | No data on funding source.
| Among children with osteogenesis imperfecta Type I (n=17) the average child was a community walker without aides. Among children with Type III (n=11) the average child was a therapy walker with aides. Among children with Type IV (n=12) the average child was a household walker without aides. | No comparison to normal children.
| Among children with osteogenesis imperfecta Type I (n=17), the average joint range of motion on a scale of 0 (normal) to 4 (maximally decreased) was 0.5 for arms and 0 for legs. Among children with Type III (n=11) the average arm range of motion was 1.8 and leg range of motion was 3.3. Among children with Type IV (n=12) the average arm range of motion was 1.3 and leg range of motion was 1.7. | Meaning of scales unclear.
| Among children with osteogenesis imperfecta Type I (n=17), the average muscle strength on a scale of 0 (no muscle activity) to 5 (normal muscle strength) was 4.5 for arms and 4.8 for legs. Among children with Type III (n=11) the average arm strength was 3.5 and leg strength was 3.6. Among children with Type IV (n=12) the average arm strength was 4.5 and leg strength was 3.8.
Falvo 1973 74013834 | Among children with osteogenesis imperfecta mean pulmonary vital capacity was 85% of predicted normal (n=10), mean residual volume was 119% of predicted normal (n=10), mean FEV_1_/FVC was 99% of predicted normal (n=10), mean arterial oxygen partial pressure was 88 mm Hg (n=8), and mean arterial carbon dioxide partial pressure was 35 mm Hg (n=8). | Limited analyses | Study was government and privately funded.
| “No patient had severe hypoxemia or hypercapnea. Reduction of VC and increase in RV were found only in patients with kyphoscoliosis. Other parameters of pulmonary function were within normal limits.”
Fowler 1997 97356792 | Among children with achondroplasia, by parental report, the mean age of sitting unsupported was 12 months (n=37), the mean age of standing alone was 19 months (n=21), and the mean age of walking alone was 18 months (n=24). “Virtually all fine motor skills were delayed when compared with children without achondroplasia.” | Includes subjects in Pauli 1995 | No data on funding source
| | Data on motor development from few subjects enrolled in study
Pauli 1995 95193803 | Among children with achondroplasia, 72% had decreased truncal tone (n=39), 70% had decreased limb tone (n=44), 32% had abnormal arm strength (n=40), and 50% had abnormal leg strength (n=40). No child had marked abnormalities in neurological examination. | Earlier subset of subjects in Fowler 1997 | Study was hospital funded
| Among children with achondroplasia (n=52) 42% had an abnormality by neurological history. These included disproportionate developmental delays (10%), asymmetries (21%), weakness (14%), sensory abnormalities (4%), arching/opisthotonos (10%), clonus (8%), seizures (8%), and apnea (27%).
| Among children with achondroplasia (n=35) by polysomnography 40% had mild to severe central apnea, 66% had mild to severe central hypopnea, and 23% had mild obstructive apnea
Hecht 1991 92152267 | Among infants with achondroplasia (n=13) mean BSID Mental Development Index score was 97 (1 or 2 infants had scores <70, text and table disagree) and mean Psychomotor Development Index score was 63 (62% scored <50). | 5 of 13 patients were initially seen (and thus included) for apnea, motor delay or neurological complication | Study was government funded
| Among infants with achondroplasia (n=13) 77% had normal polysomnography. Two infants (15%) had obstructive apnea, 1 had hypoxemia and respiratory acidosis. | Reporting errors
Hunter 1998 98299528 | Among children with chondroplasias (n=55) 7% had moderate or severe depression per the Beck Depression Inventories, which was not significantly different than among normal siblings (11%, n=35). | None noted | No data on funding source
| Among children with chondroplasias (n=55) the mean Speilberger Child State Anxiety score was 28.4 and Trait Anxiety score was 32.5, which were significantly lower (implying less anxiety) than general population means for boys (31.0 and 36.7, respectively) and girls (30.7 and 38.0, respectively).
Kuurila 2000 20379515 | Among children with osteogenesis imperfecta (n=45), 7% had hearing loss: 2 children had conductive hearing loss and 1 had sensorineural deafness. | Descriptive study only | No data on funding source.
Norimatsu 1982 82163323 | Among children with osteogenesis imperfecta congenita (n=8) 38% were wheelchair bound; the remainder walked with assistance. | Multiple subjects were closely related. | No data on funding source
| Among children with osteogenesis imperfecta tarda (n=14) 14% were wheelchair bound; the remainder walked with assistance. Among children with osteogenesis imperfecta congenita (n=8) 88% had severe scoliosis (59°–139°; one had mild scoliosis (17°). Among children with osteogenesis imperfecta tarda (n=14) 21% had severe scoliosis (55°–125°), 14% had moderate scoliosis (32° & 33°), 64% had mild scoliosis (5°–28°). | Descriptive study only
Poussa 1991 92054945 | Among children with diastrophic dysplasia (n=38) 29% had scoliosis. Of those ≤ 10 years (n=17) 6% had scoliosis; of those between 11 and 20 years (n=21) 48% had scoliosis. Those with scoliosis (n=11) had a mean magnitude of curvature of 39° (range 15°–80°). | Descriptive analysis only | No data on funding source.
| | | Subjects are part of the study. Descriptive data only.
Reid 1988 89193370 | Among children with achondroplasia (n=26) 85% had a history of respiratory abnormalities including pneumonia, loud snoring, cyanotic spells or apnea in the preceding 6 months; 35% had obstructive sleep apnea. | Descriptive study only | No data on funding source
| Among children with achondroplasia (n=26) 42% had paresis. | No specific definitions of conditions reported
| | Appears to be subgroup of subjects included in Stokes 1988
Stokes 1988 88110722 | Among children with achondroplasia (n=24) mean forced vital capacity was 72% of predicted, significantly lower than population norms. | Limited details of pediatric sub-sample. | Study funded by government, hospital and private sources
| | Appears to include subjects in Reid 1988
Reite 1972 72182015 | Among children with osteogenesis imperfecta (n=12) the mean IQ was 107, ranging from 78–133. | Only children with “severe” osteogenesis imperfecta | Study was government and privately funded.
| | Incomplete data reported
Rogers 1979 79200737 | Among school aged children with achondroplasia (n=19) mean Full scale IQ was 96, Verbal IQ was 95, and Performance IQ was 100; 5% had IQ<70. | Descriptive study only | Study was government funded
| Among preschool aged children with achondroplasia (n=15) mean Full scale IQ was 97; 13% had IQ<70.
| Among school aged children with other skeletal dysplasias (n=22) mean Full scale IQ was 104, Verbal IQ was 104, and Performance IQ was 103; none had IQ<70.
| Among preschool aged children with other skeletal dysplasias (n=12) mean Full scale IQ was 100; none had IQ<70.
Ruiz-Garcia 1997 97346439 | According to summary table, among children with achondroplasia (n=39) 59% had hypotonia, 15% had quadriparesis, 31% had weakness, and 10% had a sensory deficit. | No definitions of outcomes | No data on funding source
| According to text, 49% had hypotonia, 13% had quadriparesis, 26% had weakness, and 5% had sensory deficit. In additon, 31% had compressive neural syndromes (18% craniocervical, 13% lumbar). | Results reported in text differ from results reported in table
| According to the text, among children with achondroplasia (n=32), 50% had abnormal hearing as tested by brainstem auditory evoked response. | Descriptive study only.
Shurka 1976 | Among children with skeletal dysplasias (n=7) mean Full scale IQ was 102, Verbal IQ was 103, and Performance IQ was 99. | Very small sample size. | No data on funding source
| | Multiple, poorly defined causes of dwarfism.
Skeletal Dysplasia Group 1989 89192477 | Among children with Morquio disease (n=15) 33% had “known neurological complications.” | Limited data reported | No data on funding source
| | Conditions and outcomes not defined
| | Only subset met criteria for inclusion in SSA report
Stewart 1989 90125184 | Among children with osteogenesis imperfecta (n=13), 15% had hearing loss. | Incomplete reporting | Study was private funded
| | Descriptive only
Thompson 1999 99221075 | Among children with achondroplasia mean WISC-R Verbal IQ was 94 (n=16), Performance IQ was 101 (n=16), WRAT-R Spelling score was 88 (n=14), Arithmetic was 89 (n=15), and Sentence writing was 80 (n=12). These scores were all statistically similar to normal controls (IQ ND, Spelling 97, Arithmetic 96, Sentence writing 95, n=17). | Biased sample as some children dropped who were unable to complete the testing for many measures and excluded children with IQ<69. | Study was government funded.
| Among children with achondroplasia (n=13) Gross Motor Arm Coordination score on McCarthy Scales was 73 and Leg Coordination was 79, significantly lower than normal controls (93, 104, respectively; n=13). | | Subjects were recruited as part of larger previous study of hydrocephalus
| Among children with achondroplasia (n=13) visual motor skills were significantly lower (Beery 82, JLO 85) than among normal controls (Beery 92, JLO 100, n=12). Various measures of fine motor skills were similar between the two groups.
Waters 1993 94029092 | Among children with achondroplasia (n=20) 75% had > 5 apneic episodes per hour of sleep. | Descriptive study only | No data on funding source

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Asthma - Part I

Author, Year | Demographics | Inclusion Criteria | Exclusion Criteria | Types of Diseases / Conditions | Study Design (Duration)
Balfour-Lynn 1986 | Location: UK | Chronic perennial asthma | None reported | Asthma | Prospective longitudinal cohort
87074993 | Setting: Pediatric asthma clinic | | | | (Mean 8.9 y)
| Initial mean age: 7.5 y
| Initial age range: 2–12 y
| Follow-up mean age: 21 y
| Follow -up age range: 13–26 y
| Mean height: ND
| Male: 68%
| Race: ND
| SES: ND
| Enrolled: 66
| Evaluated: 66
| Number of sites: 1
Cernelc 1975 | Location: Yugoslavia | Asthmatic children with normal or pathological lung function tests | None reported | Asthma | Prospective cross-sectional
76016195 | Setting: Clinic
[Also in cardiac section] | Mean age: ND
| Mean height: ND
| Male: ND
| Race: ND
| SES: ND
| Enrolled: ND
| Evaluated: 337
| Number of sites: ND
Ferguson 1982 | Location: Canada | Children with a diagnosis of asthma and short stature (height < 3^rd^percentile) | None reported | Asthma | Preliminary study of a prospective longitudinal study
82190765 | Setting: Regional
| Mean age: ND
| Age range: ~3–17 y
| Mean height: ND
| Male: 89%
| Race: ND
| SES: ND
| Enrolled: 36
| Evaluated: 36
| Number of sites: 1
Hauspie 1979 | Location: Belgium and Hungary | Hungary : asthmatic boys residing in the National Sanatorium for Children | None reported | Asthma /Respiratory disease | Retrospective cross-sectional cohort
80114229 | Setting: Sanatorium; Asthma clinic | Belgium: boys with chronic aspecific respiratory affection, asthma or asthma and eczema.
| Mean age: ND
| Age range: 3–16 y
| Mean height: ND
| Male: 100%
| Race: ND
| SES: ND
| Enrolled: 1107
| Evaluated: 1107
| Number of sites: 2
Klein 1991 | Location: US | Children with moderately severe, non-steroid-dependent asthma | > 6 short courses of steroids during previous year | Asthma | Prospective cross-sectional
91314975 | Setting: Clinic
| Mean age: 8.5 y
| Age range: 2–15 y
| Mean height: ND
| Male: ~ 69%
| Race: ND
| SES: ND
| Enrolled: 176
| Evaluated: 176
| Number of sites: 4
Martin 1981 | Location: Australia | Asthmatic children | None reported | Asthma | Prospective longitudinal cohort
82110081 | Setting: Region | Aged 7 y in 1964 | | | (14 y follow-up)
| Initial age: 7 y
| Follow-up ages: 10 y, 14 y, 21 y
| Mean height: ND
| Male: 63%
| Race: ND
| SES: ND
| Enrolled: 375
| Evaluated: 315
| Number of sites: 1
McNicol 1970 | Location: Australia | Asthmatic children | None reported | Asthma | Prospective longitudinal cohort
71076839 | Setting: Unclear | | | | (Ages 7 and 10)
| Ages: 7 and 10 y
| Mean heights: 123 cm (age 7 y); 138 cm (age 10)
| Male: ND
| Race: ND
| SES: ND
| Enrolled: 226
| Evaluated: 226
| Number of sites: ND
Neville 1996 | Location: UK | Tayside Childhood Asthma Project (1990-92) | Loss to follow-up | Asthma | Secondary analysis of prospective longitudinal cohort
96427603 | Setting: Pediatric practices | Possible asthma, based on medication prescriptions, from chart review
| Mean age: ND | Age 3.5–13 y
| Age range: 3.5–13 y | Height and weight measurements available
| Mean height: ND
| Male: 57%
| Race: ND
| SES: “Broad range”
| Enrolled: 2915
| Evaluated: 699
| Number of sites: 12
Rona 1980 | Location: UK | Parental reporting of asthma in last 12 months | None reported | Asthma | Retrospective cross-sectional cohort
81025712 | Setting: Schools
| Mean age: ND
| Age range: 5–11 y
| Mean height: ND
| Male: 68%
| Race: ND
| SES: Proportionally more lower SES areas
| Enrolled: 102
| Evaluated: 102
| Number of sites: 28
Sant'Anna 1996 | Location: Brazil | Children with asthma followed in Division of Allergy, Clinical Immunology and Rheumatology | Phenotypical deviations | Asthma | Retrospective cross-sectional case series
97295750 | Setting: Pediatric immunology clinic | | Clear changes in body proportions
| Mean age: ND | | Other chronic diseases
| Age range: 6 mo – 16 y | | Rash and/or atopic dermatitis
| Mean height: ND
| Male: 58%
| Race: ND
| SES: ND
| Enrolled: 514
| Evaluated: 514
| Number of sites: 1
Spock 1965 | Location: US | Children with bronchial asthma | Concomitant chronic illness | Asthma | Retrospective longitudinal cohort
| Setting: Pediatrics department | Age > 4 y at the first visit | Cyproheptadine use | | (19 y)
| Mean age: 7 y | Followed for minimum of 3 y
| Age range: 4–12 y
| Mean height: ND
| Male: 65%
| Race: White
| SES: ND
| Enrolled: 200
| Evaluated: 200
| Number of sites: 1

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Asthma - Part II

Author, Year | Severity of Illness Groups | Outcomes
Balfour-Lynn 1986 | Treatment required to control asthma | Initial growth retardation (not defined)
87074993 | • Bronchodilators alone or children whose asthma resolved before puberty | Growth along centile lines
| • Sodium cromoglycate and bronchodilators in children whose asthma did not improve at puberty | Final adult height
| • Steroids and bronchodilators | Percentile, based on Tanner and Whitehouse growth chart
Cernelc 1975 | Pulmonary function tests | Height by age (linear regression)
76016195 | • Normal | Compared to normal values for Slovenian children
| • Pathological (not defined)
Ferguson 1982 | Asthma symptom score, based on frequency of wheezing in past year, duration of wheezing, level of therapy required, and bronchodilator medication days in past year (16 point scale) | Height
82190765 | • Mild: score 1–7 | Percent average height for age
| • Moderate: score 8–12
| • Severe: score 13–16
Hauspie 1979 | Hungarian sample: Ovsáth's system, based on based on frequency of attacks, seriousness of dyspnea, duration of dyspnea, and number of symptom-days per year | Height Z-scores
80114229 | • Class II: Less severe
| • Class III: More severe
| • Class IV: Most severe
| Belgian sample: Disease diagnosis
| • Chronic aspecific respiratory affection
| • Asthma
| • Asthma and eczema
| Belgian sample: Treatment required to control asthma:
| • No corticotherapy
| • Interrupted corticotherapy
| • Continuous corticotherapy for at least 6 months
Klein 1991 | Asthma severity score (by event), based on hospitalization and medication requirements in previous year (score: 0–60) | Height
91314975 | • Mild: score < 25 | Height percentile
| • Moderate/severe ≥ 25 | Based on National Center for Health Statistics Growth Chart
Martin 1981 | Asthma grade, based on frequency and recency of wheezing | Percentage of subjects <10^th^percentile
82110081 | • Grade A: ≤ 5 episodes of wheezing | Based on Australian Department of Health
| • Grade B: > 5 episodes of wheezing but no wheezing within 12 months of exam | Anthropometric tables
| • Grade C: Episodic asthma over a number of years and wheezing within 12 mo of exam | At ages 10, 14, and 21 y
| • Grade D: Very frequent or chronic unremitting asthma
McNicol 1970 | Asthma grade, based on frequency and recentness of asthma episodes | Height
71076839 | • Grade I: ≤ 5 episodes of asthma
| • Grade II: ≤ 20 episodes of asthma or no asthma within 12 mo of exam
| • Grade III: >20 episodes and still having asthma within 12 mo of exam
Neville 1996 | Asthma severity (British Thoracic Society treatment steps), based on medication requirements | Height
96427603 | • Step 1: Beta-agonist only in past year | SDS, based on control group within study
| • Step 2: Beta-agonist and cromoglycate
| • Step 3: Beta-agonist and low dose inhaled steroid
| • Step 4: Beta-agonist and > 400 μg/day inhaled steroid
Rona 1980 | Frequency of asthma episodes | Height SDS, based on Scottish and English norms
81025712 | • ≤ 2 episodes in the past year | • Unadjusted
| • ≥ 3 episodes in the past year | • Adjusted for parents' height, social class, number of siblings
| Hospitalization for asthma | Height gain, cm/year
| | • Unadjusted
| | • Adjusted
Sant'Anna 1996 | Asthma severity, based on the International Consensus Report on Diagnosis and Treatment of Asthma | Percentage with short stature
97295750 | • Mild | < 3^rd^percentile, based on National Center of Health Statistics, US, 1977
| • Moderate
| • Severe
Spock 1965 | Clinical status (not defined) | Linear growth rate
| • Poor | Percentage of normal, based on Stuart and Wetzel's anthropometic charts
| • Fair
| • Good
| • Excellent

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Asthma - Part III

Author, Year | Associations found | Potential Biases | Comments
Balfour-Lynn 1986 | Comparing children whose asthma was controlled with bronchodilators alone or had resolved at puberty (n=18, Group I) with those whose asthma required sodium cromoglycate and had not resolved at puberty (n=19, Group II), and with those whose asthma required treatment with steroids (n=29, Group III), there was no statistical difference in growth retardation at the start of the study. However, “growth retardation” was not defined. Of children in Group I, 2 of 18 (11%) had initial height < 10^th^ percentile. Of children in Group II, 1 of 19 (5%) had initial height < 10^th^ percentile. Of children in Group III, 3 or 29 (10%) had initial height < 10^th^ percentile. No child had height < 3^rd^ percentile. | Severity of asthma based on treatment used, not objective measures | No data on funding source
87074993 | All children “grew along expected centile lines without appreciable deviation, from initial age (mean 7.5 y) until age 10 y, regardless of treatment required. 30 of 66 (45%) children had “physiological decelerating growth velocity pattern of delayed puberty.” No data are reported regarding association with asthma severity. | Reported data incomplete
| Comparing the three groups of asthmatic children, based on treatment requirements, no statistical difference was found in final adult height. Possible minor trend toward taller adult height from Group I to II to III seen in graph. | Study sample poorly defined
| | 6 subjects lost to follow up prior to obtaining final adult height but were followed for mean 8.3 years (6.3–14.6 y)
Cernelc 1975 | Asthmatic children with normal pulmonary function tests (n=225) were not significantly different in height for age compared to asthmatic children pathological pulmonary function tests (n=112). | Limited data and analysis | No data on funding source
76016195 | No data on growth velocity. | Study sample poorly defined | Data on asthmatic children with bronchiectasis (n=22) not included because children reported to be both significantly and not significantly more likely to have growth retardation
Ferguson 1982 | The percentages of average normal height for age (50^th^ percentile) of short children whose asthma was mild (n=19, 90.7%), moderate (n=13, 90.2%) and severe (n=4, 88.5%) were not significantly different among the three groups. | Study limited to children with height < 3^rd^ percentile, however results reported as percentage of average normal height | Study was government and private funded.
82190765 | No significant correlation was found between symptom score and percentage of average normal height for age of individual subjects (r=0.20).
| No data on growth velocity
Hauspie 1979 | Mean height of Class II (relatively mild) Hungarian asthmatic boys (n=222) is normal (~ 0 SDS, from graph). The mean height of Class III asthmatic boys (n=253) was significantly lower (~ -0.3 SDS) and that of Class IV asthmatic boys (n=25) was even lower (~ -0.9 SDS). “A gradually increasing degree of growth retardation in relation to the seriousness of the disease can be observed.” | Chronic aspecific respiratory affection includes illnesses other than asthma. | No data on funding source.
80114229 | In a separate sample of Belgian asthmatic boys, those with chronic aspecific respiratory affection (n=204) had normal mean height (~ -0.1 SDS, from graph). Those with asthma (n=323) were statistically significantly but minimally shorter (~ -0.2 SDS) and those with asthma and eczema (n=80) were even shorter (~ -0.4 SDS). | Data reported mostly in graphical format only
| Belgian asthmatic boys requiring no corticotherapy (n=245) and requiring interrupted corticotherapy (n=130) had normal mean height (~ -0.1 SDS, from graph). Those who required continuous corticotherapy (n=16) were statistically shorter (~ -0.5 SDS). | Study limited to boys
| No data on growth velocity.
Klein 1991 | Children (n=176 total) with mild asthma (ND on n) had mean ± SD height of 145±10 cm; those with moderate asthma were on average 148±10 cm. The height difference was not significantly different. No data reported on children with severe asthma. | Reported data very incomplete. | No data on funding source
91314975 | “There was no relationship between the severity of asthma (as assessed by a clinical and medications score) and the height percentile.” Reported data are incomplete. | Mean heights reported as 44.8 cm and 47.8 cm. We understood this to mean 144.8 cm and 147.8 cm, however, reported numbers may refer to percentiles.
| No data on growth velocity | Children requiring > 6 short courses of steroids within previous year excluded.
Martin 1981 | The prevalence rates of height < 10^th^ percentile in 10 years old children whose asthma was rated Grade A (mild, n=64), Grade B (moderate, n=88), Grade C (severe, n=106), and Grade D (very severe, n=57) were 9%, 8%, 8%, and 15% respectively. Only children with very severe asthma had significant higher prevalence of height < 10^th^ percentile at age 10 y compared to non-asthmatic children (n=62, 4%). | None noted. | No data on funding source
82110081 | The prevalence of short stature in the asthmatic children when they were 14 years old was similar to when they were 10 years old. Height < 10^th^ percentile in Grade A asthmatics was 6%, Grade B 5%, Grade C 5%, and Grade D 17%. Only children with very severe asthma had significant higher prevalence of height < 10^th^ percentile at 14 years of age compared to non-asthmatic children (1%).
| At age 21 years, the prevalence of short stature was similar among all asthma grades. Height < 10^th^ percentile Grade A asthmatics was 15%, Grade B 15%, Grade C 9%, and Grade D 19%. There was no difference in the prevalence of height < 10^th^ percentile at 21 years of age, between the 4 groups and non-asthmatic children (12%).
| No direct data on growth velocity
McNicol 1970 | The mean heights of children at both ages 7 and 10 years were the same (123–124 cm at age 7 years; 137–139 cm at age 10 years) regardless of frequency of asthmatic episodes among 276 asthmatic children and 94 non-asthmatic controls. No significant difference was found between controls and any degree of asthma severity. | None noted | No data on funding source
71076839 | No data on growth velocity
Neville 1996 | Asthmatic children who used only beta agonists (n=537) had a mean height of +0.04 SDS. Those who used beta agonists and cromoglycate (n=64) had a mean height of +0.04 SDS. Those who used beta agonists and low dose inhaled steroids (n=39) had a mean height of +0.08. Those who used beta agonists and > 400 μg/day inhaled steroids (n=59) had a mean height of -0.38. Only those on high dose inhaled steroids were significantly shorter than normal. | Large number of potential subjects excluded due to missing height data | Study was government, privately, and pharmaceutical funded
96427603 | No data on growth velocity. | Statistical analysis implied only
| | Asthma severity based on medication use
Rona 1980 | Among children with asthma episodes, those with ≤ 2 episodes in previous year (n=33) were not significantly shorter (-0.1 SDS, - 0.2 SDS, respectively) than controls (n=4334) in both unadjusted model and model adjusted for parental height, social class, and number of siblings. Those with ≥ 3 asthma episodes in previous year (n=69) were significantly shorter (-0.4 SDS) than controls in both models. Overall, “there was a highly significant negative relationship between unadjusted [and adjusted] height and number of [asthma] episodes. | Retrospective survey of parents (for medical history) and school records | Study was government funded.
81025712 | “Hospitalization for asthma was more closely associated with shorter stature for boys than for girls, but the number of children hospitalized was too small for useful analysis.” | Logic of adjusting for number of siblings unclear.
| In adjusted model, height velocity was non-significantly lower in boys with ≤ 2 asthma episodes per year (n=22, 5.34 cm/y) and with ≥ 3 episodes per year (n=41, 5.57 cm/y) than non-asthmatic boys (n=1873, 5.72 cm/y), and in girls with ≤ 2 episodes per year (n=9, 5.67 cm/y) and with ≥ 3 episodes per year (n=16, 5.50 cm/y) than non-asthmatic girls (n=1552, 5.93 cm/y).
Sant'Anna 1996 | The prevalence of short stature (< 3^rd^ %tile) in children with mild asthma (n=211, 6%) was non-significantly lower than those with moderate asthma (n=154, 11%) and severe asthma (n=149, 11%). | Multiple height-related exclusion criteria | No data on funding source
97295750 | No data on growth velocity
Spock 1965 | The mean linear growth rate in percentage of normal was 109% for asthmatic patients with excellent clinical status (n=68), 107% for asthmatic patients with good clinical status (n=86), 102% for asthmatic patients with fair clinical status (n=30), and 97% for asthmatic patients with poor clinical status (n=16). The correlation between severity of clinical status and the linear growth rate in percentage of normal was not statistically significant. | Degree of clinical status not defined | No data on funding source.
| “No statistically significant correlation was found between the duration and/or severity of asthmatic symptoms and growth impairment for height or weight.” | The percentage of children requiring steroids was unusually low at 12%

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Cardiac Disease - Part I

Author, Year | Demographics | Inclusion Criteria | Exclusion Criteria | Types of Diseases / Conditions | Study Design (Duration)
Baum 1980 | Location: US | Diagnosis of acyanotic congenital heart disease | None reported | Congenital heart disease: | Prospective cross-sectional cohort
81065058 | Setting: Clinic | Age 2 to 6 y | | Patent ductus arteriosus
| Mean age: 3.8±1.0 y | | | Ventricular septal defect
| Age range: ND | | | Atrial septal defect
| Mean height: 99 cm | | | Pulmonic stenosis
| Male: 77% | | | Aortic stenosis
| Race: ND | | | Atrioventricular canal
| SES: ND | | | Pulmonary artery band
| Enrolled: 26 | | | Right ventricular band
| Evaluated: 26 | | | Mitral stenosis
| Number of sites: 1 | | | Mitral insufficiency
Cernelc 1975 | Location: Yugoslavia | Children with congenital heart disease with or without cyanosis | None reported | Congenital heart disease: | Prospective cross-sectional
76016195 | Setting: Clinic | | | Not defined
[Also in asthma section] | Mean age: ND
| Mean height: ND
| Male: ND
| Race: ND
| SES: ND
| Enrolled: ND
| Evaluated: 22
| Number of sites: ND
Feldt 1969 | Location: US | Diagnosis of congenital heart disease | Trisomy 21 | Congenital heart disease: | Prospective longitudinal cohort
69176079 | Setting: Clinic | | Gonadal dysgenesis | Ventricular septal defect | (5 mo)
| Mean age: ND | | Clinically recognized maternal rubella syndrome | Tetralogy of Fallot
| Age range: 1 wk – 17 y | | | Aortic stenosis
| Mean height: ND | | | Pulmonary stenosis
| Male: ND
| Race: ND
| SES: ND
| Enrolled: 463
| Evaluated: 311
| Number of sites: 1
Levy 1977 | Location: US | Diagnosis of ventricular septal defect | None reported | Ventricular septal defect | Retrospective longitudinal cohort
78125814 | Setting: Cardiology clinic | | | | (mean[range] 6.4 [4–8] y)
| Mean age: ND
| Age range: ND
| Mean height: ND
| Male: 50%
| Race: ND
| SES: ND
| Enrolled: 1,210
| Evaluated: 777
| Number of sites: ND
Strangway 1976 | Location: Canada | Diagnosis of congenital heart disease | Additional major congenital lesion | Congenital heart disease: | Retrospective longitudinal cohort
76101945 | Setting: Cardiology clinic | | Mental retardation | Tetralogy of Fallot | (5 y)
| Mean age: ND | | Undergone corrective surgery | Ventricular septal defect
| Age range: < 2–11 y | | Acute or chronic intercurrent illness | Atrial septal defect
| Mean height: ND | | | Pulmonary stenosis
| Male: ND | | | Aortic stenosis
| Race: ND | | | Coarctation of aorta
| SES: ND | | | Patent ductus arteriosus
| Enrolled: 568 | | | Arterioventricular canal
| Evaluated: 568 | | | MIscellaneous
| Number of sites: 1
White 1970 | Location: US | Diagnosis of congenital heart disease | Tetralogy of Fallot with total corrective surgery | Congenital heart disease: | Prospective cross-sectional
72024496 | Setting: Adolescent cardiac clinic | Age < 19 y | | Ventricular septal defect
| Mean age: ND | | | Atrial septal defect
| Age range: 12–18 y | | | Patent ductus arteriosus
| Mean height: ND | | | Pulmonary stenosis
| Male: ND | | | Aortic stenosis
| Race: White 96% | | | Coarctation of aorta
| SES: Generally middle class | | | Aortic insufficiency
| Enrolled: 80 | | | Undiagnosed acyanotic
| Evaluated: 80
| Number of sites: 1

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Cardiac Disease - Part II

Author, Year | Predictors (N) | Outcomes
Baum 1980 | Heart Failure (not defined) | Height by age (linear regression)
81065058 | | Height percentile
| | Based on National Center for Health Statistics growth charts
Cernelc 1975 | Cyanosis | Height by age (linear regression)
76016195 | | Compared to normal values for Slovenian children
[Also in asthma section]
Feldt 1969 | Pulmonic valve pressure gradient | Growth failure preoperative height (and weight) ≤ -2 SDS
69176079 | Aortic valve pressure gradient | Height SDS based on Reed and Stuart, 1959
| Tetralogy of Fallot lesion severity
| • Hematocrit
| • Oxygen saturation (cyanosis)
| • Magnitude of right to left shunt
| • History of hypoxemia
| Ventricular septal defect shunt severity
| • Pulmonary vascular disease (pressure)
Levy 1977 | Ventricular septal defect severity | Height SDS
78125814 | • I: Trivial to mild, pulmonary artery mean pressure < 20 mm Hg
| • II: pulmonary artery mean pressure ≥ 20 mm Hg and pulmonary to systemic resistance ratio < 0.20
| • III-IV: Severe: pulmonary artery mean pressure ≥ 20 mm Hg and pulmonary to systemic resistance ratio ≥ 0.20
Strangway 1976 | Cardiac problems | Height velocity fraction of the normal mean for the same age and sex
76101945 | • Cyanosis
| • Cardiac enlargement (cardiothoracic ratio > 59% age < 2 y, > 55% age >2 y)
| • Congestive heart failure
White 1970 | Cyanosis | Short stature, height < 2^nd^percentile
72024496

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Cardiac Disease - Part III

Author, Year | Associations found | Potential Biases | Comments
Baum 1980 | Children with congenital heart disease with early heart failure (n=12) were significantly shorter for age than asymptomatic children (n=14). On average, children age 2–6 years with heart failure were 5–9 cm shorter than those without. The differences in height were greater with older age. | None noted | No data on funding source.
81065058 | Six (50%) of the 12 children with early heart failure had height below the 5^th^ percentile, while none of the 14 asymptomatic children had height below the 10^th^ percentile.
| No data on growth velocity.
Cernelc 1975 | Children with congenital heart disease and cyanosis (n=11) were significantly more likely to be short for age than normal population, as opposed to children with congenital heart disease without cyanosis (n=11) who were not significantly different in height for age than normal population. | Limited data and analysis | No data on funding source
76016195 | | Study sample poorly defined
[Also in asthma section]
Feldt 1969 | Among children with aortic or pulmonary stenosis (n=73), those “with mild pressure gradients (< 50 mm Hg) across either the pulmonic or the aortic valve usually were of normal weight and height. In contrast, patients with severe valvular gradients were more likely to have severe growth failure.” | No statistical analyses | Study was government funded.
69176079 | The severity of growth failure of children with Tetralogy of Fallot (n=83) “was not related to any criteria for seveity of the lesion such as hemaglobin value, oxygen saturation…, magnitude of right to left shunt, or history of hypoxemic spells.” Specifically height SDS was not associated with hemoglobin level. | Growth retardation included both short stature and low weight
| Among children with ventricular septal defect (n=155) “there was no correlation between the extent of growth failure and the degree of pulmonary vascular disease assessed either at cardiac catheterization of from pressure measurements taken at the time of operation.”
| No data correlated height velocity to severity of disease.
Levy 1977 | For children with ventricular septal defect, the mean initial height SDS for those with mild disease (n=492) was -0.23 SDS, for those with moderate disease (n=170) -0.63 SDS, and for those with severe disease (n=115) -0.86. The height of children in each category was statistically significantly lower than normal children. The statistical significance of the association between height and severity of disease is implied only. | Reporting of statistical analyses unclear and incomplete | Study was government funded.
78125814 | No data on growth velocity
Strangway 1976 | Among children aged 0 to 2 years with congenital heart disease (n=181), height velocity percentile was significantly lower in children with cyanosis (-14%) than those without cyanosis (+7%), was similar in children with cardiac enlargement (+2%) as without cardiac enlargement (+1%), and was non-significantly lower in children with congestive heart failure (-20%) than without congestive heart failure (+2%). | Because of the calculation of height velocity, some subjects missing follow-up measures of height were excluded from analyses. | Study was government funded.
76101945 | Among children aged 2 to 11 years with congenital heart disease (n=387), height velocity percentile was similar in children with cyanosis (+10%) as those without cyanosis (+7%), was similar in children with cardiac enlargement (+15%) as without cardiac enlargement (+6%), and was non-significantly lower in children with congestive heart failure (-13%) than without congestive heart failure (+7%).
White 1970 | Among children with congenital heart disease, height < 2^nd^ percentile was more common among those with cyanosis (n=27, 19%) than those without cyanosis (n=53, 2%) | No statistical analyses performed | Study was partial government funded.
72024496 | | Reporting of data unclear

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Insulin Dependent Diabetes Mellitus - Part I

Author, Year | Demographics | Inclusion Criteria | Exclusion Criteria | Types of Diseases / Conditions | Study Design (Duration)
Arreola 1991 93191566 | Location: Mexico | Patients with type I diabetes seen at outpatient diabetes clinic from 1984 to 1998 | None reported | Insulin dependent diabetes | Retrospective longitudinal cohort (4–5 y)
| Setting: Outpatient diabetes clinic | Age 1–16 y
| Mean age: ND
| Age range: 1–16 y
| Mean height: ND
| Male: ND
| Race: ND
| SES: ND
| Enrolled: 198±8 each year (1984-1988)
| Evaluated: 198±8 each year
| Number of sites:1
Court 1982 83021090 | Location: UK | Children with diabetes attending clinics in the Newcastle region | None reported | Diabetes (implied insulin dependent) | Retrospective cross-sectional cohort
| Setting: Region
| Mean age: 13±3.7 y
| Age range: ND
| Mean height, SDS: -0.69
| Male: 54%
| Race: ND
| SES: ND
| Enrolled: 121
| Evaluated: 111
| Number of sites: ND
Herber 1988 88180314 | Location: UK | Patients with Type I diabetes who have attended the pediatric diabetic clinic for at least 3 years | None reported | Insulin dependent diabetes | Retrospective longitudinal cohort (3 y)
| Setting: Pediatric diabetic clinic
| Initial mean age: 10 y
| Follow-up mean age: 13 y
| Age range: ND
| Initial height, SDS: -0.24±1.16
| Follow-up height, SDS: -0.20±1.08
| Male: 64%
| Race: ND
| SES: ND
| Enrolled: 67
| Evaluated: 67
| Number of sites: 1
Izumi 1995 96105591 | Location: Japan | Children participated in Summer camp program | None reported | Insulin dependent diabetes mellitus | Retrospective longitudinal cohort (18 y)
| Setting: Summer camp | More than 3 determinations of Hgb_A_1c
| Initial mean age: ND | Age < 18 y at final examination.
| Follow-up mean age: 14 y
| Age range: ND
| Mean height: ND
| Male: 40%
| Race: ND
| SES: ND
| Enrolled: 385
| Evaluated: 107
| Number of sites: ND
Jivani 1973 73134278 | Location: UK | Children with diabetes > 3 y follow-up | Other condition which might have affected growth (12 subjects with fair control were not analyzed) | Diabetes (implied insulin dependent) | Retrospective longitudinal cohort (mean [range] 7 [3–13] y)
| Setting: Children's hospital
| Mean age: ND
| Age range: 9 mo - 13 y
| Mean height: ND
| Male: 46%
| Race: ND
| SES: ND
| Enrolled: 116
| Evaluated: 104
| Number of sites: 1
Pitukcheewanont 1995 96136504 | Location: US | Type I diabetes | < 3 visits during study | Insulin dependent diabetes | Retrospective longitudinal cohort (6 y)
| Setting: Clinic | | Other problems that might affect growth (thyroid disease, cerebral palsy, foster care placement, methylphenidate therapy)
| Mean age: 11.5±3.8 y | | Precocious or delayed puberty
| Age range: ND
| Mean height: ND
| Male: 49%
| Race: White 100%
| SES: ND
| Enrolled: 82
| Evaluated: 82
| Number of sites: 1
Rosenbloom 1982 83032889 | Location: US | Children with Type I diabetes | None reported | Insulin dependent diabetes mellitus | Prospective longitudinal cohort (ND)
| Setting: Clinic | Pre-puberty
| Mean age: ND | Duration of DM >3 y
| Age range: ND
| Mean height: ND
| Male: ND
| Race: ND
| SES: ND
| Enrolled: 309
| Evaluated: 142
| Number of sites:8
Salardi 1987 87127000 | Location: Italy | Children with Type I diabetes | None reported | Insulin dependent diabetes mellitus | Prospective longitudinal cohort (Mean [Range] 4.5 [1–10.7] y)
| Setting: Pediatric clinic
| Mean age: 7.4±3.6 y
| Age range: 0.7–15 y
| Mean height: ND
| Male: 44%
| Race: ND
| SES: ND
| Enrolled: 79
| Evaluated: 79
| Number of sites: 1
Soliman 1996 96412723 | Location: Oman | Prepubertal children with diagnosis of Type I diabetes mellitus | Intra-uterine growth retardation | Insulin dependent diabetes mellitus | Prospective longitudinal cohort (1 y)
| Setting: Diabetes clinic | | Systemic or endocrine disease
| Mean age: 9 y | | Dysmorphic trait
| Age range: 2–12 y | | Central nervous system irradiation
| Mean height: ND | | Hypothyroid
| Male: ND
| Race: ND
| SES: ND
| Enrolled: 47
| Evaluated: 45
| Number of sites: 1
Vanelli 1992 93052062 | Location: Italy | Diabetic children referred to diabetes clinic at diagnosis | Endocrinological disease affecting linear growth | Insulin dependent diabetes mellitus | Prospective longitudinal cohort (ND)
| Setting: Diabetes unit | Treated with daily insulin
| Mean age: ND | Subset analysis of girls who became diabetic at onset of puberty
| Age range: 1.5–21 y
| Mean height: ND
| Male: 0% (analyzed)
| Race: ND
| SES: ND
| Enrolled: 204
| Evaluated: 42
| Number of sites: 1
Wise 1992 92387067 | Location: US | Children and adolescents with diabetes | Other problems that might affect growth (thyroid disease, cerebral palsy, foster care placement, methylphenidate therapy, or precocious or delayed onset of puberty) | Insulin dependent diabetes mellitus | Prospective longitudinal cohort
| Setting: Pediatric diabetes clinic
| Mean age: ND
| Age range: ND
| Mean height: ND
| Male: ND
| Race: ND
| SES: ND
| Enrolled: 122
| Evaluated: 122
| Number of sites: 1

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Insulin Dependent Diabetes Mellitus - Part II

Author, Year | Severity of Illness Groups | Outcomes
Arreola 1991 93191566 | Diabetes control | Height velocity
| • HgbA1c | cm/month
| • Poor control: HgbA1c > 11%
| • Good control: HgbA1c < 11%
Court 1982 83021090 | Diabetes control (text unclear) | Height SDS, based on Tanner 1976
| • Poor control: Glucosuria (>2%) frequency >75% or 24 hour urine glucose > 50 g | Growth velocity SDS
| Good control: Glucosuria frequency < 10% or 24 urine glucose < 20 g
Herber 1988 88180314 | HgbA1c | Change in height SDS
Izumi 1995 96105591 | HgbA1c category | Height SDS, based on Japanese Ministry of Education statistics
| • <10.0%
| • 10.0–12.4%
| • ≥12.0% (unclear why overlap)
Jivani 1973 73134278 | Diabetes control | Height percentile, based on Tanner, 1966
| • Poor: Ketonuria, glycosuria up to 5% at clinic, BS > 250 mg/dL, severe or frequent hypoglycemic reactions
| • Good: No ketonuia, ≤ 1% glycosuria at clinic, blood sugar < 150 mg/dL, rare mild hypoglycemic reactions
Pitukcheewanont 1995 96136504 | HgbA1c | Height SDS, based on National Center for Health Statistics
| | Height velocity, SDS
Rosenbloom 1982 83032889 | Limited joint mobility (“associat[ed with] early microvascular complications) | Height percentile, based on National Center for Health Statistics
| • None | < 25%
| • Mild: Involving 1 or 2 interphalangeal joints, 1 large joint, or only the metacarpophalangeal joints bilaterally
| • Moderate/Severe: Involving 3 or more interphalangeal joints or 1 finger joint and 1 large joint bilaterally or cervical spine involvement or obvious hand deformity at rest
Salardi 1987 87127000 | HgbA1c | Height SDS, based on Tanner's centiles
| | Height velocity SDS, based on Tanner's centiles
Soliman 1996 96412723 | Diabetes control | Height velocity SDS, based on age-matched population
| • HgbA1c < 10%
| • HgbA1c > 10%
Vanelli 1992 93052062 | Diabetes severity (apparently post hoc grouping) | Peak height velocity (during pubertal growth) cm/year
| • Lower insulin requirement: Mean ± SD insulin 37±1.5 U/m^2^/day; HgbA1c 10±1.8%
| • Higher insulin requirement: Insulin 42±0.5 U/m^2^/day; HgbA1c 9±2.4%
Wise 1992 92387067 | HgbA1c level categories | Height velocity
| • 6.0–7.9 | Change in SDS, based on National Center for Health Statistics
| • 8.0–9.9
| • 10.0–11.9
| • 12.0–13.9
| • 14.0–15.9
| • 16.0–21.9

Evidence Table 3. Association of Decrease Growth Velocity with Severity of Disease Insulin Dependent Diabetes Mellitus - Part III

Author, Year | Associations found | Potential Biases | Comments
Arreola 1991 93191566 | Children with diabetes with HgbA1c > 11% (no data on number of subjects) had significantly lower height velocity (0.54 cm/month, from graph) compared to those with HgbA1c < 11% (0.22 cm/month). There was a significant correlation between HbA1c level and height velocity. | True number of subjects included not reported. | No data on funding source
Court 1982 83021090 | For children with diabetes that was under poor control (n=57) mean height (-0.96 SDS) was significantly lower than those under good control (n=54, -0.22 SDS). | Determination of diabetes control based on glucosuria frequency and 24 hour urine glucose instead of HgbA1c | No data on funding source.
| Mean height velocity was significantly lower for children under poor control (-1.22 SDS) than those under good control (-0.61 SDS).
Herber 1988 88180314 | In children with diabetes (n=67), “no significant effect on [change in height] was apparent with differing levels of HgbA1c.” | Specific data on height SDS in relation to HbA1c levels was not given. | No data on funding source.
| | Overall good control (mean HbA1c levels at commencement 10.2%; mean HbA1c levels at end 9.9%.
Izumi 1995 96105591 | Among children with diabetes, mean height of those with HgbA1c < 10% (n=28) was -0.54 SDS, of those with HgbA1c of 10–12.4% (n=53) was -0.76, and of those with HgbA1c ≥ 12% (n=26) was -0.75. Height was not significantly associated to HgbA1c level. | Categories of severity of diabetes overlapping. | No data on funding source.
| No data on high velocity. | Unclear if statistical analysis based on groups or on individual HgbA1c levels
Jivani 1973 73134278 | The mean height percentile among girls with diabetes with poor control (n=22) was 38% and among those with good control (n=34) was 40%. There was no significant difference between the two groups. | Eligibility criteria unclear. | No data on funding source.
| The mean height percentile among boys with diabetes with poor control (n=19) was 35% and among those with good control (n=29) was 29%. There was no significant difference between the two groups. | Age of children at time of follow-up analysis unclear. | The text and table of the criteria for assessment of diabetic control were not concordant.
| Among both boys and girls with diabetes, height velocity was not associated with level of diabetes control | Statistical analysis unclear.
| | Determination of diabetes control based on factors other than HgbA1c
Pitukcheewanont 1995 96136504 | Among children with type I diabetes (n=82), there was no association between mean HgbA1c and mean height SDS in univariate analysis. In multivariate analysis, controlling for age of diabetes onset and initial height, there remained no association between HgbA1c and height. | Retrospective analysis | No data on funding source.
| There was no association between mean HgbA1c and mean height velocity at any Tanner stage in univariate analysis.
Rosenbloom 1982 83032889 | Diabetic children with mild (n=31), moderate (n=19) or severe (n=24) limited joint mobility were significantly more likely to be below the 25^th^ percentile for height (~75%, from graph) than those without limited joint mobility (n=68, ~37%)). However, the correlation between HgbA1c and joint mobility was poor. | Joint mobility is a poor proxy for severity of diabetes. | Study hospital funded
| No data on height velocity | Only looked at quartiles of height.
Salardi 1987 87127000 | In children with insulin dependent diabetes (n=79), height SDS and height velocity SDS were not significantly correlated with HgbA1c. | Only summary of results reported. | Study was government funded
Soliman 1996 96412723 | Children with diabetes whose HbA1c < 10% (n=30) had significant higher growth velocity (+0.75 SDS) than DM subject HbA1c > 10% (n=15, -1.6 SDS). | None noted | No data on funding source.
Vanelli 1992 93052062 | In a subset of girls who became diabetic at onset of puberty (n=42), the 23 treated with greater amounts of insulin (mean 41.5 U/m^2^/d) and who had lower mean HgbA1c (8.9%) had significantly higher mean peak growth velocity (8.5 cm/y) than the 19 treated with less insulin (37.3 U/m^2^/d and higher HgbA1c (10.1%), at 6.9 cm/y. | Study poorly defined. | No data on funding source
| | Unclear a priori hypotheses
| | Definitions of sample groups poorly defined
| | Single analysis of subgroup only
Wise 1992 92387067 | Among children with diabetes (n=122) a significant linear relationship was seen between HgbA1c and growth velocity. HgbA1c < 8% was associated with growth acceleration (+0.10 SDS); the most severe growth retardation occurred when HgbA1c levels were > 16% (-0.07 SDS). | None noted | No data on funding source

Evidence Table 3. Association of Decreased Growth Velocity with severity of Disease β-thalassemia - Part I

Author, Year | Demographics | Inclusion Criteria | Exclusion Criteria | Types of Diseases / Conditions | Study Design (Duration)
Constantoulakis 1975 75129833 | Location: Greece | Diagnosis of homozygous β- thalassemia | None reported | β thalassemia major | Retrospective longitudinal cohort
| Setting: Outpatients | | | | (Range 4–7 y)
| Mean age: ND
| Age range: 7 months - 28 y
| Mean height: ND
| Male: 58%
| Race: ND
| SES: ND
| Enrolled: 229
| Evaluated: 171
| Number of sites: 1
Kattamis 1970 71003038 | Location: Greece | Diagnosis of homozygous β-thalassemia | Clinical picture of thalassemia intermedia and hemoglobin between 7–10 g/dL | β thalassemia major | Prospective cross-sectional cohort
| Setting: Clinic | | Age > 11 y
| Mean age: ND
| Age range: 1–11 y
| Mean height: ND
| Male: 53%
| Race: ND
| SES: ND
| Enrolled: 74
| Evaluated: 74
| Number of sites: 1
Madeddu 1978 78167848 | Location: Italy | Homozygous β thalassemia | None reported | β thalassemia major | Prospective cross-sectional
| Setting: Clinic
| Mean age: ND
| Age range: 2–13 y
| Mean height: ND
| Male: 46%
| Race: ND
| SES: ND
| Enrolled: 50
| Evaluated: 50
| Number of sites: 1

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease β-thalassemia - Part II

Author, Year | Severity of Illness Groups | Outcomes
Constantoulakis 1975 75129833 | Multiple linear regression including | Height percentiles, based on various Greek sources
| • Mean hemoglobin level over previous 2–4 years
| • Total blood transfused since birth
| • “Index of severity of disease” based on amount of blood transfused during previous 2 years
| • (Age)
Kattamis 1970 71003038 | β-thalassaemia severity | Height percentile, based on Children's Medical Center, Boston growth chart
| • Group I: Pre-transfusion hemoglobin > 8 g/dL, frequent transfusions
| • Group II: Unable to follow regularly, pre-transfusion hemoglobin 6–8 g/dL, either very low SES or had to travel “very long distance” for transfusion
| • Group III: Transfused only when hemoglobin < 6 g/dL, usually < 5 g/dL
Madeddu 1978 78167848 | Hemoglobin concentration between two transfusions | Height percentile, based on Tanner, 1962

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease ß-thalassemia-Part III

Author, Year | Associations found | Potential Biases | Comments
Constantoulakis 1975 75129833 | Among children will ß-thalassemia major (n=171) there was a trend toward lower height percentiles being associated with low hemoglobin levels and severity of disease; however, neither was statistically significant in a linear regression controlling for age. Total blood transfused since birth was not associated with height. | No data on hemoglobin levels, total blood transfused since birth, and index of severity of disease. Provides only the regression results. | No data on funding source
| No data on height velocity. | Definition of the severity of the disease unclear.
| | Large numbers of subjects were not included in analyses. No explanation.
| | Model adjusted for non-independent variables.
Kattamis 1970 71003038 | Children with ß-thalassemia major (n=38) had significantly higher mean height percentile (56%) than children with moderate (n=14, 22%) and severe (n=22, 7%) disease. | Thalassemia severity based on how low hemoglobin allowed to fall before transfusion | No data on funding source
| No data on height velocity.
Madeddu 1978 78167848 | Children with ß thalassemia who were <3^rd^ percentile for height (n=18) had mean hemoglobin of 6.6 g/dL, which was not significantly lower than those whose height was 3^rd^ –25^th^ percentile (n=12, 7.2 g/dL) and whose height was 25^th^–75^th^ percentile (n=19, 7.0 g/dL) (One child had height above 75^th^ percentile). | Cross-sectional study cannot evaluate previous degree of anemia | No data on funding source
| No data on height velocity.

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Inflammatory Bowel Disease - Part I

Author, Year | Demographics | Inclusion Criteria | Exclusion Criteria | Types of Diseases/Conditions | Study Design (Duration)
Farmer 1979 80023814 | Location: US | Crohn's disease established by clinical, radiographic and/or histological means | Unable to obtain follow-up data | Crohn's disease | Retrospective longitudinal case series
| Setting: Clinic | Age < 20 y | | | (Mean 7.7 y)
| Mean age: ND (41% < 16 y) | Diagnosis made form 1955-1974
| Age range: < 20 y
| Mean height: ND
| Male: ND
| Race: ND
| SES: ND
| Enrolled: 522
| Evaluated: 522
| Number of sites:1
Griffiths 1993 93345883 | Location: Canada | Diagnosis of Crohn's disease | Transferred after initial diagnosis and referred for consultation only | Crohn's disease | Retrospective longitudinal case series
| Setting: Clinic | Tanner stage 1 or 2 | | | (≥ 2 y)
| Mean age: 11±2.3 y
| Age range: 5–17 y
| Mean height, SDS: -1.1±1.3
| Male: 66%
| Race: ND
| SES: ND
| Enrolled: 100
| Evaluated: 100
| Number of sites: 1
Saha 1998 98182041 | Location: Finland | Diagnosis of inflammatory bowel disease | None reported | Inflammatory bowel disease: Ulcerative colitis Crohn's disease | Retrospective longitudinal cohort
| Setting: Pediatrics department | | | | (13 y)
| Mean age: 7 y
| Age range: ND
| Mean height: ND
| Male: 43%
| Race: ND
| SES: ND
| Enrolled: 47
| Evaluated: 47
| Number of sites: 1

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Inflammatory Bowel Disease - Part II

Author, Year | Severity of Illness Groups | Outcomes
Farmer 1979 80023814 | Location of Crohn's disease | Short stature
| •Ileocolic pattern | Height < 3^rd^ percentile, based on growth charts
| •Colon pattern
| •Small intestine pattern
| •Anorectal pattern
Griffiths 1993 93345883 | Severity of gastrointestinal symptoms over given year | Height velocity cm/year
| •Quiescent: No symptoms, normal complete blood count and sedimentation rate | Percent with growth retardation < 4 cm/year
| •Mild: Some symptoms, no prednisone treatment needed | Height SDS, based on National Center for Health Statistics
| •Moderate: Intermittent exacerbations requiring prednisone or nutritional support | Change in height SDS
| •Severe: Chronic unremitting symptoms requiring prednisone or alternate treatment
| Location of Crohn's disease
| •Small bowel
| •Ileocecal
| •Ileocolic
| •Colon
Saha 1998 98182041 | Severity of Crohn's disease/ulcerative colitis | Height SDS, based on Finnish population mean
| 12 point scale based on number of relapses, exacerbations, medications and need for surgery (correct scoring mechanism not clear) | Height velocity SDS
| •Mild: 1–3 points
| •Moderate: 4–6 points
| •Severe: ≥ 7 points

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Inflammatory Bowel Disease - Part III

Author, Year | Associations found | Potential Biases | Comments
Farmer 1979 80023814 | Among children with Crohn's disease likelihood of short (< 3^rd^ height percentile) was not related to location of disease. Of those with ileocolic disease (n=175) 7% were short; of those with colonic disease (n=162) 8% were short; of those with small intestine disease (n=151) 6% were short; of those with anorectal disease (n=34) 9% were short. | No statistical analyses. | No data on funding source
| No data on height velocity | “Severity” based on location of disease
Griffiths 1993 93345883 | Among children with Crohn's disease, “severity of gastrointestinal symptoms was the major factor influencing linear growth during the first two years [after diagnosis]. Height velocity significantly decreased with increasing gastrointestinal symptoms during both year and year two, after adjusting for corticosteroid use. During year one, height velocity of children with quiescent disease (n=14) was ~5.7 cm/year (from graph), with mild disease (n=54) was ~4.6 cm/year, with moderate disease (n=23) was ~3 cm/year, and with severe disease (n=9) was ~2.7 cm/year. During year two, height velocity of children with quiescent disease (n=23) was ~7.3 cm/year, with mild disease (n=44) was ~4.5 cm/year, with moderate disease (n=24) was ~4 cm/year, and with severe disease (n=8) was ~4.1 cm/year. | Retrospective | No data on funding source
| Among children with Crohn's disease who were followed to maturity, initial and ultimate height were not associated with disease severity. Initial and ultimate height severity were -0.88 and -0.43 SDS for those with mild disease (n=26), -1.17 and -1.15 SDS for those with moderate disease (n=15), -1.48 and -0.70 SDS for those with moderate or severe disease with sustained remission (n=14), and -1.12 and -1.37 SDS for those with chronically severe disease (n=12).
| Among children with Crohn's disease who were followed to maturity, change in height was significantly associated with disease severity. Change in height was 0.58 SDS for those with mild disease (n=26), 0.03 SDS for those with moderate disease (n=15), 0.68 SDS for those with moderate or severe disease with sustained remission (n=14), and -0.11 SDS for those with chronic severe disease (n=12).
| Among children with Crohn's disease, at year two (n=100), disease location was not significantly associated with height velocity (cm/year) or percentage with height velocity < 4 cm/year. Among those with long-term follow-up (n=65), disease location was not associated with initial height SDS, ultimate height SDS, or change in height SDS.
Saha 1998 98182041 | Among children with ulcerative colitis (n=29), mean overall change in height over 4 years was -0.16 SDS for those with mild disease, -1.09 SDS for those with moderate disease, and -1.74 SDS for those with severe disease. This trend did not reach statistical significance. The overall change in height velocity was significantly greater in those with mild disease (+1.14 SDS) than those with moderate disease (+0.39 SDS) and those with severe disease (+0.12 SDS). | Height outcomes are difficult to interpret. | Study was hospital and privately funded.
| Among children with Crohn's disease (n=18), mean overall change in height over 4 years was +0.51 SDS for those with mild disease, -0.27 SDS for those with moderate disease, and -0.11 SDS for those with severe disease. This trend did not reach statistical significance. The overall change in height velocity was significantly greater in those with mild disease (+0.42 SDS) than those with moderate disease (+0.09 SDS) and those with severe disease (-1.09 SDS). | Numbers of subjects in each category not reported.

Evidence Table 3. Association of Decreased Growth Velocity with Severity of disease Juvenile Rheumatoid Arthritis - Part I

Author, Year | Demographics | Inclusion Criteria | Exclusion Criteria | Types of Diseases / Conditions | Study Design (Duration)
Bernstein 1977 87026009 | Location: US | Children with diagnosis of juvenile rheumatoid arthritis | None reported | Juvenile rheumatoid arthritis | Retrospective longitudinal cohort (mean [range] 6.6[2.3–11] y, up to age of 15)
| Setting: Clinic
| Mean age: ND
| Initial age range: 1–12 y
| Mean height: ND
| Male: 24%
| Race: ND
| SES: ND
| Enrolled: 31
| Evaluated: 31
| Number of sites: 1
Polito 1997 97283189 | Location: Italy | Children with active juvenile rheumatoid arthritis for ≥ 1 y | Steroid use | Juvenile rheumatoid arthritis: | Retrospective longitudinal case series
| Setting: Pediatric clinic | Follow-up for ≥ 1 y | Growth hormone therapy | Pauciarticular onset | (≥ 1 y)
| Initial mean age: 7 y | | | Systemic onset
| Follow-up mean age: 12 y | | | Polyarticular onset
| Age range: ND
| Initial mean height, SDS: +0.34
| Follow-up mean height, SDS: -0.05
| Male: 26%
| Race: ND
| SES: ND
| Enrolled: 58
| Evaluated: 58
| Number of sites:1
Saha 1999 99374796 | Location: Finland | Children with mild to moderate juvenile onset chronic arthritis | Ullrich-Turner syndrome | Juvenile rheumatoid arthritis: | Retrospective longitudinal case series
| Setting: Hospital based clinic | Prepuberty | | Pauciarticular onset | (1–11 y, until age 12 y)
| Mean age: 4 y | Followed for ≥ 1 y | | Systemic onset
| Age range: 0.9–11 y | | | Polyarticular onset
| Mean height: ND
| Male: 36%
| Race: ND
| SES: ND
| Enrolled: 64
| Evaluated: 64
| Number of sites: 1

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Juvenile Rheumatoid Arthritis - Part II

Author, Year | Severity of Illness Groups | Outcomes
Bernstein 1977 87026009 | Mode of onset of juvenile rheumatoid arthritis | Mean percent change in height per year
| • Systemic
| • Polyarticular
| • Pauciarticular
Polito 1997 97283189 | Type of juvenile rheumatoid arthritis | Change in height SDS, based on Tanner 1976
| • Systemic | Change in height SDS per year
| • Polyarticular
| • Pauciarticular
| Number of joints affected (systemic or polyarticular only)
| Sum of periods of time with disease flares (systemic or polyarticular only) joint swelling, tenderness, functional impairment, ESR > 25 mm/hr)
| Functional class, not defined (systemic or polyarticular only)
Saha 1999 99374796 | Severity of juvenile chronic arthritis score | Height velocity SDS, based on Tanner 1966
| 6 point scale based on local anti-inflammatory administrations and number of systemic antirheumatics | Height SDS
| • Mild: Score 1–3
| • Moderate: Score ≥ 4
| Type of disease
| • Pauciarticular
| • Polyarticular
| • Systemic
| • Iridocyclitis

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Juvenile Rheumatoid Arthritis - Part III

Author, Year | Associations found | Potential Biases | Comments
Bernstein 1977 87026009 | Among children with juvenile rheumatoid arthritis, those with systemic disease (n=13) had significantly greater mean change in height per year (-0.85%) than those with polyarticular disease (n=9, +0.04%) and those with pauciarticular disease (n=9, -0.01%). | Definition of outcome measure (percent change in height per year) not well defined | Study was privately funded.
Polito 1997 97283189 | Among children with juvenile rheumatoid arthritis, those with pauciarticular disease (n=21) were less likely to lose > 1 height SDS between first and last visits (0%) than those with systemic disease (n=19, 26%) or those with polyarticular disease (n=18, 28%). No statistical analysis was performed. | Retrospective analysis | No data on funding source
| Among children with either systemic or polyarticular disease (n=37), change in height SDS per year was not associated with number of affected joints but was associated with the sum of the periods of disease flares. Children in functional class I (not defined) had significantly smaller change in height SDS per year (-0.01 SDS) than those in functional class II (-0.06 SDS) | Inclusion criteria was no steroids, thus children with most severe disease, were excluded.
| | Functional class not defined.
Saha 1999 99374796 | Among children with juvenile rheumatoid arthritis (n=64), by multivariate analysis of covariance “the most obvious decrease in [height] velocity was seen in children with polyarthritis and growth velocity was affected slightly more in children with moderate than mild disease,” adjusting for sex and duration of disease. | Exclusion criteria unclear. | Study hospital and privately funded
| “Heights were more affected in children with polyarthritis and the severity of the disease had an additive effect,” adjusting for glucocorticoid use and duration of disease. | No children with severe arthritis.
| | Limited reporting of data.
| | Statistical significance of relevant findings not reported.

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Chronic Kidney Disease / Kidney Failure - Part I

Author, Year | Demographics | Inclusion Criteria | Exclusion Criteria | Types of Diseases / Conditions | Study Design (Duration)
Claris-Appiani 1989 91002131 | Location: Italy | Children with chronic kidney disease | Acute obstruction | Chronic kidney disease | Prospective longitudinal cohort
| Setting: ND | Pre-dialysis | Pyelonephritis | Stage 3
| Mean age: 1.6–9 y | Stable | Hypertension | Stage 4
| Age range: ND | | Hyposthenuria
| Mean height: ND | | Salt wasting
| Male: 65% | | Steroid treatment
| Race: ND
| SES: ND
| Enrolled: 17
| Evaluated: 17
| Number of sites: ND
Ismaili 2001 21219717 | Location: Belgium | Infants with kidney dysplasia and chronic kidney disease | Obstructive renal dysplasia | Chronic kidney disease | Retrospective longitudinal cohort
| Setting: Pediatric nephrology | | | Kidney dysplasia | (4 y)
| Initial mean age: 6 mo | | | Stage 4
| Follow-up mean age: 4 y | | | Stage 5
| Age range: ND
| Mean height: ND
| Male: 55%
| Race: ND
| SES: ND
| Enrolled: 11
| Evaluated: 11
| Number of sites: 1
Karlberg 1996 96384503 | Location: Europe | Onset of chronic kidney disease age < 6 mo | Primary glomerulonephropathy | Chronic kidney disease | Prospective longitudinal case series
| Setting: Pediatric nephrology clinics | GFR < 3 SD below mean for age | Systemic metabolic disorder | Stage 4 | (Mean [Range] 7.3 [3–16] y)
| Mean age: ND | ≥ 2 height measurements before age 1 y and followed until at least age 3 y | | Stage 5
| Age range: 0–5 y
| Mean heights (various ages), SDS: -1.05 to -3.09
| Male: 70%
| Race: ND
| SES: ND
| Enrolled: 73
| Evaluated: 61
| Number of sites: 22
Konrad 1995 96162281 | Location: Europe | Autosomal recessive polycystic kidney disease | Single growth measurement only | Autosomal recessive polycystic kidney disease | Prospective longitudinal case series
| Setting: Pediatric nephrology clinics | Prepuberty | | Stage 1 | (≥ 1 y)
| Initial mean age: 1.7 y | Girls ≤ 9 y old | | Stage 2
| Initial age range: 1–8 y | Boys ≤ 10 y old | | Stage 3
| Follow-up man age: 5.6 y | Age ≥ 1 y at first assessment | | Stage 4
| Follow-up age range: 2–9 y | ≥ 1 y follow-up
| Mean height: ND | Subset of Karlberg, 1996 [#226] and Schaefer, 1996 [#3001]
| Male: 59%
| Race: ND
| SES: ND
| Enrolled: 67
| Evaluated: 58
| Number of sites: 22
Schaefer 1996 96384504 | Location: Europe | Born between 1970 and 1992 | Primary glomerulonephropathy | Chronic kidney disease | Prospective longitudinal case series
| Setting: Pediatric nephrology clinics | Marked reduction in functional kidney mass | Systemic metabolic disorder | Stage 4 | (Median [Range] 3.3 [0.5–10] y)
| Initial median age: 2.6 y | | | Stage 5
| Initial age range: 0–8 y
| Follow-up age: ~ 10 y
| Height range, SDS: -4.2 to +4.1
| Male: ND
| Race: White 96%, Arab or Asian 4%
| SES: ND
| Enrolled: 500
| Evaluated:321
| Number of sites: 22
Norman 2000 21024968 | Location: UK | Children scheduled for GFR measurements | Congenital growth abnormalities | Chronic kidney disease | Prospective cross-sectional cohort
| Setting: Clinic | | Receiving dialysis | Stage 1
| Mean age: ND | | | Stage 2
| Age range: 2–17 y | | | Stage 3
| Mean height: ND | | | Stage 4
| Male: 63%
| Race: ND
| SES: ND
| Enrolled: 95
| Evaluated: 95
| Number of sites: 1
Rizzoni 1984 85010647 | Location: Italy | Children with GFR < 70 ml/min/1.73 m^2^ | Proteinuria | Chronic kidney disease | Retrospective longitudinal case series
| Setting: Pediatric clinic | ≥ 1 bone age determined | Nephrotic syndrome | Stage 2 | (Mean [Range] 4.3 [1–12] y)
| Mean age: 6 y | Follow-up for ≥ 1 y | Steroid treatment | Stage 3
| Age range: < 6 mo – 15 y | | | Stage 4
| Initial mean height, SDS: -1.6 | | | Stage 5
| Follow-up mean height, SDS: -1.5
| Male: 69%
| Race: ND
| SES: ND
| Enrolled: 47
| Evaluated: 47
| Number of sites: 1
Schärer 1999 20068988 | Location: US | Prepubertal children with idiopathic nephrotic syndrome | Chronic kidney failure | Idiopathic nephrotic syndrome | Prospective longitudinal cohort
| Setting: Clinic | | | | (Mean [Range] 9.0 [2–19] y)
| Mean age: 4.5 y
| Age range: 1.2–10 y
| Mean height: ND
| Male: 67%
| Race: ND
| SES: ND
| Enrolled: 45
| Evaluated: 38
| Number of sites: ND
Tejani 1983 84068349 | Location: US | Nephrotic syndrome | Diffuse increase in mesangial cells or with mesangial deposition of immunoglobulin | Focal segmental sclerosis | Retrospective longitudinal case series
| Setting: Pediatric nephrology clinic | Biopsy-proven focal segmental sclerosis | | | (Steroid resistant: 7±5 y; Steroid sensitive: 13±8 y))
| Mean age at onset: | Biopsy performed because of lack of response to steroids or relapse after treatment with steroids
| Steroid resistant 7.7±3.7 y; Steroid sensitive, 3.5±2.5 y
| Age range at onset: 10 mo – 15 y
| Mean height: ND
| Male: 42%
| Race: White 16%, Black 50%, Hispanic 33%
| SES: ND
| Enrolled: 25
| Evaluated: 24
| Number of sites: 1
Tsau 1989 90155156 | Location: Taiwan | Nephrotic syndrome beginning before age 15 y | Development of chronic kidney insufficiency | Nephrotic syndrome | Retrospective longitudinal cohort
| Setting: Hospital | Followed up for at least 2 y | | | (5.5±2.8 y)
| Mean age of onset: 5 y
| Age range: ND
| Mean height: ND
| Male: 83%
| Race: Chinese
| SES: ND
| Enrolled: 52
| Evaluated: 52
| Number of sites: 1

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Chronic Kidney Disease / Kidney Failure - Part II

Author, Year | Severity of Illness Groups | Outcomes
Claris-Appiani 1989 91002131 | GFR, Schwartz formula estimate | Height SDS, based on Tanner 1976
| | Growth velocity per year SDS
Ismaili 2001 21219717 | Chronic kidney disease severity, Schwartz formula estimate and direct measurement | Height SDS, based on Tanner 1966
| • GFR < 15 mL/min/1.73 m^2^
| • GFR > 15 mL/min/1.73 m^2^
Karlberg 1996 96384503 | GFR, age-specific Schwartz formulae estimates | Height SDS, based on normal Swedish children
Konrad 1995 96162281 | GFR, Schwartz formula estimate | Height SDS, based on First Zurich Longitudinal Growth Study
| Chronic kidney disease severity
| • GFR < 60 mL/min/1.73 m^2^
| • GFR > 260 mL/min/1.73 m^2^
Schaefer 1996 96384504 | GFR, age-specific Schwartz formulae estimates | Height SDS
| Chronic kidney disease severity | Height velocity SDS
| • GFR < 25 mL/min/1.73 m^2^
| • GFR > 25 mL/min/1.73 m^2^
Norman 2000 21024968 | Chronic kidney disease severity, based on GFR direct measurements | Height SDS, based on normal UK population
| • Normal: GFR > 75 mL/min/1.73 m^2^
| • Mild: GFR 50–75 mL/min/1.73 m^2^
| • Moderate: GFR 25–50 mL/min/1.73 m^2^
| • Severe: GFR < 25 mL/min/1.73 m^2^
Rizzoni 1984 85010647 | GFR, estimate or direct measurement | Height SDS, based on Tanner 1976
| | Height velocity, cm/year
Schärer 1999 20068988 | Final kidney status | Height SDS
| • Reached final height in absence of kidney function deterioration or ESRD | Change in height SDS
| • Reached final height with serum creatinine > 1.2 mg/dL after age 13.6 years
| • (Lost to follow-up before kidney function deterioration -- not evaluated in this report)
| • Developed ESRD before reaching adult height
| Idiopathic nephrotic syndrome severity (mean serum albumin level and serum protein level)
Tejani 1983 84068349 | Responsiveness (improvement of proteinuria) of focal segmental sclerosis to steroids | Growth retardation
| • Steroid responsive: Complete remission within 8 wk of prednisone, persisting for 2 mo after cessation of treatment | Height for age < 5^th^ percentile at follow-up
| • Steroid resistant: No remission after 8 wk of treatment
Tsau 1989 90155156 | Nephrotic syndrome severity | Change in Height SDS, based on Department of Health, Taiwan
| • Less favorable clinical courses, including frequent relapsing, steroid-dependent, and steroid-resistant nephrotic syndromes | Growth velocity index
| • Had responded to steroid therapy initially with occasional or no relapse | Ratio of actual growth velocity to normal growth velocity for age (% of expected growth)

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Chronic Kidney Disease/Kidney Failure - Part III

Author, Year | Associations found | Potential Biases | Comments
Claris-Appiani 1989 91002131 | Among children with pre-dialysis chronic kidney disease (n=17) there was a significant positive correlation between height SDS and creatinine clearance. | Univariate analysis only was performed for height. | No data on funding source
| In multivariate analysis, height velocity was not associated with creatinine clearance, controlling for bone age, BUN, change in BUN, PTH, calcitriol, caloric and protein intake. | No univariate analysis for height velocity and creatinine clearance. Creatinine clearance not independent of other variables.
| | Far too few subjects for multivariate analysis
Ismaili 2001 21219717 | Among infants with chronic kidney disease with GFR < 15 mL/min/1.73 m^2^ at age 6 months (n=5) mean height did not improve between age 6 months (-2.6 SDS) and 4 years (-2.3 SDS). Among those with GFR > 15 mL/min/1.73 m^2^ (n=6) mean height increased from age 6 months (-2.6 SDS) to 4 years (-1.4 SDS). | Small sample size | No data on funding source.
Karlberg 1996 96384503 | Among children with chronic kidney disease (n=47) change in height SDS between 9 months and 2 years was not associated with GFR in a multiple linear regression. | No data on variables in model. | Study was pharmaceutical funded.
| Among infants with chronic kidney disease (n=14) change in height SDS during the “first postnatal months of life” were not associated with GFR. | Many children not included in all analyses | Same dataset as Schaefer 1996
Konrad 1995 96162281 | Among girls with autosomal recessive polycystic kidney disease, those with GFR < 60 mL/min/1.73 m^2^ (n=9) had mean height of -2.1 SDS; those with higher GFR (n=15) had mean height of -0.3 SDS. Boys with GFR < 60 mL/min/1.73 m^2^ (n=10) had mean height of -1.5 SDS; those with higher GFR (n=24) had mean height of -0.5 SDS. There was a significant correlation between GFR and height SDS among girls but not among boys. | None noted | No data on funding source.
| No data on height velocity. | | Subset of Karlberg, 1996 [#226] and Schaefer, 1996 [#3001]
Schaefer 1996 96384504 | Among children with chronic kidney disease (n=321) height velocity was positively correlated with GFR among 6 year olds and among children of 4 other age groups (of 9 age groups total). | Numbers of children analyzed with GFR > 25 mL/min/1.73 m^2^ and with lower GFR not reported Results for specific age groups not reported | Study was pharmaceutical funded.
| Children with GFR > 25 mL/min/1.73 m^2^ had consistently higher annual height velocities than children with lower GFR. | Results for specific age groups not reported | Same dataset as Karlberg 1996
| Children with GFR > 25 mL/min/1.73 m^2^ were taller (mean height -1.65 SDS) than those with lower GFR (-2.79 SDS).
Norman 2000 21024968 | Among children with chronic kidney disease, those with GFR > 75 mL/min/1.73 m^2^ (n=35) had mean height of +0.40 SDS, those with GFR 50–75 mL/min/1.73 m^2^ (n=23) had mean height of -0.34 SDS, those with GFR 25–50 mL/min/1.73 m^2^ (n=19) had mean height of -0.58 SDS, those with GFR < 25 mL/min/1.73 m^2^ (n=18) had mean height of -1.52. Those with moderate and severe chronic kidney disease had significantly lower height than those with normal GFR. | None noted | No data on funding source.
| No data on height velocity
Rizzoni 1984 85010647 | Among children with chronic kidney disease (n=47) there was no association between GFR and growth velocity. or height SDS. | Limited data reported | No data on funding source
Schärer 1999 20068988 | Children with nephrotic syndrome who reached final height without deterioration of kidney function (n=16) had a mean change in height SDS from onset of kidney disease to final height of +0.27 SDS; those who developed serum creatinine > 1.2 mg/dL before reaching final height (n=8) had a mean change in height SDS of -0.08 SDS; those who developed ESRD before reaching final height (n=9) had a mean change in height of -1.35 SDS. Children who developed ESRD had a significant decrease in their height SDS compared to other groups. | Analyses performed on only subgroups of subjects | No data on funding source.
| Among children with steroid resistant nephrotic syndrome in whom steroid therapy was stopped before puberty (n=16) change in prepubertal height SDS and height velocity SDS correlated positively and significantly with total protein and albumin levels. | Categorization of children by severity of disease is retrospective. Categorized only after reaching final height.
| | Serum albumin and protein are poor markers of disability-related severity of disease
Tejani 1983 84068349 | In children with focal segmental sclerosis, those with steroid responsive disease (n=10) were significantly less likely to have short stature (< 5^th^ percentile) than those with steroid resistant disease (n=14) despite greater steroid doses among the former. | Detailed results not reported. | No data on funding source
| No data on growth velocity
Tsau 1989 90155156 | Among children with nephrotic syndrome, those with relapsing disease (n=29) had significantly lower height velocity (80% of normal) and change in height SDS (-0.63 SDS) than those without relapsing disease (n=23, 104%, +0.19 SDS). This association was true for up to 7 years of follow-up | Cannot distinguish the effect of steroid use from severity of disease. Those with relapsing disease required significantly longer duration of steroid use (8 months) than those without relapsing disease (4 months). | No data on funding source

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Human Immunodeficiency Virus - Part I

Author, Year | Demographics | Inclusion Criteria | Exclusion Criteria | Types of Diseases / Conditions | Study Design (Duration)
Brettler 1990 91011887 | Location: US | Hemophilia | None reported | HIV (with hemophilia) | Prospective and retrospective longitudinal cohort
| Setting: Hemophilia clinic | HIV infection | | | (ND)
| Median age: 8 y | 2 y of growth data before HIV diagnosis
| Age range: 2.5–15 y | Age ≤ 12.5 y in 1980
| Mean height: ND
| Male: 100%
| Race: ND
| SES: ND
| Enrolled: 36
| Evaluated: 36
| Number of sites: 1
Matarazzo 1994 95143841 | Location: Italy | Perinatal HIV infection | None reported | HIV | Prospective longitudinal cohort
| Setting: Pediatric clinic | | | | (24 mo)
| Median age: 2.6 y
| Age range: 0–8 y
| Mean height: ND
| Male: 49%
| Race: ND
| SES: ND
| Enrolled: 24
| Evaluated: 24
| Number of sites: 1

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Human Immunodeficiency Virus - Part II

Author, Year | Severity of Illness Groups | Outcomes
Brettler 1990 91011887 | Progression to AIDS or ARC (not defined) | Growth failure
| | Decrease in > 15 percentile points in height or weight for age for 2 consecutive years
Matarazzo 1994 95143841 | Clinical condition | Height SDS, based on Tanner 1966
| • Stable: not defined | Height velocity SDS
| • Clinical deterioration: not defined

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Human Immunodeficiency Virus - Part III

Author, Year | Associations found | Potential Biases | Comments
Brettler 1990 91011887 | Among boys with hemophilia and HIV infection “progression to AIDS or [AIDS related complex]” was more common in those with “growth failure” over 2 years (n=9, 55%) than those with normal growth (n=27, 7%). In multivariate analysis, “growth failure was the strongest prognostic variable” for progression to AIDS or AIDS related complex, adjusted for CD4, p24 antigenemia, and possibly other variables. | Methods, predictors and outcomes poorly defined | No data on funding source
| | Variables included in multivariate analysis not reported
| | Definition of growth failure includes weight
Matarazzo 1994 95143841 | Among children with perinatal HIV infection (n=24), those with stable disease courses (n=14) had mean height at 1 year follow-up of -0.7 SDS, mean height at 2 year follow-up of -0.7 SDS, mean height velocity at 1 year follow-up of +1.2 SDS, and mean height at 2 year follow-up of +0.4 SDS. Children with unstable disease courses (n=10) had lower heights and height velocities. Mean height at 1-year follow-up was -2.0 SDS, mean height at 2 year follow-up of -2.6 SDS, mean height velocity at 1 year follow-up of -2.6 SDS, and mean height at 2 year follow-up of -3.0 SDS. | Direct comparison of children with stable and unstable disease had to be calculated from reported raw data. | Study was government and privately funded
| “At follow-up [after 2 years], most children with normal growth maintained a stable clinical condition, whereas those with growth reduction showed progression in the severity of the disease…Growth failure was a simple, sensitive predictor of clinical course [stable condition vs clinical deterioration].” | Clinical condition not defined.
| | No statistical analysis.

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Atopic Dermatitis / Eczema - Part I

Author, Year | Demographics | Inclusion Criteria | Exclusion Criteria | Types of Diseases / Conditions | Study Design (Duration)
Massarano 1993 93312068 | Location: UK | Diagnosis of eczema | Chronic non-atopic disease which would limit growth | Atopic eczema | Prospective cross-sectional cohort
| Setting: Pediatric clinic | Prepubertal
| Mean age: 6 y
| Age range: 2.3–12 y
| Mean height: ND
| Male: 68%
| Race: ND
| SES: ND
| Enrolled: 68
| Evaluated: 68
| Number of sites: 1
Patel 1988 99014336 | Location: UK | Atopic dermatitis that began before age 1 y | Systemic steroids | Atopic dermatitis | Prospective longitudinal cohort
| Setting: Pediatric clinic | Prepubertal, age 2–11 y | | | (2 y)
| Mean age: 5.5±0.3 (SEM) | Referred by pediatrician or dermatologist because of severity of disease
| Age range: 2–10 y
| Mean height, initial, SDS: +0.1±0.1 (SEM)
| Mean height, follow-up, SDS: -0.1±0.2 (SEM)
| Male: 55%
| Race: ND
| SES: ND
| Enrolled: 80
| Evaluated: 80
| Number of sites:1

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Atopic Dermatitis / Eczema - Part II

Author, Year | Severity of Illness Groups | Outcomes
Massarano 1993 93312068 | Maximum percentage of skin surface area affected by atopic eczema (erythema, vesicle, and crusts) | Height SDS, based on Tanner 1966
| Subgroups by percentage of skin surface area affected
| • < 50%
| • > 50%
Patel 1988 99014336 | Percentage body surface area affected by atopic dermatitis | Height SDS, based on Tanner 1966
| • < 50% | Height velocity SDS
| • > 50%
| Coexistence of disease
| • With asthma
| • Without asthma

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Atopic Dermatitis / Eczema - Part III

Author, Year | Associations found | Potential Biases | Comments
Massarano 1993 93312068 | Among children with atopic eczema (n=68), in a multivariate regression analysis, height SDS was correlated with surface area of eczema, controlling for parental height, diet, duration of eczema, treatment and asthma. | None noted | No data on funding source
| Those children with < 50% of skin affected (n=41) had mean height of +0.11 SDS; those with 50% of skin affected (n=27) had significantly shorter mean height of -0.83 SDS.
| No height velocity data.
Patel 1988 99014336 | Among children with atopic dermatitis height SDS and height velocity SDS “did not differ between patients with < 50% body surface area (n=43) involvement and those with ≥ 50% body surface area involvement (n=37)…and between patients without asthma (n=36) and those with asthma (n=44).” | Complete results not reported. | No data on funding
| | No statistical analyses reported.

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Miscellaneous Diseases - Part I

Author, Year | Demographics | Inclusion Criteria | Exclusion Criteria | Types of Diseases / Conditions | Study Design (Duration)
Evliyaoglu 1996 97097381 | Location: Turkey | Homozygote sickle cell anemia | None reported | Homozygous sickle cell anemia | Prospective cross-sectional cohort
| Setting: Pediatric hematology clinic
| Mean age: 10 y
| Age range: 5.5–15 y
| Mean height, percentile: 20±22%
| Height range, percentile: 3–75%
| Male: ND
| Race: ND
| SES: ND
| Enrolled: 24
| Evaluated: 24
| Number of sites: 1
Rasat 1995 95372015 | Location: New Zealand | Congenital adrenal hyperplasia diagnosed and treated at one hospital between 1962 and 1993 | None reported | Congenital adrenal hyperplasia | Retrospective longitudinal case series
| Setting: ND | | | | (Median [Range] 14 [2–31] y)
| Median age: 15 y
| Age range: 2–31 y
| Mean height: ND
| Male: 50%
| Race: ND
| SES: ND
| Enrolled: 16
| Evaluated: 9
| Number of sites: 1
Samson-Fang 1998 99066563 | Location: US | Children with cerebral palsy | Genetic disorders | Cerebral Palsy | Retrospective cross-sectional cohort
| Setting: Rehabilitation center | Age < 10 years old at the mid-point of assessing growth interval | Complicating medical issues
| Mean age: 4.5 y | Minimum time interval of measurements of 0.8 years
| Age range: 1–12 y
| Mean height, SDS: -1.2±1.5
| Male: 53%
| Race: White 80%, Black 20%
| SES: ND
| Enrolled: 175
| Evaluated: 81
| Number of sites: 1

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Asthma Miscellaneous Diseases - Part II

Author, Year | Severity of Illness Groups | Outcomes
Evliyaoglu 1996 97097381 | Severity of sickle cell anemia | Height percentile (not defined)
| • Mild: No blood transfusion or crises
| • Severe: Blood transfusion needed early in life, frequent crises
Rasat 1995 95372015 | Number of episodes of biochemical escape from congenital adrenal hyperplasia suppression (morning 17-OH Progesterone > 60 nmol/L) | Height SDS. based on Tanner 1966
| • < 3 episodes over at least 2 years
| • > 3 episodes
Samson-Fang 1998 99066563 | Cerebral palsy cognitive impairment | Growth velocity SDS, based on Rikken 1992
| • Cognitive impairment: Learning disability, or delay in problem solving or receptive language skills
| • No cognitive impairment
| Type of cerebral palsy
| • Spastic
| • Extrapyramidal
| • Mixed
| Ambulatory status
| •Ambulatory: Functionally ambulated with or without aids at home
| •Non-ambulatory

Evidence Table 3. Association of Decreased Growth Velocity with Severity of Disease Abbreviations

Author, Year | Associations found | Potential Biases | Comments
Evliyaoglu 1996 97097381 | Among children with sickle cell anemia, those with mild disease (n=12) had significantly greater mean height percentile (22.5%) than those with severe disease (n=12, 17.3%). | Only mild and severe sickle cell. | No data on funding source
| No data on height velocity | Height measurement (percentile) not clear.
| | Unclear why all children had low height percentile
Rasat 1995 95372015 | Among children with congenital adrenal hyperplasia there was no significant difference in final height SDS in those with < 3 biochemical escape episodes (n=4) and those with > 3 episodes (n=5). | Very small numbers | No data on funding source
| No data on height velocity. | Results shown only graphically.
Samson-Fang 1998 99066563 | Among children with cerebral palsy those with cognitive impairment (n=62) had significantly lower mean growth velocity (-1.25 SDS) than those with no cognitive impairment (n=19, -1.25 SDS)) | Exclusion criteria limit most severe impairments due to cerebral palsy | Study was privately funded.
| Those age ≥ 2 years who were non-ambulatory (n=35) had significantly lower mean growth velocity (-1.20 SDS) than those who were ambulatory (n=37, -0.35 SDS).
| There was no significant difference in mean height velocity among those with spastic disease (n=22, mean height velocity = -0.69 SDS), those with extrapyramidal disease (n=36, -0.86 SDS), and those with mixed disease (n=22, -1.50 SDS)