# References and Bibliography

Online Mendelian Inheritance in Man. http://www.ncbi.nlm.nih.gov/Omim/.2002. Ref Type: Internet Communication
Disability evaluation under Social Security. Social Security Administration,Office of Disability; 1999
International consensus report on diagnosis and treatment of asthma. 92–3091. 1992. National Heart and Blood Institute, National Institutes of Health. Ref Type: Report
Instability of the upper cervical spine. Skeletal Dysplasia Group. Archives of Disease in Childhood 1989 Feb;64(2):283–8.
Abbott D, Rotnem D, Genel M, et al. Cognitive and emotional functioning in hypopituitary short-statured children. Schizophrenia Bulletin. 1982;8(2):310-9. [pmid: 7112044].
Abrams S A. Chronic pulmonary insufficiency in children and its effects on growth and development. [Review] [40 refs]. Journal of Nutrition. Mar. 2001;131(3):938S-41S. [pmid: 11238790].
Alston J. Children with brittle bones. Special Education: Forward Trends. Dec. 1979;6(4):18. [pmid: 531627].
Angehrn V, Zachmann M, Prader A. Silver-Russell syndrome. Observations in 20 patients. Helvetica Paediatrica Acta. Sep. 1979;34(4):297-308. [pmid: 521296].
Apajasalo M, Sintonen H, Rautonen J, et al. Health-related quality of life of patients with genetic skeletal dysplasias. European Journal of Pediatrics. Feb. 1998;157(2):114-21. [pmid: 9504784].
Arreola F, Junco E, Partida-Hernandez G, et al. HbA1, height velocity and weight gain as indicators of metabolic control in type I diabetic children. A 5 year survey. Archivos de Investigacion Medica. Jul. 1991;22(34):303-7. [pmid: 1844116].
Attie KM. Genetic studies in idiopathic short stature. [Review] [34 refs]. Current Opinion in Pediatrics. Aug. 2000;12(4):400-4. [pmid: 10943824].
Bacon GE, Spencer ML, Hopwood NJ et al. A practical approach to pediatric endocrinology. 3ed. Chicago, IL: Year Book Medical Publishers, Inc.; 1990:62–77
Bailey J A. Elbow and other upper limb deformities in achondroplasia. Clinical Orthopaedics & Related Research. Oct. 1971;80:75-8. [pmid: 5133334].
Balfour-Lynn L. Growth and childhood asthma. Archives of Disease in Childhood. Nov. 1986;61(11):1049-55. [pmid: 3098185].
Baum D, Beck R, Kodama A, et al. Early heart failure as a cause of growth and tissue disorders in children with congenital heart disease. Circulation. Dec. 1980;62(6):1145-51. [pmid: 7438349].
Benson D R, Donaldson D H, Millar E A. The spine in osteogenesis imperfecta. Journal of Bone & Joint Surgery - American Volume. Oct. 1978;60(7):925-9.
Bernstein B H, Stobie D, Singsen B H, et al. Growth retardation in juvenile rheumatoid arthritis (JRA). Arthritis & Rheumatism. Mar. 1977;20(2 Suppl):212-6. [pmid: 263898].
Bleck EE. Nonoperative treatment of osteogenesis imperfecta: orthotic and mobility management. Clinical Orthopaedics & Related Research 1981 Sep;(159):111–22.
Brettler D B, Forsberg A, Bolivar E, et al. Growth failure as a prognostic indicator for progression to acquired immunodeficiency syndrome in children with hemophilia. Journal of Pediatrics. Oct. 1990;117(4):584-8. [pmid: 2213383].
Brinkmann G, Schlitt H, Zorowka P, et al. Cognitive skills in achondroplasia. American Journal of Medical Genetics. Oct 1. 1993;47(5):800-4. [pmid: 8267016].
Cernelc D, Cernelc M. Comparative study of growth in asthmatic children and other children with chronic disease to a control group. Allergie und Immunologie. 1974;20–21(1):7-13.
Claris-Appiani A, Bianchi M L, Bini P, et al. Growth in young children with chronic renal failure. Pediatric Nephrology. Jul. 1989;3(3):301-4. [pmid: 2702111].
Constantoulakis M, Panagopoulos G, Augoustaki O. Stature and longitudinal growth in thalassemia major. A study of 229 Greek patients. Clinical Pediatrics. Apr. 1975;14(4):355-8. [pmid: 164311].
Court S, Parkin M, Roberts D F, et al. HLA antigens and growth in diabetic children. Annals of Human Biology. Jul. 1982;9(4):329-36. [pmid: 7125584].
Cox J R, Simmons C L. Osteogenesis imperfecta and associated hearing loss in five kindreds. Southern Medical Journal. Oct. 1982;75(10):1222-6. [pmid: 7123292].
Daly K, Wisbeach A, Sanpera I Jr, et al. The prognosis for walking in osteogenesis imperfecta [see comments]. Journal of Bone & Joint Surgery - British Volume. May. 1996;78(3):477-80. [pmid: 8636190].
Downie A B, Mulligan J, Stratford R J, et al. Are short normal children at a disadvantage? The Wessex growth study. BMJ. Jan 11. 1997;314(7074):97-100. [pmid: 9006466]. [pmcid: 2125607].
Downie A B, Mulligan J, McCaughey E S, et al. Psychological response to growth hormone treatment in short normal children. Archives of Disease in Childhood. Jul. 1996;75(1):32-5. [pmid: 8813867].
Engelbert R H, Gulmans V A, Uiterwaal C S, et al. Osteogenesis imperfecta in childhood: perceived competence in relation to impairment and disability. Archives of Physical Medicine & Rehabilitation. Jul. 2001;82(7):943-8. [pmid: 11441383].
Engelbert R H, Uiterwaal C S, Gulmans V A, et al. Osteogenesis imperfecta in childhood: prognosis for walking. Journal of Pediatrics. Sep. 2000;137(3):397-402. [pmid: 10969267].
Engelbert R H, Beemer F A, van der G Y, et al. Osteogenesis imperfecta in childhood: impairment and disability--a follow-up study. Archives of Physical Medicine & Rehabilitation. Aug. 1999;80(8):896-903. [pmid: 10453765].
Engelbert R H, Gerver W J, Breslau-Siderius L J, et al. Spinal complications in osteogenesis imperfecta: 47 patients 1–16 years of age. Acta Orthopaedica Scandinavica. Jun. 1998;69(3):283-6. [pmid: 9703404].
Engelbert R H H, Custers J W H, van der Net J, et al. Functional outcome in osteogenesis imperfecta: disability profiles using the PEDI. Pediatr Phys Ther. 1997;9:18-22.
Evliyaoglu N, Kilinc Y, Sargin O. Thyroid functions in mild and severe forms of sickle cell anemia. Acta Paediatrica Japonica. Oct. 1996;38(5):460-3. [pmid: 8942004].
Falvo K A, Klain D B, Krauss A N, et al. Pulmonary function studies in osteogenesis imperfecta. American Review of Respiratory Disease. Nov. 1973;108(5):1258-60. [pmid: 4746589].
Farmer R G, Michener W M. Prognosis of Crohn's disease with onset in childhood or adolescence. Digestive Diseases & Sciences. Oct. 1979;24(10):752-7. [pmid: 487911].
Feldt R H, Strickler G B, Weidman W H. Growth of children with congenital heart disease. American Journal of Diseases of Children. May. 1969;117(5):573-9. [pmid: 4181126].
Ferguson A C, Murray A B, Tze W J. Short stature and delayed skeletal maturation in children with allergic disease. Journal of Allergy & Clinical Immunology. May. 1982;69(5):461-6. [pmid: 7076986].
Fowler E S, Glinski L P, Reiser C A, et al. Biophysical bases for delayed and aberrant motor development in young children with achondroplasia. Journal of Developmental & Behavioral Pediatrics. Jun. 1997;18(3):143-50. [pmid: 9213228].
Frisch H, Hausler G, Lindenbauer S, et al. Psychological aspects in children and adolescents with hypopituitarism. Acta Paediatrica Scandinavica. Jun. 1990;79(67):644-51. [pmid: 2386056].
Gilmour J, Skuse D. Short stature--the role of intelligence in psychosocial adjustment. Archives of Disease in Childhood. Jul. 1996;75(1):25-31. [pmid: 8813866].
Gordon M, Post E M, Crouthamel C, et al. Do children with constitutional delay really have more learning problems?. Journal of Learning Disabilities. May. 1984;17(5):291-3. [pmid: 6202811].
Gordon M, Crouthamel C, Post E M, et al. Psychosocial aspects of constitutional short stature: social competence, behavior problems, self-esteem, and family functioning. Journal of Pediatrics. Sep. 1982;101(3):477-80. [pmid: 7108676].
Griffiths A M, Nguyen P, Smith C, et al. Growth and clinical course of children with Crohn's disease. Gut. Jul. 1993;34(7):939-43. [pmid: 8344582]. [pmcid: 1374230].
Hauspie R C, Gyenis G, Alexander F, et al. Heights and weights of Hungarian and Belgian asthmatic boys. Human Biology. Dec. 1979;51(4):507-21.
Hecht J T, Thompson N M, Weir T, et al. Cognitive and motor skills in achondroplastic infants: neurologic and respiratory correlates. American Journal of Medical Genetics. Nov 1. 1991;41(2):208-11. [pmid: 1785636].
Herber S M, Dunsmore I R. Does control affect growth in diabetes mellitus?. Acta Paediatrica Scandinavica. Mar. 1988;77(2):303-5. [pmid: 3354344].
Holmes C.S, Karlsson JA, Thompson RG. Longitudinal evaluation of behavior patterns in children with short stature. In: Stabler B and Underwood LE, editors. Slow grows the child: Psychosocial aspects of growth delay. Hillsdale, NJ: Lawrence Erlbaum Associates; 1986. p. 1–12.
Holmes C S, Karlsson J A, Thompson R G. Social and school competencies in children with short stature: longitudinal patterns. Journal of Developmental & Behavioral Pediatrics. Oct. 1985;6(5):263-7. [pmid: 4066961].
Hunter A G. Some psychosocial aspects of nonlethal chondrodysplasias: II. Depression and anxiety. American Journal of Medical Genetics. Jun 16. 1998;78(1):9-12. [pmid: 9637415].
Ismaili K, Schurmans T, Wissing K M, et al. Early prognostic factors of infants with chronic renal failure caused by renal dysplasia. Pediatric Nephrology. Mar. 2001;16(3):260-4. [pmid: 11322375].
Izumi K, Hoshi M, Kuno S, et al. Glycemic control, growth and complications in children with insulin-dependent diabetes mellitus--a study of children enrolled in a Summer camp program for diabetics in Kinki district, Japan. Diabetes Research & Clinical Practice. Jun. 1995;28(3):185-90. [pmid: 8529497].
Jivani S K, Rayner P H. Does control influence the growth of diabetic children?. Archives of Disease in Childhood. Feb. 1973;48(2):109-15. [pmid: 4690506].
Karlberg J, Schaefer F, Hennicke M, et al. Early age-dependent growth impairment in chronic renal failure. European Study Group for Nutritional Treatment of Chronic Renal Failure in Childhood. Pediatric Nephrology. Jun. 1996;10(3):283-7. [pmid: 8792391].
Kattamis C, Touliatos N, Haidas S, et al. Growth of children with thalassaemia: effect of different transfusion regimens. Archives of Disease in Childhood. Aug. 1970;45(242):502-9. [pmid: 5506935].
Kelts D G, Grand R J, Shen G, et al. Nutritional basis of growth failure in children and adolescents with Crohn's disease. Gastroenterology. Apr. 1979;76(4):720-7. [pmid: 105960].
Klein G L, Dungy C I, Galant S P. Growth and the nutritional status of nonsteroid-dependent asthmatic children. Annals of Allergy. Jul. 1991;67(1):80-4. [pmid: 1859045].
Konrad M, Zerres K, Wuhl E, et al. Body growth in children with polycystic kidney disease. Arbeitsgemeinschaft fur Padiatrische Nephrologie. Acta Paediatrica. Nov. 1995;84(11):1227-32. [pmid: 8580616].
Kranzler J H, Rosenbloom A L, Proctor B, et al. Is short stature a handicap? A comparison of the psychosocial functioning of referred and nonreferred children with normal short stature and children with normal stature [see comments]. Journal of Pediatrics. Jan. 2000;136(1):96-102. [pmid: 10636982].
Kuurila K, Grenman R, Johansson R, et al. Hearing loss in children with osteogenesis imperfecta. European Journal of Pediatrics. Jul. 2000;159(7):515-9. [pmid: 10923226].
Lai K Y, Skuse D, Stanhope R, et al. Cognitive abilities associated with the Silver-Russell syndrome. Archives of Disease in Childhood. Dec. 1994;71(6):490-6. [pmid: 7726606].
Levy R J, Rosenthal A, Miettinen O S, et al. Determinants of growth in patients with ventricular septal defect. Circulation. Apr. 1978;57(4):793-7. [pmid: 564759].
Madeddu G, Dore A, Marongiu A, et al. Growth retardation, skeletal maturation and thyroid function in children with homozygous beta-thalassaemia. Clinical Endocrinology. May. 1978;8(5):359-65. [pmid: 206391].
Mahoney C P. Evaluating the child with short stature. [Review] [91 refs]. Pediatric Clinics of North America. Aug. 1987;34(4):825-49. [pmid: 3302894].
Martin A J, Landau L I, Phelan P D. The effect on growth of childhood asthma. Acta Paediatrica Scandinavica. Sep. 1981;70(5):683-8. [pmid: 7324918].
Massarano A A, Hollis S, Devlin J, et al. Growth in atopic eczema. Archives of Disease in Childhood. May. 1993;68(5):677-9. [pmid: 8323339].
Matarazzo P, Palomba E, Lala R, et al. Growth impairment, IGF I hyposecretion and thyroid dysfunction in children with perinatal HIV-1 infection. Acta Paediatrica. Oct. 1994;83(10):1029-34. [pmid: 7841697].
McCauley E, Kay T, Ito J, et al. The Turner syndrome: cognitive deficits, affective discrimination, and behavior problems. Child Development. Apr. 1987;58(2):464-73. [pmid: 3829787].
McCauley E, Ito J, Kay T. Psychosocial functioning in girls with Turner's syndrome and short stature: social skills, behavior problems, and self-concept. Journal of the American Academy of Child Psychiatry. Jan. 1986;25(1):105-12. [pmid: 3950258].
Mcnicol K N, Williams H E, Gillam G L. Chest deformity, residual airways obstruction and hyperinflation, and growth in children with asthma. I. Prevalence findings from an epidemiological study. Archives of Disease in Childhood. Dec. 1970;45(244):783-8. [pmid: 5491882].
Meyer-Bahlburg H F, Feinman J A, MacGillivray M H, et al. Growth hormone deficiency, brain development, and intelligence. American Journal of Diseases of Children. Jun. 1978;132(6):565-72. [pmid: 207180].
Neville R G, McCowan C, Thomas G, et al. Asthma and growth--cause for concern? Asthma & Growth in Tayside Children. Annals of Human Biology. Jul. 1996;23(4):323-31. [pmid: 8830919].
Norimatsu H, Mayuzumi T, Takahashi H. The development of the spinal deformities in osteogenesis imperfecta. Clinical Orthopaedics & Related Research 1982 Jan;(162):20–5.
Norman L J, Coleman J E, Macdonald I A, et al. Nutrition and growth in relation to severity of renal disease in children. Pediatric Nephrology. Dec. 2000;15(34):259-65. [pmid: 11149122].
Oliva M M, Lake A M. Nutritional considerations and management of the child with inflammatory bowel disease. [Review] [76 refs]. Nutrition. Mar. 1996;12(3):151-8. [pmid: 8798217].
Osvath P. Allergical and immunological diseases of childhood (In Hungarian). Budapest: Medicina; 1976
Patel L, Clayton P E, Addison G M, et al. Linear growth in prepubertal children with atopic dermatitis. Archives of Disease in Childhood. Aug. 1998;79(2):169-72. [pmid: 9797602].
Pauli R M, Horton V K, Glinski L P, et al. Prospective assessment of risks for cervicomedullary-junction compression in infants with achondroplasia. American Journal of Human Genetics. Mar. 1995;56(3):732-44. [pmid: 7887429]. [pmcid: 1801157].
Pitukcheewanont P, Alemzadeh R, Jacobs W R, et al. Does glycemic control affect growth velocity in children with insulin-depende diabetes mellitus [published erratum appears in Acta Diabetol 1996 Mar;33(1). Acta Diabetologica. Oct. 1995;32(3):148-52. [pmid: 8590782].
Plotnick LP. Growth, growth hormone, and pituitary disorders. In: Oski FA, DeAngelis CD, Feigin RDet al., editors. Principles and practice of pediatrics. Philadelphia: Lippincott & Co.; 1990. p. 1803–11.
Polito C, Strano C G, Olivieri A N, et al. Growth retardation in non-steroid treated juvenile rheumatoid arthritis. Scandinavian Journal of Rheumatology. 1997;26(2):99-103. [pmid: 9137323].
Pollitt E, Money J. Studies in the psychology of dwarfism I. Intelligence quotient and school achievement. Journal of Pediatrics. 1964;64:415-21. [pmid: 14130715].
Poussa M, Merikanto J, Ryoppy S, et al. The spine in diastrophic dysplasia. Spine. Aug. 1991;16(8):881-7. [pmid: 1948373].
Rasat R, Espiner E A, Abbott G D. Growth patterns and outcomes in congenital adrenal hyperplasia; effect of chronic treatment regimens. New Zealand Medical Journal. Aug 11. 1995;108(1005):311-4. [pmid: 7644165].
Reid C S, Pyeritz R E, Kopits S E, et al. Cervicomedullary cord compression in young children with achondroplasia: value of comprehensive neurologic and respiratory evaluation. Basic Life Sciences. 1988;48:199-206. [pmid: 3240254].
Reite M, Davis K, Solomons C, et al. Osteogenesis imperfecta: psychological function. American Journal of Psychiatry. Jun. 1972;128(12):1540-6. [pmid: 4337133].
Rizzoni G, Basso T, Setari M. Growth in children with chronic renal failure on conservative treatment. Kidney International. Jul. 1984;26(1):52-8. [pmid: 6482179].
Robinson A, Bender B, Borelli J, et al. Sex chromosomal anomalies: Prospective studies in children. Behavior Genetics. 1983;13(4):321-9. [pmcid: 351728].
Rogers J G, Perry M A, Rosenberg L A. IQ measurement in children with skeletal dysplasia. Pediatrics. Jun. 1979;63(6):894-7. [pmid: 450527].
Rona R J, du V F. National study of health and growth: respiratory symptoms and height in primary schoolchildren. International Journal of Epidemiology. Mar. 1980;9(1):35-43. [pmid: 7419329].
Rosenbloom A L, Silverstein J H, Lezotte D C, et al. Limited joint mobility in diabetes mellitus of childhood: natural history and relationship to growth impairment. Journal of Pediatrics. Nov. 1982;101(5):874-8. [pmid: 7131180].
Ross J L, Feuillan P, Kushner H, et al. Absence of growth hormone effects on cognitive function in girls with Turner syndrome [see comments]. Journal of Clinical Endocrinology & Metabolism. Jun. 1997;82(6):1814-7. [pmid: 9177388].
Ross J L, Stefanatos G, Roeltgen D, et al. Ullrich-Turner syndrome: neurodevelopmental changes from childhood through adolescence. American Journal of Medical Genetics. Jul 31. 1995;58(1):74-82. [pmid: 7573160].
Rovet, J. F., Netley, C., and MacLeod, V. Cognitive Function in Individuals with Atypical Pubertal Development. 1986. Toronto, Ontario Mental Health Foundation. Ref Type: Report
Ruiz-Garcia M, Tovar-Baudin A, Castillo-Ruiz V, et al. Early detection of neurological manifestations in achondroplasia. Childs Nervous System. Apr. 1997;13(4):208-13.
Saha M T, Verronen P, Laippala P, et al. Growth of prepubertal children with juvenile chronic arthritis. Acta Paediatrica. Jul. 1999;88(7):724-8. [pmid: 10447130].
Saha M T, Ruuska T, Laippala P, et al. Growth of prepubertal children with inflammatory bowel disease. Journal of Pediatric Gastroenterology & Nutrition. Mar. 1998;26(3):310-4. [pmid: 9523867].
Salardi S, Tonioli S, Tassoni P, et al. Growth and growth factors in diabetes mellitus. Archives of Disease in Childhood. Jan. 1987;62(1):57-62. [pmid: 3813637].
Samson-Fang L, Stevenson R D. Linear growth velocity in children with cerebral palsy. Developmental Medicine & Child Neurology. Oct. 1998;40(10):689-92. [pmid: 9851238].
Sant'Anna C A, Sole D, Naspitz C K. Short stature in children with respiratory allergy. Pediatric Allergy & Immunology. Nov. 1996;7(4):187-92. [pmid: 9151340].
Schaefer F, Wingen A M, Hennicke M, et al. Growth charts for prepubertal children with chronic renal failure due to congenital renal disorders. European Study Group for Nutritional Treatment of Chronic Renal Failure in Childhood. Pediatric Nephrology. Jun. 1996;10(3):288-93. [pmid: 8792392].
Scharer K, Essigmann H C, Schaefer F. Body growth of children with steroid-resistant nephrotic syndrome. Pediatric Nephrology. Nov. 1999;13(9):828-34. [pmid: 10603130].
Shurka E, Laron Z. Adjustments and rehabilitation problems of children and adolescents with growth retardation. III. Bone diseases. Acta Med Auxiol. 1976;8:215-21.
Siegel P T, Clopper R, Stabler B. The psychological consequences of Turner syndrome and review of the National Cooperative Growth Study psychological substudy. Pediatrics. Aug. 1998;102(2 Pt 3):488-91. [pmid: 9685450].
Siegel PT, Clopper RR, Stoppani C et al. The psychological adjustment of short normal children and normal controls. In: Stabler B and Underwood LE, editors. Growth, stature, and adaptation. Chapel Hill: University of North Carolina; 1994
Siegel PT, Hopwood NJ. The relationship of academic achievement and intellectual functioning and affective conditions of hypopituitary children. In: Stabler B and Underwood LE, editors. Slow grows the child: Psychosocial aspects of growth delay. Hillsdale, NJ: Lawrence Erlbaum Associates; 1986. p. 57–71.
Skuse D, Gilmour J. Quality of life of children with normal short stature. Clinical Pediatric Endocrinology. 1997;6 (suppl 9):29-37.
Skuse D, Gilmour J, Tian CS et al. Psychosocial assessment of children with short stature: a preliminary report. Acta Paediatrica 1994 Dec;Supplement. 406:11–6.
Soliman A T, Ahmed H I, Asfour M G. Growth parameters, growth hormone (GH) response to clonidine and circulating insulin-like growth factor-I (IGF-I), free thyroxine (FT4) and cortisol concentrations in relation to glycaemic control in children with insulin-depe diabetes mellitus. Journal of Tropical Pediatrics. Aug. 1996;42(4):228-32. [pmid: 8816035].
Spock A. Growth patterns in 200 children with bronchial asthma. Annals of Allergy. Dec. 1965;23(12):608-15. [pmid: 5854309].
Stathis S L, O'Callaghan M J, Williams G M, et al. Behavioural and cognitive associations of short stature at 5 years. Journal of Paediatrics & Child Health. Dec. 1999;35(6):562-7. [pmid: 10634984].
Steinhausen H C, Stahnke N. Psychoendocrinological studies in dwarfed children and adolescents. Archives of Disease in Childhood. Oct. 1976;51(10):778-83. [pmid: 188386].
Stewart E J, O'Reilly B F. A clinical and audiological investigation of osteogenesis imperfecta. Clinical Otolaryngology & Allied Sciences. Dec. 1989;14(6):509-14. [pmid: 2612030].
Stokes D C, Pyeritz R E, Wise R A, et al. Spirometry and chest wall dimensions in achondroplasia. Chest. Feb. 1988;93(2):364-9. [pmid: 3338305].
Strangway A, Fowler R, Cunningham K, et al. Diet and growth in congenital heart disease. Pediatrics. Jan. 1976;57(1):75-86. [pmid: 128732].
Tanner J M, Lejarraga H, Cameron N. The natural history of the Silver-Russell syndrome: a longitudinal study of thirty-nine cases. Pediatric Research. Aug. 1975;9(8):611-23. [pmid: 168551].
Taybi H, Lachman RS. Radiology of syndromes, metabolic disorders, and skeletal dysplasias. 4ed. St Louis, MO: Mosby-Year Book, Inc.; 1996:746–951
Tejani A, Nicastri A D, Sen D, et al. Long-term evaluation of children with nephrotic syndrome and focal segmental glomerular sclerosis. Nephron. 1983;35(4):225-31. [pmid: 6358923].
Thompson N M, Hecht J T, Bohan T P, et al. Neuroanatomic and neuropsychological outcome in school-age children with achondroplasia. American Journal of Medical Genetics. Apr 16. 1999;88(2):145-53. [pmid: 10206234].
Tolmie JL. Down syndrome and other autosomal trisomies. In: Rimoin DL, Connor JM, and Pyeritz RE, editors. Principles and Practice of Medical Genetics. New York: Churchill Livingstone; 1997. p. 925–71.
Tsau Y K, Chen C H, Lee P I. Growth in children with nephrotic syndrome. Taiwan I Hsueh Hui Tsa Chih - Journal of the Formosan Medical Association. Sep. 1989;88(9):900-6.
US Census. Profiles of general demographic characteristics. 2000 Census of population and housing. 2001. Ref Type: Internet Communication
Vanelli M, de Fanti A, Adinolfi B, et al. Clinical data regarding the growth of diabetic children. Hormone Research. 1992;37 Suppl 3:65-9. [pmid: 1427645].
Voss LD, Mulligan J. The short normal child in school: sef-esteem, behavior, and attainment before puberty (The Wessex Growth Study). In: Stabler B and Underwood LC, editors. Growth, stature, and adaptation. Chapel Hill: University of North Carolina; 1994
Voss L D, Bailey B J, Mulligan J, et al. Short stature and school performance--the Wessex Growth Study. Acta Paediatrica Scandinavica - Supplement. 1991;377:29-31. [pmid: 1785313].
Waters K A, Everett F, Sillence D, et al. Breathing abnormalities in sleep in achondroplasia. Archives of Disease in Childhood. Aug. 1993;69(2):191-6. [pmid: 8215519].
White R I Jr, Jordan C E, Fischer K C, et al. Delayed skeletal growth and maturation in adolescent congenital heart disease. Investigative Radiology. Sep. 1971;6(5):326-32. [pmid: 4329610].
Wilson DM, Duncan PM, Dornbusch SM et al. The effects of growth on intellectual function in children and adolescents. In: Stabler B and Underwood LE, editors. Slow grows the child: Psychosocial aspects of growth delay. Hillsdale, NJ: Lawrence Erlbaum Associates; 1986. p. 139–50.
Wise J E, Kolb E L, Sauder S E. Effect of glycemic control on growth velocity in children with IDDM. Diabetes Care. Jul. 1992;15(7):826-30. [pmid: 1516499].
Young-Hyman D. Effects of short stature on social competence. In: Stabler B and Underwood LE, editors. Slow grows the child: Psychosocial aspects of growth delay. Hillsdale, NJ: Lawrence Erlbaum Associates; 1986. p. 27–45.