# Appendix B. Acronyms and Abbreviations

AAP | American Academy of Pediatrics
ACH | Achondroplasia
ADL | Activities of daily living
AHRQ | Agency for Healthcare Research and Quality
AIDS | Acquired immunodeficiency syndrome
ARC | AIDS-related complex
ARPKD | Autosomal recessive polycystic kidney disease
BAER | Brainstem auditory evoked responses
BAS | British Ability Scales
BASC | Behavior Assessment System for Children
BDI | Beck Depression Inventory
BSA | Body surface area
BSID | Bayley Scales of Infant Development
CARA | Chronic aspecific respiratory affection
CAS | Cognitive abilities score
CBCL | Child Behavior Checklist
CBPC | Child Behavior Problem Checklist
CGD | Constitutional growth delay
CHD | Congenital heart disease
CHF | Congestive heart failure
CHIPS | Children's Interpersonal Problem Solving Scale
CKD | Chronic kidney disease
CKF | Chronic kidney failure
CP | Cerebral palsy
CPQ | Children's Personality Questionnaire
DDST | Denver developmental screening test
Dept | Department
DM | Diabetes mellitus
EPC | Evidence-based Practice Center
ESRD | End-stage renal disease
FEV_1_/FVC | Forced expiratory volume in 1 second divided by forced vital capacity
FRNS | Focal relapsing nephrotic syndrome
FSGS | Focal segmental glomerular sclerosis
FSS | Familial short stature
FVC | Forced vital capacity
GFR | Glomerular filtration rate
GH | Growth hormone
GHb | Glycohemoglobin
GHD | Growth hormone deficiency
GVI | Growth velocity index
HANES | Hamburg Neuroticism Extraversion Scale
Hgb | Hemoglobin
Hgb A_1c_ | Hemoglobin A_1c_ (Glycosylated hemoglobin)
HIV | Human immunodeficiency virus
HRQOL | Health-related quality of life
IBD | Inflammatory bowel disease
IQ | Intelligence quotient
ISS | Isolated short stature
IUGR | Intrauterine growth retardation
JLO | judgment of line orientation
JRA | Juvenile rheumatoid arthritis
K-BIT | Kaufman-Brief Intelligence Test
KTEA | Kaufman Test of Educational Achievement
LPA | Little People of America
LPS | Structural Intelligence Test, in German
MES | Marburg Scales of Perceived Parental Behavior
MHD | Multiple hormone deficiency
min | Minutes
N&S | Nowicki and Strickland Locus of control scale
NCHS | National Center for Health Statistics
Neale | Neale analysis of reading ability, British edition
NS | Non-significant
OI | Osteogenesis imperfecta
ORNS | Occasional or no relapsing nephrotic syndrome
P CO2 | Carbon dioxide partial pressure
P O2 | Oxygen partial pressure
PEDI | Pediatric Evaluation of Disability Inventory
PIAT | Peabody Individual Achievement Test
PKD | Polycystic kidney disease
PPVT-R | Peabody Picture Vocabulary Test-Revised
RBQ | Rutter's Behavior Questionnaire
ROM | Range of motion
RR | Relative Risk
RSS | Russell-Silver Syndrome
RV | Residual volume
SB | Stanford-Binet Intelligence Scale
SD | Standard deviation
SDNS | Steroid dependent nephrotic syndrome
SDS | Standard deviation score
SEP | Somatosensory evoked potentials
SES | Socioeconomic status
SIT | Slosson Intelligence Test
SRNS | Steroid-resistant nephrotic syndrome
SSA | Social Security Administration
SSTAI | Spielberger State-Trait Anxiety Inventory Score
TS | Turner Syndrome
UC | Ulcerative colitis
VMI | Visual motor integration
VSD | Ventricular septal defect
WISC | Wechsler Intelligence Scale for Children
WRAT | Wide Range Achievement Test