# Appendix A

Table 1. Main search performed in MEDLINE^®^

# | Search History | Results | Summary
1 | disab$.af. | 66184 | Disability
2 | Limitation$.af. | 45673
3 | Handicap$.af. | 13104
4 | Impair$.af. | 152795
5 | 1 or 2 or 3 or 4 | 263105
6 | exp bone diseases, developmental/ | 36107 | Height, growth disorders and short stature
7 | exp growth disorders/ | 16301
8 | exp body height/ | 18639
9 | short stature.tw. | 3374
10 | 6 or 7 or 8 or 9 | 68793
11 | 5 and 10 | 3203 | Questions 1 & 2
12 | exp *bone diseases, developmental/ | 27528 | Linear growth and linear growth delay
13 | (short stature or skeletal dysplasia).tw. | 3798
14 | Growth velocity.tw. | 1257
15 | Growth retardation.tw. | 8452
16 | Growth delay.tw. | 1306
17 | Growth restriction.tw. | 725
18 | Height retardation.tw. | 16
19 | (height adj6 restrict$).tw. | 54
20 | linear velocity.tw. | 160
21 | (height adj6 delay).tw. | 89
22 | Length delay.tw. | 106
23 | (length adj6 retardation).tw. | 145
24 | exp growth disorders/ | 16301
25 | 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 | 51939
26 | *fetal development/ | 6938 | Excluded diseases/conditions
27 | *pregnancy/ | 21154
28 | *facial bones/ | 3492
29 | *facies/ | 103
30 | *failure to thrive/ | 443
31 | *thanatophoric dysplasia/ | 122
32 | *fetal growth retardation/ | 3897
33 | exp basal cell nevus syndrome/ | 536
34 | exp craniofacial dysostosis/ | 3267
35 | exp klippel-feil syndrome/ | 469
36 | exp synostosis/ | 4073
37 | exp funnel chest/ | 828
38 | exp gigantism/ | 823
39 | exp leg length inequality/ | 1670
40 | exp marfan syndrome/ | 2697
41 | exp fibrous dysplasia of bone/ | 2313
42 | exp hyperostosis, cortical, congenital/ | 353
43 | exp hyperostosis frontalis interna/ | 241
44 | exp exostoses, multiple hereditary/ | 601
45 | exp osteopetrosis/ | 1419
46 | exp osteopoikilosis/ | 209
47 | exp acquired hyperostosis syndrome/ | 37
48 | exp platybasia/ | 278
49 | 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 | 54379
50 | 25 not 49 | 32177 | Question 3
51 | 11 or 50 | 36731 | Questions 1, 2 & 3
52 | Case Report/ | 964105 | Exclude case reports
53 | 51 not 52 | 22559
54 | limit 53 to human | 18613 | Limit to humans and English language
55 | limit 54 to English language | 14258
56 | limit 55 to (newborn infant <birth to 1 month> or infant <1 to 23 months> or preschool child <2 to 5 years> or child <6 to 12 years> or adolescence <13 to 18 years>) | 9857 | Limit to children
57 | 55 not 56 | 4401
58 | limit 57 to (adult <19 to 44 years> or middle age <45 to 64 years> or “aged <65 and over>” or “aged, <80 and over>”) | 900
59 | 55 not 58 | 13358
60 | limit 59 to (addresses or bibliography or biography or comment or dictionary or directory or editorial or festschrift or interview or letter or news or periodical index) | 714
61 | 59 not 60 | 12644

Table 2. Supplemental searches performed in MEDLINE^®^

# | Search History | Results | Summary
1 | exp growth | 203509 | Growth/Growth disorders
2 | exp growth disorders | 16301
3 | 1 or 2 | 215194
4 | exp Heart diseases | 445916 | Growth & Heart disease
5 | 3 and 4 | 9467
6 | limit 5 to human, English, and children; Exclude main search results | 667
7 | exp Arthritis, rtheumatpid | 44173 | Growth & Arthritis
8 | 3 and 6 | 184
9 | limit 8 to human, English, and children; Exclude main search results | 47
10 | exp Asthma | 52692 | Growth & Asthma
11 | 2 and 8 | 618
12 | limit 11 to human, English, and children; Exclude main search results | 169
13 | 6 ro 9 or 12 | 883 | Total