# Evidence Tables

Evidence Table 1. Studies associating anthropometrics to Failure to Thrive cases compared to healthy control group in developed countries Part I

Author, Year, UI | Demographics | | | | Maternal / household demographics | | | Inclusion criteria | Exclusion criteria | Definition of FTT | Study design
Mitchell, 1980 80166667 | Country: US | | | | Maternal educ: ND | | | See Definition of FTT | Organic cause of FTT, single anomalous low wt recorded, clinic registration by age 6 mo, < 3 visits | Wt for age < 80% of nl up to age 24 mo | Ambidirectional longitudinal
| Setting: Outpatient clinic | | | | Income: ND | | | Controls - wt = 80% of nl, matched for age, sex, mother's age/ marital status & family problems | | | 1 fwup at age 3–6 y
| | [underlined: FTP] | [underlined: Ctrl] | | Health insur:
| Age(y) | 2–5 | 2–5 | | FTP-53% Medicaid
| Wt/age | ND | ND | | Ctrl-49% Medicaid
| Ht/length | ND | ND
| Enrolled : cohort of 312(323)*
| Evaluated | 30 | 282
| % Male | 36.7 | 51.8
| % Black | 70 | 70
| * See Potential biases column
Haynes, 1984 84233543 | Country: US | | | | [underlined: Maternal Educ] | [underlined: Income*] | | Consecutive admissions for NOFTT | ND | < 5 percentile or significant decline from birth wt percentiles | Prospective longitudinal
| Setting: Inpatient & Outpatient | | | | Gp1 10 | 379(0–750) | | Controls - thriving non-hospitalized patients matched for age, sex, birth wt, & mother's age, ethnicity, number of living children | | | 1 assessment 6 mo after intake
| Age: ND | | | | Gp2 11 | 372(0–950)
| Wt/age: ND | | | | Ctrl 10 | 362(0–1100)
| Ht/length: ND | | | | Health insur: ND
| | [underlined: FTT1]* | [underlined: FTT2†] | [underlined: Ctrl] | * @ mo
| Enrolled/Eval | 25 | 25 | 25
| % Race
| Sp-Am M | 44 | 44 | 44
| Sp-Am F | 40 | 52 | 52
| White M | 36 | 44 | 36
| White F | 36 | 24 | 28
| Black M | 20 | 12 | 20
| Black F | 24 | 24 | 20
| % Male: ND
| * std care & lay health visitor intervention, † std care only; M=male; F=female
Kelleher, 1993 93234174 | Country: US | | | | | [underlined: FTT] | [underlined: Ctrl] | Gestation age ≤ 37 wks, birth wt ≤ 2500 g, FTT | Live outside catchment area, discharged outside recruitment period, discharge or died within 48 hr, hospitalized > 60 d, oxygen support > 90 d, twin, triplet or quadruplet of ineligible child, maternal drug/alcohol abuse, insufficient Eng skills, psychiatric hosp | < 5^th^ percentile for gestation corrected age based on NCHS, growth status on “wt curve below that recorded at last regular assessment visit.” | Prospective longitudinal
| Setting: Primary care clinic | | | | Maternal educ(%) <HS | 40.6 | 38.1 | Controls matched for - birth wt +/- 250 g, maternal education, maternal race, & infant sex | | | Fwup at ages 12, 24, 36 mo
| | [underlined: FTT] | [underlined: Ctrl] | | HS | 30.0 | 29.3
| GA(wk)* | 33.0 | 33.1 | | Some col | 14.4 | 20.8
| Wt(g)* | 1679 | 1845 | | ≥ col grad | 15.0 | 11.8
| Enrolled: 842* | | | | Income <10K | 38.6 | 34.5
| Evaluated | 180 | 591 | | 10–20K | 19.9 | 23.9
| % Male | 52.2 | 47.9 | | >20K | 38.1 | 37.4
| Race: % Black | 50 | 53.8 | | Health insur: ND
| * At birth
Reif, 1995 95362505 | Country: Israel | | | | | [underlined: FTT] | [underlined: Ctrl] | FTT, < 2 y, term infants > 2500g birth wt | Organic cause of FTT, malnutrition, serious perinatal morbidity | Ht & wt < 5% in ≥ 2 measurements within 6 mo on Hamill PVV, Drizd TA growth chart, | Ambidirectional longitudinal
| Setting: Outpatient | | | | Maternal educ* | 12.27 (0.29) | 12.14 (0.24) | Controls matched for age, sex, social class, & ethnic affiliation; admitted or evaluated in ER for intercurrent & nonsign disease | | | Re-evaluation at mean 5.12 yr
| | [underlined: FTT] | [underlined: Ctrl] | | Income: ND
| Mean age(y) | 6.2 | 6.8 | | Health insur: Socialized medicine
| Wt/age* | 18.05 | 36.15 | | * Mean (SD)
| Ht/length* | 21 | 33.55
| Enrolled | 86 | 65
| Evaluated | 61 | 65
| % Male | 52.5 | 54
| Race:
| Sephardic | 38 | 36
| Ashkenazi | 23 | 29
Corbett, 1996 97113595 | Country: UK | | | | Maternal educ: ND | | | Full term singleton with records of 6 or more weights over first 18 months age | Non-Caucasian, “poor growth resulting from major organic disease” | Weight deviated downward from maximal centile achieved at 4–8 wks, across ≥ 2 centile lines, & stayed at level ≥ 2 measurements ( 1 mo (Tanner & Whitehouse) | Ambidirectional longitudinal
| Setting: Clinic | | | | Income: “...most economically deprived wards in Newcastle” | | | Consecutive controls matched for age & sex | | | 5 year follow-up of cases
| Age: 6–7 yr | | | | Health insur: National healthcare
| | [underlined: FTT] | [underlined: Ctrl]
| Wt/age | ND | ND
| Ht/length | ND | ND
| Enrolled | 52 | 52
| Evaluated | 48 | 46
| % Male: ND
| Race: 100% White
Black, 1999 99162090 | Country: US | | | | | [underlined: FTT] | [underlined: Ctrl] | < 25 mo, full-term, AGA, no congenital or handicapping conditions | ND | < 5% for wt for age or wt vs. ht by NCHS growth charts | Prospective longitudinal
| Setting: Outpatient | | | | Maternal educ* | 11.4 (1.62) | 10.76 (1.44) | | | | FTT: three 6 mo followed by annual visits from ages 3–6
| | [underlined: FTT] | [underlined: Ctrl] | | Income: AFDC 76% | | | | | | Control: annual visits ages 3–6
| Age: | ND | ND | | Health insur: ND
| Wt/age | <5% | >5% | | * Mean (SD)
| Ht/length | <5% | >5%
| Enrolled/Eval | 127 | 98
| Male: ND
| Race: 92% African American
Drewett, 1999 99284054 | Country: UK | | | | | [underlined: FTT] | [underlined: Ctrl] | At least 1 wt at age 0–2 mo & 2 subsequent wts, thrive index < 5^th^ centile = 2 occasions between 3 & 18 mo | ND | Lowest 5% for change of SD score; avg taken of SD scores for all wt bet 0–2 mo, expected wt from 3–18 mo calculated for “thrive index” | Ambidirectional longitudinal
| Setting: Clinic / home visits | | | | Maternal educ* | 72 | 66 | Controls with at least 1 wt at age 0–2 mo & 2 subsequent wts, no thrive index < 10^th^ centile, age ± 1 mo, similar/same residential area or GP practice | | | Five years from enrollment of age 1 y
| | FTT | Ctrl | | Income: NA
| Age(y) | 8.12(0.62) | 8.10(0.57) | | Health insur: National healthcare
| Wt(kg)* | 27.9 | 23.8 | | * % left school at 16 y
| BMI* | 14.9 | 16.3
| Enrolled | 136 | 136
| Eval† | 107/111 | 117/122
| % Male‡ | 40 | 38
| % White‡ | 91 | 91
| * Median, † Psychological / anthropometric evaluation, ‡ FTT = 107, Ctrl = 117

Evidence Table 1. Studies associating anthropometrics to Failure to Thrive cases compared to healthy control group in developed countries Part II

Author, Year | Correlates | Associations found | Potential biases | Comments
Mitchell, 1980 80166667 | Weight - % of normal | Expect wt and HC of the FTT group was significantly lower than the controls (p < .05 each), wt remained ~15% below control group through age 5, ht ~5% below till age 4. Expected ht was not significant. FTT girls recovered more slowly. | Physical exams & growth status by PI not blinded | Government & privately funded
| Height - % of normal
| HC - % of normal
Haynes, 1984 84233543 | Weight | All FTT had some wt gain during hospitalization, at reeval-some minor wt gain, 8 FTT gain > 20 percentile pts or within 5 percentile of birth wt percentile. There were no differences for both FTT groups compared to the controls after 6 mo for wt gain except in some minor cases. | “...because of scheduling, few admissions were not evaluated”, 2 refused participation; 10 Gp1 & 3 Gp2 premature - overall similar from FTT vs. Ctrl; at 6 mo fwup: for FTT1 & FTT2 each-3 cases refused reevaluation & from1 dissolution of pair, 1Gp1 died SIDS, 1 Gp2 mother gave up child | Block assignment to Gp1 & Gp2 for hospital convenience & case load requirements; government funded
Kelleher, 1993 93234174 | Anthropometric outcomes | FTT length, weight, & head circumference below 5^th^ percentile at 12, 24, 36 mo, below Control averages, p < 0.0001. | Of 985 enrolled, 71 LTF | 21% of sample developed FTT by 36 wks; ND on funding source
Reif, 1995 95362505 | Final weight | There were significant differences between FTT and Control groups for height (p < .01) and weight (p < .001), as well as compared to ideal ht/wt (p < .001). Mother's education was a significant covariate for FTT long-term wt (p < .05). Number of person's per room was a significant covariate for FTT long-term wt (p < .05) & long-term ht (p < .0005) | 25 cases not re-evaluated because not located or refused participation; inpatient enrollment of FTT-48 & Ctrl-42; outpatient enrollment of FTT-13 & Ctrl-23(ER) | ND on funding source
| Final height
| Ideal weight
| Long-term weight of FTT
| Long-term height of FTT
| Mother's education
| Persons @ room
Corbett, 1996 97113595 | Mean height SDS | Height and weight centiles were significantly lower (p = .020 & p < .001) in the FTT group at time of entering school | 3 from each group refused consent at follow-up, LTF or moved - 2 cases, 3 controls, 1 case not originally studied participated for follow-up study, 4 of those cases were the slowest growing 5% - also removed from home, all controls stayed with parents. Edward's diagnostic criteria for growth measure considered limited. | ND on funding source.
| Mean weight SDS
Black, 1999 99162090 | Height | Despite catch-up, wt & ht growth were significantly slower than controls for all fwup intervals; sex & education did not predict outcome; perception of poor child health correlates with poor growth; no gender differences for ht or wt, but girls grew faster than males. | --- | Government funded
| Weight
| Gender
Drewett, 1999 99284054 | Height | FTT children were smaller in ht (t = 6.3, p < .01), wt (χ^2^ = 27.9, p < .001), and head circumference (t = 3.86, p < .01), as well as have fathers who were also shorter than the controls. | Of 136 cases, 1 died, 9 LTF, 15 declined psychological testing, 4 moved; of 136 controls, 2 were preterm, 5 LTF, 12 declined psychological testing, 14 moved & were replaced. 2 FTT cases & 1 control with medical condition affecting growth, & 9 FTT cases & 2 controls with possible medical conditions | Testers blinded to child's status; privately funded
| Weight
| Head circumference

Evidence Table 2. Studies associating anthropometrics with malnourished patients compared to well-nourished control subjects in developing countries Part I

Author,Year | Demographics | | | | | Maternal / household demographics | | Inclusion criteria | Exclusion criteria | Definitionof malnutrition | Study design
Branko, 1979 79228898 | Country: Ethiopia | | | | | Maternal educ: ND | | Formerly hospitalized & for successful treatment of marasmus or kwashiorkor | ND | Marasmus: nutritional etiology, wt < 60% of Boston 50^th^ percentile for age/sex, absence of edema | Ambidirectional
| Setting: Outpatient | | | | | Income: ND | | | | Kwashiorkor: nutritional edema, growth retardation, muscular atrophy, “psychomotor alterations”, hair or pigment chg, or “moon face” | Last assessment avg 7½ (2.5) y after D/C
| | [underlined: Gp1*] | [underlined: Gp2]† | [underlined: Ctrl] | | Health insur: Free medical care
| Age(y) | 5.5–14 | 5.5–12.8 | 5–14
| Wt/age | ND | ND | ND
| Ht/age | ND | ND | ND
| Enrolled/eval | 44 | 43 | 559
| % Male | 61 | 48 | 52
| Race: 100% Black
| * Marasmus, † Kwashiorkor
Evans, 1980 81008912 | Country: South Africa | | | | | ND | | Gp1 - newborns of families with hx of undernutrition | ND | ND | Prospective longitudinal
| Setting: outpatient clinic | | | | | | | Ctrl1 - siblings with hx of undernourishment, record of `< 3^rd^ percentile for ht & wt | | | Fwup 6 ½ y after intervention
| Wt/age See Correlates column | | | | | | | Gp2 - at least 1 hospitalization for kwashiorkor
| Ht/length See Correlates column | | | | | | | Ctrl2 - siblings closet in age Gp2 w/no hx of kwashiorkor but underweight
| | [underlined: Gp1] | [underlined: Ctrl1] | [underlined: Gp2] | [underlined: Ctrl2]
| Mean age(SD) | 8.9(0.5) | 10.7(1.0) | 13(1.9) | 12(2.1)
| Enrolled | 14 | 14 | 14 | 14
| Evaluated | 14 | 13 | 14 | 13
| % Male | 64 | 54 | 100 | 77
| Race: “Cape coloured”
Galler, 1985a 85241832 | Country: Barbados | | | | | Maternal educ: ND, universal education, 95% population literate | | Discharged 5 – 11 yr olds w/dx at age 1 yr with PEM Grade II–III, BW > 5 lbs | Pre- or peri-natal complications, edema, seizures, head trauma, loss of consciousness, high fever | Gomez Scale PEM: Grade II- 61–75% or Grade III- ≤ 60% standard wt for age on Harvard Standard Scale | Ambidirectional longitudinal
| Setting: Outpatient | | | | | Income: lower for cases compared to control group | | Controls without PEM, matched for age, gender, handedness, & same school / neighborhood | 1985a/1985b: hx head seizures | | Fwup 6 – 12 y after D/C
| Age(y): 9–15 | | | | | Health insur: ND
| | [underlined: Gp] | [underlined: Ctrl]
| Wt/age | ND | ND
| Ht/length | ND | ND
| Enrolled | 141 | 129
| Evaluated | 108 | 107
| % Male | 57 | 60
| Race: 100% Black
Alvear, 1986 86185605 | Country: Chile | | | | | ND | | Hx of hospitalization for PEM at yrs 1–2, Chilean population & white Amerindian origin from Santiago Chile, SES grade 5 or 6 (modified Graffar scale) | Hormonal imbalance, debilitating disease not due to nutritional deficiency | PEM at yrs 1–2; < 60% wt for age, < 85% wt for length | Prospective longitudinal
| Setting: Outpatient | | | | | | | | Controls matched for age/sex/SES, attend same nursery sch as cases, no hx of mal-nourishment, normal wt & ht (WHO) | | | 4 y after D/C
| | [underlined: Gp] | [underlined: Ctrl]
| Age(mo) | 16(8–20) | ND
| Wt/age* | ND | ND
| Ht/length* | ND | ND
| Enrolled/Eval | 40 | 38
| % Male | 45 | 47
| Race: ND*
| * See inclusion criteria
Grantham-McGregor, 1987, 1982 82236679 87117313 | Country: Jamaica | | | | | Maternal educ: HS not completed | | Gp, age 6 – 24 mo, attempt for SES of mothers who had not completed secondary education, substandard housing, residence in city of Kingston | Physical handicap, disease that might affect mental development (other than malnutrition) | Severe PEM based on Wellcome classification | Prospective longitudinal
| Setting-Recruitment: hospital | | | | | Income: housing ‘below certain defined standards’ | | Control - included above criteria but adequately nourished, hospitalized with diseases other than malnutrition | | | 6 fwups from 6 to 72 m after D/C l
| Follow-up: hospital & home | | | | | Health insur: ND
| | [underlined: Gp1*] | [underlined: Gp2]† | [underlined: Ctrl]† | | | [underlined: Maternal PPVT]
| Age: | 12.8(2.9) | 13.4(4.5) | 12.2(4.4) | | Gp1 | 62.3(14.7)
| | | | | | Gp2 | 59.7(15)
| Ht/age‡ | 89.0(4.5) | 88.4(4.4) | 101.3(3.5) | | Ctrll | 67.4(9.3)
| HC/age‡ | 91.3(3.7 | 91.2(3.3) | 99.0(3.8)
| Wt/ht‡ | 74.9(9.2) | 72.4(10.2) | 89.0(10.1)
| Enrolled | 21 | 18 | 21
| Evaluated | 18 | 16 | 20
| % Male: | 67 | 38 | 60
| Race: ND, assumed Black
| Mean (SD) for evaluated cases; * Intervention, † Standard care, ‡ % of expected value
Bénéfice, 1992 92296639 | Country: Senegal | | | | | ND | | Age 9 – 14 y from 2 villages with per capita caloric intake of 2200 & 2400 | Recent serious illness, clinical signs of malnutrition or anemia | Wt/age < -1 SD median WHO/NCHS | Prospective cross-sectional
| Setting: Outpatient
| Age: ND
| Enrolled: 100
| Evaluated: Gp 64, Ctrl 34
| % Male: 46
| Race: ND
Walker, 1996 97154651 | Country: Jamaica | | | | | ND | | Stunted children 9 – 24 mo, weight for age < -2 SD, housing & maternal education below standard level, singleton, BW > 1,8 kg | Physical or mental handicap | See Inclusion criteria | Prospective longitudinal
| Setting: Outpatient | | | | | | | Nonstunted children matched for age, sex, & neighborhood | | | Assessments @ 2 & 4 y after intervention
| Mean age*: 18.7(4.1) mo
| Enrolled: Stunted 129
| Nonstunted 32
| | [underlined: Gp1]† | [underlined: Gp2]‡ | [underlined: Gp3]§ | [underlined: Ctrl1]\|\| | [underlined: Ctrl2]¶
| Eval | 31 | 29 | 30 | 32 | 32
| | [underlined: Wt(kg)]** | [underlined: Ht(cm)]** | [underlined: % Male]††
| Gp1 | 8.61(0.97) | 73.3(3.5) | 61
| Gp2 | 8.43(0.90) | 72.9(3.9) | 55
| Gp3 | 8.37(0.90) | 72.9(3.6) | 57
| Ctrl1 | 8.65(1.03) | 72.8(4.3) | 59
| Ctrl2 | 11.46(1.06) | 82.3(4.6) | 56
| Race: ND
| Mean(SD), * N = 129, † supplement, ‡ Psychosocial, § Both intervention, \|\| No intervention, ¶ Nonstunted, ** Enrollment, †† Evaluation

Evidence Table 2. Studies associating anthropometrics with malnourished patients compared to well-nourished control subjects in developing countries Part II

Author, Year | Correlate & measures | | | | | | Associations found | Potential biases | Comments
Branko,1979 79228898 | | [underlined: Gp1] | [underlined: Gp2] | [underlined: Ctrl*] | | | Maramus gp was on avg 3 cm smaller than Ctrl (p < .011), weighed 2.1 kg less, (p < .011), and their HC was 0.85 cm less (p < .007); | --- | ND on funding source
| Ht (cm) | 93–154 | 90.0–143 | 99.1(3.6)–144.7(3.3) | | | The Kwashiorkor gp was smaller than Ctrl on avg 0.84 cm (p < .607), weighed 0.6 kg less (p < .082), & their HC was 0.3 cm smaller (p < .368);
| Wt(Kg) | 11.4–35.0 | 11.0–29.5 | 14.6(1.2)–34.3(5.4) | | | Comparing Marasmus vs. Kwashiorkor gps, the Kwashiorkor gp was heavier (p < .05), taller (p < .02), & had larger HC (p < .05).
| HC (cm) | 47.0–53.0 | 48.0–53 | 49.0(0.8)–53.4(1.1)
| * mena range by sex & age ranges of 6 mo from age 5 to 14 y
Evans, 1980 81008912 | | [underlined: Gp1] | [underlined: Ctrl1] | [underlined: Gp2] | [underlined: Ctrl2] | | 2 years after supplementation had ceased, height & weight were significantly higher for Gp1 (p < 0.01) vs. 3 other groups; by 6.5 + y post-intervention, there were no differences. | 1 child died in each of the controls, sex unkn | Gp1 received supplements until mean 28 mo, examiner blinded to subject's group status, testing 6–7 y after cessation of supplements; US government & South African Medical Research Council
| ~Wt1* | 86 | 77 | 75 | 72
| ~Ht1y* | 90 | 84 | 82.5 | 82
| ~Wt2† | 79 | 78 | 77 | 76
| ~Ht2† | 90 | 89.5 | 90 | 90
| * 2 y after supplements, † 6.7 y after supplements
Galler, 1985a 85241832 | | [underlined: Gp?] | [underlined: Ctrl?] | [underlined: Gp?] | [underlined: Ctrl?] | | At ages 9–15, there was persistent poor height & weight gain for the index group with emphasis on the girls' weight (F = 28.88, p < .001). Early PEM was a predictor of sexual maturation for females (F = 5.69, p < .001). | 1983-Withdraws/non-participation - 4 refused consent, 7 LTF, 1 cerebral palsy; Severe PEM | Relevant WISC subtests utilized & some items altered for cultural setting; findings of dominant hand performance of fine motor skill tasks deficient in formerly malnourished children correlates or co-varies with IQ & other soft neurologic signs; private & hospital funded
| Ht* | 148.92(12.5) | 150.4(12.18) | 145.25(11.4) | 149.63(11.02)
| Wt† | 37.02(10.74) | 39.37(10.35) | 35.42(7.63) | 41.9(35.42)
| *cm, † kg
Alvear, 1986 86185605 | | [underlined: Gp?] | [underlined: Gp?] | [underlined: Ctrl?] | [underlined: Ctrl?] | | At birth, the cases were smaller in wt (boys p < 0.01, girls p < 0.001) and length (boys p < 0.01, girls p < 0.001) compared to controls. At the end of follow-up, there was no difference in bone age between cases and control groups by group or by sex, but there was a significant difference for female cases who were smaller than male cases for bone age (p < .01). Arm fat areas were greater for controls vs. cases (girls p < .001, boys p < .05). | --- | No data on whether children were failing to thrive at 4–6 years when anthropological data were collected; university funded
| Birth wt | 3018.2(490.3) | 2654.6(579.0) | 3453.5(522.3) | 3328.4(563.4)
| Birth length | 48.4(2.2) | 46.8(2.6) | 51.1(2.3) | 49.5(2.2)
| Bone age* | 60.3(8.6) | 76.7(14.2) | 69.2(9.7) | 86.7(27.2)
| Arm fat area | 73.5(15.3) | 64.5(16.5) | 91.0(24.7) | 95.7(28.5)
| * Gp n=25 (?=12, ?=13), Ctrl n=20 (?s=9, ?=11)
Grantham-McGregor, 1987, 1982 82236679 87117313 | | [underlined: Gp1] | [underlined: Gp2] | [underlined: Ctrl] | | | Assessments 6, 12, 18, 24 months; weight for height measures were not statistically significant, but the two case groups were significantly shorter for all time points than the control group (p < 0). At 24, 36, 48, 60, & 72 month; height for age was significantly lower for the two groups vs. controls. | Controls had better housing than other 2 groups regardless of attempts to match; 2 died & 1 WD from intervention group, 1 from nonintervention moved & 1 was adopted by middle-class family, 1 from control WD; edema: Gp1 10 of 21, Gp2 4 of 18, Ctrl 0 of 21 | Tester blinded to subjects' group, controls hospitalized mainly for gastroenteritis & respiratory infections; government & private funding
| Wt for ht* | 91.7(7.5) | 95.1(8.4) | 92.5(6.8)
| Ht for age* | 94.9(2.5) | 93.9(4.5) | 100.6(3.8)
| Assessment at 72 mo, * Mean percentages
Bénéfice,1992 92296639 | | [underlined: Gp] | [underlined: Ctrl] | | | | Children with malnutrition had less body fat (t = 3.5, p < .001) & arm muscle (t = 6.0, p < .001) compared to nourished controls. | Child's age determined by recall, no records available; no explanation on missing case from each group not in analyses | ND on funding source
| % body fat | 15.0(0.28) | 16.9(0.39)
| Arm muscle area | 18.7(0.33) | 21.8(0.47)
| Adjusted mean (SD)
Walker, 1996 97154651 | | [underlined: Gp1] | [underlined: Gp2] | [underlined: Gp3] | [underlined: Ctrl1] | [underlined: Ctrl2] | Signf for three measures of Ctrl2 vs. combined stunted groups, p < .001, covariates - sex & age (mean 7.7 @ gp) | 127 of 129 children completed studies; 4 yr after completion of intervention, of stunted gps - 3 relocated & 2 LTF | Observers blinded to child's group, evaluation 4 y after 2 y intervention; privately funded
| Ht(c) | 119.8(5.0) | 119.5(5.4) | 118.8(4.1) | 118.9(4.7) | 130.9(4.9) | No difference between the different groups of stunted children in height, weight, and head circumference, but difference between the combined stunted groups with non-stunted children.
| Wt(k) | 21.2(3.5) | 20.9(3.1) | 19.9(1.9) | 20.4(2.2) | 26.2(2.3)
| HC(c) | 51.2(1.3) | 50.9(1.4) | 51.0(1.3) | 50.8(1.5) | 52.4(1.4)

Evidence Table 3. Studies associating immunologic response or infectious diseases with Failure to Thrive patients compared to healthy control subjects in developed countries Part I

Author, Year, UI | Demographics | | | Maternal / household demographics | | | Inclusion criteria | Exclusion criteria | Definition of FTT | Study design
Carvalho,1984 85145406 | Country: Brazil | | | ND | | | Moderate & chronic primary PCM, > 6 mo < 5 y, body wt 25.1 & 40% of “standard values”, subcutaneous tissue, absence of edema, arm circumference < 13.5 cm, ht “within normal limits”, low SES | Infection, transfusions, general anesthetics, corticosteroids or immunotherapy < 6 mo prior, drug tx | ND | Prospective cross-sectional
| Setting: Outpatient clinic | | | | | | Controls - same criteria but “normal” body weight, “good- economic level and enjoyed good nutritional intake”
| Age: ND
| | [underlined: FTT] | [underlined: Ctrl]
| Enrolled/ Eval | 20 | 40
| % Male: ND
| Race: ND
Sherrod, 1984 85026403 | Country: US | | | | [underlined: NOFTT] | [underlined: Ctrl] | NOFTT, abused, or neglected | ND | Wt gain fallen below 2/3 of Harvard 50^th^ percentile on growth curve | Retrospective longitudinal
| Setting-Recruitment: Prenatal clinic | | | Maternal educ | 10.3 | 11.2 | Controls - no hx of abuse, FTT, or neglect | | | 3 annual assessments
| Follow-up: Pediatric clinic | | | Income* | 13 | 13
| | [underlined: NOFTT] | [underlined: Ctrl] | Health Insur† | ND | ND
| Birth wt(g) | 3031 | 3054 | * # employed, † p < .05, ‡ p < .01
| Enrolled/ Eval* | 31 | 24
| Race-White | 10 | 14
| Black | 21 | 10
| % Male: ND
| * 4 arm study - Data for FTT & Ctrl only;abused or neglected cases excluded

Evidence Table 3. Studies associating immunologic response or infectious diseases with Failure to Thrive patients compared to healthy control subjects in developed countries Part II

Author, Year, UI | Correlates | Measures | | | | | Method / Instruments utilized
Carvalho, 1984 85145406 | Phagocytosis | | [underlined: FTT] | [underlined: Ctrl] | [underlined: % variation] | | Light microscope phagocytosis assay (% zymosan particles ingested)
| Eagle solution | | 18.7(7.3) | 27.6(9.2) | -32.3 | p < .01
| NI human serum | | 54.2(24.6) | 78.5(7.8) | -30.9 | p < 001
| Patient serum | | 56.7(22.4) | 75.9(10.9) | -25.3 | p < .01
| Chemotaxis | | | | | | Boydan chamber (avg distance cells migrate)
| Eagle solution | | 25.4(10.0) | 34.2(8.0) | -26.0 | p < .01
| LPS & nl human serum | | 42.6(17.7) | 64.4(15.3) | -33.8 | p < .001
| LPS & patient serum | | 44.3(19.0) | 68.5(18.4) | -35.3 | p < .001
| Total complement (u/ml) | | 235.2(55.1) | 244.6(61.6) | -3.8 | NS | Percent cell lysis
| C3 (mg/dl) | | 89.3(21.3) | 80.5(19.3) | +10.9 | NS
| C4 (mg/dl) | | 38.5(11.2) | 37.3(13.3) | +3.4 | NS
Sherrod, 1985 85026403 | Infections | | [underlined: NOFTT] | [underlined: Ctrl] | | | Chart review
| | 1y | 1.13 | .46
| | 2y | .35 | .29
| | 3y | .03 | .00

Evidence Table 3. Studies associating immunologic response or infectious diseases with Failure to Thrive patients compared to healthy control subjects in developed countries76 Part III

Author, Year | Associations found | Potential biases | Comments
Carvalho, 1984 85145406 | The values for phagocytosis response and chemotactic function were significantly lower for the malnourished children in 3 tests: Zymosan incubated in Eagle, incubated with pooled normal human serum & incubated with serum from patient. The values were not significant for total complement, C3 and C4 components. | Cases and controls from different hospitals serving different SES groups; no data on age matching | Phagocytosis tests on 20 children, chemotaxis on other 20, total complement on 20 chosen at random; privately funded
Sherrod, 1985 85026403 | NOFTT had more infections than controls during the 1^st^ year (χ^2^ = 5.38, p < .025) and across all 3 years (χ^2^ = 5.79, p < .025). NOFTT illness were significantly increased during first 6 mo of life. | Attending physicians alerted to give special treatment to children suffering from maltreatment, analysis showed no increase in outcome variability; study design to identify relationship of illness to abuse, not FTT to illness | Data collectors blind to child group assignment; government & privately funded

Evidence Table 4. Studies associating immunologic response or infectious diseases with malnourished patients compared to wellnourished control subjects in developing countries Part I

Author, Year, UI | Demographics | | | | | Maternal / household demographics | Inclusion criteria | Exclusion criteria | Definition of malnutrition | Study design
Ferguson, 1974 75022280 | Country: Ghana | | | | | ND | Severe protein-calorie malnutrition | ND | Severe protein-calorie malnutrition | Prospective cross-sectional
| Setting: Cases - inpatient | | | | | | Controls - “normal”, matched for age
| Controls - ND
| | [underlined: Gp] | [underlined: Ctrl]
| Mean age(mo) | 28.9(12–48) | 38.8(24–55)
| Wt/age | ND | ND
| Ht/length | ND | ND
| Enrolled/Eval | 10 | 10
| % Male | ND | ND
| Race | ND | ND
Neumann, 1975 75106463 | Country: Ghana | | | | | ND | See Definition of FTT | ND | Gp1: 51–60% of 50^th^ percentile Harvard Std for American children & albumin < 2.5 g/100ml, Gp2: 71–80% of Harvard Std & albumin > 2.5 g/100ml | Prospective cross-sectional
| Setting: hospital/in & outpatient clinic | | | | | | Controls matched for age, = 81% Harvard Std, nl serum albumin, no signs of malnutrition
| Age: 6 mo – 6 y
| Wt/age: ND
| Ht/length: ND
| | [underlined: Gp1*] | [underlined: Gp2†] | [underlined: Ctrl]
| Enrolled/Eval | 34 | 42 | 41
| % Male | 62 | 50 | 44
| Race: Africans (assumed black)
| * Severely malnourished: kwashiorkor(23) & marasmus(11), † Moderately malnourished
Tuck, 1979 79254720 | Country: Australia & Indonesia | | | | | ND | ND | Immunological deficiencies in normal children attending hospital in one site | NA | Prospective cross-sectional
| Setting: Hospital | | | | | | | | (Patients classified according to Wellcome Working Party: underweight - 60–80% SWFA, marasmic - < 60% SWFA)
| Setting: Hospital
| Age(mo): ND
| Wt/age: ND
| Ht/length: ND
| Enrolled/Eval:
| Gp1 marasmic 21
| Gp2 underweight 23
| Gp3 normal 25
| % Male: ND
| Race: ND
Friedland, 1992 93159117 | Country: South Africa | | | | | ND | Children w/kwashiorkor, marasmus, marasmic kwashiorkor admitted, ages 2 – 84 mo | ND | Wellcome criteria with growth charts from NCHS | Prospective cross-sectional
| Setting: Inpatient | | | | | | Controls - “well-nourished & children w/nutritional growth retardation admitted during same time period”, same age range
| | [underlined: Gp] | [underlined: Ctrl]
| Age(mo) | 11 | 12
| Enroled/Eval | 1582 | 7282
| % Male | ND | ND
| Race: ND (assumed all black)
Ballard, 1995 95239862 | Country: Kenya | | | | | Maternal reading level - average 3.5 yrs of schooling | 14–25 mo, free from lower respiratory infections for = 4 wks | ND | Gp1 - ht/age < 90% of median | Prospective longitudinal cohort
| Setting: Rural village/ community outreach | | | | | | Controls - “normal;” | | Gp2 - ht/age 90% to <95% of median | Followed for max of 12 mos
| Mean age*: 19.2 m (17.7–25.1)
| Wt/age: ND
| Ht/length: ND
| Enrolled: 114
| Evaluated† | [underlined: Gp1] | [underlined: Gp2] | [underlined: Ctrl]
| | 27 | 51 | 31
| 49% Male (enrollment)
| Race: 100% Black Africans
| * At enrollment, † Gp1 Mod-severe malnutrition, Gp2 Mild malnutrition
Pandey, 1996 97246349 | Country: India | | | | | ND | Random selection of < 5 y | ND | Graded nutritional status as GrI though GrIV clinically & by wt/age | Prospective longitudinal
| Setting: Outpatient | | | | | | | | | Assessments @ 2 wks for 1 y
| Age(mo): Range 0–59, Mode 24–35
| Enrolled: 200 households
| Evaluated:
| [underlined: Gr1] | [underlined: GrII] | [underlined: GrIII] | [underlined: GrIV] | [underlined: NI]
| 37 | 56 | 18 | 4 | 85
| % Male: ND
| Race: ND

Evidence Table 4. Studies associating immunologic response or infectious diseases with malnourished patients compared to wellnourished control subjects in developing countries Part II

Author, Year | Correlates / Outcomes and measures | | | | | | Associations found | Potential biases | Comments
Ferguson, 1974 75022280 | Immunologic - Rosette forming cells | | | | | | (percent of total lymphocytes) Gp - 16.6% (2.7 SE), Ctrl - 59.7% (1.4 SE) | 7 diagnosed kwashiorkor & 3 with marasmus | US government funded
| | | | | | | Marked decrease in rosette forming cells (measure of cellular immunity) in severe malnutrition; RFC re-measured in 5/10 cases 7–17 d after feeding high protein, high calorie diet - values returned to nl (%RFC = 63.2% ± 2.4). Other measures of impaired immune function - in vitro response of lymphocytes to PHA stimulation showed trend to be diminished in cases, but NS (no data)
Neumann, 1975 75106463 | Clinical infections / parasites | | | | | | There was a marked increased in infections for severely malnourished group (Gp1), slight increase for the moderate malnourished group (Gp2) compared to Ctrl. The incidence of intestinal parasites were similar across the 3 gps, except for 10x increase in strongyloides stercoralis for Gp1, and 1 malarial case @ gp. Tonsil sz was decreased signf in Gp1 vs. Gp2 & Ctrl. | Gp1 hospitalized cases, 16 of 34 had received nutritional tx before studies, Gp2 included 25 newly admitted & 17 living in orphanage or attendance at rehab clinic & were treated. Controls attended private nursery school or resided in orphanage & had some vitamin/mineral deficiencies | Government funded
| Antibody responses | | | | | | Antibody responses were similar across all 3 gps. Lymphocyte response was signf lower in Gp1 vs. Gp2 or Ctrl. Cutaneous delayed hypersensitivity to PHA, monilia, SK-SD was signf lower in Gp1 & Gp2 vs. Ctrl. Response to KLH was slightly lower in the cases.
| | [underlined: Gp1] | [underlined: Gp2] | [underlined: Ctrl] | | | Vitamin deficiencies in all groups, most prevalent in Gp1. Complement 3 decreased signf in Gp1 vs. Gp2 & Ctrl; NS results for 4. Other nutritional deficiencies included decreased iron & transferrin in Gp1.
| Tonsil size*. | (%) | (%) | (%)
| Score† 0 | 36 | 5 | 0
| 1+ | 52 | 50 | 34
| 2+ | 12 | 40 | 56
| 3+ | 0 | 5 | 10
| Delayed hypersensitivity response
| Lymphocyte response† | 19 | 0 | 0
| PHA‡ | 44 | 29 | 5
| Monilia‡ | 59 | 38 | 20
| SK-SD‡ | 76 | 57 | 23
| KLH‡ | 5 | 0 | 0
| Total serum proteins(SE) | 5.1(.4)/6.3(.4)§ | 7.5(.1) | 7.9(.1)
| CBC & differential
| Hemoglobin | 60 | 17.5 | 12.5
| Iron | 44.8 | 29.7 | 20
| %Transferrin saturation | 41.3 | 55.3 | 50
| Complement - C3 | 60.4(4.1) | 86(3.9) | 86.9(2.4)
| * 0 = trace or absent, 1 = visible, 2 = enlarged beyond arch, 3 = extended past arch to uvula midline; † Percent reduced response; ‡ Percent nonresponders, § kwashiorkor/marasmus
Tuck, 1979 79254720 | Candida killing capacity | | | | | | Candida-killing ability, as determined by Kolmogorov-Smirnov test, was reduced in each of two underweight populations compared with the well-nourished population (p < .001), NS between the underweight & marasmic gps | Normal adults included in the control group, number of adults not known, site(s) of adults unknown, one of the 3 sites had no malnourished children who may have also been outpatients | NS between the two malnourished groups on ability to resist candida; ND on funding source
| [underlined: Marasmic] | [underlined: Underweight] | [underlined: Normal]
| 13.7%(3.4)* | 17.6%(4.4)* | 44.5%(8.8)* * SEM
Friedland, 1992 93159117 | | [underlined: Gp] | [underlined: Ctrl] | | | | Index group are statistically significantly at higher risk than control group for community-acquired bacteremia (p < 0.001, RR for FTT 1.6, CI 1.3 – 1.9), nosocomial bacteremia (p < 0.001, RR for FTT 2.0, CI 1.4 – 3.0), and mortality, including mortality related to bacteremia (p < 0.001, RR for FTT 3.2, CI 2.7 – 3.8). | Index group considered severe malnutrition. Control group consisting of “nutritional growth retardation” which most likely represents what is recognized as FTT. Both factors invalidates the "controls' | Risk of death of malnourished children 2.5 more likely to die than bacteremic non-malnourished; ND on funding source; Government, private, & hospital funded
| Bacteraemia | (%) | (%)
| Community acquired | 7.7 | 4.9
| Nosocomial | 2.2 | 1.1
| Overall | 9.9 | 6.0
| Mortality
| Overall | 13.3 | 4.1
| With bacteremia | 31 | 13
Ballard, 1995 95239862 | Acute lower respiratory infection | | | | | | Children classified as having moderate to severe stunting/malnutrition were at higher risk for ALRI (RR = 4.5, ht/age < 90% median) compared to non-stunted/malnourished children (ht/age = 95% of median) (classification by NCHS criteria) | 8 LTF within 1 month of enrollment or had ALRI 4–8 wk period prior to observation; inconsistent data for # pts at evaluation; potential recall bias | US government & privately funded
Pandey, 1996 97246349 | | [underlined: No. of children] | [underlined: # ARI episodes per child/yr] | | | | The 28 children with evidence of vitamin A deficiency had significantly higher # ARI than children without vit A deficiency (χ^2^ = 8.64, p < .01). There was association of increased malnutrition with more frequent # ARIs (χ^2^ = 36.17, p < .05). There was no age or sex difference. | Vit A deficiency diagnosed by “ocular signs using a brightly illuminated torch” | Follow-up intervals @ 2 wk for 1 yr; ND on funding source
| Vit A deficient | 28 | 7.4
| Not deficient | 172 | 5.6
| Age(mo) | [underlined: 0–11] | [underlined: 12–23] | [underlined: 24–35] | [underlined: 36–47] | [underlined: 48–59]
| # ARI | 6.2 | 5.8 | 5.7 | 5.9 | 5.8
| Sample n | 27 | 31 | 62 | 34 | 46
| ARIs/year
| [underlined: Gr1] | [underlined: GrII] | [underlined: GrIII] | [underlined: GRIV] | | [underlined: NI]
| 5.6 | 6.9 | 7.4 | 7.7 | | 4.8

Evidence Table 5. Studies associating behavioral problems with Failure to Thrive patients compared to healthy control subjects in developed countries Part I

Author, Year, UI | Demographics | | | | Maternal / household demographics | | | | Inclusion criteria | Exclusion criteria | Definition of FTT | Study design
Pollitt, 1976 76109110 | Country: US | | | | | [underlined: FTT] | [underlined: Ctrl] | | Outpatient clinic, 12–60 mo, ht & wt < 3%, bw = 2500 gm, GA = 36 wks, nl birth, nonorganic, singleton, maternal ht = 154.5 cm & English-speaking ability | Birth complications, physical disability, genetic or organic retardation, brain damage, organic growth retardation | Boston Growth Standards - ht & wt = 3^rd^ percentile | Prospective cross-sectional
| Setting: Outpatient | | | | Maternal educ | 11 (2) | 12 (1) | | Controls matched for age (± 3 mo), sex, race, ht & wt = 25% | | | Weekly interviews for 7–11 sessions
| | [underlined: FTT] | [underlined: Ctrl] | | Income - Gross annual | 6943 (3444) | 9541 (4768)
| Mean age*: Male | 33(14) | 34(13) | | Per capita | 1557 (725) | 2648 (1517)
| Female | 39(14) | 39(15) | | Health insur | ND | ND
| Mean ht†: Male | 93(2) | 101(1)
| Female | 90(2) | 102(3)
| Enrolled/Eval | 19 | 19
| % Male | 47 | 47
| Race: ND
| * Months, † centimeters
Mitchell, 1980 80166667 | Country: US | | | | Maternal education: ND | | | | See definition of FTT Controls: wt = 80% of nl, matched for age, sex, mother's age/ marital status & family problems | Organic cause of FTT, single anomalous low wt recorded, clinic registration by age 6 mo, < 3 visits | Wt for age < 80% of nl up to age 24 mo | Ambidirectional longitudinal
| Setting: Outpatient clinic | | | | Income: ND | | | | | | | 1 fwup at age 3 – 6 y
| | [underlined: FTT] | [underlined: Ctrl] | | Health insur:
| Age(y) | 2–5 | 2–5 | | FTT-53% Medicaid
| Wt/age | ND | ND | | Ctrl-49% Medicaid
| Ht/length | ND | ND
| Enrolled : cohort of 312(323)*
| Evaluated | 30 | 282
| % Male | 36.7 | 51.8
| % Black | 70 | 70
| * See Potential biases column
Polan, 1991 92098539 | Country: US | | | | Maternal education: ND | | | | FTT, age 6 – 36 mo Controls from same site, wt & ht = 10^th^ percentile on NCHS growth charts | Life threatening or terminal illnesses | =35 wks gestation & normal birth wt, wt fell < 5^th^ percentile, or decrease in wt gain in 6 mo = 2 major percentiles based on NCHS | Prospective cross-sectional
| Setting: Outpatient clinic | | | | Income($1,000):
| | [underlined: FTT] | [underlined: Ctrl] | | | [underlined: FTT] | [underlined: Ctrl]
| Mean age* | 16.7(6.9) | 18.9(7.3) | | Mean | 39.4 (51.4) | 40.1 (49.6)
| Wt/age | ND | ND | | Median | 27.5 | 28.5
| Ht/age | ND | ND | | Health insur | ND | ND
| Enrolled/Eval | 28 | 14
| % Male | 50 | 43
| Race: | ND | ND
| * Months
Drotar, 1992 92372721 | Country: US | | | | | [underlined: FTT] | [underlined: Ctrl] | | Hospitalized for NOFT with nutritional intervention, age 1 – 9 months | Physical abuse, residence > 1 hr from hospital, bw < 1500 gm | Wt < 5^th^ percentile based on NCHS, absence of disease, wt gain in hospital, poor wt velocity | Prospective longitudinal
| Setting: Outpatient fwup | | | | Maternal educ | 10.94 (1.74) | 11.51 (1.57) | | Controls matched for age at intake, sex, race, birth order, gestational age, maternal educ & age, family income & size | | | 1 fwup at age 42–48 months
| | [underlined: FTT] | [underlined: Ctrl] | | Income | 5446 (5561) | 7792 (10309)
| Mean age* | 4.92(2.81) | 5.05(2.85) | | Health insur | ND | ND
| Wt/age | ND | ND | | Mean (SD)
| Ht/length | ND | ND
| Enrolled | 68 | 68
| Evaluated | 48 | 47
| % Male | 71 | 57
| Race: Black | 29(60%) | 35(74%)
| White | 29(40%) | 12(26%)
| *At intake
Hutcheson, 1993 94015754 | Country: US | | | | | [underlined: FTT] | [underlined: Ctrl] | | NOFTT, age 8 – 24 mo Controls matched for age, sex, race | Congenital disorder, chronic disease, < 37 wk gestation, SGA | Wt for age ≤ 5^th^ percentile, or wt for ht ≤ 10^th^ percentile, based on NCHS | Prospective cross-sectional
| Setting: Primary care clinic | | | | Maternal educ* | 38 | 70
| | [underlined: FTT] | [underlined: Ctrl] | | Income† | 64 | 70
| Mean age* | 15.1(5.2) | 14.9(5.1) | | Health insur | ND | ND
| Wt/age | 2.83 | 63.17 | | * % HS graduate
| Ht/age | 23 | 63 | | † % receiving AFDC
| Race: Black | 32 | 32
Kelleher, 1993 93234174 | Country: US | | | | | [underlined: FTT] | [underlined: Ctrl] | | Gestation age ≤ 37 wks, birth wt ≤ 2500 g, FTT | Live outside catchment area, D/C outside recruitment period, D/C or died within 48 hr, hospitalized > 60 d, oxygen support > 90 d, twin, triplet or quadruplet of ineligible child, maternal drug/alcohol abuse, insufficient English skills, psychiatric hosp | < 5^th^ percentile for gestation corrected age based on NCHS, growth status on “wt curve below that recorded at last regular assessment visit.” | Prospective longitudinal
| Setting: Primary care clinic | | | | Maternal educ* <HS | 40.6 | 38.1 | | Controls matched for - birth wt +/- 250 g, maternal education, maternal race, & infant sex | | | Fwup at ages 12, 24, 36 mo
| | [underlined: FTT] | [underlined: Ctrl] | | HS | 30.0 | 29.3
| GA(wk)* | 33.0 | 33.1 | | Some col | 14.4 | 20.8
| Wt(g)* | 1679 | 1845 | | ≥col grad | 15.0 | 11.8
| Enrolled: 842*
| Evaluated | 180 | 591 | | Income - <10K | 38.6 | 34.5
| % Male | 52.2 | 47.9 | | 10–20K | 19.9 | 23.9
| Race: % Black | 50 | 53.8 | | >20K | 38.1 | 37.4
| * At birth | | | | Health insur | ND | ND
| | | | | * % HS graduate
Skuse, 1994 94253258 | Country: UK | | | | Maternal educ: ND | | | | District-centered until 12 mo of age, singleton deliveries of 38–41 wks gestation | ≤ 3^rd^ centile, no wt data | Wt for age ≥ -1.88 by 12 mo of age & sustained 3 mo (based on NCHS) | Prospective longitudinal
| Setting: Outpatient | | | | Income: income/welfare support FTT-16, Control-11 | | | | Controls matched for sex, age, ethnic origin, bw within 300 g, ordinal position, SES | | | Assessments at age 15 mo & 4y
| | [underlined: FTT] | [underlined: Ctrl] | | Health insur: National healthcare
| Age(mo)* | 14.6(1.4) | 14.2(1.4)
| Wt/age† | -2.07(.44) | .10(.96)
| Ht/length† | -1.27(.94) | .18(.73)
| Enrolled | 49 | 50
| Evaluated | 47 | 47
| % Male | 49 | 49
| % Non-white | 43 | 34
| * Mean (SD), † z score, p < .001
Puckering, 1995 95378341 | Country: UK | | | | | [underlined: FTT] | [underlined: Ctrl] | | From inner city population sample - Caucasian born in 1980 with longitudinal growth data from birth to 4 years | Prematurity, congenital defects/ diseases affecting growth, no perinatal insults | Ht & wt < 10% based on standard British growth charts (Tanner & Whitehouse) | Ambidirectional cross-sectional
| Setting: Outpatient | | | | Maternal educ* | 15.6 (1.4) | 15.6 (1.4) | | Controls matched for sex, gestational age ≥ 38 wks, & ethnic origin
| | [underlined: FTT] | [underlined: Ctrl] | | Income† | 11 48% | 7 30%
| Age(mo) | 48.9(1.8) | 48.2(0.8) | | Health insur: Socialized medicine
| Wt/age(SDS)* | -2.01(0.6) | -0.32(1.1) | | * Age leaving full-time
| Ht/length(SDS)* | -2.24(0.5) | -0.6(0.9) | | † Income support/welfare
| Enrolled/Eval | 23 | 23
| % Male | 48 | 48
| Race: 100% White
| * based on NCHS, p <.001
Corbett, 1996 97113595 | Country: UK | | | | Maternal educ: ND | | | | Full term singleton with records of 6 or more weights over first 18 months age | Non-Caucasian, “poor growth resulting from major organic disease” | Weight deviated downward from maximal centile achieved at 4–8 wks, across ≥ 2 centile lines, & remained at level ≥ 2 measurements ≥ 1 mo - chart based on Tanner & Whitehouse | Ambidirectional longitudinal
| Setting: Clinic | | | | Income: “…most economically deprived wards in Newcastle” | | | | Consecutive controls matched for age & sex | | | 5 year follow-up of cases
| Age at follow-up: 6–7 yr | | | | Health insur: National healthcare
| | [underlined: FTT] | Ctrl
| Wt/age | ND | ND
| Ht/length | ND | ND
| Enrolled | 52 | 52
| Evaluated | 48 | 46
| % Male: ND
| Race: 100% White
Wilensky, 1996 97022837 | Country: Israel | | | | | [underlined: FTT] | [underlined: Ctrl] | | FTT infants by review of records who have reached 15 months born in 1991 | Birth wt < 2500 gm, < 37 weeks, wt/ht ratio > 10 %, organic cause of FTT | Wt < 3% by NCHS for = 3 months prior to age 15 months | Ambidirectional cross-sectional
| Setting: Community pediatric clinic | | | | Maternal educ* | 13.8 (1.62) | 13.4 (1.44) | | Controls from same maternal & child health clinic matched for birth month, maternal educ, maternal age, parity, and infants' birth wt
| | [underlined: FTT] | [underlined: Ctrl] | | Income: AFDC 76%
| Mean age(mo)* | 15/20 | 15/20 | | Health insur: ND
| Wt/age | ND | ND | | * Mean (SD), based on record review of potential subjects
| Ht/length | ND | ND
| Enrolled† | 55 | 1352
| Evaluated | 50 | 50
| % Male | ND | ND
| Race: ND;
| Maternal country of birth - 68% Israel, 25% Europe/America, 5% N Africa, 2% Asia
| * At entry / assessment
Chatoor, 1998 99026462 | Country: US | | | | Maternal educ: ND | | | | Infantile anorexia, toddlers who are picky eaters | Organic cause for feeding problems, food refusal after traumatic event/post-traumatic feeding disorder, gestational age < 36 wks, psychiatric illness, mother with medical or mental illness that compromised ability to care for child or was nonEnglish speaking | Infantile anorexia: onset 6–36 mo, food refusal ≥ 1mo, acute and/or chronic malnutrition, parental concern & anxiety, conflictual feeding interactions | Prospective cross-sectional
| Setting: Outpatient | | | | Income: | | | | Controls & picky eaters matched for age, sex, SES ethnicity | | Picky eating: food selectivity ≥ 1mo, no malnutrition, variable parental concern
| | [underlined: Gp1*] | [underlined: Gp2†] | [underlined: Ctrl] | | [underlined: Gp1*] | [underlined: Gp2†] | [underlined: Ctrl]
| Age(mo) range | 21.4 (12–37) | 23.7 (13–37) | 22.5 (13–36) | SES* | II | II | II
| Wt/age | ND | ND | ND | † I | 41 | 35 | 32
| Ht/length | ND | ND | ND | II | 29 | 32 | 44
| Enrolled | 34 | 34 | 34 | III | 9 | 26 | 9
| Evaluated | 33 | 34 | 34 | IV | 9 | 3 | 12
| % Male | 39 | 58 | 44 | V | 12 | 3 | 3
| Race | | | | Health insur: ND
| White | 58 | 58 | 59 | * Mean Hollingshead Four Factor Index rating of SES
| Af-Am | 27 | 27 | 29 | † % toddlers in each Hollingshead category
| Latino | 3 | 6 | 6
| Asian | 15 | 12 | 6
Wright, 2000 20161504 | Country: UK | | | | Maternal educ: ND | | | | Baseline wt at 6–8 wk & 2^nd^ wt at 9–18 mo | 2^nd^ twin sibling | Weight decline of 1.26 SD from age 6–8 wks to 2^nd^ weighing at 9–18 months | Prospective cross-sectional
| Setting: Outpatient | | | | Income: ND | | | | Controls from 3 “generally representative” of Newcastle
| | [underlined: FTT] | [underlined: Ctrl] | | | [underlined: FTT*] | [underlined: Ctrl*]
| Age(mo) | 15.1* (7–28) | ND (16–18) | | Unemployed parent | 39 | 13
| Wt/age | -2.00(.93) | ND | | Nonhome- owner | 54.7 | 53.6
| Ht/length | -1.06(.96) | ND | | No car | 48.3 | 50
| Enrolled | 120 | 40 | | Health insur: National healthcare
| Evaluated | 97 | 28 | | * Percent
| % Male | 54 | 61
| % Nonwhite | 9 | 0
Kerr, 2000 20277217 | Country: US | | | | | [underlined: Maternal educ] | [underlined: Income*] | | FTT, < 24 mo, wt/age < 5^th^ %, gestational age = 37 wks & appropriate birth wt Ctrl from same site, bet ages 3 – 30 mo, wt/age > 10^th^ %, gestational age = 37 wks & appropriate birth wt Subgroups Gp2 & Ctrl1: including hx of maltreatment defined as at least one report with Child Protective Services (CPS) by age 6, including neglect, physical abuse, & sexual abuse | History of perinatal complications, congenital disorders, chronic illness | Wt/age < 5^th^ % by NCHS growth charts | Ambidirectional longitudinal Assessment at age 6 y
| Setting: Inner-city hospital clinic | | | | Gp1 | 11.2(1.9) | 56
| | [underlined: Age (mo)] | [underlined: Mean wt/age] | [underlined: Ht/length] | Gp2 | 10.4(1.7) | 81
| Gp1* | 73.3±1.9 | ND | ND | Ctrl1 | 11.2(1.4) | 65
| Gp2† | 74.2±3.2 | ND | ND | Ctrl2 | 11.4(1.9) | 62
| Ctrl1‡ | 73.0±1.2 | ND | ND | Health insur: ND
| Ctrl2§ | 73.5±1.9 | ND | ND | Mean, * percent AFDC
| | [underlined: Evaluated] | [underlined: % Male] | [underlined: % Race\|\|]
| Gp1 | 64 | 56 | 88
| Gp2 | 28 | 48 | 87
| Ctrl1 | 21 | 53 | 94
| Ctrl2 | 80 | 51 | 97
Steward, 2001 21291243 | Country: US | | | | | [underlined: FTT] | [underlined: Ctrl] | | Diagnosed FTT, 2–12 months, birthweight ≥ 2500g | Absence of disease process, pre- or post-natal complications | Weight for age fallen below 5 percentiles or fallen across 2 major percentiles | Prospective cross-sectional
| Setting: Outpatient primary care clinic | | | | Maternal educ* | 12.2 | 12.5 | | Controls matched for age, sex, & race - “growing appropriately”
| | [underlined: FTT] | [underlined: Ctrl] | | Income: ND
| Age (mo) | 9.2 | 8.6 | | Health insur: ND
| Wt/age(kg)* | 7.14 | 8.54 | | * NS for educ & age
| Ht/length | ND | ND
| Enrolled | 17 | 16
| Evaluated | 14 | 14
| % Male | 36 | 36
| Race: white | 9 | 9
| black | 5 | 5
| Mean * p < 0.05

Evidence Table 5. Studies associating behavioral problems with Failure to Thrive patients compared to healthy control subjects in developed countries Part II

Author, Year | Correlates & correlate measures | | | | | Method / Instrument | Associations found
Pollitt, 1976 76109110 | | [underlined: FTT] | Ctrl | | | Reported or observed feeding, history of other behaviors, direct measures | FTT were reported to have significantly more feeding behavior problems than controls in difficulty in feeding (χ^2^ = 5.97, p < .02); eating patterns (χ^2^ = 8.74, p < .03); supported by caloric intake measures (t = 2.06, p = .03). FTT had a trend for exhibiting autoerotic & self-harm behavior problems; analyzed for sum any of these atypical behaviors, the FTT exhibited significant higher incidence (χ^2^ = 8.19, p < .01)
| Feeding difficulty | 10 | 2
| Meal pattern-often skipped/skimpy | 16 | 6
| Caloric intake | 1400(300) | 1700(500)
| Response to food -
| correlation to wt % | ND | ND
| Eating disorder -
| [underlined: FTT 4] exhibiting eating & drinking nonfood items, polydipsia, gorging, & hiding food
| [underlined: Ctrl] none reported
| Autoerotic | 2 | 0
| Self harm | 2 | 0
| Sum children with abnormal behavior | 10 | 1
Mitchell, 1980 80166667 | Behavior problems | [underlined: FTT] | [underlined: Ctrl] | | | Behavior problems questionnaire | NS but FTT group had higher incidence of behavioral problems.
| | 3.3% | 2.8%
Polan, 1991 92098539 | FTT status on positive & negative affect in feeding in 4 channels of emotion - facial display pattern, vocalization, gesture, body posture & movement | | | | | Kiddie Affect Inventory and Assessment of 11 affects scored independently | FTT had significantly decreased positive affect during feeding & nonfeeding (t=-2.92, p=.04; t=-3.151, p = .003, respectively) Also FTT had significantly increased negative affect during feeding (t=2.567, p=.01).
Drotar, 1992 92372721 | | [underlined: FTT] | [underlined: Ctrl] | | | California Child Q-set Lock box - Rectangular container w/10 locked compartments Child Behavior Checklist | FTT children have poor problem-solving, behavior problems, & “deficiencies in personality development” versus controls. The ego development score was lower, ego resiliency score was significantly lower (p<.05). FTT behavior organization & problem scores were significant lower (p<.001, p<.05, respectively)
| Personality development
| • ego control | 376.67(32.28) | 413.42(30.73)
| • ego resiliency | 376.06(41.21) | 397.37(41.45)
| Behavioral organization | .95(1.92) | 8.45(12.08)
| Behavioral problems | 58.5(10.7) | 53.2(12.7)
Hutcheson, 1993 94015754 | Child temperament | [underlined: FTT1*] | [underlined: FTT2†] | [underlined: Ctrl1*] | [underlined: Ctrl 2†] | Infant Characteristics | The FTT cases rated as more difficult with significant finding on effect of infant age on maternal report of infant level of difficulty (F=4.21, p = 0.04). Though no age or group differences found on perceived life stresses, parenting stresses, informal support, and negative affectivity, the FTT infants had fewer life events than FTT toddlers, whereas the reverse was true for the comparison group. The maternal effect was less positive toward FTT toddlers than FTT infants. Controlling for maternal education, wt for age, & ht for age - significant group by age interaction for maternal factors (F=4.98, p = 0.02) due to maternal affective tone (F=9.33, p = 0.005)
| | 0.48 | 0.49 | 0.06 | -0.19 | Questionnaire
| * Infants: 8–13.4 mo
| † Toddlers: 13.5–24 mo
Kelleher, 1993 93234174 | Behavioral disorder | [underlined: FTT] | [underlined: Ctrl] | | | Bates Temperament scale CBCL | Sample of LBW or premature infants followed had lower HOME scores at 12 months, NS. There was a trend towards more behavioral problems for the FTT as reported by parents.
| Age(m) | 12 | 73.0 | 73.6
| | 24 | 9.4 | 8.9 | | CBCL
Skuse, 1994 94253258 | Behavior Assessment at 15 mo | | | | | TRIB | No difference between groups for expression of positive affect in relation to task directed behavior or task persistence
Puckering, 1995 95378341 | Behavior score | [underlined: FTT] | [underlined: Ctrl] | | | Behavior Screening | There was no difference in BSQ scores for the two groups (p=.2). MANOVA performed on calculated mean GCI & BSQ scores vs. unconditional & conditional interactions grouped by high or low (above & below overall mean value for interaction) - results indicate that parenting style does not account for GCI or BSQ differences between FTT & Ctrl.
| | 8.7(4.4) | 6.9(3.5) | | | Questionnaire (BSQ)
Corbett, 1996 97113595 | Behavioral disorder | [underlined: FTT] | [underlined: Ctrl] | | | CBCL | There was a trend towards more behavioral problems for the FTT as reported by teachers (NS, p = .296)
| Parental reporting | 33 | 34
| Teacher reporting | 23 | 14
| Median
Wilensky, 1996 97022837 | Feeding problems | [underlined: FTT] | [underlined: Ctrl] | | | Maternal questionnaire | FTT children had significantly more feeding problems than the controls (p < .05)
| • showing hunger | 53.4% | 46.2%
| • turns head from food | 59.7% | 20.7%
| • shows pleasure at meals | 76.7% | 94.3%
| • nervous at meals | 23.2% | 5.6%
| • eats variety | 48.8% | 69.8%
| • spits out food | 65.1% | 33.9%
Chatoor, 1998 99026462 | | [underlined: Gp1] | [underlined: Gp2] | [underlined: Ctrl] | | Ainsworth & Cassidy & Marvin attachment classification | There was significant relationship between diagnostic group and frequency of insecure attachments (χ^2^ = 8.0, p < .05). Infant anorexia group exhibited more frequent insecure relationships compared to picky eater or healthy eater groups (χ^2^ = 6.7, p < .01; χ^2^ = 3.9, p < .05). There was main effect for group for Attachment security scale (F = 5.8, p < .01) with the infantile anorexia group as least secure. The closer to ideal weight was correlated to increased security (r = 0.31, p < .01).
| Attachment classification | | | | | Strange Situation Security Scale / 9 point Likert
| Secure | 20 | 30 | 28
| Avoidant | 4 | 3 | 3
| Resistant | 7 | 1 | 3
| Disorganized | 2 | 0 | 0
| Attachment security
| scale rating | 4.9(2.1) | 6.1(1.3) | 6.0(1.5)
| Percent ideal weight
Wright, 2000 20161504 | Behavior & temperament | | | | | | Parental reporting / Likert scale | FTT had higher maternal reporting of infants as undemanding & shy in temperament (p = .005 & p = .002, respectively). Higher maternal reporting of infancy feeding problems, variable eating pattern.
| | [underlined: FTT] | [underlined: Ctrl]
| Sociable | 47 | 26
| Average | 17 | 2
| Shy | 12 | 0
| Demanding | 18 | 13
| Average | 48 | 15
| Undemanding | 11 | 0
Kerr, 2000 20277217 | | [underlined: Gp1] | [underlined: Gp2] | [underlined: Ctrl1] | [underlined: Ctrl2] | | There is main effect from risk status (FTT, FTT & maltreatment, maltreatment alone) as being associated with worse scores in cognitive & adaptive performance (F = 3.527, p < .01), school & home behavior (F = 2.986, p < .01; F = 2.453, p < .05, respectively). There was a trend for worse scores in all areas for FTT vs. no risks factors or maltreatment alone.
| Adaptive functioning at school | 15.85 (7.2) | 13.88 (6.9) | 16.92 (6.9) | 17.85 (9.7) | Teacher Report Form (↑ numbers = better score)
| School behavior | 31.45 (27.1) | 53.53 (35.7) | 29.18 (25.0) | 28.87 (29.1) | Teacher Report Form (↓ numbers = better score)
| Home behavior | 28.11 (22.8) | 34.85 (21.2) | 29.00 (20.5) | 26.67 (18.4) | Child Behavior Checklist (↓ numbers = better score)
Steward, 2001 21291243 | | | [underlined: FTT] | [underlined: Ctrl] | | PCERA subscale | FTT group scored significantly lower on the communication subscale (p < 0.02); during interactions with the mother had less visual contact, more gaze aversion & vocalized less than controls, had difficult to read cues. They also scored lower than controls on the mood scale, were more irritable & apathetic (p < 0.05).
| | Communication | 3.19 | 4.07
| | Mood effect | 3.65 | 4.26

Evidence Table 5. Studies associating behavioral problems with Failure to Thrive patients compared to healthy control subjects in developed countries Part III

Author, Year | Potential biases | Comments
Pollitt, 1976 76109110 | 4 cases with FTT hx within ht 3^rd^ & 10^th^ percentiles included in study | Government & privately funded
Mitchell, 1980 80166667 | Physical exams & growth status by PI not blinded | Government & privately funded
Polan, 1991 92098539 | 37% of mothers of normal growth children refused study or failed to appear for 1^st^ appointment, no FTT mothers refused study; randomly selected subset of 107 who completed video lab observation session; acute and chronic conditions in sample, 6 organic FTT based on Woolston score | FTT subgroup analyses no difference in sex, mother's marital status, family income, but organic FTT significantly younger at 10.8 mo vs. 18.3 for NOFTT, p = 0.016. NS for degree of acute or chronic malnutrition and positive or negative affect in feeding & nonfeeding activities; government & privately funded
Drotar, 1992 92372721 | --- | No difference for attrition group vs group evaluated, index gp hospitalized avg 14 d for dx & nutritional intervention; government funded
Hutcheson, 1993 94015754 | 76% of index group met both criteria for NOFTT (wt for age, & ht for age), 24% met one criterion; unknown n for age by group comparisons | Government & privately funded
Kelleher, 1993 93234174 | Of 985 enrolled, 71 LTF, 12%(20) OFTT, 16%(28) were both OFTT & NOFTT | 21% of babies develop FTT by 36 wks; ND on funding source
Skuse, 1994 94253258 | 2 cases & 3 controls didn't complete assessments & were excluded from analyses, 1 case had microcephaly, hypotonia, & an action tremor or ataxia of unknown origin | Researchers blinded to patient's status in measures except anthropometry; privately funded
Puckering, 1995 95378341 | --- | Other than clinic anthropometric measures, home visits by assessors blinded to child's group status; The FTT children were significantly smaller than the controls; government funded
Corbett, 1996 97113595 | 3 from each group refused consent at follow-up, LTF or moved - 2 cases, 3 controls, 1 case not originally studied participated for follow-up study, 4 of those cases were the slowest growing 5% - also removed from home, all controls stayed with parents. Edward's diagnostic criteria for growth measure considered limited. | Additional aubgroup analyses for FTT cases showed significant association between full-scale IQ and cases with lowest Thrive Index values, p = 0.03; ND on funding source
Wilensky, 1996 97022837 | Feeding behaviors and HOME environment are causal factors given time dissociation as FTT was established at 15 months, where as, maternal interview/home assessment at 25 months | 2/5^th^ of infants diagnosed as FTT no longer fit the criteria at 20-month follow-up, yet had positive association on Bayley MDI. Reported associations for FTT without specific data: paternal age (p<.01), maternal education, & behavioral observations of lower sociability (p<.05) & fear of examiner (p<.05); ND on funding source
Chatoor, 1998 99026462 | 1 infant anorexia withdrew because mother became ill | Testers blinded to child's status; poor discussion of SES markers, no quantification of malnutrition, no demonstration of equivalency of control groups; government funded
Wright, 2000 20161504 | Of 120 cases, 23 recovered above screening threshold & had no subsequent data, 21 families received social work input of which, 4 cases registered at risk of abuse or neglect, 17 cases had “relevant organic conditions”…but only 4 said to be main explanation for their FTT”, age difference between groups | Government & privately funded
Kerr, 2000 20277217 | Hx of maltreatment not part of original recruitment criteria; unknown number of original sample, also inMackner 1997 sample (n=177) is reported to be a subsample; maltreatment group may not include all because of definition of a CPS report filed | At 6 year, most FTT children had recovered & 3% had weight for height < 5^th^ percentile; government funded
Steward, 2001 21291243 | Withdraws include: mother changed mind, not available for home visit, opposition of mother's significant other (numbers of each not given) | Majority of single mothers, difference in birthwt - FTT, 2822 g vs. controls, 3344 g (p < 0.013); government & privately funded

Evidence Table 6. Studies associating behavioral problems with malnourished patients compared to healthy control subjects in developing country Part I

Author, Year, Ul | Demographics | | | Maternal/household demographics | Inclusion criteria | Exclusion criteria | Definition of FTT | Study design
Galler, 1983b 83136863 | Country: Barbados | | | Maternal educ: ND, universal education, 95% population literate | Discharged 5 – 11 y olds w/dx at age 1 y with PEM Grade II–III, BW > 5 lbs | Pre- or peri-natal complications, edema, seizures, head trauma, loss of consciousness, high fever | Gomez Scale PEM: Grade II- 61–75% or Grade III- ≤ 60% standard wt for age on Harvard Standard Scale | Ambidirectional longitudinal
| Setting-Outpatient | | | Income: lower for cases compared to controls | Controls without PEM, matched for age, gender, handedness, & same school / neighborhood | | | Fwup 4 – 10 y after D/C
| Age(y): 5–11 | | | Health insur: ND
| | [underlined: Gp] | [underlined: Ctrl]
| Wt/age | ND | ND
| Ht/length | ND | ND
| Enrolled | 141 | 129
| Evaluated | 129 | 129
| % Male | 60 | ND
| Race: 100% Black

Evidence Table 6. Studies associating behavioral problems with malnourished patients compared to healthy control subjects in developing country Part II

Author, Year | Correlates & correlate measures | Method / Instrument | Associations found | | | | Potential biases | Comments
Galler, 1983b 83136863 | Classroom behavior - | Study specific teacher questionnaire | From ages 5–11, The index group's behavioral development was lower than the comparison group. Early PEM is associated with increased problems in attention, deficit, social interaction, & physical appearance. | | | | Withdraws/non-participation - 4 refused consent, 7 LTF, 1 cerebral palsy; severe PEM | Private & hospital funded
| Gp status by | | Signf for -
| Factor 1-attention deficit | | | [underlined: Factor 1] | [underlined: Factor 2] | [underlined: Factor 3]
| Factor 2-social interaction | | Gp status | F = 37.2 | F = 8.3 | F = 14.3
| Factor 3-physical appearance | | | p ≤ .001 | p ≤ .05 | p ≤ .001
| | | Gp vs. Ctrl | t = 5.5 | t = 4.1 | t = 3.1
| | | | p ≤ .01 | p ≤ .01 | p ≤ .01

Evidence Table 7. Studies associating cognitive & neurological development with Failure to Thrive patients compared to healthy control subjects in developed countries Part I

Author, Year, UI | Demographics | | | | | Maternal / household demographics | | | | Inclusion criteria | Exclusion criteria | Definition of FTT | Study design
Mitchell, 1980 80166667 | Country: US | | | | | Maternal educ: ND | | | | See Definition of FTT | Organic cause of FTT, single anomalous low wt recorded, clinic registration by age 6 mo, < 3 visits | Wt for age < 80% of nl up to age 24 mo | Ambidirectional longitudinal
| Setting: Outpatient clinic | | | | | Income: ND | | | | Controls: wt = 80% of nl, matched for age, sex, mother's age/ marital status & family problems | | | 1 fwup at age 3 – 6 y
| | [underlined: FTT] | [underlined: Ctrl] | | | Health insur:
| Age(y) | 2–5 | 2–5 | | | FTT-53% Medicaid
| Wt/age | ND | ND | | | Ctrl-49% Medicaid
| Ht/length | ND | ND
| Enrolled : cohort of 312(323)*
| Evaluated | 30 | 282
| % Male | 36.7 | 51.8
| % Black | 70 | 70
| * See Potential biases column
Hack, 1982 82227864 | Country: US | | | | | | [underlined: Gp1] | [underlined: Gp2] | | VLBW, < 1500g, divided into two groups: SGA < 2 SD or AGA | ND | Wt < 2 SD below mean for age @ term and/or @ 8 mo of age | Prospective longitudinal
| Setting-Recruitment: Hospital | | | | | Maternal educ <HS | 12 | 32 | | | | | Assessments at age 40 wk & 8 m
| Follow-up: hospital/clinic | | | | | Income* | 28 | 99
| | [underlined: Gp1*] | [underlined: Gp2†] | | | Health insur | ND | ND
| Mean age‡ | 32(2.8) | 29(1.9) | | | * Hollingshead Social Class 4 & 5
| Wt/age(g) | 1141(285) | 1197(206)
| Length(cm) | 37.9(3.8) | 38(2.7)
| Enrolled\|\| | ND | ND
| Evaluated | 38 | 154
| % Male | 47 | 47
| % Black | 52 | 63
| * SGA, † AGA, ‡ wks gestation, \|\| n = 204
Singer, 1984 85057547 | Country: US | | | | | | [underlined: NOFTT] | [underlined: OFTT] | | NOFTT-unknown organic cause of condition, absence of wt gain during or shortly after hospitalization | ND | ND | Prospective longitudinal
| Setting-Recruitment: hospital | | | | | | [underlined: Ctrl] | | | NFTT-documented organic cause of condition | | | Assessments at age 8 mo, 20 mo, 3 y
| Follow-up: ND | | | | | Maternal educ* | 12.5(1.4) | 11.4(1.4) | 12.5(12.5) | Controls -“not FTT”
| | [underlined: NOFTT] | [underlined: OFTT] | [underlined: Ctrl] | | Income: ND
| GA(wk)* | 39(1.8) | 37(3.5) | 38(1.8) | | Health insur: ND
| range | 36–40 | 28–40 | 36–40 | | * At evaluation
| PA(wk)† | 30(7.0) | 30(7.5) | 30(10.1)
| range | 20–44 | 21–44 | 20–44
| Birth wt | 2847 | 2378 | 3027
| Enrolled | 13 | 13 | 13
| Eval‡ | 11 | 11 | 11
| Age: 20.6 mo
| % Male: ND
| Race: ND
| Mean (SD), * gestational age, † postnatal
| age, ‡ mo follow-up
Haynes, 1984 84233543 | Country: US | | | | | | [underlined: FTT1] | [underlined: FTT2] | [underlined: Ctrl] | Consecutive admissions for NOFTT | ND | < 5 percentile or significant decline from birth wt percentiles | Prospective longitudinal
| Setting: In & Out-patient | | | | | Maternal educ | 10 | 11 | 10 | Controls - thriving non-hospitalized patients matched for age, sex, birth wt, & mother's age, ethnicity, number of living children | | | 1 assessment 6 mo after intake
| Age: ND | | | | | Income* | 379 (0–750) | 372 (0–950) | 362 (0–1100)
| Wt/age: ND | | | | | Health insur: ND
| Ht/length: ND | | | | | * @ mo
| | [underlined: FTT1*] | [underlined: FTT2†] | [underlined: Ctrl]
| Enrolled/Eval | 25 | 25 | 25
| % Sp-Am M | 44 | 44 | 44
| Sp-Am F | 40 | 52 | 52
| White M | 36 | 44 | 36
| White F | 36 | 24 | 28
| Black M | 20 | 12 | 20
| Black F | 24 | 24 | 20
| % Male: ND
| * std care & lay health visitor intervention, † std care only; M=male; F=female
Drotar, 1992 92372721 | Country: US | | | | | | [underlined: FTT] | [underlined: Ctrl] | | Hospitalized for NOFT with nutritional intervention, age 1 – 9 months | Physical abuse, residence > 1 hr from hospital, bw < 1500 gm | Wt < 5^th^ percentile based on NCHS, absence of disease, wt gain in hospital, poor wt velocity | Prospective longitudinal
| Setting: Inpatient with outpatient follow-up | | | | | Maternal educ | 10.94 (1.74) | 11.51 (1.57) | | Controls matched for age at intake, sex, race, birth order, gestational age, maternal educ & age, family income & size | | | 1 fwup at age 42–48 mo
| | [underlined: FTT] | [underlined: Ctrl] | | | Income | 5446 (5561) | 7792 (10309)
| Mean age* | 4.92(2.81) | 5.05(2.85) | | | Health insur | ND | ND
| Wt/age | ND | ND | | | Mean (SD)
| Ht/length | ND | ND
| Enrolled | 68 | 68
| Evaluated | 48 | 47
| % Male | 71 | 57
| Race: Black | 29(60%) | 35(74%)
| White | 29(40%) | 12(26%)
| * Age in months, at intake
Kelleher, 1993 93234174 | Country: US | | | | | | [underlined: FTT] | [underlined: Ctrl] | | Gestation age ≤ 37 wks, birth wt ≤ 2500 g, FTT | Live outside catchment area, D/C outside recruitment period, D/C or died within 48 hr, hospitalized > 60 d, oxygen support > 90 d, twin, triplet or quadruplet of ineligible child, maternal drug/ alcohol abuse, insufficient Eng skills, psychiatric hospitalization | < 5^th^ percentile for gestation corrected age based on NCHS, growth status on “wt curve below that recorded at last regular assessment visit.” | Prospective longitudinal
| Setting: Primary care clinic | | | | | Maternal educ* | - | | | Controls matched for - birth wt +/- 250 g, maternal education, maternal race, & infant sex | | | Fwup at ages 12, 24, 36 mo
| | [underlined: FTT] | [underlined: Ctrl] | | | <HS | 40.6 | 38.1
| GA(wk)* | 33.0 | 33.1 | | | HS | 30.0 | 29.3
| Wt(g)* | 1679 | 1845 | | | Some col | 14.4 | 20.8
| Enrolled: 842* | | | | | ≥col grad | 15.0 | 11.8
| Evaluated | 180 | 591 | | | Income - <10K | 38.6 | 34.5
| % Male | 52.2 | 47.9 | | | 10–20K | 19.9 | 23.9
| Race: % Black | 50 | 53.8 | | | >20K | 38.1 | 37.4
| * At birth | | | | | Health insur | ND | ND
| | | | | | * % HS graduate
Skuse, 1994 94253258 | Country: UK | | | | | Maternal educ: ND | | | | District-centered until 12 mo of age, singleton deliveries of 38–41 wks gestation | ≤ 3^rd^ centile, no wt data | Wt for age ≥ -1.88 by 12 mo of age & sustained 3 mo (based on NCHS) | Prospective longitudinal
| Setting: Outpatient | | | | | Income: | | | | Controls matched for sex, age, ethnic origin, bw within 300 g, ordinal position, SES | | | Assessments at age 15 mo & 4 y
| | [underlined: FTT] | [underlined: Ctrl] | | | Income/welfare support- FTT 16, Ctrl 11
| Age(mo)* | 14.6(1.4) | 14.2(1.4) | | | Health insur: National healthcare
| Wt/age† | -2.07(.44) | 10(.96)
| Ht/length† | -1.27(.94) | 18(.73)
| Enrolled | 49 | 50
| Evaluated | 47 | 47
| % Male | 49 | 49
| % Non-white | 43 | 34
| * Mean (SD), † z score, p <.001
Reif, 1995 95362505 | Country: Israel | | | | | | [underlined: FTT] | [underlined: Ctrl] | | FTT, < 2 yrs, term infants > 2500g birth wt | Organic cause of FTT, malnutrition, serious perinatal morbidity | Ht & wt < 5% in ≥ 2 measurements within 6 mo on Hamill PVV, Drizd TA growth chart, | Ambidirectional longitudinal
| Setting: Outpatient fwup | | | | | Maternal educ* | 12.27 (0.29) | 12.14 (0.24) | | Controls matched for age, sex, social class, & ethnic affiliation; admitted or evaluated in ER for intercurrent & nonsign disease | | | Re-evaluation at mean 5.12 y
| | [underlined: FTT] | [underlined: Ctrl] | | | Income | ND | ND
| Mean age(y)* | 6.2 | 6.8 | | | Health insur: Socialized medicine
| Wt/age* | 18.05 | 36.15 | | | * Mean (SD)
| Ht/length* | 21 | 33.55
| Enrolled | 86 | 65
| Evaluated | 61 | 65
| % Male | 52.5 | 54
| Race: Sephardic | 38 | 36
| Ashkenazi | 23 | 29
| * At re-evaluation
Puckering, 1995 95378341 | Country: UK | | | | | | [underlined: FTT] | [underlined: Ctrl] | | From inner city population sample - Caucasian born in 1980 with growth data from birth to 4 years | Prematurity, congenital defects/ diseases affecting growth, no perinatal insults | Ht & wt < 10% based on standard British growth charts (Tanner & Whitehouse) | Ambidirectional cross-sectional
| Setting: Outpatient | | | | | Maternal educ* | 15.6 (1.4) | 15.6 (1.4) | | Controls matched for sex, gestational age ≥ 38 wks, ethnic origin
| | [underlined: FTT] | [underlined: Ctrl] | | | Income † | 11 | 7
| Age(mo) | 48.9(1.8) | 48.2(0.8) | | | | 48% | 30%
| Wt/age(SDS)* | -2.01(0.6) | -0.32(1.1) | | | Health insur: Socialized medicine
| Ht/length(SDS)* | -2.24(0.5) | -0.6(0.9) | | | * Age leaving full-time education
| Enrolled/Eval | 23 | 23 | | | † Income support/welfare
| % Male | 48 | 48
| Race: 100% White
| * based on NCHS, p < .001
Corbett, 1996 97113595 | Country: UK | | | | | Maternal educ: ND | | | | Full term singleton with records of 6 or more weights over first 18 months age | Non-Caucasian, “poor growth resulting from major organic disease” | Weight deviated downward from maximal centile achieved at 4–8 wks, across ≥ 2 centile lines, & remained at level ≥ 2 measurements ≥ 1 mo - chart based on Tanner & Whitehouse | Ambidirectional longitudinal
| Setting: Clinic | | | | | Income: “…most economically deprived wards in Newcastle” | | | | Consecutive controls matched for age & sex | | | 5 year follow-up of cases
| Age at follow-up: 6–7 y | | | | | Health insur: National healthcare
| | [underlined: FTT] | [underlined: Ctrl]
| Wt/age | ND | ND
| Ht/length | ND | ND
| Enrolled | 52 | 52
| Evaluated | 48 | 46
| % Male: ND
| Race: 100% White
Wilensky, 1996 97022837 | Country: Israel | | | | | | [underlined: FTT] | [underlined: Ctrl] | | FTT infants by review of records who have reached 15 months born in 1991 | Birth wt < 2500 gm, < 37 weeks, wt/ht ratio > 10 %, organic cause of FTT | Wt < 3% by NCHS for = 3 months prior to age 15 months | Ambidirectional cross-sectional
| Setting: Community pediatric clinic | | | | | Maternal educ* | 13.8 (1.62) | 13.4 (1.44) | | Controls from same health clinic matched for birth month, maternal educ, maternal age, parity, and infants' birth wt
| | [underlined: FTT] | [underlined: Ctrl] | | | Income: AFDC 76%
| Mean age(m)* | 20 | 20 | | | Health insur: ND
| Wt/age | ND | ND | | | * Mean (SD), based on record review of potential subjects
| Ht/length | ND | ND
| Enrolled† | 55 | 1352
| Evaluated | 50 | 50
| % Male | ND | ND
| Race: ND; Maternal country of birth: 68% Israel, 25% Europe/America, 5% N Africa, 2% Asia
| * At assessment
Mackner,^a^ 1997 97381196 | Country: US | | | | | | | [underlined: Maternal* educ] | [underlined: Income†] | [underlined: Health insurt‡] | Original criteria: FTT, , 24 mo, wt/age < 5^th^ %, gestational age = 37 wks & appropriate birth wt | History of perinatal complications, congenital disorders, chronic illness | Wt/age < 5^th^% by NCHS growth charts | Ambidirectional cross-sectional
| Setting: Inner-city hospital prenatal clinic | | | | | Gp1 | 10.58 | 70 | 89 | Controls from same site, bet ages 3 – 30 mo, wt/age > 10^th^ %, gestational age = 37 wks & appropriate birth wt
| | [underlined: Age* (mo)] | [underlined: Mean wt/age] | [underlined: Ht/ lngth] | [underlined: Enrolled/Eval]
| Gp1† | 14±5.3 | <5% | ND | 27 | Gp1 | 10.58 | 70 | 89
| Gp2‡ | 14±5.6 | <5% | ND | 70 | Gp2 | 11.09 | 68 | 78
| Ctrl1§ | 16±5.9 | >10% | ND | 23 | Ctrl1 | 11.04 | 74 | 82
| Ctrl2\|\| | 18±6.9 | >10% | ND | 57 | Ctrl2 | 11.72 | 81 | 89
| % Male: 58 | | | | | * p <0.05, † percent AFDC, ‡ percent Medicaid
| Race: 94.4 % African American 5.6% White
| * p < 0.001, † FTT & neglect, ‡ FTT only, § Neglect only, \|\| Neither
Drewett, 1999 99284054 | Country: UK | | | | | | [underlined: FTT] | [underlined: Ctrl] | | At least 1 wt at age 0–2 mo & 2 subsequent wts, thrive index < 5^th^ centile = 2 occasions between 3 & 18 mo | ND | Lowest 5% for change of SD score; avg taken of SD scores for all wt bet 0–2 mo, expected wt from 3–18 mo calculated for “thrive index” | Ambidirectional longitudinal
| Setting: Clinic / home visits | | | | | Maternal educ* | 72 | 66 | | Controls with at least 1 wt at age 0–2 mo & 2 subsequent wts, no thrive index < 10^th^ centile, age ± 1 mo, similar/same residential area or GP practice | | | Five years from enrollment of 1 y old cases
| | [underlined: FTT] | [underlined: Ctrl] | | | Income: NA
| Age(y) | 8.12(0.62) | 8.10(0.57) | | | Health insur: National healthcare
| Wt(kg)* | 23.8 | 27.9 | | | * % left school at 16 y
| BMI* | 14.9 | 16.3
| Enrolled | 136 | 136
| Evaluated† | 107/111 | 117/122
| % Male‡ | 40 | 38
| %White‡ | 91 | 91
| * Median, † Psychological / anthropometric
| evaluation, ‡ FTT = 107, Ctrl = 117
Kerr,^a^ 2000 20277217 | Country: US | | | | | | [underlined: Maternal educ] | [underlined: Income*] | | History of FTT & Controls seeMackner 1997 | History of perinatal complications, congenital disorders, chronic illness | Wt/age < 5^th^ % by NCHS growth charts | Ambidirectional longitudinal
| Setting: Inner-city hospital clinic | | | | | Gp1 | 11.2 | 56 | | Subgroups - Gp2 & Ctrl1: hx of maltreatment defined as at least one report with Child Protective Services (CPS) by age 6, including neglect, physical abuse, & sexual abuse | | | Assessment at age 6 y
| | [underlined: Age (mo)] | [underlined: Mean wt/age] | [underlined: Ht/ lngth] | | Gp2 | 10.4(1.7) | 81
| Gp1* | 73.3±1.9 | ND | ND | | Ctrl1 | 11.2(1.4) | 65
| Gp2† | 74.2±3.2 | ND | ND | | Ctrl2 | 11.4(1.9) | 62
| Ctrl1‡ | 73.0±1.2 | ND | ND | | Health insur: ND
| Ctrl2 | 73.5±1.9 | ND | ND | | Mean, * percent AFDC
| | [underlined: Evaluated] | [underlined: % Male] | [underlined: % Race\|\|]
| Gp1 | 64 | 56 | 88
| Gp2 | 28 | 48 | 87
| Ctrl1 | 21 | 53 | 94
| Ctrl2 | 80 | 51 | 97

Evidence Table 7. Studies associating cognitive & neurological development with Failure to Thrive patients compared to healthy control subjects in developed countries Part II

Author, Year | Development measures | | | | | Instruments utilized & criteria | Associations found
Mitchell, 1980 80166667 | General cognitive index | | | | | McCarthy scale | Though there was a trend for lower GCI scores for FTT group, there was no statistical difference between the two groups.
| | [underlined: FTT] | [underlined: Ctrl]
| | 87.5 | 92.5
Hack, 1982 82227864 | | [underlined: Gp1Sub]* | [underlined: Gp2Sub1]† | [underlined: Gp2Sub2]‡ | [underlined: Ctrl]§ | Bayley | At 8 months, infants from both groups had similar developmental quotients if catch-up growth is achieved. Subnormal wts at 8 months experienced by subset of both groups is associated with lower DQ scores (p < .005) and higher rate of neurological impairment.
| | 99(18) | 89(22) | 93(17) | 108
| Neurosensory impairment | | | | | Neurological examine
| | 6(32%) | 6(46%) | 8(27%) | 13(10%)
| * SGA-subnormal wt at 40 wk & i m (n=19), † AGA-subnormal wt at 8 m (n=13), ‡ AGA-subnormal wt at 40 wk & 8 m (n=30), § 4 subgroups - appropriate for age (n=30)
Singer, 1984 85057547 | Cognitive & sensorimotor development | | | | | Bayley MDI/Kent Scoring Adaptation | At initial 8 month assessment, there was main effect of group (F = 23.98, p < .001). Both FTT groups showed a significant delay in sensorimotor skills compared to control group (F=46.45, p < .001). At 20 months, it was also reported that there was a main effect of group (F = 21.3, p < .001). Home placement or placement outside the home affected the MDI scores with mean MDI home scores higher regardless of group status (87.5 vs. 68.8).
| | [underlined: 8 m assessment] | [underlined: 20 m assessment] | [underlined: Placed outside home]* | [underlined: Home placement]*
| NOFTT | 77.6(20.5) | 80.5 | 70.2 | 67.4
| OFTT | 67.7(13.8) | 75.4 | 90 | 83.3
| Ctrl | 120.2(10.7) | ND | ND | ND
| * 20 mo assessment, sample size unknown
| Visual recognition memory (8 m assessment) | | | | | Recognition memory tasks - fixation of familiar vs. novel | At 8 month assessment, the OFTT showed a significant delay in visual perceptual-cognitive abilities compared to NOFTT vs. controls where there were no significant differences (F = 19.88, p < .001).
| | [underlined: NOFTT] | [underlined: OFTT] | [underlined: Ctrl]
| | 68%(9.1) | 52.6(8.5) | 62.5(9.2)
Haynes, 1984 84233543 | Cognitive & motor development | | | | | Bayley Scale of Infant Development | There were no differences for the FTT groups after 6 mo for development except for a few cases. Approximately 60% FT were developmentally delayed or retarded vs. 5 Ctrls as delayed. Intervention, or home vs. foster care had no effect.
| | | [underlined: FTT]*(%) | [underlined: Ctrl](%)
| Intake† | ≥90 | 19(38) | 21(81)
| | < 70–89 | 31(62) | 5(19)
| Fwup‡ | ≥ 90 | 15(40.5) | 17(81)
| | < 70–89 | 22(59.5) | 4(19)
| * intervention & non-intervention combineal, † FTT=50 Ctrl=25, ‡ FTT=37 Ctrl=21
Drotar, 1992 92372721 | Intelligence quotient | | | | | Stanford Binet Intelligence Scale | ---
| | [underlined: FTT] | [underlined: Ctrl]
| | 86.3(15.34) | 88.74(14.32)
Kelleher, 1993 93234174 | | [underlined: FTT] | [underlined: Ctrl] | | | Bayley MDI & PDI | LBW & premature infants were followed & subjects who developed FTT scored significantly lower in cognitive & motor development at 12 and 24 months (p < 0.005).
| Mental | 103.7 / 92.6 | 109.5 / 98.1
| Psychomotor | 90.9 / 90.1 | 98.2 / 95.8
| age 12 m / age 24 m
Skuse, 1994 94253258 | | [underlined: FTT] | [underlined: Ctrl] | | | Bayley MDI & PDI | At 15 months of age, FTT had lower cognitive & motor development scores than controls (F = 8.07, p = .007). Model predicted lowering wt up to 6 months of age to lower MDI & PDI scores at 15 months. Increased oral motor score was negative correlated with FTT MDI score (r = -.38, p = .008).
| Mental | 98.2(19.0) | 108.5(14.4)
| Psychomotor | 96.7(17.3) | 103.6(14.4)
Reif, 1995 95362505 | | [underlined: FTT] | [underlined: Ctrl] | | | Reporting/survey | FTT had reported developmental delays and none were for Controls (p < .005). Academic performance was lower for the FTT compared to Controls (p < .01).
| Developmental delay | 7(11.5%) | 0
| Learning difficulties | 11(18%) | 2(3.1%)
Puckering, 1995 95378341 | General cognitive index | | | | | McCarthy scale | The FTT children had significantly lower DQ scores (t = -3.93, p = .001) & had few positive & more negative mother - child interactions than the controls. MANOVA performed on calculated mean GCI & BSQ scores vs. unconditional & conditional interactions grouped by high or low (above & below overall mean value for interaction) - results indicate that parenting style does not account for GCI or BSQ differences between FTT & Ctrl.
| [underlined: FTT] | [underlined: Ctrl]
| 77.1(17.6) | 97.7(15.2)
Corbett, 1996 97113595 | Intelligence quotient | | | | | WPPSI-R omitting optional animal pegs & sentences subtests | Though not statistically significant, there was a trend for lower IQ score for FTT group with correlation to the severity of FTT (p = .160).
| [underlined: FTT] | [underlined: Ctrl]
| 83.6(11.5) | 87.0(11.9)
Wilensky, 1996 97022837 | | [underlined: FTT] | [underlined: Ctrl] | | | Bayley MDI | At 20 months, the FTT group mental development lagged behind the control group (p < .05). In addition, an assessment showed the home environment to be less stimulating. 2/5^th^ of infants diagnosed as FTT no longer fit the criteria at 20 mo fwup, yet had positive association on Bayley MDI.
| Mental | 99.7 | 107.2
Mackner,^a^ 1997 97381196 | | [underlined: Gp1] | [underlined: Gp2] | [underlined: Ctrl1] | [underlined: Ctrl2] | Bayley MDI | Main effect for grouping (F = 4.899, p < .01). The Neglect & FTT group scored significantly lower than FTT only or Neglect only group, both of which scored lower than the group with neither risk factors in cognitive development, (p < .01). Maternal IQ & child age as covariates -significant relationship with Bayley MDI, F = 4.90, p < .01
| Mental* | 85.45(13.62) | 97.38(13.79) | 97.72(12.25 ) | 100.81(16.4)
| * Adjusted score
Drewett, 1999 99284054 | | [underlined: FTT] | [underlined: Ctrl] | | | | The IQs & reading scores from the FTT to the controls were not significantly different, but there was a significant relationship between the child's IQ & their mother's IQ (β = 0.76 ± 0.06, t = 12.09, p < .0001). Also a significant relationship between the child's reading score & their mother's IQ (β = 0.56 ±0.07, t = 8.21 p < .0001). There was a relationship between reading scores & FTT cases (n=9) with possible organic causes (β = -11.91 ±4.49, t = 2.65, p < .01).
| Mean IQ* | 87.6(17.4) | 90.6(17.1) | | | WISC-III
| Mean Reading† | 93.5(162) | 94.5(15.6) | | | WORD test
| * FTT n = 105, Ctrl n = 117
| † FTT n = 105, Ctrl n = 116
Kerr,^a^ 2000 20277217 | [underlined: Gp1] | [underlined: Gp2] | [underlined: Ctrl1] | [underlined: Ctrl2] | | WPPSI-R: scores standardized score with mean of 100 ± 15 | In all four outcome measures were consistent for main effect from risk status (FTT, FTT & maltreatment, maltreatment alone) as being associated with worse scores in cognitive & adaptive performance, school & home behavior (F = 2.930, p < .01). In addition, there was a significant difference between the FTT & maltreatment group vs. the group with no risk factors for cognitive & adaptive development, and school performance (p < .05).
| 81.98(12.8) | 77.98(13.8) | 83.58(12.4) | 83.95(12.5)

Evidence Table 7. Studies associating cognitive & neurological development with Failure to Thrive patients compared to healthy control subjects in developed countries Part III

Author, Year | Potential biases | Comments
Mitchell, 1980 80166667 | Physical exams & growth status by PI not blinded | Government & privately funded
Hack, 1982 82227864 | 8 LTF, 4 incomplete data | SGA mothers incr % pregnancy HTN (p < .05) & multiple births (p < .05) than AGA, also incr antepartum risk score (p < .005) & greater gestational age (p < .005); privately funded
Singer, 1984 85057547 | Recognition memory tasks differed based on age; etiology for OFTT includes primary neurological disease, methadone addiction, cerebral palsy, congenital heart disease, pulmonary stenosis, cyanotic heart disease, polycystic renal disease, necrotizing enterocolitis, & Aarskoog syndrome | Government funded
Haynes, 1984 84233543 | “…because of scheduling, few admissions were not evaluated”, 2 refused participation; 10 Gp1 & 3 Gp2 premature - overall similar from FTT vs. Ctrl; at 6 mo fwup: for FTT1 & FTT2 each-3 cases refused reevaluation & from1 dissolution of pair, 1Gp1 died SIDS, 1 Gp2 mother gave up child | Block assignment to Gp1 & Gp2 for hospital convenience & case load requirements; government funded
Drotar, 1992 92372721 | --- | No difference for attrition group vs. group evaluated, index gp hospitalized avg 14 d for dx & nutritional intervention; government funded
Kelleher, 1993 93234174 | Of 985 enrolled, 71 LTF, 12%(20) OFTT, 16%(28) were both OFTT & NOFTT | 21% of babies develop FTT by 36 wks; ND on funding source
Skuse, 1994 94253258 | 2 cases & 3 controls didn't complete assessments & were excluded from analyses, 1 case had microcephaly, hypotonia, & an action tremor or ataxia of unknown origin | Researchers blinded to patient's status in measures except anthropometry; government & privately funded
Reif, 1995 95362505 | 25 cases not re-evaluated because not located or refused participation; inpatient enrollment of FTT-48 & Ctrl-42; outpatient enrollment of FTT-13 & Ctrl-23(ER) | ND on funding source
Puckering, 1995 95378341 | --- | Other than clinic anthropometric measures, home visits by assessors blinded to child's group status; The FTT children were significantly smaller than the controls; government funded
Corbett, 1996 97113595 | 3 from each group refused consent at follow-up, LTF or moved - 2 cases, 3 controls, 1 case not originally studied participated for follow-up study, 4 of those cases were the slowest growing 5% - also removed from home, all controls stayed with parents. Edward's diagnostic criteria for growth measure considered limited. | Additional aubgroup analyses for FTT cases showed significant association between full-scale IQ and cases with lowest Thrive Index values, p = 0.03; ND on funding source.
Wilensky, 1996 97022837 | Feeding behaviors and HOME environment are causal factors given time dissociation as FTT was established at 15 months, where as, maternal interview/home assessment at 25 months. | Reported associations for FTT without specific data: paternal age (p<.01), maternal education, & behavioral observations of lower sociability (p<.05) & fear of examiner (p<.05); ND on funding source
Mackner,^a^ 1997 97381196 | By group sex data not given, unknown whether Bayley tester was blinded to subject's group assignment | Government funded
Drewett, 1999 99284054 | Of 136 cases, 1 died, 9 LTF, 15 declined psychological testing, 4 moved; of 136 controls, 2 were preterm, 5 LTF, 12 declined psychological testing, 14 moved & were replaced. 2 FTT cases & 1 control with medical condition affecting growth, & 9 FTT cases & 2 controls with possible medical conditions | Testers blinded to child's status; privately funded
Kerr,^a^ 2000 20277217 | Hx of maltreatment not part of original recruitment criteria; unknown number of original sample, also inMackner 1997 sample (n=177) is reported to be a subsample; maltreatment group may not include all because of definition of a CPS report filed | At 6 year, most FTT children had recovered & 3% had weight for height < 5^th^ percentile; government funded

* Overlapping sample for Mackner 1997 & Kerr 2000.

Evidence Table 8. Studies associating cognitive & neurological development with malnourished patients compared to well-nourished control subjects in developing countries Part I

Author, Year | Demographics | | | | | Maternal / household demographics | | | | Inclusion criteria | Exclusion criteria | Definition of malnutrition | Study design
Bartel, 1978, 1979 78180773 79162492 | Country: South Africa | | | | | ND | | | | Bk 6 – 12 yr olds hospitalized during first 27 months of life for kwashiorkor, 5 – 10 yrs prior to commencement of study | Neurological involvement, brain damage, fits, birth trauma, hospital coma, hypoglycemia | Wellcome criteria for kwashiorkor: <3^rd^percentile, edematous, and dermatitis and/or nutritional hair changes | Ambidirectional longitudinal
| Setting: Outpatient | | | | | | | | | Controls close in age, no hx of PCM: | | | Assessment at 4 – 12 y after hospitalization
| Age: ND | | | | | | | | | Ctrl1-Siblings close in age
| Wt/age: ND | | | | | | | | | Ctrl2-Yardmates of cases
| Ht/length: ND | | | | | | | | | Ctrl3-High SES Whites
| | | [underlined: Enrolled*] | [underlined: Eval*] | [underlined: Race]
| Gp | | 31/30 | 31/30 | Black
| Ctrll1 | | 31/30 | 31/30 | Black
| Ctrll2 | | 31/30 | 31/30 | Black
| Ctrll3† | | NA/90 | NA/90 | White
| % Male: ND
| * Bartel 1978 / Bartel 1979
| † reported in Bartel 1979
Evans, 1980 81008912 | Country: South Africa | | | | | ND | | | | Gp1 - newborns of families with hx of undernutrition | ND | ND | Prospective longitudinal
| Setting: Outpatient clinic | | | | | | | | | Ctrl1 - siblings with hx of undernourishment, record of `< 3^rd^percentile for ht & wt | | | Fwup 6 ½ y after intervention
| Wt/age: See Cognitive development measures column | | | | | | | | | Gp2 - at least 1 hospitalization for kwashiorkor
| Ht/length: See Cognitive development measures column | | | | | | | | | Ctrl2 - siblings closet in age Gp2 w/no hx of kwashiorkor but underweight
| | [underlined: Gp1] | [underlined: Ctrl1] | [underlined: Gp2] | [underlined: Ctrl2]
| Mean age(SD) | 8.9(0.5) | 10.7(1.0) | 13(1.9) | 12(2.1)
| Enrolled | 14 | 14 | 14 | 14
| Evaluated | 14 | 13 | 14 | 13
| % Male | 64 | 54 | 100 | 77
| Race: “Cape coloured”
Galler, 1983a, 1985b 83136873 85241833 | Country: Barbados | | | | | Maternal educ: Universal education, 95% population literate | | | | 5 – 11 yr olds with hx at age 1 yr of hospitalization for PEM Grade II–III, BW > 5 lbs | Pre- or peri-natal complications, edema, seizures, head trauma, loss of consciousness, high fever | Gomez Scale PEM: Grade II- 61–75% or Grade III- ≤ 60% standard wt for age on Harvard Standard Scale | Ambidirectional longitudinal
| Setting: Outpatient | | | | | Income: lower for cases compared to Ctrl | | | | Controls without PEM, matched for age, gender, handedness, & same school / neighborhood | | | Fwup 4 – 10 y after D/C
| Age(y): 5–11 (1983) | | | | | Health insur: ND
| 9–15 (1985)
| | | | [underlined: Gp] | [underlined: Ctrl]
| Wt/age | | | ND | ND
| Ht/length | | | ND | ND
| Enrolled | | | 141 | 129
| Eval 1983a | | | 129 | 129
| 1985b | | | 109 | 107
| % Male 1983a | | | 60 | ND
| 1985b | | | 58 | 60
| Race: 100% Black
Grantham-McGregor, 1987, 1978, 1980, 1982, 1983 87117313 79086701 81051042 82236679 83246270 | Country: Jamaica | | | | | Maternal educ: HS not completed | | | | PEM, age 6 – 24 mo, attempt for SES of mothers who had not completed secondary education, substandard housing, residence in city of Kingston | Physical handicap, disease that might affect mental development (other than malnutrition) | Severe PEM based on Wellcome classification | Prospective longitudinal
| Setting-Recruitment: hospital | | | | | Income: housing ‘below certain defined standards’ | | | | Controls, included above criteria but adequately nourished, hospitalized with diseases other than malnutrition | | | 6 fwups from 6 to 72 m after D/C
| Follow-up: hospital & home | | | | | Health insur: ND
| | | [underlined: Gp1*] | [underlined: Gp2]† | [underlined: Ctrl]† | | | | [underlined: Maternal PPVT]
| Age(m) | | 12.8(2.9) | 13.4(4.5) | 12.2(4.4) | Gp1 | | | 62.3(14.7)
| Ht/age‡ | | 89.0(4.5) | 88.4(4.4) | 101.3(3.5) | Gp2 | | | 59.7(15)
| HC/age‡ | | 91.3(3.7 | 91.2(3.3) | 99.0(3.8) | Ctrl | | | 67.4(9.3)
| Wt/ht‡ | | 74.9(9.2) | 72.4(10.2) | 89.0(10.1)
| Enrolled | | 21 | 18 | 21
| Evaluated | | 18 | 16 | 20
| % Male | | 67 | 38 | 60
| Race: ND, assumed Black
| Mean (SD) for evaluated cases; * Intervention, † Standard care, ‡ % of expected value
Agarwal, 1992 92372206 | Country: India | | | | | Maternal educ: < 4% > grade school, 31.9% overall women's literacy | | | | Newborns between 11/1981 - 31983; see Definition of malnutrition Controls > 80% of 50^th^ % wt for age, | ND | Malnutrition based on NCHS 50^th^ centile wt for age as reference pt: wt ≥ 80% of 50^th^% = normal, Grade I < 80-70%, Grade II < 70-60%, Grade III < 60% | Prospective longitudinal
| Setting: Outpatient | | | | | Income: 40% household per capita < Rs.60 p.m. | | | | | | | Assessments at age 18, 24, 30, 36 m
| Age: NA | | | | | Health insur: ND
| Wt/age: ND
| Ht/age: ND
| Enrolled: 650
| | | [underlined: GpI*] | [underlined: Gp2]† | [underlined: Ctrl]
| Evaluated: | | 245 | 324 | 64
| % Male: ND
| Race: ND (assumed Indians)
| * Grade I, † Grade II/III
Drewett, 2001 21174599 | Country: Ethiopia | | | | | | [underlined: Maternal educ*] | [underlined: Income]† | [underlined: Health insur] | All subjects: < 2 y on Nov 1, 1994, recorded initial (< 16 d) wt ≥ 2500 g, recorded 7^th^ visit (alive at 1 yr) | ND | Centiles based on NCHS | Ambidirectional longitudinal
| Setting: Outpatient | | | | | Gp1 | 37 | 37 | ND | Gp1: wt < 3^rd^ centile at visits 2 or 3(2 & 4 mo) | | | Assessment at age 2 y (22–24 m)
| | | [underlined: Gp1*] | [underlined: Gp2]† | [underlined: Ctrl] | Gp2 | 51 | 41 | ND | Gp2: wt < 3^rd^ centile at visits 6 or 7(10 & 12 mo), & not visits 2 or 3 | | | See Comments section
| Age‡ | | ND | ND | ND | Ctrl | 41 | 35 | ND | Control: wt ≥ 3^rd^ centile at visit 2, 3, 6, & 7
| Wt§ ? | | 8.3(1.6) | 8.9(1.0) | 10.4(1.0) | * % > 3 y, † % > 2 key possessions
| ? | | 8.5(1.1) | 9.4(1.0) | 10.6(1.1)
| Lngth§? | | 72.6(5.0) | 75.2(4.4) | 79.6(3.2)
| ? | | 74.9(2.5) | 76.2(3.6) | 80.4(3.9)
| Enrolled | | 27 | 70 | 100
| Evaluated | | 27 | 70 | 100
| % Male | | 33 | 70 | 55
| Race: ND
| * Early growth faltering, † Late growth faltering, ‡ criteria < 16 d, § age 2 y, (SD), wt in kg, length in cm

Evidence Table 8. Studies associating cognitive & neurological development with malnourished patients compared to well-nourished control subjects in developing countries Part II

Author, Year | Development measures | | | | | Instrument | Associations found
Bartel, 1978, 1979 78180773 79162492 | Psychomotor development | | | | | LOMDS | There were no significant difference (F=1.50) between the children with history of kwashiorkor, siblings, & yardmates on motor skills except for intergroup comparisons for 2 of 93 items tested of LOMDS. The groups did not differ significantly on grip strength (F=1.45) or finger tapping tests (F=1.43).
| | | [underlined: Gp] | [underlined: Ctrl1] | [underlined: Ctrl2]
| Motor development | | 80.73 | 91.16 | 82.55
| Grip strength* | | 14.80 (5.24) | 16.59 (6.22) | 15.15 (5.41) | Smedley hand dynamometer
| Finger-tapping / fine motor speed* | | 34.47(6.35) | 37.25(8.22) | 35.21(5.17) | Reitan Indiana & Halstead neuropsychological test batteries
| Mean(SD), * Dominant hand scores
Evans, 1980 81008912 | | [underlined: Gp1] | [underlined: Ctrl1] | [underlined: Gp2] | [underlined: Ctrl2] | New S. African Individual Intelligence scale | 6–7 years after early infant supplements, the Gp1 full scale intelligence score was significantly higher than Ctrl1 (older siblings), p < .05; or Gp2 (kwashiorkor), p < .01; or Ctrl2 (siblings of kwashiorkor), p < .05. There were higher trends for verbal & performance scores with Gp1 verbal score higher than Ctrl1, p < 05; and Gp 1 higher than Gp2, p < .05; or Ctrl2, p < .01. Bender-Gestalt test reported NS findings.
| Full scale | 82.0(13.0) | 71.9(12.5) | 70.0(13.5) | 72.0(14.6) | Bender-Gestalt test/Koppitz scoring
| Verbal | 81.3(13.0) | 70.6(13.3) | 74.3(16.1) | 75.0(17.3)
| Performance | 86.3(10.4) | 80.5(11.2) | 71.3(8.8) | 74.4(9.2)
| mean(SD)
Galler, 1983a, 1985b 83136873 85241833 | | [underlined: Gp?] | [underlined: Ctrl?] | [underlined: Gp ?] | [underlined: Ctrl?] | WISC | 1983 - From ages 5–11, the index group scored significantly lower than the controls by sex, p < .05; the mean score for the index group was 12 points lower than the controls. There was no effect on Full IQ by sex, age, or SES.
| Full scale IQ | 91.3(14.3) | 100.1(13.0) | 90.5(16.7) | 107.7(12.1) | | 1985 - At ages 9–14 The index group had statistically significant deficits in fine motor coordination of the dominant hand compared to controls (F = 2.85 , p < .05) with significant effect by age (F = 6.3, p < .001)
| Motor coordination deficiency - | | | | | Purdue pegboard tasks, Neuman-Keuls
| | | [underlined: 8–10 yr] | [underlined: 11–13 yr] | [underlined: 14–15 yr]
| Dominant hand performance
| Gp | | 11.24(2.22) | 13.1(2.38) | 12.81(2.07)
| Ctrl | | 12.41(0.94) | 13.53(1.72) | 12.73(2.02)
| Assembly tests
| Gp | | 23.94(4.08) | 29.40(4.51) | 30.27(5.66)
| Ctrl | | 23.00(4.21) | 26.77(6.00) | 29.81(7.21)
Grantham-McGregor, 1987, 1978, 1980, 1982, 1983 87117313 79086701 81051042 82236679 83246270 | | | [underlined: Gp1] | [underlined: Gp2] | [underlined: Ctrl] | Griffith's Mental Development Scales for Babies and Young Children including subscales - hand & eye coord, hearing & speech, performance, practical reasoning, & locomotor | Development assessment taken at D/C, 6, 12, 18, 24 months, and annual thereafter showed consistently the nonintervention group (Gp2) was significantly behind the control group with intervention group (Gp1) scoring higher than the nonintervention group, but still behind the control group. At 6 months, the Gp1 was significantly behind the Gp2, (F = 4.43, p < 0001), but NS vs. Ctrl (F = 1.85). Gp2 was significantly behind the Ctrl (F = 5.83, p < .0001). PPVT at 36 months, showed effect by group, p < .005. At 60 months after D/C, (2 yr post intervention) both Gp1 & Gp2 were statistically behind the control group, p < 0.01. At 60 months, the results of Stanford-Binet Test showed that the “relative positions of groups maintained”.
| DQ at D/C | | 86(12.7) | 77(12.0) | 98(14.8)
| DQ at 6 m | | 96(11.3) | 82(12.1) | 105(11.2)
| DQ at 60 m | | 86.1(8.2) | 78.1(9.7) | 93.2(11.2)
| PPVT at 36 m | | 26.9(10.6) | 18.3(7.5) | 26.2(12.2) | Peabody Picture Vocabulary Test
| IQ at 60 m | | 71.5(8.7) | 63.3(7.8) | 75.2(10.5) | Stanford-Binet Test
Agarwal, 1992 92372206 | | | [underlined: Gp1] | [underlined: Gp2] | [underlined: Ctrl] | Binet Kulshrestha Intelligence Scale | At 36 month assessment, there were differences in scores between the normal, Grade I, and Grade II/III for cognitive (F = 13.27, p < .001) & language (F = 9.308, p < .001) development, motor coordination (F = 10.52, p < .001), concept formation (F = 6.235, p < .01), and reasoning (F = 7.774, p < .001). The mean scores decreased with increasing degrees of malnutrition. Home environment was most important variable in predicting IQ, accounting for 26.22% of total variance in IQ, p < .001
| Cognitive | | 91.9(8.6) | 86.8(7.7) | 95.5(7.9) | Developmental Quotient calculated for Binet Kulshrestha intelligence subsets
| Motor coordination | | 1.13(.22) | 0.97(.27) | 1.16(.19) | Caldwell Inventory
| Language | | 0.85(.14) | 0.78(.11) | 0.90(.14)
| Concept formation | | 1.32(.43) | 1.07(.54) | 1.38(.37)
| Reasoning | | 1.15(.79) | 0.75(.79) | 1.43(.89)
Drewett, 2001 21174599 | | | [underlined: Gp1] | [underlined: Gp2] | [underlined: Ctrl] | Bayley PDI & MDI - nonstandard scoring based on number of items passed | Group status was correlated to psychomotor development (F = 9.3, p < .001; Gp1&Gp2 vs. Ctrl, t = 3.8, p < .001; Gp1 vs .Gp2, t = 2.0, p < .05) with early growth faltering group scoring lower than the late growth faltering group who in turn scored lower than the controls. Similar pattern for mental development scores (Group effect, F = 12.7, p < .001; Gp1 vs. Gp2, t = 4.0, p < .01; Gp1 vs. Gp2, t = 3.0, p < .01). Child's wt at 2 years was related to both scores (PDI: r = .53, MDI: r = .49, p < .001), & maternal education related to mental development (MDI: t = 2.1, p < .05). No relationship between households with greater than 2 key possessions and psychomotor &mental scores. The difference in initial weights of the 3 groups were statistically significant (F = 21.4, p < .01).
| Psychomotor | | 6.6*(4.2) | 8.5*(4.3) | 10.2(3.7)
| Mental | | 22.6(6.2) | 26.6(6.1) | 28.9(5.8)
| Initial wt (g) | | 2819(323) | 3141(351) | 3368(430)
| * Gp1 n= 25, Gp2 n=66

Evidence Table 8. Studies associating cognitive & neurological development with malnourished patients compared to well-nourished control subjects in developing countries Part III

Author, Year | Potential biases | Comments
Bartel, 1978, 1979 78180773 79162492 | No data on difference of number of children between two reports | Single tester blinded to child's group assignment for Bartel 1978; partially funded by African Medical Research Council
Evans, 1980 81008912 | 1 child died in each of the controls, sex unkn | Gp1 received supplements until mean 28 months, one examiner blinded to subject's group status, testing 6–7 years after cessation of supplements; US government & South African Medical Research Council
Galler, 1983a, 1985b 83136873 85241833 | Withdraws/non-participation - 4 refused consent, 7 LTF, 1 cerebral palsy; Severe PEM | Relevant WISC subtests utilized & some items altered for cultural setting; findings of dominant hand performance of fine motor skill tasks deficient in formerly malnourished children correlates or co-varies with IQ & other soft neurologic signs; private & hospital funded
Grantham-McGregor, 1987, 1978, 1980, 1982, 1983 87117313 79086701 81051042 82236679 83246270 | Controls had better housing than other 2 groups in spite of attempts to match; 2 died & 1 WD from intervention group, 1 from nonintervention moved & 1 was adopted by middle-class family, 1 from control WD; 10 of 21 Gp1 had edema, 4 of 18 in Gp2, & none in the control group | Tester blinded to subjects' group, controls hospitalized mainly for gastroenteritis & respiratory infections; government & private funding
Agarwal, 1992 92372206 | ND on 17 of 650 in cohort; 5.5% of population were normal for growth at 24 months corresponding to 5.9% for 1989-90. | Funded by Indian Council of Medical Research
Drewett, 2001 21174599 | Initial weight a proxy for birth weight as most births at home; 27 of 40 early wt faltering group recruited & tested; significant higher proportion of males in Gp2 vs. Gp1, χ^2^ = 5.56, p < .05; 6 cases (Gp1–2 & Gp2–4) with lower limb disabilities could not participate in psychomotor test | Sample subset of Jimma Birth Cohort study; Gp2 & Controls selected at random from sampling frame; systematic method for selection of broad comparisons for Control group; testers blinded to child's status; Private & hospital funded

Evidence Table 9. Studies associating other correlates / outcomes with Failure to Thrive patients compared to healthy control subjects in developed countries Part I

Author, Year, UI | Demographics | | | | Maternal / household demographics | | | Inclusion criteria | Exclusion criteria | Definition of FTT | Study design
Pollitt, 1976 76109110 | Country: US | | | | | [underlined: FTT] | [underlined: Ctrl] | Outpatient clinic, 12–60 mo, ht & wt < 3%, bw = 2500 gm, GA = 36 wks, nl birth, nonorganic, singleton, maternal ht = 154.5 cm & English-speaking ability | Birth complications, physical disability, genetic or organic retardation, brain damage, organic growth retardation | Boston Growth Standards - ht & wt = 3^rd^ percentile | Prospective cross-sectional
| Setting: Outpatient | | | | Maternal | 11 | 12 | Controls matched for age (± 3 mo), sex, race, ht & wt = 25% | | | Weekly interviews for 7–11 sessions
| | [underlined: FTT] | [underlined: Ctrl] | | educ | (2) | (1)
| Mean age(SD)* | | | | Income
| Male | 33(14) | 34(13) | | Gross | 6943 | 9541
| Female | 39(14) | 39(15) | | annual | (3444) | (4768)
| Mean ht† | | | | Per capita | 1557 | 2648
| Male | 93(2) | 101(1) | | | (725) | (1517)
| Female | 90(2) | 102(3) | | Health Insur: ND
| Enrolled/Eval | 19 | 19
| % Male | 47 | 47
| Race: ND
| * months, † centimeters
Mitchell, 1980 80166667 | Country: US | | | | Maternal educ: ND | | | See Definition of FTT | Organic cause of FTT, single anomalous low wt recorded, clinic registration by age 6 mo, < 3 visits | Wt for age < 80% of nl up to age 24 mo | Ambidirectional longitudinal
| Setting: Outpatient clinic | | | | Income: ND | | | Controls: wt = 80% of nl, matched for age, sex, mother's age / marital status & family problems | | | 1 fwup at age 3 – 6 y
| | [underlined: FTT] | [underlined: Ctrl] | | Health insur:
| Age(y) | 2–5 | 2–5 | | FTT-53% Medicaid
| Wt/age | ND | ND | | Ctrl-49% Medicaid
| Ht/length | ND | ND
| Enrolled: cohort of 312
| Evaluated | 30 | 282
| % Male | 36.7 | 51.8
| % Black | 70 | 70
Hack, 1982 82227864 | Country: US | | | | | [underlined: Gp1] | [underlined: Gp2] | VLBW, < 1500g, divided into two groups: SGA < 2 SD or AGA | ND | Wt < 2 SD below mean for age @ term and/or @ 8 mo of age | Prospective longitudinal
| Setting-Recruitment: Hospital | | | | Maternal | | | | | | Assessments at age 40 wk & 8 mo
| Follow-up: hospital/clinic | | | | educ <HS | 12 | 32
| | Gp1* | Gp2† | | Income* | 28 | 99
| Mean age‡ | 32(2.8) | 29(1.9) | | Health
| Wt/age(g) | 1141(285) | 1197(206) | | Insur | ND | ND
| Length(cm) | 37.9(3.8) | 38(2.7)
| Enrolled\|\| | ND | ND | | * Hollingshead Social Class 4 & 5
| Evaluated | 38 | 154
| % Male | 47 | 47
| % Black | 52 | 63
| * SGA, † AGA, ‡ wks gestatin, \|\| n = 204
Haynes, 1984 84233543 | Country: US | | | | Maternal | | Consecutive admissions for NOFTT | ND | | < 5 percentile or significant decline from birth wt percentiles | Prospective longitudinal
| Setting: In & Out-patient | | | | [underlined: educ] | [underlined: Income*] | Controls - thriving non-hospitalized patients matched for age, sex, birth wt, & mother's age, ethnicity, number of living children | | | | 1 assessment 6 mo after intake
| Age: ND | | | | Gp1 | 10 | 379(0–750)
| Wt/age: ND | | | | Gp2 | 11 | 372(0–950)
| Ht/length: ND | | | | Ctrl | 10 | 362(0–1100)
| | [underlined: FTT1]* | [underlined: FTT2]† | [underlined: Ctrl] | Helath insur: ND
| Enrolled/Eval | 25 | 25 | 25 | * @mo
| % Race
| Sp-Am M | 44 | 44 | 44
| Sp-Am F | 40 | 52 | 52
| White M | 36 | 44 | 36
| White F | 36 | 24 | 28
| Black M | 20 | 12 | 20
| Black F | 24 | 24 | 20
| % Male: ND
| * std care & lay helath visitor intervention, † std care only; M=male; F=female
Sherrod, 1984 85026403 | Country: US | | | | | [underlined: NOFTT] | [underlined: Ctrl] | NOFTT, abused, or neglected | ND | Wt gain fallen below 2/3 of Harvard 50^th^ percentile on growth curve | Retrospective longitudinal
| Setting-Recruitment: Prenatal clinic | | | | Maternal | | | Controls - no hx of abuse, FTT, or neglect | | | 3 annual assessments
| Follow-up: Pediatric clinic | | | | educ | 10.3 | 11.2
| | [underlined: NOFTT] | [underlined: Ctrl] | | Income* | 13 | 13
| Birthwt(g) | 3031 | 3054 | | Health
| Enrolled/Eval* | 31 | 24 | | Insur† | ND | ND
| Race-White | 10 | ND | | * # employed, † p < .05, ‡ p < .01
| Black | 21 | ND
| % Male: ND
| * 4 arm study - Data for FTT & Ctrl only; abused or neglected cases excluded
Casey, 1985 84206364 | Country: US | | | | | [underlined: FTT] | [underlined: Ctrl] | All pts referred for FTT evaluation, > 12 wks age, FTT as defined or wt % decreased > 2 SD over time, residence ≤ 30 miles of clinic | Organic illness | Weight < 3^rd^ percentile for corrected age | Prospective cross-sectional
| Setting: Outpatient clinic or home | | | | Maternal | | | Control with normal growth, matched for age, race, sex, maternal education, household income, marital status, & crowdedness | | | 3 wk assessment from time of diagnosis
| | [underlined: FTT] | [underlined: Ctrl] | | educ | 11.3 | 10.9
| Age(mo)* | 16.4 | 16.9 | | Income | 5,451 | 6,188
| Wt/age* | 72.5% | 94.5% | | Helath insur: ND
| Ht/length* | 93.9% | 98.5%
| Enrolled/Eval | 23 | 23
| % Male | 57 | 57
| Race:
| % White | 26 | 26
| * At diagnosis
Hutcheson, 1993 94015754 | Country: US | | | | | [underlined: FTT] | [underlined: Ctrl] | Age 8 – 24 mo, NOFTT | Congenital disorder, chronic disease, < 37 wk gestation, SGA | Wt for age ≤ 5^th^ percentile, or wt for ht ≤ 10^th^ percentile, based on NCHS | Prospective cross-sectional
| Setting: Primary care clinic | | | | Maternal | | | Controls matched for age, sex, race
| | [underlined: FTT] | [underlined: Ctrl] | | educ* | 38 | 70
| Age(mo) | 15.1(5.2) | 14.9(5.1) | | Income† | 64 | 70
| Wt/age | 2.83 | 63.17 | | Helath insur | ND | ND
| Ht/age | 23 | 63
| Enrolled/Eval | 34 | 34 | | * % HS graduate
| % Male | 62 | 62 | | † % receiving AFDC
| Race: Black | 32 | 32
Kelleher, 1993 93234174 | Country: US | | | | | [underlined: FTT] | [underlined: Ctrl] | Gestation age ≤ 37 wks, birth wt ≤ 2500 g, FTT | Live outside catchment area, D/C outside recruitment period, D/C or died within 48 hr, hospitalized > 60 d, oxygen support > 90 d, twin, triplet or quadruplet of ineligible child, maternal drug/ alcohol abuse, insufficient Eng skills, psychiatric hosp | < 5^th^ percentile for gestation corrected age based on NCHS, growth status on “wt curve below that recorded at last regular assessment visit.” | Prospective longitudinal
| Setting: Primary care clinic | | | | Maternal | | | Controls matched for - birth wt +/- 250 g, maternal education, maternal race, & infant sex | | | Fwup at ages 12, 24, 36 mo
| | [underlined: FTT] | [underlined: Ctrl] | | educ* <HS | 40.6 | 38.1
| GA(wk)* | 33.0 | 33.1 | | HS | 30.0 | 29.3
| Wt(g)* | 1679 | 1845 | | Some col | 14.4 | 20.8
| Enrolled: 842* | | | | ≥col grad | 15.0 | 11.8
| Evaluated | 180 | 591 | | Income <10K | 38.6 | 34.5
| % Male | 52.2 | 47.9 | | 10–20K | 19.9 | 23.9
| Race: % Black | 50 | 53.8 | | >20K | 38.1 | 37.4
| * At birth | | | | Health insur | ND | ND
| | | | | * % HS graduate
Drotar, 1994 94308313 | Country: US | | | | | [underlined: FTT] | [underlined: Ctrl] | Hospitalized for NOFTT, ages 1–9 m | Physical abuse, residence > 1 hr from hospital, bw < 1500 gm | Wt = 5^th^ percentile based on NCHS, absence of disease, wt gain with inpatient tx, poor wt velocity | Prospective longitudinal
| Setting: Inpatient with outpatient follow-up | | | | Maternal | 10.9 | 11.3 | Controls matched for age at intake, sex, race, birth order, gestational age, maternal educ & age, family income & size | | | 1 follow-up at 3 yrs
| | [underlined: FTT] | [underlined: Ctrl] | | educ | (2.0) | (1.4)
| Age(mo)* | 4.7(2.8) | 5.0(2.7) | | Income | 6414 | 7495
| Wt/age: | ND | ND | | | (6669) | (10721)
| Ht/length: | ND | ND | | Health Insur:ND
| Enrolled | 48 | 52 | | Mean (SD)
| Evaluated | 31 | 39
| Male | 23(74%) | 25(64%)
| Race: Black | 17(55%) | 28(72%)
| White | 14(45%) | 11(28%)
| *Mean (SD), at enrollment
Skuse, 1994, 1995 94253258 96091265 | Country: UK | | | | Maternal education: ND | | | District-centered until 12 mo of age, singleton deliveries of 38–41 wks gestation | ≤ 3^rd^ centile, no wt data | Wt for age ≥ - 1.88 by 12 mo of age & sustained 3 mo (based on NCHS) | Prosepective longitudinal
| Setting: Outpatient | | | | Income: income/welfare support FTT-16, Ctrl-11 | | | Control matched for sex, age, ethnic origin, bw within 300 g, ordinal position, SES | | | Assessments at age 15 mo & 4y
| | [underlined: FTT] | [underlined: Ctrl] | | Health insur: National healthcare
| Mean age(SD)* | 14.6(1.4) | 14.2(1.4)
| Wt/age† | -2.07(.44) | .10(.96)
| Ht/length† | -1.27(.94) | .18(.73)
| Enrolled | 49 | 50
| Evaluated | 47 | 47
| % Male | 49 | 49
| % Non-white | 43 | 34
| * Age in months † z score, p < .001
Puckering, 1995 95378341 | Country: UK | | | | | [underlined: FTT] | [underlined: Ctrl] | From inner city population sample - Caucasian born in 1980 with longitudinal growth data from birth to 4 years | Prematurity, congenital defects/ diseases affecting growth, no perinatal insults | Ht & wt < 10% based on Tanner & Whitehouse growth charts | Ambidirectional cross-sectional
| Setting: Outpatient | | | | Maternal | 15.6 | 15.6 | Controls matched for sex, gestational age ≥ 38 wks, & ethnic origin
| | [underlined: FTT] | [underlined: Ctrl] | | educ* | (1.4) | (1.4)
| Age(mo) | 48.9(1.8) | 48.2(0.8) | | Income† | 11 | 7
| Wt/age* | -2.01(0.6) | -0.32(1.1) | | | 48% | 30%
| Ht/length* | -2.24(0.5) | -0.6(0.9) | | Health insur:
| Enrolled/Eval | 23 | 23 | | Socialized medicine
| % Male | 48 | 48
| Race: 100% White | | | | * Age leaving full-time education
| * SDS, based on NCHS, p < .001 | | | | † Income support/welfare
Wilensky, 1996 97022837 | Country: Israel | | | | | [underlined: FTT] | [underlined: Ctrl] | FTT infants by review of records who have reached 15 months born in 1991 | Birth wt < 2500 gm, < 37 weeks, wt/ht ratio > 10 %, organic cause of FTT | Wt < 3% by NCHS for = 3 months prior to age 15 months | Ambidirectional cross-sectional
| Setting: Community pediatric clinic | | | | Maternal | 13.8 | 13.4 | Controls from same maternal & child health clinic matched for birth month, maternal educ, maternal age, parity, and infants' birth wt
| | [underlined: FTT] | [underlined: Ctrl] | | educ* | (1.62) | (1.44)
| Mean age(mo)* | 15/20 | 15/20 | | Income: AFDC 76%
| Wt/age | ND | ND | | Health insur: ND
| Ht/length | ND | ND
| Enrolled† | 55 | 1352 | | * Mean (SD), based on record reiew of potential subjects
| Evaluated | 50 | 50
| % Male | ND | ND
| Race: ND;
| Maternal country of birth - 68% Israel, 25% Europe/America, 5% N Africa, 2% Asia
| * At entry / assessment
Drewett, 1999 99284054 | Country: UK | | | | | [underlined: FTT] | [underlined: Ctrl] | At least 1 wt at age 0–2 mo & 2 subsequent wts, thrive index < 5^th^ centile = 2 occasions between 3–18 mo | ND | Lowest 5% for change of SD score; avg taken of SD scores for all wt bet 0–2 mo, expected wt from 3–18 mo calculated for “thrive index” | Ambidirectional longitudinal
| Setting: Clinic / home visits | | | | Maternal educ* | 72 | 66 | Controls - at least 1 wt at age 0–2 mo & 2 subsequent wts, no thrive index < 10^th^ centile, age ± 1 mo, similar/same residential area or GP practice | | | Five years from enrollment of 1 y old cases
| | [underlined: FTT] | [underlined: Ctrl]
| Age(y) | 8.12(0.62) | 8.10(0.57) | | Income: NA
| Wt(kg)* | 23.8 | 27.9 | | Health insur: National healthcare
| BMI* | 14.9 | 16.3
| Enrolled | 136 | 136
| Evaluated† | 107/111 | 117/122 | | * % left school at 16 y
| % Male‡ | 40 | 38
| %White‡ | 91 | 91
| * Median, † Psychological / anthropometric evaluation, ‡ FTT = 107, Ctrl = 117
Wright, 2000 20161504 | Country: UK | | | | Maternal educ: ND | | | Baseline wt at 6–8 wk & 2^nd^ wt at 9–18 mo | 2^nd^ twin sibling | Weight decline of 1.26 SD from age 6–8 wks to 2^nd^ weighing at 9–18 months | Prospective cross-sectional
| Setting: Outpatient | | | | Income: ND | | | Controls from 3 “generally representative” of Newcastle
| | [underlined: FTT] | [underlined: Ctrl] | | | [underlined: FTT*] | [underlined: Ctrl*]
| Median age* | 15.1 | ND | | Unemployed parent | 39 | 13
| range | (7–28 m) | (16–18 m)
| Wt/age | -2.00(.93) | ND | | Nonhome-owner | 54.7 | 53.6
| Ht/length | -1.06(.96) | ND
| Enrolled | 120 | 40 | | No car | 48.3 | 50
| | Evaluated | 97 | 28 | | Health insur: National healthcare
| % Male | 54 | 61
| % Nonwhite | 9 | 0 | | * Percent

Evidence Table 9. Studies associating other correlates / outcomes with Failure to Thrive patients compared to healthy control subjects in developed countries Part II

Author,Year | Correlates / outcomes & measures | | | | | Associations found | Potential biases | Comments
Pollitt, 1976 76109110 | | [underlined: FTT*] | [underlined: Ctrl*] | | | The FTT mothers had less education (t = 1.88, p = 0.05) and the FTT household per capita income levels were also lower than the controls' (t = 2.77, p = .01). | 4 cases with FTT hx within ht 3^rd^ & 10^th^ percentiles included in study | Government & privately funded
| Maternal educ | 11(2) y | 12(1) y
| Income
| Gross annual | 6943(3444) | 9541(4768)
| Per capita | 1557(725) | 2648(1517)
| *Mean (SD)
Mitchell, 1980 80166667 | | [underlined: FTT] (%) | [underlined: Ctrl] (%) | | | The FTT had significantly more neonatal problems (p < .05) such as jaundice, poor suckling, & possible sepsis, and family problems (p < .01) compared to controls. NS but FTT group had higher incidence of prematurity and physical abuse. There were no differences in occurrences of illness, or “problems noted on physical examination”. | Physical exams & growth status by PI not blinded; significantly fewer cases had completed immunizations, p < .01 | Government & privately funded
| Neonatal abnormalities | 30 | 15
| Prematurity (<37 wk) | 16.7 | 9.2
| Family problems | 36.7 | 11
| Physical abuse | 3.3 | 2.1
| Acute or chronic illness | ND | ND
Hack, 1982 82227864 | Neonatal risk score | | | | | Subnormal wts at 8 months experienced by subset of both groups is associated with lower neonatal period (r = 0.28, p < .001), extended hospital stay (r = 0.30, p < .001) and increased illness severity (r = 0.32, p < .005). | 8 LTF, 4 incomplete data | SGA mothers incr % pregnancy HTN (p < .05) & multiple births (p < .05) than AGA, also incr antepartum risk score (p < .005) & greater gestational age (p < .005); privately funded
| Extended hospital stay
| Chronic disease
Haynes, 1984 84233543 | Catch-up growth | | | | | All FTT had some wt gain during hospitalization, at reeval-some minor wt gain, 8 FTT gain > 20 percentile pts or within 5 percentile of birth wt percentile | “...because of scheduling, few admissions were not evaluated”, 2 refused participation; 10 Gp1 & 3 Gp2 premature - overall similar from FTT vs. Ctrl; at 6 mo fwup: for FTT1 & FTT2 each-3 cases refused reevaluation & from1 dissolution of pair, 1Gp1 died SIDS, 1 Gp2 mother gave up child | Block assignment to Gp1 & Gp2 for hospital convenience & case load requirements; government funded
| ADL | | | | | At reeval, only minor improvement in mother's response to child's needs, majority of mothers hostile or incoordination
| | [underlined: FTT(%)]* | [underlined: Ctrl(%)] | | | Though NS as a risk factor, FTT had higher trend for prematurity and LBW
| Prematurity | 13(26) | 5(20) | | | 26% of FTT were re-hospitalized, 0% for Ctrl
| LBW | 11(22) | 5(20)
| Re-hospitalization | 13(26) | 0
| * intervention & non-intervention combined
Sherrod, 1985 85026403 | Anatomical defects - | | | | | Compared to controls, NOFTT group revealed more anatomical abnormalities such as hernias and heart disease during the 1^st^ year (χ^2^ = 4.23, p < .05) and during all 3 years (χ^2^ = 5.44, p < .025); and more family dysfunction during the 1^st^ year or during all 3 years (χ^2^ = 9.29, p < .01; χ^2^= 5.32, p < .025) accounting for clinic visits or identified at clinic visits. | Attending physicians alerted to give special treatment to children suffering from maltreatment, analysis showed no increase in outcome variability; study design to identify relationship of illness to abuse, not NOFTT to illness | Data collectors blind to child group assignment; government & privately funded
| | [underlined: FTT] | [underlined: Ctrl]
| 1y | .13 | .08
| 2y | .06 | .04
| 3y | .13 | .00
| Family dysfunction
| (ND due to low frequencies)
Casey, 1985 84206364 | HOME environment | | | | | There is an association between the lower HOME total (p < .04)& subset scores in maternal responsiveness (p < .03), maternal acceptance (p < .01), home organization p < .02), and FTT group. Coddington Life Events showed no difference between groups. | --- | All FTT pts referred to Growth & Development Clinic at hospital, all SES represented-majority low SES, assessor blinded to subject's group; government & privately funded
| | [underlined: FTT] | [underlined: Ctrl]
| Total score | 29.2(7.7) | 33.0(6.1)
| Maternal responsivity | 7.7(2.3) | 8.9(1.9)
| Maternal acceptance | 5.1(1.6) | 6.2(1.1)
| Organization of environment | 4.7(1.2) | 5.3(0.7)
Hutcheson, 1993 94015754 | | [underlined: FTT1]* | [underlined: FTT2]† | [underlined: Ctrl1]* | [underlined: Ctrl2]† | Though there were no age or group differences found on perceived life stresses, parenting stresses, informal support, and negative affectivity, the FTT infants had fewer life events than FTT toddlers, whereas the reverse was true for the comparison group. Controlling for maternal education, wt for age, & ht for age - significant group by age interaction for maternal factors (F=4.98, p = 0.02) due to maternal affective tone (F=9.33, p = 0.005). The maternal affect was less positive toward FTT toddlers than FTT infants. | 76% of index group met both criteria for NOFTT (wt for age, & ht for age), 24% met one criterion; unknown n for age by group comparisons | Government & privately funded
| Maternal psychological functioning -
| Negativity affectivity | 0.38 | 0.20 | 0.28 | -0.11
| Family stress/support -
| • Parenting stress | 0.53 | 0.57 | 0.70 | 0.67
| • Informal support | 1.12 | 1.19 | 1.26 | 1.46
| • Life events | 11.29 | 7.32 | 9.31 | 10.13
| Mother-child interaction -
| Maternal affective tone | 4.26 | 3.51 | 3.96 | 4.05
| Z scores given
| * Infants: 8 – 13.4 m
| †Toddlers: 13.5 – 24 m
Kelleher, 1993 93234174 | | [underlined: FTT(%)] | [underlined: Ctrl(%)] | | | Sample of LBW or premature infants were followed. Infants who developed FTT were more likely to have congenital heart disease, bronchopulmonary dysplasia, and cerebral palsy. General health status was lower for FTT as measured by Stein Total health Score (p < .003) and by the Rand General Health Ratings (p < .0001). For GI disorders, NS for vomiting & diarrhea. There were significant differences in environmental variables between the two gps (p < 0.03). | Of 985 enrolled, 71 LTF, 12%(20) OFTT, 16%(28) were both OFTT & NOFTT | 21% of babies develop FTT by 36 wks; ND on funding source
| Prematurity | 100 | 100
| LBW | 100 | 100
| Bronchopulmonary dysplasia | 13.9 | 9.6
| Congenital heart disease | 7.2 | .3
| Neurological - cerebral palsy | 8.9 | 4.6
| Environmental variables* | 32.6 | 33.9
| General health ratings | ND | ND
| Gastrointestinal disorders | ND | ND
| * HOME Inventory - total score
Drotar, 1994 94308313 | Family Relationship Index | | | | | Patients with NOFTT had poor family relationships at time of diagnosis which persisted for 3.6 years despite various interventions compared to the control group (F = 8.11, p < .01). There was an effect of time in the scores for both groups (F = 5.13, p < .05). | --- | Government & privately funded
| | [underlined: FTT] | [underlined: Ctrl]
| Intake | 47.9 (0.8) | 53.7 (5.6)
| Follow-up | 51.2 (8.2) | 56.0 (9.4)
Skuse, 1994, 1995 94253258 96091265 | 15 month assessment - | | | | | At 15 month assessment, NS but the cases had a trend for anemia & lower maternal IQ. At 4 year fwup, FTT at high risk for child abuse or neglect (RR = 4.43). | 1994: 2 cases & 3 controls didn't complete assessments & were excluded from analyses, 1 case had microcephaly, hypotonia, & an action tremor or ataxia of unknown origin | Researchers blinded to patient's status in measures except anthropometry, 1994 noted 1554 potential subjects in population sample vs. 2609 in 1995; privately funded
| | [underlined: FTT] | [underlined: Ctrl]
| Mother's IQ | 83.4(17.1) | 86.4(16.2)
| Maternal/child interaction | ND | ND
| Oral-motor function | ND | ND
| Anemia | 25.5% | 23.9%
| Abuse/neglect -
| 6 FTT & 90 nonFTT from sampling frame 2609
Puckering, 1995 95378341 | Maternal interactions | | | | | FTT signf less positive mother-child interactions compared to Ctrls dyads (combined unconditional measures, t = -2.69, p = .01); | --- | Other than clinic anthropometric measures, home visits by assessors blinded to child's group status; The FTT children were significantly smaller than the controls; government funded
| | [underlined: FTT] | [underlined: Ctrl] | | | FTT signf less positive interactions (combined conditional measures), t = -0.88, p = 0.4
| Positive - | | | | | NS but trend for more negative mother-child interactions (combined unconditional measures, t = 1.22, p = 0.2)
| Unconditional | -1.37 | 1.37 | | | NS (combined conditional measures), t = 0.12, p = 0.8
| Conditional | -0.16 | 0.16
| Negative -
| Unconditional | 1.16 | -1.16
| Conditional | 0.04 | -0.12
Wilensky, 1996 97022837 | | [underlined: FTT] | [underlined: Ctrl] | | | The FTT group was found to have lower birth weight (p < .05), and were more likely to be hypotonic than the control population (p < .05). They were twice as likely to be admitted in the hospital during their first year (χ^2^ = 5.10, p < .05). In addition, an assessment showed the home environment to be less stimulating (p < .05). | Feeding behaviors and HOME environment are causal factors given time dissociation as FTT was established at 15 months, where as, maternal interview/home assessment at 25 months. | 2/5^th^ of infants diagnosed as FTT no longer fit the criteria at 20-month follow-up, yet had positive association on Bayley MDI. Reported associations for FTT without specific data: paternal age (p<.01), maternal education, & behavioral observations of lower sociability (p<.05) & fear of examiner (p<.05); ND on funding source
| Birthweight* | 3074 | 3230
| Hypotonia* | 7.27% | 2.27%
| Hospitalization | 33.9% | 16.9%
| HOME environment
| • Active stimulation | .84(.17) | .92(.11)
| • Family encouraging development | .55(.31) | .71(.24)
| • Verbal & emotional reactivity | .85(.20) | .93(.14)
| * Record review of 55 FTT & 1352 Ctrl
Drewett, 1999 99284054 | | [underlined: FTT] | [underlined: Ctrl] | | | FTT children were significantly more likely to visit the hospital or outpatient clinic than the controls (χ^2^ = 4.54, p = .033). Paternal ht of FTT were significantly shorter than controls (t = 2.69, p < .01). 9% of cases vs. 3% of controls had relevant medical conditions that may have affected growth. FTT children had significantly more feeding problems than the controls (χ^2^ = 12.1, p < .01) | Of 136 cases, 1 died, 9 LTF, 15 declined psychological testing, 4 moved; of 136 controls, 2 were preterm, 5 LTF, 12 declined psychological testing, 14 moved & were replaced. 2 FTT cases & 1 control with medical condition affecting growth, & 9 FTT cases & 2 controls with possible medical conditions | Testers blinded to child's status; privately funded
| Hx hospital admission / hospital outpatient clinic | 66(62%) | 56(48%)
| Father's height | 174.2(7.8) | 177.0(7.2)
| Medical condition affecting growth - “definitely” / “possibly” | 2/9 | ½
| Feeding problems | 49(46%) | 28(24%)
Wright, 2000 20161504 | | [underlined: FTT] | [underlined: Ctrl] | | | 22% of cases received social work input of which 4% were registered as at risk for abuse or neglect vs. none for the controls. 3 or 4 FTT registered placed in foster care. FTT significantly later start in eating solids (p = .003) & finger foods (p = .005) compared to control group. | Of 120 cases, 23 recovered above screening threshold & had no subsequent data, 21 families received social work input of which, 4 cases registered at risk of abuse or neglect, 17 cases had “relevant organic conditions”…but only 4 said to be main explanation for their FTT”, age difference between groups | Government & privately funded
| Social work input | 21/97 | 0/28
| Abuse/neglect risk | 4/97 | 0/28
| Started solids* | 3.89 | 3.04
| Started finger foods* | 7.15 | 6.14
| * age (mo)
| (Belongs in Developmental table)

Evidence Table 10. Studies associating other correlates / outcomes with mainourished patients compared to well-nourished control subjects in developing countries Part I

Author, Year | Demographics | | | | Maternal / household demographics | Inclusion criteria | Exclusion criteria | Definition of malnutrition | Study design
Ghosh, 1979 80028795 | Country: India | | | | ND | 6 – 48 months, children with PEM, see Definition of FTT | ND | Based on 50^th^ percentile by Harvard scale: Grade 1-mild 71–80%, Grade 2- malnutrition 61–70%, Grades 3 & 4 severe ≤ 60% | Prospective cross-sectional
| Setting: Inpatient | | | | | Control matched for age, > 80% of 50% weight for age
| | [underlined: Gp1]* | [underlined: Gp2]† | [underlined: Ctrl]
| Age(mo) | 6–36 | 6–48 | 6–48
| Wt/age | ND | ND | ND
| Ht/age | ND | ND | ND
| Enrolled/Eval | 28 | 39 | 60
| % Male | 64 | 54 | 67
| Race: ND (assured Indians)
| * Mild-moderately malnourished, † Severe malnutrition
Bartel, 1978, 1979 78180773 79162492 | Country: South Africa | | | | ND | Bk 6 – 12 yr olds hospitalized during first 27 months of life for kwashiorkor, 5 – 10 yrs prior to commencement of study | Neurological involvement, brain damage, fits, birth trauma, hospital coma, hypoglycemia | Wellcome criteria for kwashiorkor: | Ambidirectional longitudinal
| Setting: Outpatient | | | | | Controls close in age, no hx of PCM: | | <3^rd^ percentile, edematous, and dermatitis and/or nutritional hair changes | Assessment at 4 – 12 y after hospitalization
| Age: ND | | | | | Ctrl1-Siblings close in age
| Wt/age: ND | | | | | Ctrl2-Yardmates of FTT
| Ht/length: ND | | | | | Ctrl3-High SES Whites
| | [underlined: Enrolled]* | [underlined: Eval]* | [underlined: Race]
| Gp | 31/30 | 31/30 | Black
| Ctrll1 | 31/30 | 31/30 | Black
| Ctrll2 | 31/30 | 31/30 | Black
| Ctrll3† | 90 | 90 | White
| % Male: ND
| *Bartel 1978 /Bartel 1979, † reported inBartel 1979
Kothari, 1992 92225733 | Country: India (Developing) | | | | ND | Ages 1–5 yr with severe PEM | Controls without anemia, infection, or cardiac disease | Grade IV malnutrition < 50^th^ percent of body wt based on 50^th^ percentile by Harvard scale | Prospective cross-sectional
| Setting: Inpatient | | | | | Controls matched for age & sex with normal nutritional status
| | [underlined: FTT] | [underlined: Ctrl]
| Mean age(y) | 2.65±0.88 | ND
| Enrolled | 25 | 26
| Evaluated | 25* | 26
| % Male | 52 | 50
| Race: ND (assumed Indians)
| * Marasmus - 15, marasmic kwashiorkor - 10
Bénéfice, 1992 92296639 | Country: Senegal | | | | ND | Age 9 – 14 y from 2 villages with per capita caloric intake of 2200 & 2400 | Recent serious illness, clinical signs of malnutrition or anemia | Wt/age < -1 SD median WHO/NCHS | Prospective cross-sectional
| Setting: Outpatient
| Age: ND
| Enrolled: 100
| Evaluated: FTT 64, Control 34
| % Male: 46
| Race: ND

Evidence Table 10. Studies associating other correlates / outcomes with malnourished patients compared to well-nourished control subjects in developing countries Part II

Author, Year | Correlates / outcome & measures | | | | | Associations found | Potential biases | Comments
Ghosh, 1979 80028795 | Nerve conduction - | | | | | Highly significant results with lower nerve conduction velocities in all age groups in the severe malnutrition group compared to controls (p < .001). No difference between mild/moderate group and controls. Specific n not given, however significant delay in nerve conduction in each nerve in infants with onset PEM < 12 mo vs. cases onset > 12 mo, p < .001 | --- | ND on funding source
| ulnar, median, peroneal nerves
Bartel, 1978, 1979 78180773 79162492 | Cardiovascular - | | | | | EEG frequency results were significant for group effect for both hemisphere (p < 0.01). Also there was group effect for the incidence of a & d bands in the right & a, d, & ? in the left hemisphere (p < 0.01). The kwashiorkor consistently scored higher in the d and lower in the a bands vs. the other groups (p < 0.05). | No data on difference of number of children between two reports | Single tester blinded to child's group assignment forBartel 1978; partially funded by African Medical Research Council
| Avg EEG freq
| • freq-R | 8.17 | 8.63 | 8.44 | 8.70
| • freq-L | 8.19 | 8.67 | 8.54 | 8.75
| Incidence of EEG activity of specified freq bands
| • theta-R | 15.59 | 9.49 | 11.76 | 9.12
| • alpha-R | 43.96 | 55.54 | 51.78 | 56.41
| Mean (SD), * Dominant hand scores
Kothari, 1992 92225733 | | [underlined: Cases] | [underlined: Ctrl] | | | Left ventricular mass was less in the cases vs controls (p < 0.05, CI 2.08–11.30), but left ventricular mass/body wt was higher in the cases (p < 0.001, CI 1.28–2.76) which is associated with poorer prognosis. Cardiac index increased in the cases vs. controls (p < 0.05, 0.04–1.92) Relative cardiac sparing in most cases, although there was atrophy. No difference between groups in EJ, but there were EF < 50% in 5 cases, 2 of 5 died within 3 wks. | --- | ND on funding source
| Left ventricular mass | 25.75(8.09) | 32.44(11.64)
| Left ventricular mass / body wt | 4.44(1.45) | 2.42(0.87)
| Cardiac index* | 5.95(1.95) | 4.97(1.41)
| Ejection fraction | 62.4(10.7) | 67.0(7.8)
| Anemia - Mean hemoglobin - 7.16±1.78 g/dl
| * I/min/m^2^
Bénéfice, 1992 92296639 | | [underlined: FTT] | [underlined: Ctrl] | | | Children with malnutrition scored lower in areas of physical activity (p < .05), had less work capacity (t = 3.2, p < .001), had lower pulmonary function (p < .001), arm muscle compared to nourished controls. There was no difference in HR (t=0.37) or level of physical activity. | Child's age determined by recall, no records available; no explanation on missing case from each group not in analyses | ND on funding source
| Power work capacity | 60.9(2.8) | 75.1(4.4)
| FVC, < 132 months | 1.33(0.04) | 1.61(0.04)
| FVC, > 132 months | 1.73(0.03) | 2.23(0.09)
| 33 m dash (sec) | 7.22(0.10) | 6.60(0.15)
| Jumping (m) | 1.34(0.02) | 1.43(0.03)
| Throwing (m) | 13.4(0.4) | 15.7(0.6)
| Hand grip (kPa) | 47.5(2.0) | 54.6(2.9)
| HR (%) > 125 | 8.85(1.45) | 7.85(2.06)
| Adjusted mean (SD)