# References and Bibliography

Disability evaluation under Social Security. Social Security Administration, Office of Disability; 1999
Agarwal D K, Awasthy A, Upadhyay S K, et al. Growth, behavior, development and intelligence in rural children between 1–3 years of life. Indian Pediatr. Apr. 1992;29(4):467-80. [pmid: 1506099].
Alvear J, Artaza C, Vial M, et al. Physical growth and bone age of survivors of protein energy malnutrition. Arch Dis Child. Mar. 1986;61(3):257-62. [pmid: 3083790].
Ballard T J, Neumann C G. The effects of malnutrition, parental literacy and household crowding on acute lower respiratory infections in young Kenyan children. J Trop Pediatr. Feb. 1995;41(1):8-13. [pmid: 7723139].
Barrett DE, Frank DA. The effects of undernutrition on children's behavior. Gordon and Breach, New York, 1987.
Bartel P R, Griesel R D, Freiman I, et al. Long-term effects of kwashiorkor on the electroencephalogram. Am J Clin Nutr. Apr. 1979;32(4):753-7. [pmid: 433808].
Bartel P R, Griesel R D, Burnett L S, et al. Long-term effects of kwashiorkor on psychomotor development. S Afr Med J. Mar 11. 1978;53(10):360-2. [pmid: 653470].
Benefice E. Physical activity and anthropometric and functional characteristics of mildly malnourished Senegalese children. Ann Trop Paediatr. 1992;12(1):55-66. [pmid: 1376588].
Black M M, Krishnakumar A. Predicting longitudinal growth curves of height and weight using ecological factors for children with and without early growth deficiency. J Nutr. Feb. 1999;129(2S Suppl):539S-43S. [pmid: 10064327].
Boddy J M, Skuse D H. The process of parenting in failure to thrive. [Review] [88 refs]. Journal of Child Psychology & Psychiatry & Allied Disciplines. Mar. 1994;35(3):401-24.
Branko Z. Height, weight, and head circumference in survivors of marasmus and kwashiorkor. Am J Clin Nutr. Aug. 1979;32(8):1719-27. [pmid: 223431].
Carvalho Neves Forte W, Martins Campos J V, Carneiro Leao R. Non specific immunological response in moderate malnutrition. Allergol Immunopathol (Madr). 1984;12(6):489-96. [pmid: 6442096].
Casey P H, Bradley R, Wortham B. Social and nonsocial home environments of infants with nonorganic failure-to-thrive. Pediatrics. Mar. 1984;73(3):348-53. [pmid: 6701059].
Casey P H, Wortham B, Nelson J Y. Management of children with failure to thrive in a rural ambulatory setting. Epidemiology and growth outcomes. Clin Pediatr (Phila). Jun. 1984;23(6):325-30. [pmcid: 358331]. [pmid: 6723176].
Chatoor I, Ganiban J, Colin V, et al. Attachment and feeding problems: a reexamination of nonorganic failure to thrive and attachment insecurity. J Am Acad Child Adolesc Psychiatry. Nov. 1998;37(11):1217-24. [pmid: 9808934].
Coleman R W, Provence S A. Environmental retardation (hospitalism) in infants living in families. Pediatrics. 1957;19:285-92. [pmid: 13400604].
Corbett S S, Drewett R F, Wright C M. Does a fall down a centile chart matter? The growth and developmental sequelae of mild failure to thrive. Acta Paediatr. Nov. 1996;85(11):1278-83. [pmid: 8955452].
Drewett R, Wolke D, Asefa M, et al. Malnutrition and mental development: is there a sensitive period? A nested case-control study. J Child Psychol Psychiatry. Feb. 2001;42(2):181-7. [pmid: 11280414].
Drewett R F, Corbett S S, Wright C M. Cognitive and educational attainments at school age of children who failed to thrive in infancy: a population-based study. J Child Psychol Psychiatry. May. 1999;40(4):551-61. [pmid: 10357162].
Drotar D, Pallotta J, Eckerle D. A prospective study of family environments of children hospitalized for nonorganic failure-to-thrive. J Dev Behav Pediatr. Apr. 1994;15(2):78-85. [pmid: 8034771].
Drotar D, Sturm L. Personality development, problem solving, and behavior problems among preschool children with early histories of nonorganic failure-to-thrive: a controlled study. J Dev Behav Pediatr. Aug. 1992;13(4):266-73. [pmid: 1506465].
Evans D, Hansen J D, Moodie A D, et al. Intellectual development and nutrition. J Pediatr. Sep. 1980;97(3):358-63. [pmid: 6774071].
+Ferguson A C, Lawlor G J Jr, Neumann C G, et al. Decreased rosette-forming lymphocytes in malnutrition and intrauterine growth retardation. J Pediatr. Nov. 1974;85(5):717-23. [pmid: 4213798].
Friedland I R. Bacteraemia in severely malnourished children. Ann Trop Paediatr. 1992;12(4):433-40. [pmid: 1283674].
Galler J R, Ramsey F, Solimano G. A follow-up study of the effects of early malnutrition on subsequent development. I. Physical growth and sexual maturation during adolescence. Pediatr Res. Jun. 1985;19(6):518-23. [pmid: 3925426].
Galler J R, Ramsey F, Solimano G. A follow-up study of the effects of early malnutrition on subsequent development. II. Fine motor skills in adolescence. Pediatr Res. Jun. 1985;19(6):524-7. [pmid: 3925427].
Galler J R, Ramsey F, Solimano G, et al. The influence of early malnutrition on subsequent behavioral development. II. Classroom behavior. J Am Acad Child Psychiatry. Jan. 1983;22(1):16-22. [pmid: 6402541].
Galler J R, Ramsey F, Solimano G, et al. The influence of early malnutrition on subsequent behavioral development. I. Degree of impairment in intellectual performance. J Am Acad Child Psychiatry. Jan. 1983;22(1):8-15. [pmid: 6402542].
Ghosh S, Vaid K, Mohan M, et al. Effect of degree and duration of protein energy malnutrition on peripheral nerves in children. J Neurol Neurosurg Psychiatry. Aug. 1979;42(8):760-3. [pmid: 114607].
Grantham-McGregor S, Schofield W, Powell C. Development of severely malnourished children who received psychosocial stimulation: six-year follow-up. Pediatrics. Feb. 1987;79(2):247-54. [pmid: 3808797].
Grantham-McGregor S, Schofield W, Harris L. Effect of psychosocial stimulation on mental development of severely malnourished children: an interim report. Pediatrics. Aug. 1983;72(2):239-43. [pmid: 6191271].
Grantham-McGregor S M, Powell C, Stewart M, et al. Longitudinal study of growth and development of young Jamaican children recovering from severe protein-energy malnutrition. Dev Med Child Neurol. Jun. 1982;24(3):321-31. [pmid: 6178640].
Grantham-McGregor S, Stewart M E, Schofield W N. Effect of long-term psychosocial stimulation on mental development of severely malnourished children. Lancet. Oct 11. 1980;2(8198):785-9. [pmid: 6107460].
Grantham-McGregor S M, Stewart M, Desai P. A new look at the assessment of mental development in young children recovering from severe malnutrition. Dev Med Child Neurol. Dec. 1978;20(6):773-8. [pmid: 103763].
Hack M, Merkatz I R, Gordon D, et al. The prognostic significance of postnatal growth in very low—birth weight infants. Am J Obstet Gynecol. Jul 15. 1982;143(6):693-9. [pmid: 7091243].
Haynes C F, Cutler C, Gray J, et al. Hospitalized cases of nonorganic failure to thrive: the scope of the problem and short-term lay health visitor intervention. Child Abuse Negl. 1984;8(2):229-42. [pmid: 6539644].
Hutcheson J J, Black M M, Starr R H Jr. Developmental differences in interactional characteristics of mothers and their children with failure to thrive. J Pediatr Psychol. Aug. 1993;18(4):453-66. [pmid: 7692030].
Kelleher K J, Casey P H, Bradley R H, et al. Risk factors and outcomes for failure to thrive in low birth weight preterm infants. Pediatrics. May. 1993;91(5):941-8. [pmid: 8474814].
Kerr M A, Black M M, Krishnakumar A. Failure-to-thrive, maltreatment and the behavior and development of 6-year-old children from low-income, urban families: a cumulative risk model. Child Abuse Negl. May. 2000;24(5):587-98. [pmid: 10819092].
Kothari S S, Patel T M, Shetalwad A N, et al. Left ventricular mass and function in children with severe protein energy malnutrition. Int J Cardiol. Apr. 1992;35(1):19-25. [pmid: 1563875].
Mackner L M, Starr R H Jr, Black M M. The cumulative effect of neglect and failure to thrive on cognitive functioning. Child Abuse Negl. Jul. 1997;21(7):691-700. [pmid: 9238552].
Mitchell W G, Gorrell R W, Greenberg R A. Failure-to-thrive: a study in a primary care setting. Epidemiology and follow-up. Pediatrics. May. 1980;65(5):971-7. [pmid: 7367142].
Neumann C G, Lawlor G J Jr, Stiehm E R, et al. Immunologic responses in malnourished children. Am J Clin Nutr. Feb. 1975;28(2):89-104. [pmid: 803774].
Pandey A, Chakraborty A K. Undernutrition, vitamin A deficiency and ARI morbidity in underfives. Indian J Public Health. Jan. 1996;40(1):13-6. [pmid: 9090895].
Polan H J, Leon A, Kaplan M D, et al. Disturbances of affect expression in failure-to-thrive. J Am Acad Child Adolesc Psychiatry. Nov. 1991;30(6):897-903. [pmid: 1757438].
Pollitt E, Eichler A. Behavioral disturbances among failure-to-thrive children. Am J Dis Child. Jan. 1976;130(1):24-9. [pmid: 1246996].
Puckering C, Pickles A, Skuse D, et al. Mother-child interaction and the cognitive and behavioural development of four-year-old children with poor growth. J Child Psychol Psychiatry. May. 1995;36(4):573-95. [pmid: 7650084].
Reif S, Beler B, Villa Y, et al. Long-term follow-up and outcome of infants with non-organic failure to thrive. Isr J Med Sci. Aug. 1995;31(8):483-9. [pmid: 7543467].
Sherrod K B, O'Connor S, Vietze P M, et al. Child health and maltreatment. Child Dev. Aug. 1984;55(4):1174-83. [pmid: 6488952].
Singer L T, Fagan J F III. Cognitive development in the failure-to-thrive infant: a three-year longitudinal study. J Pediatr Psychol. Sep. 1984;9(3):363-83. [pmid: 6502402].
Skuse D, Pickles A, Wolke D, et al. Postnatal growth and mental development: evidence for a “sensitive period”. J Child Psychol Psychiatry. Mar. 1994;35(3):521-45. [pmid: 7515070].
Skuse D H, Gill D, Reilly S, et al. Failure to thrive and the risk of child abuse: a prospective population survey. J Med Screen. 1995;2(3):145-9. [pmid: 8536184].
Steward D K, Moser D K, Ryan-Wenger N A. Biobehavioral characteristics of infants with failure to thrive. J Pediatr Nurs. Jun. 2001;16(3):162-71. [pmid: 11398126].
Tuck R, Burke V, Gracey M, et al. Defective Candida killing in childhood malnutrition. Arch Dis Child. Jun. 1979;54(6):445-7. [pmid: 475427].
Walker S P, Grantham-McGregor S M, Himes J H, et al. Early childhood supplementation does not benefit the long-term growth of stunted children in Jamaica. J Nutr. Dec. 1996;126(12):3017-24. [pmid: 9001369].
Wilensky D S, Ginsberg G, Altman M, et al. A community based study of failure to thrive in Israel. Arch Dis Child. Aug. 1996;75(2):145-8. [pmid: 8869197].
Wright C, Birks E. Risk factors for failure to thrive: a population-based survey. Child Care Health Dev. Jan. 2000;26(1):5-16. [pmid: 10696514].
Wright J A, Ashenburg C A, Whitaker R C. Comparison of methods to categorize undernutrition in children. Journal of Pediatrics. Jun. 1994;124(6):944-6. [pmid: 8201483].
Zenel J A Jr. Failure to thrive: a general pediatrician's perspective. Pediatrics in Review. Nov. 1997;18(11):371-8. [pmid: 9360433].