# Future Research

The studies comprising this report, though insufficient in number and variable in their methodologic quality and their potential biases, were of sufficient validity to provide significant information regarding the association of FTT with disability. The variety and long-term nature of the disabilities associated with FTT have major impact on the child, the family, and society.

Notwithstanding this, it may well be that the most significant finding of this review was the paucity of information available on the subject. Much remains to be learned regarding the extent and specifics of these associations and disabilities. Even more remains to be determined as to the optimal management of these patients.

Similarly, whatever limitations may have been found in these studies, they have also served to better define relevant outcomes for further study. With this in mind, we offer the following recommendations for future research addressing specific problematic issues and limitationsidentified from review of existing research.

- One of the central problems in interpreting these studies was the heterogeneity of definitions of FTT. This variability in case definition makes it unclear how well the population at risk is being identified at present. Future research should apply a uniform definition of FTT. This would serve to facilitate comparison and perhaps even allow a meta-analysis of studies. It would also define more clearly the true prevalence of FTT.
- Within the definition of FTT, provisions should be made for categorization based upon 1) severity and 2) longevity or duration of growth failure. The data currently available indicate that both of these factors are strong predictors not only for the risk of associated disabilities but for potential response to therapy as well. Refining the classification of the FTT population in this way would facilitate identification of the relative risk of disability for an individual FTT child. It would also help in the evaluation of intervention studies.
- Although it is clear that the degree of disability increases with increasing severity of growth failure, this is an imprecise correlation especially in regards to children with mild to moderate FTT. Since the majority of FTT that is seen in the US tends not to be the most severe forms of marasmus and kwashiorkor, future research should specifically target those children with mild to moderate growth failure.
- Similarly, more research needs to be conducted in the US, or in developed countries with comparable social-economic structures and health care systems.
- Special emphasis should be given to outcomes focusing on neurodevelopmental and cognitive disorders. The data presented in this report indicate that this is likely one of the areas of strongest impact of FTT and certainly one with the greatest relevance for long term disability. Specifically, very few studies have focused on the issue of FTT and brain growth during the immediate post-neonatal period and early infancy. This is one of the most critical periods for dendritic arborization, axonal myelination, and the development of cognitive functions. More studies are needed in this area.
- Further study is also needed on the association of FTT with general health outcomes because of their potential impact on the healthcare system. Beyond the risk to the individual child, the data linking FTT to increased risk of infections and poorer general health may have important implications at a broader level. Such data may help us understand the true “cost” of FTT and prove useful in evaluating intervention strategies.
- In order to better define the true nature and extent of the disabilities associated with FTT, more studies are needed that prospectively follow children for a sufficient duration to capture the more complex disabilities that may result from FTT.
- A consistent finding among these studies reviewed was the ineffectiveness of existingintervention programs. Although strictly beyond the focus of this report, much work still needs to be done on developing effective treatment programs for children with FTT. Unfortunately, the optimal intervention will yet require better definition of the complex physical, medical, cognitive, and psychosocial problems associated with failure to thrive.