# Conclusions

## Overview

This research has produced an evidence base that the SSA can use to help update its disability guidelines and to revise its disability policy. The review was designed to address the following question: Among children defined by investigators as failing to thrive (FTT) or grow adequately, what evidence exists that they have a concurrent disability (or will have one within six months)?

We reviewed 275 articles and used 52 articles encompassing 43 studies to produce this evidence report. It should be stressed that the single most common reason for exclusion was the lack of a non-FTT comparison group, as we thought that no valid associations could be drawn from descriptive reports or interventional studies that lacked an appropriate control. The quality of the studies we were able to use was variable. While the study question regarding FTT is clear, most of the studies were not designed to specifically address issues relating to disability as defined by the U.S. Congress and interpreted by SSA. Despite this, the evidence extracted from the articles we reviewed clearly suggests a relationship between FTT and concurrent disability, disability within 6 months, and disability beyond 6 months. We described this evidence with respect to specific disabilities in Chapter 3, and in this section we review the implications of those findings as well as some limitations of the studies.

There are a number of potential confounders that need to be considered. The studies from developed countries looked at FTT mainly in lower social-economic status (SES) groups. Several potential risk factors for developing FTT are prevalent among lower SES populations, such as lower family income and maternal level of education, higher incidence of abuse or neglect, family dysfunction and negative maternal interaction. Such factors may exert independent and potentially stronger negative influences on childhood health, well-being and development than those of growth failure, thereby masking the specific deleterious impact of the failure to thrive. Alternatively, the diagnosis of FTT may inherently create bias by increasing clinicians' suspicion and subsequent investigation for potential covariates such as disturbances in family dynamics, or maternal interaction, abuse and neglect.

Studies from developing countries were generally examining the effects of severe malnutrition, often marasmus or kwashiorkor. The extrapolation of their results to the FTT population in the US must be approached with some caution. Lastly, even within developed countries, where the population of FTT children was generally well matched to those in the US, the available studies still demonstrated significant variation, both in specific FTT inclusion criteria, and exclusion criteria (e.g., LBW/SGA).

## Persistent Disorders of Growth

There is substantial evidence that long term growth in all parameters (weight, height, and head circumference) of children with FTT compares unfavorably with thriving children and that this disparity persists even with appropriate attempts at intervention. This pattern of a persistent growth deficit is seen in both developed and developing countries and across a wide spectrum of severity of FTT.

The effect on head growth is especially concerning, since increasing head circumference reflects brain growth, and therefore any impairment in head growth impacts neurodevelopmental outcomes. There is also evidence that the longer the growth failure continues, the less likely it becomes that treatment will be effective in reversing the negative long-term outcomes. These findings highlight the importance of early identification and intensive nutritional intervention for children with FTT syndrome to improve efficacy of the therapy and to minimize long-term damage.

## Associations of FTT With Immunologic/infectious Outcomes

The evidence that children with FTT have significantly greater susceptibility to infection is strong, and includes both markers of immunologic dysfunction at the cellular level and clinical correlates seen consistently across a variety of conditions. The laboratory indices of cellular immunologic dysfunction were apparent in children with moderate severity and, at least in such moderate cases, may be amenable to nutritional intervention. As expected, the more severe complications were most prevalent among the most severely malnourished children. The evidence is supportive of identifying children with growth failure as being at risk for multiple acute and chronic infections, especially as this may be an area where intervention may effectively reverse the associated risk.

## Behavior Difficulties Associated With Failure to Thrive

The evidence identified by the search showed that children with FTT exhibited a variety of behavioral disorders, both concurrently at diagnosis as well as at follow-up. All except one of the relevant studies were conducted in developed countries, on a population of children with moderate degrees of FTT, representing a strong match to the case mix of FTT children in the US.

Studies involving concurrent behavioral abnormalities in FTT cases examined children up to 3 years of age. The behavioral problems exhibited by the children diagnosed with FTT included various eating disorders, such as delayed introduction of solid foods, spitting, disinterest, and food aversions. Other behavioral disorders that were noted involve increased negative and decreased positive affective expressiveness, and lower scores on measures of communication and mood. These behavioral difficulties do not in themselves constitute disabilities using the SSA definition, but may contribute to functional deficits noted in neurologic and cognitive/social development.

Studies examining behavior problems in children diagnosed with FTT at follow-up focused on social situations such as classroom behavior. School-related behavioral problems such as attention deficit disorder (ADD) were found in one study to be more common among FTT children than controls. In addition, one investigator found interference with problem-solving skills more often in FTT children than in well-nourished controls.

## Developmental Disorders Associated With Failure to Thrive

The evidence identified by the search showed that children with FTT exhibited consistently poorer scores in a variety of tests of cognitive, neurological, and psychomotor development. Indeed, the deleterious effect of growth failure and malnutrition on neurodevelopment is among the strongest and most important associations found. This trend toward poor neurodevelopmental performance was consistent for all fourteen of the studies conducted in developed countries, and five of the six studies conducted in the developing countries.

Despite exclusion of children with overt neurodevelopmental abnormalities from the case definition of FTT, at the time of identification, FTT is still strongly associated with poorer developmental test scores. Again, not unexpectedly, the most severe developmental delays are found among the most severely malnourished, often hospitalized children. However, even in larger epidemiological studies, the effect of FTT on neurodevelopmental outcome is apparent. Such studies indicate that the diagnosis of FTT is associated with an average decrease in developmental test scores of roughly two-thirds of a standard deviation. This means that children with failure to thrive are also more likely to meet criteria for the SSA qualifying range of developmental delay than are children in the general population. Adding to the concern of such cases is the fact that these lower neurodevelopmental testing scores persisted regardless of intervention.

## Evidence that Failure to Thrive is Associated With Other Clinical, Psychosocial and Family Factors

There is persuasive evidence that FTT is associated with a range of organic and psychosocial difficulties. Some of these associations may be potential causal factors for the growth failure, such as low socioeconomic status and maternal education level, family dysfunction and the presence of neonatal morbidities. Others, such as the frequency of hospitalization, general health status, and specific neurologic abnormalities are more likely the result of the malnutrition. Furthermore, several of these factors may also independently predict or place a child at risk for significant disability. The possible interrelation of such factors complicates the delineation of the true nature of their association with FTT; nonetheless, they provide further insight into the complexities of the risks inherent in the diagnosis of growth failure.

Overall, the results are generally consistent across a broad spectrum of growth failure severity, and the majority of the studies are readily and creditably generalizable to the population of children with FTT as defined by SSA. Additionally, the study results further highlight the severity and potential long-term impact of these associations in their consistent finding that these psychosocial and family difficulties are not readily amenable to current interventions.

The implications of FTT on long-term morbidity and disability can vary depending upon the severity of FTT, its cause, and most importantly the chronological age at which FTT occurred. Thus, in spite of an appropriate review of literature, we may still be not be able to assess the full magnitude of FTT on developing children because of the wide age range of subjects in the reported studies. One thing we can certainly conclude is that a major FTT event in a child's life occurring particularly at a critical phase of the growth curve (which varies among body systems; brain, skeleton etc.) has a high likelihood of causing major disability. The age of the child and the magnitude of FTT thus may have differing effects on different body systems. This is an important area in which to target intervention programs as well as further probe molecular and genetic bases for such impairments.