# Appendix D. Acronyms/Abbreviations

ADHD | Attention deficit hyperactivity disorders
ADL | Activities of daily living
AFDC | Aid to Families with Dependent Children
AGA | appropriate for gestational age
ALRI | acute lower respiratory infections
ANCOVA | analyses of covariance
ARI | acute respiratory infections
BGS | Boston Growth Standard
BMI | body mass index
CBCL | Child Behavior Checklist
Ctrl | control
D | day(s)
D/C | discharge
FU | follow-up
FVC | forced vital capacity
GCI | general cognitive index
GA | gestational age
Gp | group
HC | head circumference
HOME | Home Observation for Measurement of the Environment
HR | heart rate
HS | high school
Ht | height
Hx | history
Incr | increase(d)
LBW | low birth weight
LOMDS | Lincoln-Oseretsky motor development scale
MANCOVA | multivariate of analyses of covariance
Mo | month(s)
MDI | mental development index
ND | no data
Nl | normal
NOFTT | non-organic failure to thrive
NS | not significant
NCHS | National Center for Health Statistics
Nonsignf | nonsignificant
OFTT | organic failure to thrive
PCERA | Parent-Child Early Relational Assessment scale
PCM | protein-calorie malnutrition
PDI | psychomotor development index
PEM | protein-energy malnutrition
PHA | phytohemagglutinin
PPVT | Peabody Picture Vocabulary Test
RFC | rosette forming cells
RR | relative risk
SD | standard deviation
SDS | standard deviation score
SES | social-economic status
SGA | small for gestational age
Signf | significant
SK-SD | streptokinase-streptodornase
Std | standard
SOMA | Schedule for Oral Motor Assessment
SWFA | standard weight for age
THE | tetrahydrocortisol
THF | tetrahydrocortisone
TRIB | Tester's Rating of Infant Behaviour
UI | Medline unique indentifer
WAIS | Wechsler Adult Intelligence Scale
WD | withdrawn
WPPSI / WPPSI-R | Wechsler Pre-school and Primary Scale of Intelligence
WISC | Wechsler Intelligence Scale for Children
WORD test | Wechsler Objective Reading Dimensions manual
Wt | weight