# Appendix A. Literature Search Strategies

## Search #1

1. follow-up studies/
2. follow-up.tw.
3. exp Case-Control Studies/
4. case-control.tw.
5. exp Longitudinal Studies/
6. longitudinal.tw.
7. exp Cohort Studies/
8. cohort.tw.
9. (random$ or rct).tw.
10. exp Randomized Controlled Trials/
11. exp random allocation/
12. exp Double-Blind Method/
13. exp Single-Blind Method/
14. randomized controlled trial.pt.
15. clinical trial.pt.
16. (clin$ adj trial$).tw.
17. ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw.
18. exp PLACEBOS/
19. placebo$.tw.
20. exp Research Design/
21. Comparative Study/
22. exp Evaluation Studies/
23. exp Prospective Studies/
24. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23
25. disab$.af.
26. limitation$.af.
27. handicap$.af.
28. impair$.af.
29. 25 or 26 or 27 or 28
30. exp growth disorders/ or failure to thrive/
31. exp Nutrition Disorders/
32. failure to thrive.af.
33. 30 or 31
34. 24 and 29 and 33
35. limit 34 to human
36. limit 35 to english language
37. limit 36 to (newborn infant or infant <1 to 23 months> or preschool child <2 to 5 years> or child <6 to 12 years> or adolescence <13 to 18 years>)
38. 36 not 37
39. limit 38 to (adult <19 to 44 years> or middle age <45 to 64 years> or “aged <65 and over>” or “aged, <80 and over>”)
40. 36 not 39
41. 24 and 32
42. limit 41 to (newborn infant or infant <1 to 23 months> or preschool child <2 to 5 years> or child <6 to 12 years> or adolescence <13 to 18 years>)
43. 41 not 42
44. limit 43 to (adult <19 to 44 years> or middle age <45 to 64 years> or “aged <65 and over>” or “aged, <80 and over>”)
45. 41 not 44
46. limit 45 to human
47. limit 46 to english language
48. 40 not 47
49. 47 or 48
50. exp Body Weight/
51. 24 and 29 and 50
52. limit 51 to human
53. limit 52 to (newborn infant or infant <1 to 23 months> or preschool child <2 to 5 years> or child <6 to 12 years> or adolescence <13 to 18 years>)
54. 52 not 53
55. limit 54 to (adult <19 to 44 years> or middle age <45 to 64 years> or “aged <65 and over>” or “aged, <80 and over>”)
56. 52 not 55
57. limit 56 to english language
58. 49 or 57

## Search #2

1. exp Failure to thrive/
2. exp Infant nutrition disorders/
3. exp Nutrition disorders/
4. exp failure to thrive/ or exp growth/
5. exp Growth/
6. exp Growth disorders/
7. exp Nutrition disorders/
8. exp Protein-energy malnutrition/
9. exp Child nutrition disorders/
10. exp Child nutrition/
11. exp Infant nutrition disorders/
12. exp Body weight/
13. exp Growth/
14. exp Protein-energy malnutrition/
15. exp Growth disorders/
16. exp Body height/
17. exp Dwarfism, pituitary/
18. exp Dwarfism, pituitary/
19. exp Psychosocial deprivation/
20. exp Dwarfism/
21. exp Stress, psychological/
22. exp Stress, psychological/
23. exp Psychophysiologic disorders/
24. exp Hyperphagia/
25. exp Child behavior/
26. exp Child abuse/
27. FAILURE TO THRIVE.mp.
28. childhood malnutriton.mp. [mp=title, abstract, registry number word, mesh subject heading]
29. failure to thrive.mp. [mp=title, abstract, registry number word, mesh subject heading]
30. protein energy malnutrition.mp. [mp=title, abstract, registry number word, mesh subject heading]
31. growht failure.mp. [mp=title, abstract, registry number word, mesh subject heading]
32. growth failure.mp. [mp=title, abstract, registry number word, mesh subject heading]
33. failure to grow.mp. [mp=title, abstract, registry number word, mesh subject heading]
34. pshchosocial dwarfism.mp. [mp=title, abstract, registry number word, mesh subject heading]
35. psychosocial dwarfism.mp. [mp=title, abstract, registry number word, mesh subject heading]
36. hyperphagic short stature.mp. [mp=title, abstract, registry number word, mesh subject heading]
37. childhood neglect.mp. [mp=title, abstract, registry number word, mesh subject heading]
38. childhood neglect.mp. [mp=title, abstract, registry number word, mesh subject heading]

## Search #3

1. thriv$.af.
2. follow-up studies/
3. follow-up.tw.
4. Case-Control Studies/
5. case-control.tw.
6. exp Longitudinal Studies/
7. longitudinal.tw.
8. exp Cohort Studies/
9. cohort.tw.
10. (random$ or rct).tw.
11. exp Randomized Controlled Trials/
12. exp random allocation/
13. exp Double-Blind Method/
14. exp Single-Blind Method/
15. randomized controlled trial.pt.
16. clinical trial.pt.
17. (clin$ adj trial$).tw.
18. ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw.
19. exp PLACEBOS/
20. placebo$.tw.
21. exp Research Design/
22. Comparative Study/
23. exp Evaluation Studies/
24. exp Prospective Studies/
25. 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24
26. 1 and 25
27. limit 26 to human
28. limit 27 to english language