# Evidence Tables

Evidence Table 1a. Study descriptions for vaginal delivery, maternal and infant outcomes - good or fair quality studies

Author Year Quality | Country Setting | Study design Years of Study Research Objective | Population | Exclusion criteria | Intervention Control Other Procedures | Reasons for induction
Randomized Controlled Trials
Lelaidier 1994 ^35^ | France | Unclear | Women with one prior delivery, by CD. | 1. Unknown scar; 2. Nonvertex presentation; 3. Multiple pregnancies; 4. Premature rupture of membranes; 5. Previously delivered vaginally. | Intervention: Mifepristone 200mg on days one and two, monitored on days 3 and 4. | 66% Prolonged pregnancy
| | | Bishop's scores </= 3
| | Study duration 6 months, manuscript received May 1993 | | | | 22% pre-eclampsia
FAIR | | | I/A: 16 | | | 0.1% IUGR
| | | SL: 16 | | Control: Placebo on days one and two, monitored on days 3 and 4.
| | To evaluate the tolerance and efficacy of mifepristone in women with prior CD with an unfavorable cervix. | Age: Mean age 33(m), 32(pl)
| | | Parity: 1 | | Other Procedures, Interventions:
| | | Race: Not reported | | If no labor by day 4: induction with prostaglandins if Bishops score </=3, ARM+oxytocin if >/=4
| | | Insurance:NR
Rayburn 1999 ^32^ | USA | | 1 prior low-transverse CD, gestational age >/=38 wks, accurate gestational dating by exam or ultrasound < 20 wks, no labor, no fetal growth abnormalities, reassuring FHR tracings, and unfavorable cervix (Bishop score </= 6) | 1. Medical complications (insulin-dependent DM, pregnancy-induced HTN); 2. Grand multiparity; 3. Hypertonic uterine patterns; 4. Nonvertex presentation; 5. Multifetal gestation; 6. Ruptured membranes; 7. Known hypersensitivity to prostaglandins; 8. Placenta previa; 9. Unexplained vaginal bleeding; 10. Active genital herpes infection; 11. Suspected cephalopelvic disproportion. | Intervention: Prostaglandin E2 gel (Prepidil(r)) 0.5mg into cervical canal; patients supine × 15 min after, FHM × 2 hrs, repeated at weekly visits. | NR
| | To compare effectiveness of PGE2 vaginal to expectant management
FAIR
| | | | | | Control: Expectant management (EM).
| | | IA: 143
| | | SL: 151
| | | | | | Other Procedures, Interventions:
| | | Age: Mean age 27 (both groups) | | | None, patients to return for exams in qwks 40, 41 if no labor.
| | | Parity: NS
| | | Race: White: 15% (PGE), 18% (EM)
| | | Black: 34% (PGE), 32% (EM)
| | | Hispanic: 47% (PGE), 48% (EM)
| | | Asian: 2% (PGE), 2% (EM)
| | | Other: 1% (PGE), 0% (EM)
| | | Insurance: NS
Population-Based Database
McMahon 1996 ^5^ | Canada Nova Scotia | 1986-1992 | Database Description: | 1. Non-vertex presentation (119); 2. Multiple gestation (118); 3. Vertical or T-incision (37); 4. Previa (36); 5. HSV (7); 6. Prior uterine surgery (2) | NA | NR
| | | Nova Scotia Perinatal Database covering more than 80% of pregnant women in the province
| | To determine the morbidity and mortality of TOL vs. elective repeat CS
GOOD
| | | Singleton pregnancies with one prior low transverse CD
| | | SL/IA- 3249
| | | ERCD- 2889
| | | Age:<19 – >35
| | | Parity:SL/IA- 1 = 2468 (76%)
| | | 2= 547 (16.8%)
| | | > = 234 (7.2%)
Smith 2002 ^6^ | Scotland | 1992-1997 | Database Description: All patients discharged from maternity hospitals in Scotland | 1. Multiple gestation; 2. Noncephalic outside 37–42 weeks GA; 3. Perinatal deaths or stillbirths due to congenital anomalies | NA | NR
| | To determine the risk of intrapartum still birth or neonatal death from TOL versus planned repeat CD in women with prior CD
FAIR
| | | Singleton pregnancies between 37–42 weeks, cephalic, without lethal congenital anomalies
| | | SL/IA- 15515
| | | Repeat CD- 9014
| | | Age: SL/IA- median 30 (interquartile range 26–33)
| | | ERCD- median 31 (interquartile range 27–34)
| | | Parity: NR
| | | Race: NR
Prospective Cohort
Blanchette 2001^52^ | USA | 1996-99 | All patient with prior CD offered TOL, unless medically contraindicated | Not defined | Intervention: Misoprostol and/or oxytocin. | NR
| | To report the results of a 4 year attempt to aggressively promote a TOL.
FAIR | | | IA- 16 | | Control: SL
| | | SL- 9
| | | | | Other procedures, interventions:
| | | Age: NR | | None stated
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR
Blanco 1992 ^34^ | USA | 1987-88 | Prior lower segment CD attempting TOL, with a medical indication for delivery, an unfavorable cervix and a singleton, vertex fetus with a reactive nonstress test | 1. Asthma; 2. OB indication for an immediate delivery; 3. Active labor; 4. Favorable cervix | Intervention: 1mg PGE2 gel (pharmacy compounded) intracervically with repeat after 4 hrs if active labor not established | NR
| | To determine the safety and efficacy of PGE2 gel for induction of labor or ripening the cervix in women with a prior low-transverse CD for a TOL.
FAIR
| | | IA- 25 (I) of these 5 (I+a) | | Control: SL
| | | SL- 56 of these 9 (a) | | Other procedures, interventions:
| | | | | FHR and uterine contractions monitored.
| | | Age: mean 24.7 (PGE2), 22.4 (oxy)
| | | Parity: mean 1.4 (PGE2), 1.3 (oxy)
| | | Race: NR
| | | Insurance: NR
Cowan 1994 ^25^ | USA | 1990-91 | Any woman with prior CD choosing TOL | 1. Known vertical scar; 2. Breech presentation; 3. Multiple gestation | Intervention: NA | NR
| | To examine factors that may affect the success rate for TOL, as well as those for uterine rupture | I- 67 | | Control: NA
FAIR | | | A-167
| | | SL-359 | | Other procedures, interventions:
| | | | | Continuous EFM, Oxytocin used for induction or augmentation of labor
| | | Age: NR
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR
Duff 1988 ^26^ | USA Madigan Army Medical Center | 1984-1987 | All women with 1 prior low transverse cesarean | 1. Indication for repeat cesarean; 2. EFW >4500gm; 3. Unknown scar. | Intervention: NA | NR
| | To evaluate the outcome of TOL in women with a history of a single low transverse CD. | | | Control: NA
| | | SL/IA- 227
GOOD | | | (281 eligible; 54 excluded for vertical incision (10), unknown incision (5), footling breech (3), medical complications of pregnancy and unfavorable cervix (18), EFW>4500g (18)) | | Other procedures, interventions:
| | | | | Oxytocin used for induction or augmentation if indicated. Uterine exploration after VD for defect.
| | | ERCD- NR
| | | Age: NR
| | | Parity: NR
| | | Race: NR
| | | Insurance: Armed services medical coverage
Flamm 1997 ^33^ | USA Southern California, Kaiser | 1990-92 | All pregnant women with prior CD | 1. Known classical or low vertical incision; 2. Breech presentation; 3. Twin gestation. | Intervention: PGE2 gel (pharmacy compounded) 2–4 mg intravaginally q 4hrs (max dose not stated). | NR
| | To evaluate the use of intravaginal PGE2 in patients with prior CD. | IA- 453
FAIR | | | SL-4569
| | | Age: NR | | Control: SL
| | | Parity: NR
| | | Race: NR | | Other procedures, interventions:
| | | Insurance: NR | | Electronic FHM in all patients.
| | | | | Oxytocin induction or augmentation if indicated.
Flamm 1994 ^20^ | USA Southern California, Kaiser | 1990 | All women with prior CD delivery (unknown scar and more than 1 prior CD allowed) | 1. Known prior classical or low vertical uterine incision; 2. Spontaneous abortion (491); 3. Therapeutic abortion (79); 4. Transfer out of Kaiser (56); 5. Incomplete medical records (26) | Intervention: NA | NR
| | To evaluate the outcomes of TOL and ERCD. | | | Control: NA
FAIR
| | | SL/IA- 5022 | | Other procedures, interventions:
| | | ERCD- 2207 | | Oxytocin used for induction/augmentation as needed. Postpartum exam of uterus at discretion of provider.
| | | Age: SL/IA: 294 + 5.1
| | | CD: 30.5 + 5.2
| | | Parity: NR
| | | Race (overall):
| | | White = 208,577 (38.9%)
| | | Hispanic =
| | | 226,526 (42.2%)
| | | Black = 36,522 (6.8%)
| | | Other+Unknown = 65,160 (12.1%)
| | | Insurance:
| | | Government 261,297 (48.7%)
| | | HMO 160,130 (28.9%)
| | | PPO 64,669 (12.1%)
| | | Private 19,071 (3.6%)
| | | Self-pay 19,069 (3.6%)
| | | BCBS 11,328 (2.1%)
| | | Misc 1221 (0.2%)
Flamm 1990 ^22^ | Southern California, Kaiser | 1986-1988 | Prior CD wanting to attempt TOL. | 1. Know breech presentation; 2. Classical or low vertical scar; 3. Twin gestation | Intervention: NA
| | To evaluate the probability of rare events such as uterine rupture in women with prior CD attempting TOL. | IA- 1201 | | Control: NA
FAIR | | | Repeat CD- 2756
| | | | | Other procedures, interventions:
| | | Age: NR | | FHR monitored continuously in all patients, Oxytocin as per standard of care.
| | | Parity: 156 >1 prior CD
| | | Race: not clear, reported by hospital system
| | | Insurance: NR
Flamm 1987 ^28^ | USA Southern California, Kaiser | 1984-85 | Prior CD | 1. Known breech presentation; 2. Twin gestation | Intervention: Oxytocin as per standard, up to max dose of 20mU/min | NR
USA | | To evaluate the outcome of oxytocin administration inpatients with prior CD attempting TOL. | IA- 485
| | | SL- 1291
GOOD | | | | | Control: Those who did not receive oxytocin
| | | Age: mean age 27 (oxytocin), 28 (control)
| | | Parity: NR
| | | Race: NR | | Other procedures, interventions:
| | | Insurance:NR | | None stated
Martin 1983 ^24^ | USA Universities in Mississippi and Alabama | 1981-1982 | One or more prior CD (includes low vertical (76)) | 1. Classical, suspected macrosomia (EFW >4000gm); 2. Fetal malpresentation; 3. Multiple gestation | Intervention: NA | NR
| | To evaluate the safety of VBAC. | | | Control: NA
FAIR | | | SL/IA- 717
| | | (789 eligible; 72 ineligible for study) 162 attempted TOL | | Other procedures, interventions:
| | | | | All uteri explored postpartum, if dehiscence noted not repaired unless >2cm diameter. Oxytocin used for augmentation.
| | | ERCD- 555
| | | 8 desired cesarean and delivered vaginally
| | | Age:
| | | SL/IA:Successful VBAC = 22.2 + 0.9
| | | Failed VBAC = 21.8 + 0.9
| | | ERCD:mean = 23.3 + 0.3
| | | Parity:
| | | “Distributed approximately equally”
| | | Race:
| | | “Distributed approximately equally”
| | | Insurance: NR
Meehan 1989 ^50^ | Ireland | 1982-87 | One prior CD without a recurring indication for CD | Not defined | Intervention: NA | NR
| | To evaluate the safety of TOL. | | | Control: NA
FAIR | | | IA- 127 (I)
| | | Oxy: 17 | | Other procedures, interventions:
| | | ARM: 16 | | Continuous cardiotocography, oxytocin, AROM, prostaglandins and combinations used for induction and augmentation, uterine exploration immediately post-delivery.
| | | PG: 8
| | | ARM+oxy: 42
| | | ARM+PG: 21
| | | A+O+P:23 217 (a)
| | | oxy: 30
| | | ARM: 137
| | | ARM+oxy: 50
| | | SL- 162
| | | ERCD- 430
| | | Age: NR
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR
Meier 1982 ^57^ | USA Kaiser SanDiego | 1980 | All TOL, 1st 6 of each month with elective repeat and one prior CS | 1. Recurrent indication for cesarean; 2. No obvious CPD | Intervention: NA
| | to assess the safety of having most patients with prior cesarean attempt TOL | | | Control: NA
FAIR | | | SL/IA- 207
| | | ERCD- 62 | | Other procedures, interventions:
| | | | | All monitored with IUPC and FSE, oxytocin used for augmentation and induction when indicated, more than 1 cesarean not excluded.
| | | Age: NR
| | | Parity: NR
| | | Race: NR
| | | Insurance: Kaiser Permanente Health Plan
Phelan 1987 ^23^ | USA | 1982-1984 | TOL | 1. Classical; 2. Multiple gestation; 3. Malpresentation | Intervention: NA | NR
| USC | | 1982-3 1 prior CD | | Control: NA
| | To evaluate the risks of TOL. | 1983-4 1–2 prior CD (low vertical, unknown allowed) | | Other procedures, interventions:
FAIR | | | | | oxytocin administered according to ACOG guidelines, epidurals allowed, uterine exploration routinely performed
| | | SL/IA- 1796 (SL,I+A)
| | | ERCD- 314
| | | Age: NR
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR
Stovall 1987 ^27^ | USA | 1985-86 | All patient with prior CD offered TOL (low-transverse or low-vertical sections), unless medically contraindicated. | 1. Prior classical incision; 2. Prior low-vertical in preterm pregnancy (e.g. preterm breech); 3. Low-transverse and low-vertical scar (T incision); 4. Failed TOL after primary CD | Intervention: NA | NR
| | To determine whether the indications for TOL, use of epidural anesthesia, and use of oxytocin can be safely liberalized. | | | Control: NA
FAIR
| | | IA- 133 | | Other procedures, interventions:
| | | SL-139 | | Internal monitoring,Oxytocin for induction or augmentation mean dose 7mU/min (range 0.4 – 32) mean duration 276 min (range 45–960).
| | | Age: NR
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR
Retrospective Cohorts
Lao 1987 ^31^ | Hong Kong | 1992-1993 | One previous lower segment CS | 1. Recurring cause of previous CS; 2. Non-cephalic presentation; 3. X-ray pelvimetry showing obstetric conjugate of <10cm and transverse diameter of <11.5cm | Bishop score 4–6: amniotomy + oxytocin | NR
| | Report experiences with induction of labor in women with previous CS | SL- 529 | | Bishop score <4: 3mg PGE2 tablets + amniotomy + oxytocin
FAIR | | | | IA-137 (102 (a/o), 35 (a)
| | | | | Also, manual monitoring of contractions and fetal HR
| | | Age: NR
| | | Parity: NR | | Reason for Induction: 43% post-maturity
| | | Race: NR
| | | Insurance: NR | | 6% PROM
| | | | | 13% hypertension
| | | | | 23% leaking at term7% antepartum hemorrhage

IA=induced or augmented; TOL=trial of labor; CD=cesarean delivery; NR=not reported; SL=spontaneous labor; ERCD=elective repeat cesarean delivery; HR=heart rate; CPD= cephalopelvic disproportion; PGE=prostaglandin E2; IUGR=intrauterine growth restriction; GA=gestational age; EM=electronic monitoring

Evidence Table 1b. Study descriptions for vaginal delivery, maternal and infant outcomes - poor quality studies

Author Year Quality | Country Setting | Study design Years of study Research objective | Population | Exclusion criteria | Intervention Control Other Procedures | Reasons for Induction
Randomized Controlled Trials
Xenakis 1995^175^ | USA | 1993 | IA: 22 | - Malpresentation; - Placenta previa; - Previous classic CD; - Multiple gestation | Intervention: Low-dose: oxytocin 1mU/min increased by 1mU/min q30min up to max 4mU/min × 2 hrs. If no adequate contractions after 2hrs, dose increased by 1mU/min every 30 min until adequate contractions. | Augmentation started if: arrest of dilation or descent defined as no cervical change for 2hrs after latent phase with cervix >/=4cm, or no change in station of presenting part at full dilation for >1hr.
| | | IC: 26
| | To compare efficacy and safety of low-dose versus high-dose oxytocin augmentation
POOR | | | All nulliparous or multiparous women admitted >/= 37 wks gestation in active labor (including those with prior low transverse CD attempting TOL).
| | | Age: mean age 24 yrs
| | | Parity: NR | | Control: High dose: oxytocin 4mU/min and increased by 4mU/min every 15min until adequate contractions.
| | | Race:
| | | White: 10% (LD), 11% (HD)
| | | Black: 4.5% (LD), 2.6% (HD)
| | | Hispanic: 83% (LD), 86% (HD)
| | | Other: 2% (LD), 1% (HD) | | Other Procedures, Interventions: Protocols for labor management, criteria for diagnosis of labor abnormalities, and indications for operative delivery were the same for both groups.
| | | Insurance: NR
Wing 1998^176^ | USA | NR | IA: 17 | NR | Intervention: Misprostol 25mcg intravaginally q6 hrs to max 4 doses. | NR
| | | IC: 21
| | To compare the safety and efficacy of vaginally administered misoprostol with IV oxytocin for cervical ripening and labor induction in women with Prior CD
POOR | | | Requiring induction of labor for medical or OB indications with a history of one immediate prior CD without subsequent VD
| | | | | Control: Oxytocin by standard protocol (doses not stated).
| | | Age: NR | | Other Procedures, Interventions: use of continuous FHR, uterine activity monitoring, and amniotomy in all patients.
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR
Lyndon-Rochelle 2001^72^ | USA Washington state | 1987-1996 | Primiparous women who gave birth to singleton infants by CD and delivered a second child. | Women who delivered before 1989 b/c “repeat cesarean no labor” was not specified in birth cert until 1989 | Other Procedures, Interventions: SL, induction of labor with or without prostaglandins on hospital discharge | Reasons not specified, health conditions such as diabetes, chronic hypertension, breech presentation, herpes, previa, preeclampsia reported
| | To examine the risk of uterine rupture associated with VBAC (spont, induced) and repeat C/S | Age: 14–48
| | | SL: n=10,789
POOR | | | IA: n=1,960 induced with PGs; 366 without PGs
| | | ERCD: n=6,980
| | | Parity: Overall- P2
| | | Race: SL- White = 8949 (82.9%)
| | | Black = 318 (2.9%)
| | | Hispanic = 621 (5.8%)
| | | Other = 901 (8.4%)
| | Database Description: Retrospective. Washington state birth certificates,hospital discharge data (Comprehensive Hospital Discharge Reporting System). | ERCD:
| | | White = 6056 (86.8%)
| | | Black = 164 (2.3%)
| | | Hispanic = 281 (4.0%)
| | | Other = 479 (6.9%)
| | | Insurance:
| | | SL:
| | | Commercial = 5659 (52.5%)
| | | Medicaid/uninsured = 2730 (25.3%)
| | | Managed care = 1992 (18.5%)
| | | Other = 408 (3.8%)
| | | IA:
| | | Without PG:
| | | Commercial = 1081 (55.2%)
| | | Medicaid/uninsured = 473 (24.7%)
| | | Managed care = 384 (19.6%)
| | | Other = 22 (1.1%)
| | | IA: White =1999
| | | Black = 318
| | | With PG:
| | | Commercial=206 (56.3%)
| | | Medicaid/uninsured = 90 (24.6%)
| | | Managed care = 64 (17.5%)
| | | Other = 6 (1.6%)
| | | ERCD:
| | | Commercial= 3936 (56.4%)
| | | Medicaid/uninsured = 1741 (24.9%)
| | | Managed care = 1119 (16.0%)
| | | Other = 184 (2.6%)
Stone 2000 ^177^ | Australia | 1995 | Women who gave birth in 1995 and whose penultimate delivery within a 5-year period was a cesarean | Multiple getation in current or previous delivery | NR
| | To describe the population-based delivery outcomes for women giving birth in 1995 whose penultimate delivery was a cesarean
POOR
| | | SL/IA- 1482
| | | Repeat CD-4663
| | | Age: NR
| | | Parity: one - 3079
| | Database Description: Perinatal Morbidity Statistics maintained by Victoria Perinatal Data Collection Unit, mandatory reporting of all births in Victoria represents 99.6% of all births | 2 or more - 1584
| | | Race: aboriginal - 32
| | | non-aboriginal 3579
| | | Insurance: NR
Gregory 1999 ^164^ | USA California | 1995 | All hospital deliveries in the state of CA (DRG 370–375) classified as prior cesarean if ICD9=654.2 | NR | NR | NR
| | To describe attempted and successful VBAC rates and rupture rates for women with and without prior cesareans and compare outcomes in hospitals with difference attempted VBAC rates
POOR
| | | No Prior CD- 469,929
| | | SL/IA- 39,096 TOL
| | | 15,072 failed VBAC
| | | 24,024 VBAC
| | | ERCD- 27760
| | | Age:
| | | >35 = 71,815 (13.4%)
| | | <35 = 464,970
| | | Parity: NR
| | Database Description: California Office of Statewide Health Planning and Development | Race: NR
| | | Insurance: NR
Rageth 1999 ^60^ | Switzerland | 1983-1996 | Prior cesarean | Twin pregnancies | Other Procedures, Interventions: Methods of Augmentation and Induction NR | NR
| | To examine risk of VBAC | NPCS- 226407
POOR | | | SL- 15154
| | | IA- 2459
| | Database Description: containing 40% of Switzerland's deliveries | ERCD- 11433
| | | Age: SL/IA- <30 = 8640 (49.05%)
| | | Parity: NR
| | | Race: NR
| | | Insurance: SL/IA- private = 6293 (35.73%)
| | | ERCD- private = 4862 (42.53%)
Holt 1997 ^59^ | USA Washington state | 1987-1993 | Primiparous women with prior cesarean | - Second births prior to 1989 (when TOL added to birth certificate); - Unknown delivery method with second delivery | NA | NR
| | To examine relationships between prior obstetric complications and VBAC success | SL- 6491
POOR | | | ERCD- 3619
| | | Age: <20 – >35
| | | Parity: Primiparous
| | | Race:
| | | White = 8784 (88.5%)
| | | Black = 253 (2.5%)
| | | Asian = 285 (2.9%)
| | | Hispanic = 452 (4.6%)
| | | Other = 153 (1.5%)
| | | Unknown = 183
| | | Insurance:
| | | Private = 5281 (56.6%)
| | | HMO = 1338 (14.3%)
| | | Medicaid = 2013 (21.6%)
| | | Self = 501 (5.4%)
| | | Other = 202 (2.2%)
| | | Unknown = 775
Stalnaker 1997^178^ | USA Florida | 1989 - 95 | IA- 7 | Delivering physician not participating in the fund, infant not meeting inclusion criteria and a determination by the board that the infant was not injured or that the injury was not birth-related. | NR | NR
| | | SL- 2
| | To summarize demographic information and characteristics of antepartum care, intrapartum events and neonatal outcomes from the successful claims to the Florida Neurological Injury Compensation Fund
POOR | | | Age: NR (27 for whole group)
| | | Parity: NR (0.8 for whole group)
| | | Race: NR
| | | Insurance: NR
| | | Successful claim: Injury to the brain or spinal cord of a live infant weighing at least 2500gm at birth caused by oxygen deprivation or mechanical injury occurring in the course of labor deliver, or resuscitation in the immediate post-delivery period in a hospital which renders the infant permanently and substantially mentally and physically impaired.
Prospective Cohort
Arulkumaran 1989^179^ | Singapore | Not clear | Prior lower segment CD attempting TOL, with fetus in cephalic presentation and abnormal progress of labor | Required CD for reasons other than failure to progress (e.g. fetal distress or prolapse). | Intervention: Oxytocin 2mU/min increased q30 min (by 2 units up to 12, then by 4 units up to max 24mU/min) | NR
| | To examine the characteristics, and success of TOL in patients requiring augmentation with oxytocin.
POOR
| | | IA- 63
| | | | | Control: None
| | | Age: 31 (FTOL), and 29 (VBAC)
| | | Parity: NR | | Other procedures, interventions: None stated
| | | Race: NR
| | | Insurance: NR
Bais 2001^180^ | Netherlands | 1990-1994 | Prior CS | NR | NR | NR
| | | - 20 breeches; - 36 >1 prior CS; - 30=forceps; - 4=vacuum
| | To determine clinical outcomes of VBAC in population with low overall cesarean rate
POOR
| | | SL/IA- 184
| | | 142 VBAC
| | | 42 failed VBAC
| | | ERCD- 68/252 (27%)
| | | Age: NR
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR
Gherman 2001^181^ | USA | NR | Gravidas with at least 36 weeks gestation, and one documented low transverse delivery. Bishop score <6 with medical or OB indication for labor induction | NR | Intervention: 50mcg dose. If cervical ripening or active labor did not ensue, repeat 50 mcg dose q 4 hr × max 6 doses. Oxytocin was subsequently administered. | NR
| | To evaluate the efficacy and safety of oral misoprostol for preinduction cervical ripening among patients with prior CD.
POOR
| | | IA- 10
| | | Age: NR | | Control: None
| | | Parity: NR
| | | Race: NR | | Other procedures, interventions: None stated
| | | Insurance:
Goldberger 1989^182^ | Israel | 1987-1988 | One prior uncomplicated transverse lower uterine scar, with fully documented uneventful current term pregnancy | - Recurring cause of prior CD; - Non-cephalic presentation; - Estimated fetal weight > 4000g; - Reactive NST; - Pelvis deemed inadequate for vaginal delivery | Intervention: 1.5mg PGE2 pessary to posterior fornix, repeated after 6 hrs if no contractions. | NR
| | To compare effectiveness of PGE2 vaginal to expectant management.
POOR
| | | IA: 19
| | | SL: 155 | | Control: Retrospective controls: 155 women with prior CD allowed spontaneous TOL (1985-6) and 43 women with no prior CD induced in similar way.
| | | ERCD:43
| | | Age: NR
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR | | Other procedures, interventions: Continuous recording of uterine activity and fetal HR, maternal BP, HR, UOP/color every 30min, epidural anesth. Encouraged, oxytocin augmentation if indicated (with internal tocometry).
Goldman 1998^183^ | Israel | 1991-1996 | Prior CD | - Prior classic or low vertical incision; - Unknown scar; - Prior hysterectomy or conservative myomectomy; - Multiple gestation; - Breech presentation; - >1 prior CD. | Intervention: Oxytocin dosing not stated, PGE2 vaginal gel (Prostin E2(r)) | NR
| | To report experience with oxytocin and PGE2 in TOL. | IA- 208 oxytocin, 146 PGE2
POOR | | | SL- 166
| | | | | Control: Spontaneous labor
| | | Age: “Similar”
| | | Parity: “Similar” | | Other procedures, interventions: If vaginal delivery did not occur within 12 hours, CD performed.
| | | Race: NR
| | | Insurance: NR
Norman 1992^184^ | Sweden | NR | Unripe cervix (cervical score </= 5) with one prior CD | Not defined | Intervention: 0.5mg PGE2 gel (Cerviprost (r)) intracervically, repeated at 24 hrs if cervix not changed. If cervix ripe, but no active labor at 5 and 24 hrs after gel, oxytocin started (dose not stated). | NR
| | To investigate if preinductive cervical ripening with PGE2 in women with 1 prior CD was safe.
POOR | | | IA- 30
| | | Age: Mean 30 (of those with prior VD) and 33 (those with no prior VD)
| | | Parity: NR
| | | Race: NR | | Control: None
| | | Insurance: NR
| | | | | Other procedures, interventions: External cardiotocography 30 min prior and 1 hr after gel application. After ROM, internal scalp electrodes placed on fetus.
Silver 1987^185^ | USA | 1983-85 | Singleton pregnancy, one prior low-transverse CD requiring oxytocin for induction or augmentation. Induction criteria: an OB indication for delivery, absence of regular contractions, pretreatment dilation <3cm. | Requiring oxytocin in 2nd stage only | Intervention: NR | NR
| | To evaluate if oxytocin is effective for induction or augmentation in TOL. | | | Control: NR
POOR
| | | | | Other procedures, interventions: NR
| | | Augmentation criteria: dilation >/= 4cm, regular uterine activity, no change in cervix × 1 hr
| | | I- 34
| | | A-64
| | | Age: NR
| | | Parity: Stated as not significantly different between success/failure groups
| | | Race: NR
| | | Insurance: NR
Sims 2001^186^ | USA | 1997-99 | Consecutive deliveries by women with prior CD | - Deliveries < 24 weeks; - Intrauterine fetal death. | Intervention: NR | NR
| | | | | Control: NR
| | To determine the impact of labor induction on success and safety of TOL. | IA- 57
POOR | | | SL- 179 | | Other procedures, interventions: methods of induction; 1) oxytocin, 2) misoprostol 25–50 micrograms every 4 hours for 3 doses augmented with oxytocin, 3) dinoprostone 12 hours then oxytocin
| | | ERCD- 269
| | | Age, Parity: Reported as similar
| | | Race: Reported as a significantly higher proportion of African American women in SL group
| | | Insurance: NR
Videla 1995^187^ | USA | 1988-91 | One prior CD and requiring induction for OB or medical reason with an unfavorable cervix | Classical incision, a nonreactive nonstress test, or regular uterine contractions | Intervention: PGE2 gel (pharmacy compounded); 2mg to external cervical os and posterior vaginal vault, repeated q4–6 hrs; max 4 doses | NR
| | To determine if cervical ripening with PGE2 gel is safe and effective in TOL compared to nulliparous women
POOR | | | I- 94
| | | IC- 866
| | | A- 77/94 (82%)800/899 ( 89%)
| | | | | Control: nulliparous women
| | | Age: reported as % < 20 yrs = 4(PGE2)
| | | Parity: NR | | Other procedures, interventions: FHR and uterine activity monitored for all patients, amniotomy and internal monitoring used at OB discretion, oxytocin augmentation used if needed
| | | Race: 45% white
| | | 20% Black,
| | | 30% Hispanic (PGE2)
| | | Insurance: NR
Prospective Cohort
Sakala 1990^188^ | England | 1984-86 | >/= 1 prior low-transverse CD, and patient request for TOL | - Breech presentation; - Multiple gestation; - OB contraindications to TOL. | Intervention: NR | NR
| | | | | Control: Spontaneous labor or elective CD.
| | To answer questions about oxytocin in TOL (adverse effects, success, and factors associated with failure).
POOR | | | I- 48 | | Other procedures, interventions: NR
| | | A- 25
| | | SL- 164
| | | Age: Mean 28
| | | Parity: Mean 1.7 (oxy), 1.3 (SL)
| | | Race: NR
| | | Insurance: NR
Retrospective Cohorts
Asaad 1994^189^ | | NR | PROM >/= 37 wks, one prior CD with lower segment incision and non-recurrent cause, with doubt of healing of uterine scar | - Multiple pregnancies; - Malpresentations | Intervention: oxytocin 2mU/min increased at ‘intervals’ up to 32mU/min until regular contractions. | NR
| | Not stated
POOR
| | | I- 5 | | Control: SL
| | | IC- 12 | | Other procedures, interventions: maternal pulse, temp and fetal HR checked regularly
| | | Age: NR
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR
Blanchette 1999 ^67^ | USA | Misoprostol: 1997-98 | Singleton pregnancy at term, cephalic presentation, reassuring FHR, Bishop score <5 | - Known hypersensitivity to prostaglandins; - History of CD with vertical incision; - Major uterine surgery; - Placenta previa; - Grand multiparity (>/= 6 prior deliveries); - History of asthma, glaucoma, or heart disease. | Intervention: Misoprostol 25mcg inserted into posterior vaginal fornix, with 25–50mcg q 4hrs to max 6 doses. If tachysystole (>/= 6 contractions/10 min) or contraction pattern of >/= 3/ 10 min, next dose withheld. Oxytocin was started 4 hrs after last dose of misoprostol, started at 1–2 mU/min and increased by </= 6mU/min q15–30 min until adequate pattern of contractions. | NR
| | PGE2: 1996-97
POOR | | To compare PGE1 (misoprostol) to PGE2 (dinoprostone) for cervical ripening and induction in a community hospital. | IA-16
| | | IC-9
| | | Age: Mean 29.8 (misoprostol)
| | | 29.5 (PGE2)
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR | | Control: 1) PGE2 gel (Prepidil(r)) 0.5mg intracervically q 6hrs to max 3 doses. Oxytocin if needed 6 hrs after last dose of PGE2.
| | | | | OR
| | | | | 2) PGE2 slow-release pessary (Cervidil(r)) 10mg placed in vaginal posterior fornix for up to 12 hrs, removed when adequate uterine contraction pattern appeared.
| | | | | Other procedures, interventions: Continuous FHR
Choy-Hee 2001^195^ | USA | 1996-98 | Singleton pregnancy, Bishop score <6, cephalic presentation, and reassuring FHR | None stated, but apparently vertical and classical incisions excluded (reported that 73% had low-transverse incision, 27% had unknown incision). | Intervention: 50mcg misoprostol placed in posterior vaginal fornix q 4hrs up to 24 hrs (6 doses) until cervix dilated 2 cm or regular contraction pattern seen or rupture of membranes and regular contractions. Oxytocin augmentation used when labor failed to progress or 4 hrs after the max 6 doses of misoprostol if active labor not achieved.
| | To evaluate the safety and efficacy of cervical ripening with misoprostol in women with prior CD compared to those without prior CD.
POOR | | | I- 48
| | | IC- 377
| | | Age: NR
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR
| | | | | Control: women without prior CD
| | | | | Other procedures, interventions: none specified
Chua 1989^196^ | Singapore | 1985-1988 | Prior low segment CD | NR
| | | SL/IA- 207
POOR | | | oxytocin used 97 (used for induction in 22, 75 augmented)
| | | ERCD- 98 indications incl, CPD,2 prior, malpresentation, IUGR, previa, porr fetal testing
| | | Age: NR
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR
Chuck 1995^197^ | USA | 1993 - 94 | 35 to 42 weeks gestation admitted for labor induction | nonvettex presentation, uterine scar other than prior low-transverse CD, ominous FHR tracing, multiple gestation, and complete vervical effacement | Intervention: misorprostol 50mcg intravaginally q 4hrs × max 5 doses | NR
| | To compare misoprostol tablets to dinoprostone gel in induction of labor
POOR | | | I- 5 | | Control: PGE2 gel (Prepidil (r)) 0.5mg intracervically q 4hrs × max 5 doses
| | | IC- 10
| | | Age: mean 29.3 (miso), 28.7 (PGE2) | | Other procedures, interventions: continuous FHR and tocodynomometery in all patients, cervical exam q 4hrs (more often if indicated)
| | | Parity: mean 0.8
| | | Race: NR
| | | Insurance: NR
Coltart 1990^198^ | UK | 1980-1987 | One prior CD, having second baby >26 weeks | - Failed induction; - Missing records | NR | NR
| | | SL/IA- 195
POOR | | | 117 not augmented
| | | 20 augmented
| | | 58 induced
| | | 2 AROM
| | | 6 AROM + oxytocin
| | | 32 = PG pessary
| | | 18 PG pessary + oxytocin
| | | ERCD- 158
| | | Age: NR
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR
Del Valle 1994^199^ | USA | 1988-92 | >/=1 prior low-transverse CD | None stated | Intervention: PGE2 gel (pharmacy compounded) intracervically 0.5mg q4–6 hrs or an osmotic dilator (Dilapan (r)) or both. Induction with oxytocin following ACOG guidelines (0.5–1 mU/min increased by 1–2 mU/min q30–60 min) | NR
| | To evaluate the safety and efficacy of cervical ripening in women with prior low transverse CD undergoing induction of labor with an unfavorable cervix | I- 89 (PGE2 only: 36, Dilapan only: 41, Both: 12)
POOR | | | IC- 61 (PGE2 only: 28, Dilapan only: 25, Both: 8)
| | | Age: Mean 27
| | | Parity: Mean 1.6
| | | Race: NR
| | | Insurance: NR | | Control: Women receiving dilation and induction agents, no prior CD
| | | | | Other procedures, interventions: NR
Lydon-Rochelle 2001 ^4^ | USA | 1980-83 | One prior lower segment CS | Recurring cause of prior CS, non-cephalic presentation, X-ray pelvimetry showing obstetric conjugate of <10cm and transverse diameter of <11.5cm | Intervention: Bishop score > 6: amniotomy alone | NR
| | | I- 137 (102 (a/o), 35 (a)
| | Report experiences with induction of labor in women with prior CS | SL- 529 | | Bishop score 4–6: amniotomy + oxytocin
| | | Age: NR
POOR | | | Parity: NR | | Bishop score <4: 3mg PGE2 tablets + amniotomy + oxytocin
| | | Race: NR
| | | Insurance: NR | | Control: NR
| | | | | Other procedures, interventions: NR
MacKenzie 1984^200^ | England | 1992 | All women with prior CD attempting TOL | Vertical scar, placenta previa, breech or inappropriate size, head attitude or pelvimetry; active genital herpes infection; severe preeclampsia with rapid deterioration; signs of fetal distress with inability for fetal scalp pH, or fetal anomaly precluding safe vaginal delivery | Intervention: Aggressive use of PGE2 gel for cervical ripening, oxytocin and early amniotomy for induction or augmentation | NR
| | To identify predictors of unsuccessful TOL | I- 170
POOR | | | IC-
| | | SL- 5 | | Control: SL
| | | ERCD- | | Other procedures, interventions: none specified
| | | A- 170
| | | Age: mean 26.8 VBAC, 30.3 FTOL
| | | Parity: 2.0 VBAC, 1.5 FTOL
| | | Race: NR
| | | Insurance: NR
McNally 1999 ^107^ | Ireland | 199-1994 | One prior CD | NR | 38 induced with oxytocin | NR
| | To review management of women with 1 prior CD to see predictors for success | SL/IA- 244 (73.3%)
FAIR | | | 38 induced
| | | 50 oxytocin for augmentation
| | | ERCD- 89
| | | Age: SL/IA- 28.7 + 4.9 successful
| | | 31.2 + 3.7 failed
| | | ERCD- 30.6 + 4.1
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR
Norman 1993^201^ | Canada Toronto | 1980 | All TOL, 1st 6 of each month with elective repeat and one prior CS | Recurrent indication for cesarean, no obvious CPD, | All monitored with IUPC and FSE, oxytocin used for augmentation and induction when indicated, more than 1 cesarean not excluded | NR
| | To assess the safety of having most patients with prior cesarean attempt TOL
POOR | | | SL- 207
| | | ERCD- 62
| | | Age: NR
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR
Plaut 1999 ^202^ | USA | 1983-1992 | Subject Eligibility: all women with prior CD eligible for VBAC | Classical, prior UR, contraindication to labor, from 1983-1985 unknown excluded | Twins, breech allowed, manual exploration on all VD | NR
POOR | | | SL/IA: 10,880
| | | Age: NR
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR
Plaut 1999 ^15^ | USA | 1996-98 | Subject Eligibility: not clear, those attempting TOL | None stated | Intervention: misoprostol , doses not stated | NR
| | To report 4 cases of uterine rupture with misoprostol, to conduct a literature review, purpose of retrospective cohort study not clearly stated | I- misoprostol: 89 | | Control: unclear - combines those induced with oxytocin and SL
POOR | | | IC- 423
| | | | | Other procedures, interventions: none specified
| | | Age: NR
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR
Ravasia 2000^214^ | Canada | 1992-98 | All patients with prior CD | None stated | Intervention: 1) Cervical ripening with: PGE2 gel intravaginally ; 1–2mg q6–12 hrs to max 3 doses, OR | NR
| | To determine and compare uterine rupture rates and VD rates among TOLs induced and SL | I- 575: 172 PGE2 (95 PGE2 alone, 77 PGE2/oxy)
POOR | | | 129 Foley (11 Foley alone, 118 Foley/oxy)
| | | 274 cervical ripening (26 amniotomy, 214 oxy, 34 amnio/oxy) | | 2) intracervical extra-amniotic placement of an 18-guage Foley catheter, inflated to 30–40ml with or without gentle traction and removed when the bulb was expelled through the cervical os; both followed by oxytocin if necessary
| | | SL- 1544
| | | Age: NR
| | | Parity: median 1 for PGE2 gel, Foley, and SL. 2 for Induction without cervical ripening
| | | Race: NR
| | | Insurance: NR | | 3) Induction without cervical ripening with oxytocin or amniotomy or a combination of both.
| | | | | Control: Spontaneous labor
| | | | | Other procedures, interventions:
| | | | | Oxytocin doses: 1–2 mU/min and increased by 1–2 mU q 30min.
| | | | | Oxytocin dose reduced or stopped when non-reassuring FHR occurred and restarted if appropriate. The use of oxytocin as augmentation was not recorded for this study.
Segal 1995 ^51^ | Israel | 1988-93 | Prior CD, known transverse or unknown scar, breech presentation | Other malpresentations, classical scar | Intervention: oxytocin for induction or augmentation
| | To assess rates of VBAC and complications in a rural community setting | | | Control: SL
POOR | | | I- 25 (I and/or a) | | Other procedures, interventions: none specified
| | | SL- 26
| | | ERCD- 16
| | | Age: NR
| | | Parity: 57% = 1; 43% = >1
| | | Race: 28% white
| | | 72% black
| | | Insurance: NR
Zelop 2000^193^ | USA Brigham | 1988-93 | Rupture of membranes without contractions after 2 to 6 hrs, or slow progress of labor | Prior classical incision, OB or medical contraindication to labor, or declined TOL | Intervention: oxytocin for induction or augmentation | NR
| | To examine the effect of a disciplined approach to labor management in TOL | | | Control: SL, elective repeat CD
POOR | | | I- 142 (I), | | Other procedures, interventions: FHR for all patients, internal uterine pressure sensors and internal fetal scalp electrodes when active labor started
| | | SL- 446, of these 198 (a)
| | | ERCD- 125
| | | Age: NR
| | | Parity: NR
| | | Race: 71% white
| | | 15% Black2% Hispanic
| | | Insurance: NR
Zelop 1999^194^ (3 pubs) | USA | 1984-96 | Term pregnancy with one prior lower segment (vertical, transverse or unknown) CD, no other deliveries | None stated | Intervention: PGE2 gel (pharmacy compounded) 4mg intravaginally q 4hrs max 3 doses; or oxytocin induction or augmentation (1–2 mU/min increased by 1–2mU/min q15–20 min to max 20 mU/min | NR
| | To examine the effect of labor induction on the risk of uterine rupture
POOR | | | I- 560 (I or a) (458 oxy alone, 35 PGE2 alone, 67 both)
| | | SL-2214
| | | A- 1089 | | Control: Spontaneous labor
| | | | | Other procedures, interventions: none specified
| | | Age: NR
| | | Parity: NR
| | | Race: NR
| | | Insurance: NR
Case Control
Leung 1993 ^54^ | USA | 1994-1998 | Cases: cases = dehiscence with 1 prior LSCD who underwent TOL | NA | NA | NA
| | To identify risk factors for scar dehiscence
POOR | | | Controls: Controls = one prior LSCD who underwent TOL without dehiscence
| | | Cases: 13
| | | Controls: 13
| | | Age: NR
| | | Parity: NR
| | | Race: NR
Miles 2000^203^ | UK | 1983-90 | Prior CD attempting VBAC (including twin and breech) | - Prior classic incision; - Placenta previa; - Transverse lie; - Conditions requiring immediate delivery and refusal of TOL | NR | NR
| | To thoroughly investigate the risk factors of UR in patients undergoing TOL after CD
POOR | | | Cases: patients with prior CD and UR while undergoing subsequent TOL
| | | Controls: patients with prior CD and subsequent TOL and no UR during same time, randomly selected, grouped by year
| | | Cases: 70
| | | Controls: 70
| | | Age: NR
| | | Parity: NR
| | | Race: NR
Paterson 1991 ^165^ | | 1990-1997 Database | Database Description: hospital D/C data 36,727 singleton birth, >37 weeks, cephalic, history of at least one prior cesarean and no prior VD | NR | NR | NR
POOR
| | | Age: TOL 29.0 (s.d. 4.8)
| | | ERCD 30.5 (s.d.5.0)
| | | Parity: primiparas 14,722
| | | multiparas 16,5818
| | | Race: NR
| | | Insurance: NR

IA=induced or augmented; TOL=trial of labor; CD=cesarean delivery; NR=not reported; SL=spontaneous labor; ERCD=elective repeat cesarean delivery; HR=heart rate; CPD= cephalopelvic disproportion; PGE= prostaglandin E2; IUGR=intrauterine growth restriction; GA=gestational age; EM=electronic monitoring

Evidence Table 2. Vaginal delivery- good or fair quality studies

Author Year Quality | Population | Vaginal Delivery Rate
Large population-based studies
McMahon 1996 ^5^ | One LTCD, not clear what was done with unknown | Overall: 1962/3249 (60.4%)
FAIR
Prospective Cohort
Duff 1988 ^26^ | One prior LTCD, unknown not allowed | Overall: 167/227 (74% 95% CI 66–78%)
GOOD
Flamm 1988 ^21^ | LTCD and unknown and more than 1 prior | Overall- 1315/1776 (74%)
| | SL (non-Medicated)- 3151/4047 (78%)
GOOD | | Any Oxtocin- 1140/1686 (68%)
Blanco 1992 ^34^ | One prior LTCD, PGE2 (up to 3x) Gel induction of labor vs spontaneous onset of labor (oxy as needed in either group) | Induced- PG gel
| | 18/25
FAIR | | (74%)
Flamm 1997 ^33^ | Prior LTCD, unknown allowed, more than 1 allowed | Induced- PG gel
| | 233/453 (51%)
FAIR
Flamm 1994 ^20^ | All verticals excluded, unknown allowed, more than 1 allowed | Overall- 3746/5022 (75%)
FAIR
Flamm 1990 ^22^ | LTCD, unknown, more than 1 prior | Overall: 2977/3957 (75%) 1986-1988
| | SL - 2146/2756 (78%)
FAIR | | Any Oxtocin- 831/1201 (69%)
Flamm 1987 ^28^ | LTCD, unknown, more than 1 prior | Overall: 1314/1776 (74%)
| | SL (non-Medicated)-1005/1291 (78%)
FAIR | | Any Oxtocin- 309/485 (64%)
Stovall 1987 ^27^ | LTCD or LTVS allowed more than 1 allowed not clear what was done with unknown | Overall: 214/272 (79%)
| | SL (non-Medicated)- 116/139 (83%)
FAIR | | Any Oxtocin- 98/133 (74%)
Phelan 1987 ^23^ | Low vertical, unknown, LTCD allowed during 2nd year more than 1 allowed | Overall: 1465/1796 (82%)
FAIR
Paul 1985 ^30^ | Not more than 1, low vertical, unknown and LTCD allowed | Overall: 614/751 (82%)
| | SL (non-Medicated)- 395/443 (89%)
FAIR overlapping data with Phelan 87 | | Augmented (Oxytocin)- 177/257 (69%)
| | Induced- 23/ 32 (72%)
Martin 1983 ^24^ FAIR | One or more, includes low-vertical, no rupture occurred in the 76 with prior vertical | Overall: 101/162 (62%)
FAIR
Cowan 1994 ^25^ | More than 1 prior, LTCD and unknown included, known vertical excluded (2vertical entered) | Overall: 478/593 (81%)
| | SL- 315/359 (88%)
FAIR | | Augmented (Oxytocin)- 117/167 (70%)
| | Induced- 46/67 (69%)
Retrospective Cohorts
Raynor 1993 ^29^ | LTCD,unknown, more than 1 allowed, (2 verticals allowed) | Overall- 61%
| | SL - 17/16 (65%)
FAIR | | Any Oxtocin- 14/25 (56%)

LTCD=low transverse cesarean delivery; PGE2=prostaglandin E2; SL=spontaneous labor

Evidence Table 3a. Predictive tools- good or fair quality studies

Author Year Quality | Country Setting | Study design Years of study Research objective | Population | Exclusion criteria | Methods | Number Eligible/Attempting TOL | Score development | Predictors included | Performance
Scoring Tools
Flamm 1997 ^33^ | USA | Prospective cohort | All women with a previous cesarean delivery | Elective repeat cesarean, incomplete chart data. | - Each patient attempting a TOL given a computer-generated random number; then sorted in ascending order; first 2502 assigned to score development group and last 2501 to score testing group.; - Very few patients will achieve the highest score category (6%).; - Even the lowest score group had nearly 50% vaginal delivery rate.; - This scoring system is only valid for use at the time of the admission. | 5022/5003 | Chi Square and Student t-test analysis for all predictors. Those significant at a p<0.05 were included in one of three logistic regression models: historic, intrapartum, and perinatal factors. Those predictors significant at a p<0.05 were entered into the final logistic regression model. Points were then assigned to each predictor according to their Beta Coefficient, where higher scores were given to those predictors associated with a successful TOL. Final range: 0–10. | Age under 40: (2 points) | [underlined: Score] | [underlined: % with VD]
| Southern California Kaiser Permanente | 1990-1992 | | | | | | Vaginal birth history: | 0 to 2: | 49.1
GOOD | | To develop a scoring system to predict the likelihood of vaginal birth in patients undergoing a TOL after previous cesarean delivery using factors known at the time of hospital admission. | | | | | | before and after (4) | 3: | 59.9
| | | | | | | | after CD (2) | 4: | 66.7
| | | | | | | | before CD (1) | 5: | 77.0
| | | | | | | | none (0) | 6: | 88.6
| | | | | | | | Reason other than FTP for CD: (1) | 7: | 92.6
| | | | | | | | Cervical effacement at admission: | 8 to 10: | 94.9
| | | | | | | | >75% (2)
| | | | | | | | 25–75% (1) | Overall VBAC rate: 74.9%
| | | | | | | | <25% (0)
| | | | | | | | Cervical dilation 4cm or more at admission: (1)
Vinueza 2000 ^41^ | USA | Retrospective cohort | Women with a documented previous LTCS | ERCD, suspected fetal distress within one hour of admission | - Inter-group comparisons revealed significant differences in gestational age (p=0.004), cervical dilation on admission (p<0.0001), birth weight (p=0.034); - distribution of population according to score: 0 – 21%, 1 – 41%, 2 – 28%, 3 to 4 – 10%.; - confirmed the inverse relationship between score and successful VD. | 263/636 | Applied the scoring system proposed by Troyer and Parisi (1992). | - Previous dysfunctional labor; - No prior VD; - Nonreassuring fetal heart tracing on admission; - Labor induction | [underlined: Score] | [underlined: % with VD]
| Spartanburg Regional Medical Center, South Carolina | 1992-1997 | | | | | | | 0 | 98%
FAIR | | To determine the applicability of a simple scoring system, by Troyer and Parisi, in predicting the success of a trial of labor among parturients with prior cesarean delivery. | | | | | | | 1 | 69%
| | | | | | | | | 2 | 40%
| | | | | | | | | 3 to 4 | 33%
| | | | | | | | | Overall VBAC rate: 63% (167/263)
Weinstein 1996 ^42^ | Israel | Retrospective cohort | Women with one prior abdominal delivery | ERCD, incomplete records, classic or unknown scar, hx of rupture, absolute CPD, previa, fetal malpresentation incompatible with a safe VD | - Past indication categories; Grade A: malpresentation, PIH, twins; Grade B: placenta previa/abruptio, prematurity, PROM; Grade C: fetal distress, CPD, FTP, cord accident; Grade D: macrosomia, IUGR | 572/471 | Multiple variables were examined and were entered into a logistic regression model to control for confounding and to evaluate the effect of these variables on labor outcome. The score was then developed on the basis of the relative weights (odds ratios). | Bishop score ≥4 (if yes, 4 points); VD before CD (2) Past indication - Grade A (6), Grade B (5), Grade C (4), Grade D (3) | [underlined: Score] | [underlined: % with VD]
| Hebrew University | 1981-1990 | | | | | | | ≥4 | ≥58%
FAIR | | To evaluate the relative weight of the different variables that may influence the chances of vaginal birth after one cesarean delivery, with the aim of developing a predictive score for success of such a trial. | | | | | | | ≥6 | ≥67%
| | | | | | | | | ≥8 | ≥78%
| | | | | | | | | ≥10 | ≥85%
| | | | | | | | | ≥12 | ≥88%
| | | | | | | | | - Sensitivity: 85.6% (of predicting VD); - Specificity: 67.7% (of predicting CD); - Overall accuracy: 80.0%
| | | | | | | | | Overall VBAC rate: 78.1% (368/471)
Jakobi 1993 ^37^ | Israel | Retrospective cohort | Women with one previous cesarean delivery, who attempted a TOL without using oxytocin | Unknown scar type or other than low transverse incision, nonvertex presentation, multiple gestation, ruptured membranes and no contractions for more than 16 hours or at >42 weeks gestation | It was hospital policy that no elective cesareans were done at the patients' request; the model was tested retrospectively on the same population that it was derived from. Only 8 futile TOLs took place; 76 unjustified CDs were performed. | 261/261 | Chi Square tests were used to calculate success rates associated with different factors. To address the issue of confounding, a multivariate analysis with discriminant analysis was performed. The six most significant prognostic factors were used to create a predictive model. | Previous breech (0.516 - standardized function coefficient); Previous successful VBAC (0.353); Station at admission (0.302); Admission without rupture of membranes (0.296); Dilation at admission (0.281); Previous failure to progress (-0.265) | - Predictive value for successful VBAC: 94.5% (139/147); - Predictive value for failed VBAC: 33.3% (38/114).; - Overall predictive value: 68%.
| Rambam Medical Center | Dates NR
FAIR | | To examine 15 identified prognostic factors, in order to evaluate the predictive value or a better selection of patients for VBAC.
| | | | | | | | | Overall VBAC rate: 82.3%
Troyer 1992 ^40^ | USA | Retrospective cohort | Women with a documented previous lower transverse CD, gestational age >36 weeks, singleton pregnancy, vertex presentation. | ERCD, undocumented incision, low vertical incision, classic incision, multiple gestation, malpresentation, <36 weeks gestation. | - The lowest group still had a VD rate of 46.1%; - Distribution of population according to score: 0 – 22%, 1 – 35%, 2 – 33%, 3 to 4 – 10% | 567/264 | Multiple variables were examined and four were found to be significantly associated with TOL outcome included: previous dysfunctional labor, no prior VD, nonreassuring fetal heart tracing on admission, labor induction. Each variable was assigned a point value of one. After summing the values, the higher scores were more likely to fail a TOL. | Previous dysfunctional labor; No prior VD; Nonreassuring fetal heart tracing on admission; Labor induction | [underlined: Score] | [underlined: % with VD]
| Hermann Hospital, University of Texas | 1990-1991 | | | | | | | 0 | 91.5%
FAIR | | To characterize risk factors in patients undergoing trial of labor after previous cesarean section. | | | | | | | 1 | 73.9%
| | | | | | | | | 2 | 66.7%
| | | | | | | | | 3 to 4 | 46.1%
| | | | | | | | | Overall VBAC rate: 72.7% (192/264)
Macones 2001 ^38^ | USA | Case-control | Women with a PCS. | Unknown scar type, previous vertical cesarean delivery. | Cases: n=100 | 400/400 | Over 70 predictive factors were reviewed and analyzed using unpaired t-tests and the Mann-Whitney U test. Significant associations were entered into a model that would ensure a high sensitivity (in order to detect those women who would fail a TOL). | A history of substance abuse; Prior successful VBAC; Admission cervical dilation; Need for labor augmentation. | - Sensitivity: 77% (of predicting CD); - Specificity: 65% (of predicting VD); - Overall accuracy: 69%; - Area under ROC curve: 0.77
| University of Pennsylvania | 1994-1998 | | | Controls: n=300
FAIR | | To assess the effectiveness of a neural network for predicting the likelihood of success of a TOL
| | | Cases: failed TOL
| | | Controls:VBAC
Pickhardt 1992^39^ | USA | Case-control | Women with a PCS. | Incomplete data or unobtainable charts | - R squared for Equation 2 (0.1552) was slightly larger than the R squared for Equation 1 (0.1018), indicating that Equation 2 is slightly better than Equation 1; however neither of these indicates a clear superiority.; - Pickhardt recommended that it was appropriate to encourage a TOL in almost all patients with a prior LTCS. | 336/312 | Nineteen specific obstetric variables were examined and analyzed using t-tests and chi-square tests for univariate analysis. The factors were then entered into a logistic stepwise regression (p to enter 0.05), which resulted in two different regression equations (based upon the number of subjects used to formulate the model). | - [underlined: Equation 1] (n=101): constant (-4.4183), estimated fetal weight (0.0010), number of previous CD (0.7719).; - [underlined: Equation 2] (n=306): constant (-8.6165), number of previous CD (0.8326), cervical dilation in cm (-0.4803), estimated gestational age (0.2160) | - [underlined: Equation 1:]; Sensitivity: 60.4% (of predicting CD); Specificity: 66.0% (of predicting VD); Accuracy: 63.4%; - [underlined: Equation 2:]; Sensitivity: 38.4%; Specificity: 87.9%; Accuracy: 71.9%
| Mississippi Medical Center - Jackson Mississippi | 1989
FAIR | | To determine if there are valid predictors before parturition, of vaginal birth after previous cesarean birth success that could be used to enhance the obstetric care of a patient
| | | Cases: failed TOL
| | | Controls:VBAC
| | | | | | | | | Overall VBAC rate: 63.1%
Imaging Modalities
Thubisi 1993 ^47^ | South Africa | RCT | Women with one previous LTCS. | ERCD, abnormal fetal lie or presentation, obstetric complications requiring planned delivery, maternal medical disorders contraindicating a TOL, multiple pregnancy, preterm labor, grossly contracted pelvis on examination, intrauterine death | - Patients randomly assigned (alternately) to one of two groups: 1) antepartum XRP group - XRP at 36 weeks before the mode of delivery was decided upon (n=144), 2) control group - no antepartum XRP, but they did receive a postpartum XRP (n=144).; - 60 of the 144 in the antepartum XRP group were considered to have an inadequate pelvis, leaving 84 attempting a TOL in the intervention group. | 306/228 | Measurements of the pelvis saggittal inlet (<11cm), saggittal outlet (<10cm), transverse inlet (<11.5cm), transverse outlet (bispinous <9cm), were considered inadequate, as defined by Russel and Richards (1971). | Pelvic dimensions: adequate or inadequate | - Sensitivity: 26.2% (of predicting CD); - Specificity: 45.0% (of predicting VD); - Positive Predictive Value: 40.0%; - Negative Predictive Value: 30.3%; - 27.7% (23/84) in the antepartum XRP group who were considered to have an adequate pelvis had a VD, which was significantly less than the 41.6% (60/144) in the control group (p<0.05).; - Postpartum XRP of the control group revealed that a greater proportion of those considered to have an inadequate pelvis delivered vaginally (60% - 33/55), compared to those considered to have an adequate pelvis (30% - 27/89).; - 30.3% (27/89) of those in the control group considered to have an adequate pelvis by postpartum XRP had a VD.
| King Edward VIII Hospital-Durbin | 1990
GOOD | | To determine whether antepartum XRP reliably identified women suitable for a trial of labor or repeat elective cesarean section after one previous section.
| | | Group 1: antepartum XRP
| | | Group 2: postpartum XRP

TOL=trial of labor; RCT=randomized controlled trial; NR= not reported; VBAC=vaginal birth after cesarean; FTP=failure to progress; CD=cesarean delivery; LTCD=low transverse cesarean delivery; PCD=prior cesarean delivery; ERCD=elective repeat cesarean delivery; VD=vaginal delivery; CPD=cephalopelvic disproportion; XRP=x-ray pelvimetry;

Evidence Table 3b. Predictive tools - poor quality studies

Author Year Quality | Country Setting | Study design Years of study Research objective | Population | Exclusion criteria | Methods | Number eligible/attempting TOL | Score development | Predictors included | Performance
Imaging Modalities
Abitbol 1991 ^205^ | USA | Prospective cohort | VBAC candidates per ACOG recs: without diabetes, without hypertension, with estimated fetal weight <4000gm, and a known previous lower segment scar (subset of subjects in a larger study). | Patient consent, noncephalic presentation, complications during the course of labor. | - The overall study included 100 patients, from which a subset of 34 were patients attempting a TOL following a previous CD.; - Results provided are a combination of two groups:; 1. those attempting VBAC; 2. primigravids at full term, with an unengaged fetal head.; - >12mm CPDI does not guarantee a VD; this may be due to variations in joint mobility, intensity of contractions, position of cephalic presentation, fetal abdomen, and other obstetric factors. | 34/34 | Considered three measurements: | - Biparietal diameter of the fetal head; - Anteroposterior diameter of the pelvic inlet; - Bispinal diameter of the midpelvis | [underlined: CPDI] | [underlined: % with VD]
| New York: Jamaica Hospital and State University at Stony Brook | Dates NR | | | | | 1. biparietal diameter of the fetal head; 2. anteroposterior diameter of the pelvic inlet; 3. the bispinal diameter of the midpelvis. The BPD of the fetal head was then matched to the smaller of the two pelvic dimensions (SPD). The difference between the two was termed the CPDI (=SPD-BPD). | | <9mm | 0 (0/13)
POOR | | To evaluate the efficacy of the cephalopelvic disproportion index (CPDI) in predicting the outcome of a TOL in those with and without a PCS. | | | | | | | 9–12mm | 21.1 (4/19)
| | | | | | | | | >12mm | 73.5 (50/68)
Thurnau 1991 ^48^ | USA | Prospective cohort | Women between 35 and 43 weeks' gestation with a desire for VBAC. | No XRP performed, no ultrasonographic measurements performed, inadequate labor trial before CD (cervical dilation <5cm). | - 64 patients with cephalic presentation, 1 with breech.; - 58 patients with spontaneous labor, 7 requiring induction or augmentation.; - Compared FPI with Ultrasonography based EFW and XRP. Both had low sensitivities of 0.11 and 0.17, respectively). | 74/65 | Measured the anteroposterior (APD) and transverse diameters (TD) to calculate the circumference (C=(TD+APD)×0.5pi) of the fetal cranium (HC), fetal abdomen (AC), maternal pelvic inlet (IC), and maternal midpelvis (MC). The differences between the four circumferences (HC-IC, HC-MC, AC-IC, AC-MC) were calculated and the two most positive values were summed to equal the fetal-pelvic index (FPI). A positive FPI identifies a fetus that is larger than the pelvis (fetal-pelvic disproportion); a negative FPI identifies a fetus that is smaller than the pelvis (no fetal-pelvic disproportion). | Fetal-pelvic index: positive or negative | - Sensitivity: 72% (positive test in those with CD); - Specificity: 100% (negative test in those with VD); - PPV: 100% (13/13 with positive FPI, required CD); - NPV: 90% (47/52 with negative FPI, had VD); - Overall accuracy: 92.3% (60/65); - Fischer's exact test: p<0.00001
| University of Oklahoma Oklahoma City, Oklahoma | 1988-1990
POOR | | To evaluate the efficacy of the fetal pelvic index (FPI) as a predictor of fetal-pelvic disproportion in gravid women attempting VBAC. Also to compare the FPI findings with those of x-ray pelvimetry and ultrasonographical derived estimated fetal weight > 4000gm.
Morgan 1988 ^206^ | USA | Prospective cohort | Women with PCS, who required the use of oxytocin in labor, had suspected fetal-pelvic disproportion, and suspected fetal macrosomia. | <37 weeks gestation, neonates <4000gm. | - FPI has a relatively high predictive accuracy.; - XRP and ultrasound, when used alone, do not predict fetal-pelvic disproportion accurately. | 101/34 | Measured the anteroposterior (APD) and transverse diameters (TD) to calculate the circumference (C=(TD+APD)×0.5pi) of the fetal cranium (HC), fetal abdomen (AC), maternal pelvic inlet (IC), and maternal midpelvis (MC). The differences between the four circumferences (HC-IC, HC-MC, AC-IC, AC-MC) were calculated and the two most positive values were summed to equal the fetal-pelvic index (FPI). A positive FPI identifies a fetus that is larger than the pelvis (fetal-pelvic disproportion); a negative FPI identifies a fetus that is smaller than the pelvis (no fetal-pelvic disproportion). | Fetal-pelvic index: positive or negative | - Sensitivity: 92% (positive test in those with CD); - Specificity: 71% (negative test in those with VD); - Positive Predictive Value: 67% (12/18 with a positive FPI, required a CD); - Negative Predictive Value: 94% (15/16 with a negative FPI, had a VD); - Overall accuracy: 79.4% (27/34); - Fischer's exact test: p<0.001
| University of Oklahoma Oklahoma City, Oklahoma | To compare the efficacy of three methods used to identify fetal-pelvic disproportion (FPI, XRP, EFW>4000g) in patients delivering neonates weighing >4000gm after an adequate TOL.
POOR
Lao 1987 ^31^ | Hong Kong | Retrospective cohort | Women with one previous lower segment CD who attempted a TOL. | no XRP performed | No information was provided for a summary of adequate pelvises, but only for each measurement separately (OC, TC, APO). | 666/445 | Considered three measurements: 1) obstetric conjugate (OC) inlet, 2) transverse diameter (TD) inlet, and 3) antero-posterior outlet (APO) diameter. Adequate: OC >11cm, TD >12cm, and an APO >11cm. Inadequate: OC <11cm, TD<12cm, or APO <11cm. | Pelvic dimensions: adequate or inadequate | - OC>11cm: VBAC: 84.5% (321/380); - TD>12cm: VBAC: 84.5% (324/383); - APO>11cm: VBAC: 84.1% (286/340)
| Princess Margaret Hospital Hong Kong | 1980 - 1983
POOR | | To determine if X-ray pelvimetry (XRP) is useful in a TOL after PCS.
| | | | | | | | | Similar proportions of adequate measurements in the FTOL group (NS difference).
Mahmood 1987 ^45^ | Scotland | Retrospective cohort | Women with a PCS. | More than one PCS, previous classical scar, no XRP | No uniformity among obstetricians about category of patients in whom an XRP should be performed or when it should be done; or what constituted a contracted pelvis - some considered a AP diameter of inlet <11.5cm, whereas others used a figure of <11.0cm; at other times pelvic shape determined the category of pelvis. | 239/89 | No consistent criteria for classification of contracted. Some used an AP diameter of inlet <11.5cm, while others used a cutoff of <11.0cm. Others ignored diameters and based their decision on pelvis shape. | Pelvic dimensions - measurements | No statistically significant difference in pelvic dimensions between those who failed a TOL and those with VBAC.
| Bellshill Maternity Hospital Lanarkshire | 1982-1983
POOR | | To assess the role of radiological pelvimetry in the management of patients who have had a PCS.
| | | | | | | | | [underlined: AP Inlet:]
| | | | | | | | | VBAC: 12.3±1.0cm
| | | | | | | | | FTOL: 12.1±0.8cm
| | | | | | | | | [underlined: AP Outlet:]
| | | | | | | | | VBAC: 12.2±1.0cm
| | | | | | | | | FTOL: 11.8±1.0cm
Wright 1985 ^49^ | S. Africa | Retrospective cohort | Women with one prior LTCS, with no other viable pregnancy | Inadequate antenatal assessment (specifics NR) | - Due to the lack of a concise definition regarding the decision of who should be given a ERCD, the interpretation of this data must be done cautiously.; - A pelvic brim inlet >11cm demonstrated a high success of VD, while one <11cm still demonstrated a 50% chance of VD.; - Sacrum dimensions/shape appeared to be of little value.; - Head engagement demonstrated a high PPV, while the lack of head engagement showed a fairly high specificity for CD. | 100/59 | At the 36th and 38th week of pregnancy patients had an erect lateral pelvimetry performed, where the following dimensions were considered: | Pelvic dimensions: adequate or inadequate | [underlined: Pelvic AP brim inlet:]
| Peninsula Maternity Hospital | Dates NR | | | | | | | - Sensitivity: 84% of those with a VD had >11cm inlet.; - Specificity: 50% of those with CD had <11cm inlet.; - PPV: 84% (38/45) with >11cm had a VD.; - NPV: 50% (7/14) with <11cm had a failed TOL.
POOR | | To assess the value of XRP in those undergoing a TOL following a previous CD.
| | | | | | | 1. anteroposterior diameter of pelvic brim; 2. curvature of the sacrum; 3. engagement of the fetal head | | [underlined: Sacrum:]
| | | | | | | | | - Sensitivity: 71% with a VD had a curved sacrum.; - Specificity: 40% with a CD had a flat sacrum.; - PPV: 80% with a curved sacrum had a VD.; - NPV: 24% with a flat sacrum had a CD.
| | | | | | | | | [underlined: Head engagement:]
| | | | | | | | | - Sensitivity: 66% with a VD had head engagement.; - Specificity: 79% with a CD had no head engagement.; - PPV: 91% with head engagement had a VD.; - NPV: 42% without head engagement had a CD.

VBAC=vaginal birth after cesarean; ACOG=American College of Obstetricians and Gynecologists; TOL=trial of labor; CD=cesarean delivery; CPDI= cephalopelvic disproportion index; PCD=prior cesarean delivery; VD=vaginal delivery; BPD=biparietal diameter; SPD= smallest pelvic diameter; PPV= positive predictive value; NPV= negative predictive value; FTOL=failed trial of labor; APD= anteroposterior diameter; TD= transverse diameter; EFW=estimated fetal weight; XRP=x-ray pelvimetry; FPI=fetal-pelvic index; AP=anterior-posterior;

Evidence Table 4a. Maternal outcomes - good or fair quality studies

Author Year Quality | Number in study | Uterine Rupture | Major Bleeding (req hyst, tx) | Maternal Infection (metritis, wound infection) | Maternal Death
Randomized Controlled Trials
Lelaidier 1994 ^35^ | 32 | Measured: Yes | Measured: | Measured: Yes | Measured: Yes
| | Definition: Not defined | Definition: Not defined | Definition: Not defined | Results: I- 0
| | Results: I- 1 case of scar separation reported (found during C-section). | Results: | Results: I- 1 infected wound | IC- 0
FAIR | | Control- 1 case of scar separation reported (found during C-section) | | IC- 1 infected wound
Rayburn 1999 ^32^ | 294 | Measured: Yes | Measured: | Measured: | Measured: Yes
| | Definition: Not defined | Definition: Not defined | Definition: Not defined | Results: I- 0
| | Results: I- 0 | Results: I- 0 | Results: I- 8 (5.6%) | SL- 0
FAIR | | SL- 0 | SL- 0 | SL- 7 (4.6%)
Population Based Studies
McMahon 1996 ^5^ | 6,138 | Measured: Yes | Measured: Yes | Measured: Yes | Measured: Yes
| | Definition: A defect that involved the entire wall of the uterus, that was symptomatic or required operative intervention. | Definition: Hysterectomy, transfusion | Definition: temperature >38.0 included uterine, urinary, pulmonary, wound infection or sepsis | Results: SL/IA- 0
| | | | | ERCD- 0
GOOD | | Results: SL/IA- 10 (0.3%) | Results: SL/IA- hyst = 5 (0.2%) - 2 due to UR
| | ERCD- 1 (0.0%)
| | | TX= 36 (1.1%) | Results: SL/IA- fever= 171 (5.3%)
| | | ERCD- hyst = 6 (0.2%)
| | | TX = 39 (1.3%) | abd-wound inf= 43 (1.3%)
| | | | ERCD- fever = 185 (6.4%)
| | | | abd wound inf = 63 (2.2%)
Prospective Cohort
Blanchette 2001^52^ | 25 | Measured: Yes | NR | NR | Measured: Yes
| | Definition: Uterine separation requiring an emergency laparotomy for a nonreassuring fetal heart rate tracing or maternal hemorrhage. | | | Results: 0
FAIR | | Results: IA- 11; 7 inductions (1-miso, 4-oxytocin, 2-miso/oxy) and 4 augmentations (oxy).
| | SL- 1
Blanco 1992 ^34^ | 81 | Measured: Yes | NR | Measured: Yes | Measured: Yes
| | Definition: NR | | Definition: Endometritis | Results: I- 0
| | Results: IA- 0 | | Results: SL- 3 | SL- 0
FAIR | | SL- 0
Cowan 1994 ^25^ | 593 | Measured: Yes | Measured: Yes | NR | NR
| | Definition: Scott's definition - “a complete separation of the wall of the pregnant uterus, with or without expulsion of the fetus, endangering the life of the mother or fetus” | Definition: Amount
| | | Results: SL/IA-successful
FAIR | | | VBAC:
| | bloodless uterine scar dehiscence = any defect in the preexisting scar with no fetal or maternal compromise. | 453 (95%) EBL<500
| | | 14 EBL 501–700
| | Results: SL-3 | 10 EBL 701–1000
| | IA- 2 | 1 EBL >1000
| | | UR ave EBL >1500cc
| | | 3/5 UR symptomatic blood loss
Duff 1988 ^26^ | 227 | Measured: Yes | Measured: Yes | Measured: Yes | NR
| | Definition: Dehiscence = disruption of any portion of the lower segment incision. | Definition: PP Hemorrhage classified as atony cervical or vag lacerations. | Definition: Chorioamnionitis or endomyometritis=intrapartum fever in association with uterine tenderness, fetal tachycardia and no other localizing signs of infection, endo=pp maternal temp >38, uterine and adnexal tenderness.
GOOD | | Results: SL/IA-1 received oxytocin in labor VB, decreased uterine tone, fetal bradycardia, 60% of scar disrupted, repaired).
| | | Results: SL/IA-“no differences between succesful and not”.
| | | | Results: SL/IA-12/167 with successful VBAC
| | | | 11/60 with failed VBAC
Flamm 1997 ^33^ | 5,022 | Measured: Yes | NR | NR | NR
| | Definition: NR. Exam of uterus postpartum at discretion of birth attendant.
| | Results: IA- 6/453 (1.3%) (all also received oxytocin)
FAIR | | SL- 33/4569 (0.7%)
Flamm 1990 ^22^ | 3,957 | Measured: Y | NR | NR | NR
| | Definition: any defect that involved the entire uterine wall or was symptomatic or required operative intervention
FAIR | | Results: IA- 6/1201 (0.5%)
| | IC- 4/2756 (0.15%)
Flamm 1987 ^28^ | 1,776 | Measured: Yes | Measured: Yes | Measured: Yes | Measured: Yes
| | Definition: | Definition: Not defined (hysterectomies reported). | Definition: Febrile morbidity | Results: I- 0
| | Results: IA- 2 | | Results: IA- 18/485 (3.7%) | IC- 0
GOOD | | IC- 1 | Results: IA- 1 | IC- 35/1291 (2.7%)
| | | IC- 1
Flamm 1988 ^21^ | 1,776 | Measured: Yes | Measured:Yes | NR | Measured: Yes
| | Definition: Asymptomatic uterine windows - small defects visualized at CS or palpated at VD. | Definition: hysterectomy | | Results: SL/IA-0 (none)
| | | Results: 1 successful VBAC, 1 failed TOL
GOOD | | True uterine rupture - defect involving entire uterine wall that was symptomatic or requiring operative intervention.
| | Results: SL/IA-0 - successful VD, 3 failed TOL (1 required hysterectomy) 2 oxytocin augmented (1 total expulsion of infant at 1cm dilation Apgars 1,2,8 hysterectomy), 2nd pushing oxytocin and epidural pain btwn ctx thin layer of peritoneum over infant head Apgars 1,8,9 no uterine ruptures in patients with multiple cesareans or unknown scar 11 noted to have asymtpomatic uterine windows
Flamm 1994 ^20^ | 7,229 | Measured: Yes | Measured: Yes hyst due to UR measured unsure if all hyst measured transfusion. | Measured: Yes | Measured: Y
| | Definition: Uterine rupture was defined as any defect that involved the entire uterine wall or was symptomatic or required operative intervention. | | Definition: NR | Results: SL/IA-1 (aspiration pnemonitis - TOL pt emergent CS for fetal distress)
| | | | Results: SL/IA- 12.7%
FAIR | | Results: SL/IA- 39/5022 | Definition: | ERCD-16.4%
| | | Results: SL/IA- hyst due to UR = 3/5022 (0.12%) Transfusion = 0.72%
| | | ERCD- hyst 0.27% (p=.2053) transfusion = 1.72% (p=.0001)
Flamm 1990 ^22^ | 3,957 | Measured: Yes | NR | NR | Measured: Yes
| | Definition: Uterine rupture was defined as any defect that involved the entire uterine wall, was symptomatic or required operative intervention. | | | Results: SL- None
| | | | | ERCD- 2
FAIR | | Results: SL/IA- 3 cases in 1984-5 see 1988 flamm 7/3957 1986-8 (1.8/1000)
Meier 1982 ^57^ | 269 | Measured: Yes | Measured: Yes | Measured: Yes | Measured: Yes
| | Definition: uterine scar separation | Definition: Blood transfusion | Definition: febrile morbidity, not defined | Results: SL/IA- None
| | Results: SL/IA- successful VBAC 0/175 | Results: SL/IA- NR | | ERCD- None
FAIR | | failed VBAC = 1/32 | ERCD- 1 (1.6%) | Results: 2/32 (6.3%) failed TOL, 11/62 ERCD (17.7%)
| | ERCD- 1 (1.6%)
Meehan 1989 ^50^ | 344 | Measured: Yes | NR | NR | Measured: Yes
| | Definition: Rupture of scar accompanied by intra-abdominal or vaginal bleeding or bloodless dehiscence. | | | Results: I- 0
| | | | | SL- 0
FAIR | | Results: IA- A+O+P : 1/23 (4.3%) | | | ERCD- 0
| | SL- 0
| | ERCD- 0
Paul 1985 ^30^ (see also Phelan 1987) | 889 | Measured: Yes | Measured: Yes | Measured: Yes | Measured: Yes
| | Definition: Dehiscence “scar separation” | Definition: Hysterectomy | Definition: “febrile morbidity” | Results: 0
| | rupture = scar separation requiring operative intervention. | Results: SL/IA- 0 in successful VBAC | Results: SL/IA-14/614 (2.3%) successful VBAC
| | Results: SL/IA- 11/614 successful VBAC
| | 5/137 failed VBAC | 2 failed VBAC intact scar, pphem, atony | 37/137 (27%) failed VBAC
| | ERCD- 4/157 | | ERCD- 23/157 (25%)
FAIR | | | ERCD- 5 (1 complete scar separation and percreta, 1 laceration extension into vagina, 1 accreta, 2 hem and atony
Phelan 1987 ^23^ (see Paul 1985) | 2,110 | Measured: Yes | Measured: Yes | Measured: Yes | Measured: Yes
| | Definition: Dehischence = scar separation not requiring operative intervention. | Definition: hysterectomy | Definition: NR | Results: 1 postpartum pulmonary embolus failed TOL for fetal distress
| | | Results: SL/IA- 5/1796 (all for atony) | Results: SL/IA- 159/1796
| | rupture = separation requiring operative intervention. | | 53/1465 (3.6%)successful VBAC
FAIR | | Results: SL/IA- dehiscence = 34/1796 (1.9%) | ERCD- NR
| | rupture = 5/1796 (0.3%) rupture rate oxytocin 3% vs no oxytocin 2% | | 106/331 (32%) failed VBAC
| | | | ERCD- 56/314 (18%)
| | ERCD- 7/314 dehischence or rupture
Stovall 1987 ^27^ | 272 | Measured: Yes | NR | NR | Measured: Yes
| | Definition: Dehiscence= palpable or visualized defect in previous uterine scar. | | | Results: SL/IA-0
| | uterine window= dehiscence not requiring surgical intervention.
FAIR | | rupture= dehiscence requiring surgical intervention.
| | Results: SL/IA- 1, oxytocin augmentation, epidural
Retrospective cohorts
Lao 1987 ^31^ | 666 | | Measured: Yes | NR | Measured: Yes
| | | Definition: not defined | | Results: IA=0,
| | | Results: IA=6/102 (6%) | | SL=NR
FAIR

NR=not reported; IA= induces or augmented; SL=spontaneous labor; PRBC=packed red blood cells; VBAC=vaginal birth after cesarean; ERCD=elective repeat cesarean delivery; PGE2=prostaglandin E2 LTCD=low transverse cesarean delivery

Evidence Table 4b. Maternal outcomes - poor quality studies

Author Year Quality | Number in study | Uterine rupture | Major Bleeding (required hysterectomy, treatment) | Maternal Infection (metritis, wound infection) | Maternal Death
Randomized Controlled Trials
Taylor 1993 ^190^ | NR | Measured: | Measured: | Measured: NR | Measured: Y
| | Definition: Not defined | Definition: NR | Definition: | Results: I- 0
POOR | | Results: IA - 1 (I + a) | Results: | Results: | IC- 0
| | SL- 0
Xenakis 1995^175^ | 48 | Measured: | Measured: | Measured: NR | Measured: Y
| | Definition: Not defined. | Definition: NR | Definition: | Results: I- 0
POOR | | Results: IA : 1 dehiscence; Control: 1 dehiscence | Results: | Results: | IC- 0
Wing 1998^176^ | 38 | Measured: | Measured: | Measured: NR | Measured: Y
| | Definition: Separation of the prior uterine incision that required emergency laparotomy usually diagnosed at the time of acute fetal distress requiring immediate operative intervention or acute maternal hemorrhage with hypotension and shock. | Definition: NR | Definition: | Results: I- NR
POOR | | | Results: I- 1 patient required 4 units PRBCs | Results: | IC- NR
| | | IC- NR
| | Results: IA: 1 (plus 1 dehiscence)
| | Control: 0
Population Based Studies
Bais 2001^180^ | 252 | Measured: Yes | Measured: Yes | Measured: Yes | Measured: Y
| | Definition: NR | Definition: hemorrhage= >500cc, hemorrhage >1000cc blood transfusion hysterectomy | Definition: NR pp fever | Results: Overall- None
POOR | | Results: SL/IA- 1/184 (in failed VBAC) | | Results: SL/IA- 16/184 (9%)
| | ERCD- 0/68
| | | Results: SL/IA- >500cc=31 (17%) [14 failed VBAC] | ERCD- 7/68 (10%)
| | | >1000cc = 9 (5%) [3 failed VBAC]
| | | transfusion= 8 (4%) [4 failed VBAC]
| | | hysterectomy=none
| | | ERCD- >500cc=20 (29%)
| | | >1000cc = 6 (9%)
| | | transfusion= 4 (6%)
| | | hysterectomy=none
Beall, M 1984^191^ | 857 | Measured: Yes | Measured: Yes | Measured: Yes | NR
| | Definition: Not defined | Definition: Hysterectomy | Definition: maternal fever
POOR | | “scar rupture,” scar dehiscence" used interchangeably no “complete scar rupture”. | Results: Overall- none in any group | Results:
| | | | SL/IA- 56% unknown scar
| | Results: SL/IA- 1% of 97 unknown scar (figure 2 says 8%)
| | 2% of 204 LTCD (figure 2 says 7.5%) | | 34% LTCD
| | ERCD- 1% of 354 unknown | | ERCD- NR
| | 4% of 170 LTCD
Gregory 1999 ^61^ | 469,929 | Measured: Yes | Measured: NR | Measured: NR | NR
| | Definition: NR | Definition: | Definition:
POOR | | Results: NPCD- 104/469,929 | Results: | Results:
| | 13/17,209 elective primary cesarean
| | 64/51,333 failed labor (CD)
| | 27/401,387 VD labor
| | SL/IA- 288/66,856 (0.43%)
| | 174/15,072 failed VBAC
| | 35/24,024 VBAC
| | ERCD- 79/27,760
Holt 1997 ^59^ | 10,110 | NR | Measured: NR | NR | NR
| | | Definition:
POOR | | | Results:
Lyndon-Rochelle 2001^4^ | 36,966 | Measured: Yes | Measured: Y | Measured: Y | NR
| | Definition: ICD-9-CM code 665.0 or 665.1 recorded on hospital d/c form | Definition: hysterectomy | Definition: puerperal infection
| | | Results: 12/20,004 without UR
POOR | | Results:SL- 56 | 4/91 with UR | Results: 243/20,004 without rupture
| | I- 24 (9 induced with PG, 15 without PG)
| | | | 8/91 with rupture
Stone 2000 ^177^ | NR | Measured: Yes | Measured: NR | NR | NR
| | Definition: ICD-9 coding 665.0 and 665.1 | Definition:
| | Results: | Results:
POOR
Prospective Cohort
Arulkumaran 1989^179^ | 63 | NR | Measured: NR | NR | NR
| | | Definition:
POOR | | | Results:
Asaad 1994^189^ | NR | NR | NR
POOR
Gherman 2001^181^ | 10 | Measured: Yes | Measured: NR | NR | NR
| | Definition: NR | Definition:
POOR | | Results: IA- 1/10 (10%) | Results:
Goldberger 1989^182^ | 217 | Measured: Yes | Measured: Yes | Measured: Yes | Measured: Yes
| | Definition: Not defined; post-delivery check of uterine cavity. | Definition: Not Defined | Definition: Not defined | Results: I- 0
POOR | | Results: IA- 0 | Results: IA- 0 | Results: IA- 0 | IC- 0
| | SL- 0 | IC- 0 | IC- 0 | SL- 0
| | | SL- 0 | SL- 0
Goldman 1998^183^ | 520 | Measured: Yes | Measured: Yes | NR | Measured: Yes
| | Definition: Not defined, but dehiscence reported separately. | Definition: Not defined | | Results: I- 0
POOR | | Results: IA- 0 (1 dehis) | Results: IA- 0 hyst/3 hemorrhage oxytocin | | SL- 0
| | IA- 0 (1 dehis)
| | SL- 0 (0 dehis) | 0 hyst/5 hemorrhage PGE2
| | | SL- 0 hyst/6 hemorrhage
Miller 1992 ^173^ | 318 | Measured: Yes | Measured: Yes | Measured: Yes | NR
| | Definition: NR | Definition: Blood transfusion | Definition: Temp 38° C or more on 2 occasions more than 24 hours apart.
POOR | | Results: SL/IA- 1/125 (0.8%) | Results: Overall-No difference
| | 1 previous CD fetal distress, oxytocin augmentation + epidural delivered by emergent CS for “fetal distress”.
| | | | Results: SL/IA- 15/44 (34.9%) failed VBAC required postpartum antibiotics
| | | | ERCD- 26/193 (13.5%) NS
Norman 1992^184^ | 313 | Measured:NR | Measured: NR | NR | Measured: Yes
| | Definition: | Definition: | | Results: I- 0
POOR | | Results: IA- 0 | Results:
Sakala 1990^188^ | 237 | Measured: Yes | Measured: Yes | Measured: Yes | NR
| | Definition: Symptomatic separation of prior scar, associated with perinatal morbidity. | Definition: Blood transfusion | Definition: Endometritis
POOR | | | Results: IA- 1 | Results: IA- 6
| | Results: IA- 0 | SL- 4 | SL- 7
| | SL- 0
Silver 1987^185^ | 98 | NR | Measured: Yes | Measured: Yes | NR
| | | Definition: Not defined | Definition: Described as endometritis
POOR | | | Results: IA- 2 CD patients required blood transfusion - group not described.
| | | | Results: IA- 11 cases - 9 in CD patients - group not described.
Sims 2001^186^ | 505 | Measured: Yes | Measured:NR | NR | NR
| | Definition: Asymptomatic rupture symptomatic rupture. | Definition:
POOR | | | Results:
| | Results:SL- NR “states intermediate rate”
| | IA- 7.00%
| | ERCD- 1.50%
Videla 1995^187^ | 1131 | Measured: Yes | Measured: NR | Measured: Yes | NR
| | Definition: “Overt rupture” | Definition: | Definition: “Chorioamnionitis”
POOR | | Results:SL- 3 [1 following VD, 2 failed VBAC] only 1 received oxytocin | Results:
| | | | Results: 23 successful VBAC
| | IA- 1
| | | | 14 failed VBAC
Zelop 1999^194^ | 3303 | Measured: Yes | Measured: | NR | I=0
| | Definition: complete rupture of prior uterine scar in association with >= 1 of: laparotomy for hemorrhage or hemoperitoneum, excessive injury to the bladder or extrusion into the peritoneal cavity of any portion of the fetal-placental unit, CD for nonreassuring FHR or suspected rupture as evidenced by the acute onset of incisional pain | Definition: hysterectomy | | SL=0
POOR | | | I=2 (0.4%)
| | | SL=2 4 (0.2%)
| | Results: Induction: Oxy alone: 9/459 (2%), PGE2 alone: 1/35 (2.9%), oxy plus PGE2: 3/67 (4.5%)

NR=not reported; IA= induces or augmented; SL=spontaneous labor; PRBC=packed red blood cells; VBAC=vaginal birth after cesarean; ERCD=elective repeat cesarean delivery; PGE2=prostaglandin E2 LTCD=low transverse cesarean delivery

Evidence Table 5a. Infant outcomes - good or fair quality studies

Author Year Quality | Number in study | Infant Sepsis | Infant Death | Other Infant Outcomes
Randomized Controlled Trials
Lelaidier 1994 ^35^ | 32 | NR | Measured: Yes | NR
| | | Results: I- 0
FAIR | | | IC- 0
Rayburn 1999 ^32^ | 294 | NR | Measured: Yes | NR
| | | Results: I- 0
FAIR | | | SL- 1
Population-Based Database
McMahon1996 ^5^ | 6,138 | NR | Measured: Yes | NR
| | | Results: SL/IA- 9/1000
GOOD | | | ERCD- 5/1000
Smith 2002 ^6^ | 24,529 | NR | Measured: Yes | NR
| | | Results:SL/IA- 20/15515
FAIR | | | (12 emergent CD, 8 vaginal delivery)
| | | RCD- 1/9014
Prospective Cohorts
Blanco 1992 ^34^ | 81 | NR | Measured: Yes | NR
| | | Results: I- 0
FAIR | | | SL- 0
Cowan 1994 ^25^ | 660 | NR | Measured: NR | Measured: Y- Apgar
| | | None reported | Definition:
FAIR | | | 1 serious neurologic sequelae. | Results: SL/IA- 5-min Apgar >7 = 463 (97%)
| | | Results:
| | | | <7=14
Duff 1988 ^26^ | 281 | Measured: Yes | NR | NR
| | Definition:
GOOD | | Positive culture blood, urine, CSF, CXR c/w pneumonia.
| | Results: SL/IA- “no differences between successful and not”
Flamm 1997 ^33^ | 5,022 | NR | Measured: Yes | NR
| | | Results: IA- 0
FAIR | | | SL- 0
Flamm 1987 ^28^ | 1,776 | NR | Measured: Yes | NR
| | | Results: IA- 0/485
GOOD | | | SL- 1/1291
Flamm 1988 ^21^ | 1,776 | NR | Measured: Yes | NR
| | | Results: SL/IA- 5 antepartum fetal deaths<36 weeks, no evidence of UR, “one would have been prevented by elective repeat at term”, one intrapartum death involving silastic vacuum for fetal distress no evidence of rupture on uterine exam, one died due to prematurity total 6 fetal and 1 neonatal death for rate 4/1000 (vs 11/1000 in 9 participating hospitals).
GOOD
Flamm 1994 ^20^ | 7,229 | NR | Measured: Yes | Measured: Yes-Apgar
| | | Results: rate of 7/1000 live births
FAIR | | | | Definition:
| | | | Results: SL/IA- 5-min
| | | | Apgar<7 = 1.48%
| | | | ERCD- 5-min Apgar<7 = 0.68% (p=.004)
Flamm 1990 ^22^ | 3,957 | NR | Measured: Yes | Measured: Y- Apgar
| | | Results: SL/IA-1 related to uterine rupture 2 previous cesareans unknown scar labored at home. | Definition:
FAIR | | | | Results: SL/IA- 5 min Apgar<7=9/1000 (when 20 cases of IUFD due to anencephaly, lethal malformations excluded).
Martin 1983 ^24^ | 717 | NR | Measured: Yes | NR
| | | Results: SL/IA- 3 fetal & 0 neonatal in successful VBAC
FAIR
| | | 1. 1 fetal and & neonatal in failed VBAC; 2. NO FETAL DEATHS OCCURRED IN UR OR DEHISC GROUP; 3. all fetal deaths occurred prior to labor with macerated fetuses.
| | | ERCD- 3 fetal & 5 neonatal 4/5 neonatal deaths due to RDS prior to term 1/5 congenital malformation incompatible with life.
Meehan 1989 ^50^ | 344 | NR | Measured: Yes | NR
| | | Results: I- 0
FAIR | | | SL- 0
| | | ERCD- 0
Meier 1982 ^57^ | 269 | NR | Measured: Yes | NR
| | | Results: SL/IA- 1/207 fetal death prior to labor 2 previous CS
FAIR
| | | ERCD- None
Paul 1985 ^30^ | 889 | NR | Measured: Yes | NR
| | | Results: NPCD?/SL/IA- 7 fetal - 6/7 antepartum, 1 intrapartum = (540 gm breech), 4/6 no uterine dehiscence 35–42 weeks, 2UR preterm TOL
FAIR
| | | 7 neonatal - 2 TOL with anomalies, 5<700gm
| | | ERCD- 2 neonatal with anomalies.
Phelan 1987 ^23^ (see Paul 1985) | 2,110 | NR | Measured: Yes | NR
| | | Results:17 fetal, 23 neonatal deaths; 11<750gm, 14 congenital anomalies, 6 preterm
FAIR
Stovall 1987 ^27^ | 272 | NR | Measured: Yes | Measured: Y- Apgar
| | | Results: SL/IA- None | Definition:
FAIR | | | | Results: SL/IA- 1 rupture LTCD, 5-min Apgar = 7
| | | | oxytocin 5 (3.8%) had 5-min Apgar<7, vs no oxytocin 4 (2.9%).
Retrospective Cohorts
Lao 1987 ^31^ | 666 | NR | Measured: Yes | NR
| | | Results: I- 0
FAIR | | | IC- 1
Raynor 1993 ^29^ | NR | NR | Measured: Yes | NR
| | | Results: SL- 1 28wks SROM polycystic kidneys
FAIR

NR=not reported; I=induced; SL=spontaneous labor; ERCD=elective repeat cesarean delivery; CSF=cerebral spinal fluid; CXR=chest x-ray; IA=induced or augmented;

Evidence Table 5b. Infant outcomes - poor quality studies

Author Year Quality | Number in study | Infant Sepsis | Infant Death | Other Infant Outcomes
Population Based
Bais 2001^180^ | 252 | NR | Measured: Y | Measured: Y
| | | Definition: SL/IA- 3/184 (1.2%) [ 1-rh dz,1 abruption,1-cord proplapse] | Definition: Apgar
POOR | | | | Results: SL/IA- 5-min Apgar <7 = 3/`84 (2%) - all in failed TOL
| | | | ERCD- 5-min Apgar <7 = 0/68
Beall 1984^191^ | 857 | NR | Measured: Yes | NR
| | | Results:
POOR | | | SL/IA- total of 6 perinatal deaths:
| | | 1. Term still birth may have been avoided by CD; 2. 920-gm premature may have been avoided by CD; 3. 2 other premature infants; 4. 1 premature delivered out of hospital
| | | lethal anomaly
| | | 5/1,000 LTCD
| | | 11/1,000 unknown
Holt 1997 ^59^ | 10,110 | NR | Measured: Yes | NR
| | | Results: SL/IA- 74/6491
POOR | | | ERCD- 52
Rageth 1999 ^60^ | 226,407 | NR | Measured: Yes | NR
| | | Results: I/IC/SL- 86/17613 (0.5%)
POOR | | | ERCD- 32/11433 (0.3%)
Stone 2000 ^177^ | 6145 | NR | Measured: Y | NR
| | | Results:29 preterm, 3 term1 home deliver, 1 fetal hypoxia prior to cesarean, 1 UR
POOR
Prospective Cohorts
Arulkumaran 1989^179^ | 63 | NR | NR | NR
POOR
Blanchette 2001^52^ | NR | NR | Measured: Yes
| | | Results: I- 2 (1-miso, 1-oxy)
POOR | | | SL- 0
Miller 1992 ^173^ | 318 | NR | Measured: Yes | Measured: Y-Apgar
| | | Results: No prior CD?/SL/IA- | Results: SL/IA- 5-min
POOR | | | neonatal = 1/80 successful VBAC | Apgar <7 = 6/80 (7.5%) successful VBAC
| | | perinatal = 1/80 successful VBAC
| | | neonatal = 1/45 failed VBAC
| | | prinatal = 0/45 failed VBAC | 0/45 failed VBAC
| | | ERCD- neonatal = 1/193 | ERCD- 5-min Apgar <7 = 4/193 (2.1%)
| | | perinatal = 0/193
Norman 1992^184^ | 313 | NR | Measured: Yes | NR
| | | Results: I- 0
POOR
Silver 1987^185^ | 98 | NR | Measured: I- all Apgars >/=7 | NR
| | | Results:
POOR
Retrospective Cohorts
Choy-Hee 2001^195^ | 425 | NR | Measured: Yes | NR
| | | Results: I- 0
POOR | | | IC-0
Chua 1989^196^ | 207 | NR | Measured: | Measured: Yes
| | | Results: | Definition: Apgar
POOR | | | | Results: SL- 5-min Apgar <7 = 2 (1.8%)
| | | | I- 5-min Apgar <7 = 2 1= induced, 1 augmented
| | | | ERCD- 5-min Apgar <7 = 3/98 (3.1%)
Chuck 1995^197^ | 15 | Measured: | Measured: Yes | NR
| | Definition: | Results: I- 0
POOR | | Results: | IC- 0
Del Valle 1994^199^ | 150 | NR | Measured: Yes | NR
| | | Results: I- 0
POOR | | | IC- 0
MacKenzie 1984^200^ | 170 | NR | Measured: Yes | NR
| | | Results: I- 0
POOR
Segal 1995 ^51^ | 67 | NR | Measured: Yes | NR
| | | Results: I- 0
Israel
Poor
Stone 1994^204^ | NR | NR | Measured: Yes | NR
| | | Results: I- 0
POOR
Videla 1995^187^ | 1,131 | NR | Measured: Yes | NR
| | | Results:
Poor | | | SL-
Zelop 1999^194^ | 3,303 | | Measured: Yes | NR
| | | Results: I- 0
(3 pubs) | | | SL- 0
POOR

NR=not reported; IA= induces or augmented; SL=spontaneous labor; PRBC=packed red blood cells; VBAC=vaginal birth after cesarean; ERCD=elective repeat cesarean delivery; PGE2=prostaglandin E2 LTCD=low transverse cesarean delivery

Evidence Table 6. Uterine rupture: terms, definitions, and predictors

Author Year Quality | Country Setting | Terms & definitions | Signs Symptoms | Labor factors | Patient factors
Population-based
McMahon 1996 ^5^ | Canada Nova Scotia | Term: uterine rupture | NR | NR | NR
| | Definition: a defect that involved the entire wall of the uterus, was symptomatic, and required operative intervention
GOOD
Smith 2002 ^6^ | Scotland | Term: uterine rupture | NA | NA | NA
| | Definition: NR
FAIR
Prospective Cohort
Duff 1988 ^26^ | USA Madigan Army Medical Center | Term: uterine scar dehiscence | 1/1 vaginal bleeding and fetal bradycardia | NR | NR
| | Definition: disruption of any portion of the lower segment incision
GOOD | | Use: description of case reported patient with vaginal bleeding, fetal bradycardia, delivered by repeat CD apgars 4,8, 60% of scar disrupted
Flamm 1988 ^21^ | USA Southern California Kaiser | Term: asymptomatic uterine window | No sign: 1/3 CD for failure to progress | NR | NR
| | Definition: small defects visualized at CD or palpated at VD
GOOD | | Term: true uterine rupture | Fetal distress: 1/3
| | Definition: defect involving entire uterine wall - symptomatic or requiring operative intervention | Abdominal pain: 1/3
| | Use: one CD performed for maternal pain classified as rupture had thin layer of peritoneum over scar; one with partial extrusion of fetus reported no sign of rupture, CD performed for failure to progress, both cases mother and infant did well.
Cowan 1994 ^25^ | USA | Term: bloodless uterine scar dehiscence | Abnormal fetal tracing (immediate and prolonged fetal bradycardia): 5/5 | Oxytocin: 3/5 UR (1 vertical, 1 2 prior CD) | NR
| | Definition: any defect in the preexisting cesarean scar with no maternal or fetal compromise
FAIR | | | | Epidural: 1/5 UR
| | Term: true uterine rupture
| | Definition: Scott's definition - “a complete separation of the wall of the pregnant uterus, with or without expulsion of the fetus, endangering the life of the mother or fetus”
| | Use: one rupture occurred at fundus with an intact uterine scar
Flamm 1994 ^20^ | | Term: uterine rupture | NR | NR | NR
| | Definition: any defect that involved the entire uterine wall or was symptomatic or required operative intervention
FAIR
Flamm 1990 ^22^ | USA Southern California, Kaiser | | “Variable or prolonged bradycardia most common warning sign” 7/10 had abnormal EFM | Oxytocin: 6/10 UR NS different from non-rupture | NR
FAIR
| | Use: 2/10 UR occurred following VD
Martin 1983 ^24^ | USA Universities in Mississippi and Alabama | Term: dehiscence | NR | NR | NR
| | Definition: nontraumatic separation of the uterine scar without bleeding or extrusion of fetus into wound
FAIR
| | Term: uterine rupture
| | Definition: scar separation with bleeding, hematoma formation, or extrusion of the fetus
Meehan 1989 ^50^ | Ireland | Term: bloodless dehiscence | Fetal distress: 1/1 UR | Oxytocin: NS | NR
| | Definition: dehiscence of uterine scar not associated with bleeding. It includes small ‘window’ defects and larger defects in which bleeding was not a feature | | Epidural: NS
FAIR
| | Term: True Rupture
| | | Definition: rupture of the uterine scar accompanied by intra-abdominal or vaginal bleeding
Meier 1982 ^57^ | USA Kaiser SanDiego | Term: scar dehiscence | No sign reported: 2/2 dehiscences found at CD | NR | NR
| | Definition: uterine scar separation
FAIR | | Use: incidentally noted at CD
Paul 1985 ^30^ | USA | Term: uterine dehiscence | 5 UR: | NR | NR
| USC | Definition: any palpable and/or visualized uterine defect. | 1. Abdominal Pain: 2/5; 2. Postpartum bleeding: 1/5; 3. No sign reported: arrest of dilation found; 4. Partial extrusion of fetus 1/5; 5. Abnormal fetal tracing: 1/5
FAIR | | Use: Further sub grouped into dehiscences that required no intervention and those that did require intervention, which were termed uterine rupture
| | | Comment: 25 CD for “fetal distress” - 18/751 TOL vs. 7/458 repeat CD (7/18 TOL emergent CD, 2/7 ERCD emergent CD)
Phelan 1987 ^23^ | USA | Term: uterine dehiscence | Fetal distress such as severe variable decelerations or prolonged fetal bradycardia most frequent sign | NR | NR
| USC | Definition: scar separation not requiring operative intervention
FAIR | | Term: Rupture
| | Definition: separation requiring operative intervention
| | | No cases of UR with maternal pain and changes in uterine tone
Stovall 1987 ^27^ | USA U of Tennessee | Term: dehiscence | Pain, vaginal bleeding, loss of uterine tone in the one case of UR | NR difference between UR and Non-UR | NR
| | Definition: palpable or visualized defect in previous uterine scar
FAIR | | Term: Uterine window
| | Definition: dehiscence not requiring surgical intervention or blood component replacement
| | Term: Uterine rupture
| | Definition: dehiscence requiring intervention
Case-control
Connolly 2001 ^53^ | | Term: scar dehiscence (further classified as partial and complete) | Fetal distress: 9/13 cases vs. 2/13 controls (OR 12.3 95% CI: 1.9–81) | Oxytocin | Maternal Age (mean):
| | Definition: NR | | Induction: 0/13 cases vs. 2/13 controls | 31.5 cases vs. 27.5 controls
FAIR | | Use: life threatening complication, “common symptoms include fetal distress, abdominal pain, scar tenderness, vaginal bleeding. Rarely massive hemorrhage and hypovolemic shock may be presenting symptom” | Scar tenderness: 8/13 cases vs. 0/13 controls
| | | | Augmentation: 10/13 cases vs. 3/13 controls (OR 4.5; 95% CI 0.9313–42.8) | (OR per 1 yr in age 1.35; 95% CI 1.03–2.19)
| | | Vaginal bleeding: 6/13 cases vs. 0/13 controls
| | | | | Parity (Mean):
| | | | | 3.15 cases vs. 2.85 controls
| | | | Epidural
| | | | 5/13 cases vs. 8/13 controls (OR 2.5; 95% CI 0.41–26.2) | (OR per 1-unit 1.59; 95% CI 0.17–18.9)
| | | | | Prior VD (before or after CD):
| | | | | 7/13 cases vs. 5/13 controls
| | | | | (OR 1.29; 95% CI 0.2175–11.86)
| | | | | GA (Mean):
| | | | | 39.3 cases vs. 40.3 controls NS
Leung 1993 ^54^ | | Term: uterine rupture | NR but included in case series data | Any Oxytocin: 54/70 cases vs. 39/70 controls (OR 2.7; 95% CI 1.2–6.0) | Age,Parity: NR
| | Definition: uterine scar separation and emergent laparotomy, acute fetal distress necessitating operative intervention, or acute maternal bleeding manifested by hypotension or shock | | | Prior VBAC:11/70 cases vs. 16/70 controls
FAIR
| | | | Induction = 11/70 cases vs. 10/70 controls | (OR 0.5; 95% CI 0.1–1.6)
| | | | | CD for CPD: 22/70 cases vs. 21/70 controls
| | | | Augmentation = 43/70 cases vs. 29/70 controls
| | | | | (OR 0.9; 95%CI 0.4–2.0)
| | | | Epidural | Unknown scar: 61/70 cases vs. 59/70
| | | | 29/70 cases vs. 19/70 controls
| | | | | (OR 1.3; 95% CI 0.4–3.1)>1CD: 23/70 cases vs. 11/70 controls
| | | | (OR 1.9; 95% CI 0.9–4.1)
| | | | | (OR 2.6; 95%CI 1.1 – 6.4)
Case series
Bujold 2002 ^56^ | | Term: complete uterine rupture | Fetal tracing abnormality: 20/23 patients | Oxytocin: 5/9 metabolic acidosis vs. 9/14 without acidosis NS | Maternal Age: NS difference between those with and without metabolic acidosis nor extrusion
| | Definition: “uterine scar separation with the overlying visceral peritoneum (uterine serosa) opened. All uterine ruptures had been confirmed at the time of emergency laparotomy. Records with uterine dehiscences (not defined) were excluded”
FAIR | | | Abdominal Pain: 1/23 first symptom (3 of abnormal tracings also reported pain)
| | | | Induction of labor: 3/9 with acidosis vs. 5/14 without NS
| | | Vaginal Bleeding: (1 of the patients with fetal tracing abnormality)
| | | | Epidural: 8/9 with acidosis vs. 12/14 without acidosis NS
| | | Hematuria: 2/23 first sign
Leung 1993 ^55^ | | Term: Uterine rupture | Fetal tracing abnormality: 91/99 | Oxytocin: NS difference in extrusion | Maternal Age: NS difference for extrusion
| | Definition: uterine scar separation and emergent laparotomy, acute fetal distress necessitating operative intervention, or acute maternal bleeding manifested by hypotension or shock | Pain: 13/99
FAIR | | | Vaginal Bleeding: 11/99 | Epidural: NS difference in extrusion | Parity: NS difference for extrusion
| | | | | Prior VBAC: 16 patients with prior VBAC had rupture
| | | | | CD for CPD: NS difference

NR=not reported; CD=cesarean delivery; VD=vaginal delivery; UR=uterine rupture; EFM=electro fetal monitor

Evidence Table 7. Uterine rupture details

Author Year Quality | Population | Uterine exploration | Asymptomatic Uterine Rupture TOL | Symptomatic Uterine Rupture TOL | Major Morbidity associated with Symptomatic uterine rupture TOL | Extrusion TOL | Asymptomatic Uterine Rupture ERCD | Symptomatic Uterine Rupture ERCD | Major Morbidity associated with symptomatic uterine rupture ERCD
Cowan 1994 ^25^ | All verticals excluded, unknown and more than 1 prior allowed | NR | NR | 5/593 | 1 fetus with severe neurologic sequelae | NR | NR | NR | NR
| | | | (.008%)
FAIR
Flamm 1994 ^20^ | All verticals excluded, unknown allowed | Discretion | NR | 39/5022 (.007%) | 0 maternal death | NR | NR | NR | NR
| | | | | 3/39 hysterectomy
GOOD | | | | | 0 neonatal deaths
Duff 1988 ^26^ | One prior LTCD, unknown not allowed | Yes | NR | 1/227 (.0044%) called dehiscence but symptomatic | 0 maternal or perinatal deaths | NR | NR | NR | NR
GOOD
Flamm 1988 ^21^ | LTCD and unknown and more than 1 prior | Yes (discretion?) | 11/1776 (0.6%) | 3/1776 (0.2%) (1/3 still had thin layer of peritoneum over scar) | 0 maternal death | 2 partial extrusions, both babies did well, 5-min Apgar >7, one mom required hysterectomy, 3rd peritoneum intact no maternal or neonatal sequelae | NR | NR | NR
| | | | | 0 neonatal death
GOOD | | | | | 1 hysterectomy
| | | | | ERCD: NR
Flamm 1990 ^22^ | LTCD, unknown, more than 1 prior | Majority no longer did | NR | 7/3957 (.0018%) | 0 maternal death | NR | NR | NR | NR
| | | | | 1 hysterectomy infant born vaginally Apgar 9
FAIR
| | | | | 3 Apgar <7(one cerebral palsy at 15months)
| | | | | 1 perinatal death related to rupture
Phelan 1987 ^23^ | Low vertical, unknown, LTCD allowed during 2nd year more than 1 allowed | Yes | 34/1796 (1.9%) | 5/1796 (0.3%) | 1 neonatal death, post rupture, scar intact, fetal Bradycardia = sign 4600g Apgar 0,0,3, none in transverse scar | NR | 7/314 (.022%) | NR | NR
FAIR
Stoval 1987^27^ | LTCD or LVCD allowed more than 1 allowed not clear what was done with unknown | Yes | 6/272 (.022%) | 1/272 (.0037%) | 0 maternal or fetal deaths | 1 expulsion mentioned, signs = tearing, pain, IUPC changes delay in diagnosis 20 min, total expulsion, Apgars 4,7, mom and baby did well, no intubation | NR | NR | NR
FAIR
Paul 1985 ^30^ | Not more than 1, low vertical, unknown and LTCD allowed | Yes | 11 (included in Phelan, 1987) | 5 (included in Phelan, 1987) | 2 fetal deaths (classical incision 3 prior CD, fundal incision) | 2 complete expulsions (one classical incision, one fundal incision) | see Phelan 1987 | NR | NR
FAIR
| | | | | 0 maternal deaths
| | | | | 0 hysterectomy
Martin 1983 ^24^ | One or more, includes low-vertical, no rupture occurred in the 76 with prior vertical | Yes | 1/101 successful | 1/61 failed | 0 fetal death | NR | 4/555 (.007%) | 2/555 | 0 maternal deaths
| | | 3/61 failed | (1/162=.006%) | 0 maternal death | | | (.0036%) | 0 perinatal deaths in UR group
FAIR | | | (4/162=.024%) | | no comment on hysterectomy
| | | | | | | | | 0 hysterectomy for UR
Meier 1982 ^57^ | LTCD, no unknown, no “obvious CPD”more than 1allowed | NR | 1/207 (.004%) | NR | 0 maternal or fetal deaths | NR | 1/62 | NR | NR
| | | | | | | (.016%)
FAIR
McMahon 1996 ^5^ | 1 LTCD, not clear what was done with unknown | NR | NR | 10/3249 (0.3%) | 2 perinatal deaths | NR | NR | 1/2889 | 0 maternal deaths
| | | | | 2 hysterectomy | | | (0.0%) | 0 perinatal deaths
GOOD | | | | | 0 maternal deaths | | | | 0 hysterectomy for UR

NR=not reported; LTCD=low transverse cesarean delivery; TOL=trial of labor; ERCD=elective repeat cesarean delivery LVCD=low vertical cesarean delivery; CPD=cephalo pelvic disproportion; IUPC=intrauterine pressure catheter

Evidence Table 8a. Patient satisfaction - good or fair quality studies

Author Year Quality | Country Setting | Study design Years of study Research objective | Population | Parity and previous history | TOL resulting in vaginal delivery | TOL emergency CD | ERCD
Cross-Sectional
Fawcett 1994 ^84^ | USA General hospital in Pennsylvania small town | Cross-sectional | Women who completed a VBAC. | TOL: | 70% would choose VBAC again | NA | NA
| | | | 29/32 (90.6%) had 1 prior delivery
FAIR | | BEQ 12–48 hours after delivery | Not clear if all eligible patients were recruited and number who refused. | | 30% undecided
| | | | 3/32 (9.4%) 2 or more deliveries
| | Inferred 1991-1992 | | | Greater proportion felt relieved/excited & in control during the vaginal delivery. Patients perceived they worried more about their infant with their prior CD.
| | | | ECRD:
| | Compare women's reactions to their VBAC reactions to their previous CD experience | TOL: Mean age 28.8 yrs (SD 5.5 yrs) | NA
| | | ERCD: Age, race
| | | | NA
Erb 1983 ^83^ | Canada Communities throughout Manitoba | Cross-sectional | Parents who had first or repeat CD who responded to a media campaign. | TOL: NR | NA | For mothers with repeat CD: | For repeat CD in general:
| | | | | | 35% wanted help coping with feelings | 35% wanted help coping with feelings
FAIR | | Responders to media campaign. | | ECRD: NR
| | | | | | 90% felt relieved | 90% felt relieved
| | | | | | 90% joyous | 90% joyous
| | 1979-1982 | TOL: Age, race NA | | | 35% frustrated | 35% frustrated
| | | | | | 34% disappointed | 34% disappointed
| | Assess women's feelings after first and repeat CD, 1–18 months after delivery | ECRD: Parents mean age 29 yrs | | | 20% angry | 20% angry
| | | | | | 18% failure as women | 18% failure as women
| | | | | | For fathers:
| | | | | | 94% felt joyous
| | | | | | 90% relieved
| | | | | | 52% felt fearful for baby and mother
| | | | | | 32% left out

TOL=trial of labor; CD=cesarean delivery; ERCD=elective repeat cesarean delivery; BEQ=Birth Experience Questionnaire; VBAC=vaginal birth after cesarean;

Evidence Table 8b. Patient satisfaction- poor quality studies

Author Year Quality | Country Setting | Study design Years of study Research objective | Population | Exclusion Criteria | Patients attempt TOL | TOL resulting in vaginal delivery | TOL emergency CD | ERCD
Cohort
Mould 1996 ^86^ | University college hospital. CD rate of 18%. | Prospective cohort Clinicians interviewed women 2–3 days after delivery and at their six week checks | Recruited 102 of 104 women who had an emergency CD. 26 of the 102 had prior CD. | NR | NA | NA | INVALID: | INVALID:
| | | | | | | Emergency CD not just VBAC: | ERCD not just VBAC:
POOR
| | | | | | | | 20/29 (69%) reported having medium or above say in decision
| | | | | | | 37/73 (51%) reported having medium or above say in decision
| | 1994
| | | | | | | | 2/29 (7%) reported no say
| | Assess the extent to which women contribute to the decision for a CD and their satisfaction. | | | | | 22/73 (30%) reported no say
Abitbol 1993 ^85^ | USA | Prospective cohort | Recruited all pregnant patients with prior CD who met ACOG guidelines. Refused not reported. | Patients who didn't meet ACOG standards. 38/364 (10.4%) | INVALID: | INVALID: | INVALID: | INVALID:
| VBAC program in NY hospital | Clinician and social worker interviewed women before and 2–3 days after delivery | | | 99/187 (53%) | all VBACs:
POOR | | | | | | 88/122 (68%) satisfied | 16/65 (25%) satisfied | 116/125 (93%) satisfied
| 62% service patients | | | | | 64/80 (80%) no complications
| | 18 month collection, no dates
| | | Total group:
| 38% private | | 45% white | | | 19/42 (45%) with complications
| | Investigate reasons for TOL or ERCD | 34% black
| | | 15% Latin American
| | | 6% other

TOL=trial of labor; CD=cesarean delivery; ERCD=elective repeat cesarean delivery; ACOG=American College of Obstetricians and Gynecologists; VBAC=vaginal birth after cesarean

Evidence Table 9a. Economic evaluations- good or fair quality studies

Author Year Quality | Country Setting | Study type | Perspective | Comparisons | Primary outcomes | Cost data sources Cost unit Discount rate (base) | Results | Sensitivity analyses | Generalizability | Missing from analysis | Comments
Chung 2001 ^87^ | USA | Cost-utility study | Society | TOL and ERCD | Cost per QALY | Resources used at medical center, national costs, adverse event treatment costs | If VBAC rate is | Extensive one-way sensitivity analyses. | High: most data based on national not local sources. | Cost for medical staff on standby for TOL, zero rates for fecal and urinary incontinence. | Extensive and carefully planned economic evaluation addressing societal perspective allowing comparisons to other resource demands. Including costs of standby staff for TOL would likely require higher VBAC rate for cost-effectiveness of TOL. Before cost-effectiveness recommendations are based solely on VBAC success probabilities, two-way sensitivity analyses should be performed.
| | | | | | | 1. 65%:; ERCD costs less with more QALYs; 2. 65%–74%:; ECRD more cost effective(<$50,000/QALY); 3. 74%–76%:; ECRD more QALYs but >$50,000/QALY; 4. 76%:; TOL costs less with more QALYs
GOOD | | | | | | | | Sensitive parameters:; 1. infant mortality probability; 2. VBAC success probability; 3. moderate neonate morbidity costs; 4. urinary incontinence probability
| | | | | | USA dollar
| | | | | | 3%
Grobman 2000 ^88^ | USA Illinois | Cost effectiveness | Payer or health care system | TOL and ERCD | Neonatal neurologic injury or death averted, maternal deaths, CD, costs | Literature, expert opinion and hospital charges | To prevent 1 major adverse neonatal outcome (cerebral palsy or neonatal death) costs $2.4M, 0.1 maternal deaths, 74 maternal morbid events, and 1591 CD. | Costs to prevent 1 major neonatal adverse event > $1M for all parameter values. | High | Many neonatal adverse events (low frequency or less severe), ICU time seems underestimated also. | No societal perspective. No pooled effectiveness (e.g. QALY). Broad range of included complications. 1999 US dollars. Included potential for multiple pregnancies. Assumptions about subsequent pregnancies not clear (appear to use same assumptions as for index pregnancy). Probabilities for subsequent pregnancies likely change although data for probabilities of subsequent pregnancies may be problematic. Other reasonable simplifications made to develop model.
FAIR
| | | | | | US dollar
| | | | | | 3%

TOL=trial of labor; ERCD=elective repeat cesarean delivery; QALY=quality adjusted life year; VBAC= vaginal birth after cesarean; CD=cesarean delivery

Evidence Table 9b. Economic evaluations- poor quality studies

Author Year Quality | Country Setting | Study type | Perspective | Comparisons | Primary outcomes | Cost data sources Cost unit Discount rate (base) | Results | Sensitivity analyses | Generalizability | Missing from analysis | Comments
DiMaio 2002^99^ | USA Florida | Cost analysis | Hospital (?) | TOL and ERCD | Total Cost | Hospital cost accounting data | Lower costs for TOL than for ERCD for mother, neonate, and combined | None | Limited data based on 1 hospital for 1 year | Details on costs, rehospitalizations, MD costs. | No comparison of baseline risk. Number of emergency RCDs not stated. Study does not evaluate cost-effectiveness (no effectiveness measure as life year). Does use costs rather than charges.
POOR
| | | | | | US dollar
| | | | | | NA
Clark 2000 ^94^ | USA | Cost benefit analysis | Payer (?) | TOL and ERCD | Total provider costs | Cost (charges) from health plan | Small savings for TOL (<$500). If include cerebral palsy as outcome, TOL costs more (<$220) | Only rate of long-term neonatal costs | Limited by cost data from one health care system. | Complications from ERCD, MD costs. | Omitted complications from ERCD. Limited focus of analysis. Included only one long-term outcome.
POOR
| | | | | | US dollar
| | | | | | ?
Chuang 1999^93^ | USA | Cost and expected utility model | NR | TOL and ERCD | Expected utility and costs | Costs (charges?) from one hospital in Boston MA | ECRD had higher expected utility and lower expected cost for TOL rates < 70% | Model sensitive to utilities for ERCD, successful and failed TOL | Limited by cost data from one hospital. | Perinatal costs / outcomes, maternal death | Broad categories of complications only. No incremental analysis of cost and consequences.
POOR
| | | | | | US dollar
| | | | | | NA
Shorten 1998 ^96^ | Australia | Cost analysis | Health care system | TOL and ERCD | Total average costs | Average DRG level costs | TOL reduced costs by ˜30% compared to ERCD | Breakeven point (equal cost for TOL and ERCD) at 68% emergency RCD | Limited sample size; Australian costs may differ from USA | Societal costs, utilities, effectiveness measure | Results based on experience of 170 women with prior CD. Validated comparison to 2 other data sets (1 lacked infant outcome data). Reduction of routine admission to Special Care Neonatal Nursery would increase TOL advantage. Data set relatively small; few rare complications occurred (unclear for UR).
POOR | | | | | | Australian dollar
| | | | | | NA
Traynor 1998 ^95^ | USA Illinois | Cost accounting | Hospital | 50 consecutive women each with TOL, ERCD, women with prior vaginal birth only | Total hospital charges | Hospital charge data | Mean (SD) gross patient charges: TOL $5820 ($1609), ERCD $6785 ($771), $4685 ($966) | None | Limited | | Private insurance. Excluded women if newborn treated in special care nursery. VBAC rate 84%. Excluded perinatal costs. No complications observed. No MD fees.
POOR | | | | | | US dollar
| | | | | | NA
Finkler 1997 ^89^ | USA California | Correlation analysis | Hospital | Delivery mode with resource costs, case mix, maternal LOS, neonatal morbidity | Correlation coefficients | Direct payroll and non-payroll expenses for obstetrics | As physicians lack incentive to choose mode of delivery, there were no significant correlations of Csx rates with cost per delivery | None | May be unique to setting like Kaiser-Permanente (no incentive related to mode of delivery | None | Costs directly to levels and mix of staffing, case mix and operation scale. Risk adjustment included. Cost estimates excluded perinatal costs (e.g. nursery). Results may not apply in a fee-for service environment. Included midwives on staff and scheduled coverage of physicians and midwives.
POOR
| | | | | | US dollar
| | | | | | NA
Keeler 1996 ^90^ | USA California | Retrospective Cohort | Insurer | Rate of CD before and after equalization of MD fees for Csx and VD | CD rates | MD fees paid by insurer | No change in overall CD rate, 7% increase in rates of breech presentation | None | Fee for service insurers | None | CD rates post fee equalization all within confidence limits of pre equalization period. No overall effect. A few MD's left plan following equalization.
POOR | | | | | | US dollar
| | | | | | NA
Spellacy 1991 ^91^ | USA California | Economic model | Society (?) | Cost savings from reward / penalty system for VBAC | Net costs | Rough estimates | Paying physicians 10% more for VBAC than repeat CD will save billions | None | High | None | “Back-of-the-envelope” estimate of reward to MD for VBAC. Very simplistic. May need to increase by >10% as costs of VBAC to MD may exceed 10% difference in charges.
POOR | | | | | | US dollar
Hadley 1986 ^97^ | USA Pennsylvania | Retrospective Cohort | Payer (?) | TOL and ERCD | Total charges | Patient billing data | TOL lower average charges by $1960 | None | Limited data based on 1 hospital | Charge details, costs, insurance type, long term effects | Small cohort (40 TOL and 35 ERCD). No long-term effects included. Conservative TOL criteria.
POOR | | | | | | US dollar
| | | | | | NA
Flamm 1985 ^98^ | USA California | Cost analysis | Payer (?) | TOL and ERCD | Total costs | Approximation for national data | Assuming TOL saves $300 per patient, could save up to $600M / year | None | Only crude approximation | Most details, adverse outcomes | Back of the envelope estimate of cost savings in US. Assumes TOL is appropriate for all prior CD patients. Ignores any complications.
POOR
| | | | | | US dollar
| | | | | | NA
Shy 1981 ^92^ | USA | Cost model | Payer (?) | TOL and ERCD | Mortality and direct medical costs | Blue Shield charge estimates | Fewer deaths (25%) with planned TOL. Higher costs (26%) with ERCD | None for cost model. | Limited by year of model. | All morbidity (including AE's) | No comparison of mortality and costs. Cost data very limited (only hospital, MD, anesthesiologist and neonatal ICU). Results dated. No sensitivity analyses on costs.
POOR
| | | | | | US dollar
| | | | | | NA

TOL=trial of labor; ERCD=elective repeat cesarean delivery; NA=not applicable; MD=medical doctor; RCD=repeat cesarean delivery; CD=cesarean delivery; UR=uterine rupture; ?=inferred, not stated

Evidence Table 10. Health care resources- poor quality studies

Author Year Quality | Country Setting | Years of study Research objective | Subject eligibility: Included (I)/Excluded (E) | Study Group | Sample size (enrolled/complete) | Measure | Estimate | Notes
Systematic Reviews
Roberts 1997 ^117^ | USA | 1980-1996 | (I) Article in Medline or in references/(E) Developing country | TOL | Maternal/neonatal: | Maternal/Neonatal LOS (days) | 2.94/2.99 | No risk adjustment, no standard errors
| | Comparison of TOL and ERCD | | | 10,428/379
POOR
| | | | ERCD | 3,597/599 | | 4.11/4.96
Prospective Cohort Study Designs
Flamm 1994 ^20^ | USA | 1990 | (I) Delivery at participating hospital, woman with prior CD/(E) Spontaneous or therapeutic abortion, left provider, incomplete records. | TOL | 5,022 | Mean (SD) maternal LOS (hours) | 57.2 (31.1) | P-value<0.0001. Risk adjustment performed but no details provided.
| CA | Evaluate outcomes in a cohort of women with prior CD
POOR
| | | | ERCD | 2,207 | | 84.9 (26.3) | Predictors of LOS included medical center, TOL, prior scar type unknown, no post-partum fever, no transfusion, 5-miunte Apgar>6 and no tubal ligation
Miller 1992 ^173^ | Australia | 1989-1990 | (I) Women with at least 1 prior CD who delivered in hospital | ECD | 193 | Maternal (SD) LOS (days) | 7 (2.0) | No adjustment for baseline risk or other potential confounders
| | Assess outcomes in women with prior CD
POOR
| | | | Emergency CD | 45 | | 7.0 (1.6)
| | | | VBAC | 66 | | 4.9 (2.0)
Phelan 1987 ^23^ | USA | 1982-1984 | (I) 1 or 2 prior CD, unknown scar type/(E) Known classical scar, multiple gestation, malpresentation | Successful TOL | 1,465 | Mean maternal LOS (days) | 2.2 | No risk adjustment. No test of significance.
| CA | Evaluation of risks associated with TOL
POOR
| | | | Failed TOL (RCD) | 331 | | 4.2
| | | | No TOL: VD | 69 | | 2.3
| | | | No TOL: ERCD | 314 | | 4.2
| | | | No TOL: indicated RCD | 464 | | 4.2
Stovall 1987 ^27^ | USA | 1985-1986 | (I) Patients with prior CD (lower uterine segment transverse or vertical)/(E) Classical, previous low vertical in pre-term pregnancy, lower uterine transverse or vertical scar, or failed TOL after CD. | Vaginal delivery | 216 | Maternal LOS (days) | 2.1 | No summary stats beyond mean LOS. No baseline statistics
| TN | Year-long prospective study of “liberalized” VBAC criteria
POOR
| | | | CD | 56 | | 5.3
Retrospective Cohort Study Designs
Anonymous 1998^103^ | USA | 1996 | (I) Metropolitan Life Insurance Co. Group Health enrollee | CD | 10,305 | Maternal LOS (days) | 3.01 | Based on insurance claims data
| | Estimate LOS for insurance claims
POOR
Anonymous 1998^103^ | | | | Uncomplicated VD | 40,697 | | 1.71 | LOS may be impacted by insurance coverage
POOR | | | | VBAC | 887 | | 1.76 | Based on insurance claims data
| | | | CD/Indemnity | | | 3.12 | LOS may be impacted by insurance coverage
| | | | CD/Preferred Provider | | | 3.07 | Sample size by insurance type and mode of delivery not provided
| | | | CD/Point of Service | | | 2.94
| | | | CD/HMO | | | 2.87
| | | | Uncomplicated VD/Indemnity | | | 1.83
| | | | Uncomplicated VD/Preferred Provider | | | 1.72
| | | | Uncomplicated VD/Point of Service | | | 1.62
| | | | Uncomplicated VD/HMO | | | 1.60
| | | | VBAC/Indemnity | | | 1.89
| | | | VBAC/Preferred Provider | | | 1.85
| | | | VBAC/Point of Service | | | 1.66
| | | | VBAC/HMO | | | 1.74
Curtin 1997 ^167^ | USA | 1995 | (I) Pregnancy in non-federal short-stay hospital | 1988 | | Maternal LOS for RCD/% 4 days or more | 4.3/71.7% | Exact number of women with prior CD not reported.
| | Summarize data from 1995 National Hospital Discharge Survey
POOR
| | | | 1995 | | | 3.3/21.0% | No adjustment for baseline risk or other potential confounders
Hook 1997^207^ | USA | 1992-1993 | (I) Women with prior CD, singleton delivery, >36 weeks gestation/(E) 18 neonates with congenital malformations | ERCD | 497 | Mean (SD) LOS (days): maternal/neonatal | 4.5(1)/4.5(2) | No adjustment for baseline risk or other potential confounders
| OH | Compare neonatal outcomes for ERCD and TOL
POOR
| | | | TOL | 492 | | 3.6(1)/3.7(2)
| | | | VBAC after TOL | 336 | Mean (SD) neonatal LOS (days) | 3.1 (2) | P-value<0.01 for comparison of LOS between VBAC and failed TOL
| | | | RCD after failed TOL | 156 | | 4.8 (2)
Hanley 1996^208^ | USA | 1984 | (I) Women with prior CD and either RCD or VBAC/(E) Missing record | ERCD | 107 | Maternal median (min., max.) LOS (days) | 3 (2–6) | No risk adjustment
| NJ | Describe contributions of various factors to overall RCD rate
POOR
| | | | Failed VBAC | 72 | | 4 (3–8) | Significant differences between elective and other 2 (p-value<0.05)
| | | | Indicated RCD | 53 | | 4 (2–14)
Taffel 1991^209^ | USA | 1989 | (I) Birth in non-federal general and special short-stay hospitals | RCD | | Maternal LOS (days) | 4.2 | No risk adjustment, no standard errors
| | Monitor annual trends in pregnancy outcomes
POOR
| | | | Primary CD | | | 4.8
| | | | VD (all) | | | 2.4
Eriksen 1989^210^ | USA (military) | 1985-87 | (II) Patients with prior CD (and age and parity-matched VD)/(E) Not eligible for TOL | VBAC | 69 | Mean (SD) maternal LOS (days) | 3.1 (1.6) | VBAC differs form RCD (p<0.0001) and from VD (p=0.0004)
| | Evaluate outcomes in a cohort of women with prior CD
POOR
| | | | RCD | 68 | | 5.4 (2.0)
| | | | VD no prior CD | 69 | | 2.4 (0.84)
| | | | VBAC | | Mean (SD) neonatal LOS (days) | 2.73 (1.3) | VBAC differs form RCD (p<0.0001)
| | | | RCD | | | 4.58 (2.23)
| | | | VD no prior CD | | | 2.16 (0.66) | No risk adjustment
Flamm 1988 ^21^ | USA | 1984-85 | (I) Women with prior CD who volunteered for TOL | Success-ful TOL | 1,314 | Mean (SD) maternal LOS (days) | 2.2 (0.81) | No risk adjustment
| CA | Evaluate outcomes in a cohort of women with prior CD
POOR
| | | | Failed TOL | 462 | | 4.6 (1.29)
| | | | ERCD | | | 4.3 (NR)
Placek 1988 ^169^ | USA | 1980-85 | (I) Patients in non-federal general and special short-stay hospitals | Primary CD | | Maternal LOS (days) | 6.0 | National data. No risk adjustment, no standard errors. VBAC significantly short LOS than either CD category (not other VD)
| | Summarize national survey data on delivery methods
POOR
| | | | RCD | | | 5.6 | RCD equals all repeat CD including indicated, elective, or failed TOL
| | | | VD (not VBAC) | | | 3
| | | | VBAC | | | 3.2
Placek 1988 ^211^ | USA | 1986 | (I) Patients in non-federal general and special short-stay hospitals | Primary CD | | Maternal LOS (days) | 5.2 | National data. No risk adjustment, no standard errors. VBAC significantly short LOS than either CD category (not other VD)
| | Summarize national survey data on delivery methods
POOR
| | | | RCD | | | 4.7
| | | | VD (not VBAC) | | | 2.6
| | | | VBAC | | | 2.7
Hadley 1986 ^212^ | USA | 1982-83 | (I) Prior CD, eligible for TOL/(E) >1 Prior CD, Non-low transverse scar, twins, prior uterine surgery, no consent, fetal macrosomia | ERCD | 35 | LOS (days) mother/infant | 5.9/6.1 | Maternal readmissions 2 TOL and 1 ERCD, ER visits TOL 2
| PA | Compare TOL to ERCD
POOR
| | | | Attempted TOL | 40 | | 3.6/3.7
| | | | Successful TOL | 32 | | 3.1/3.4
| | | | Failed TOL | 8 | | 5.6/6.0
Boucher 1984 ^213^ | USA | 1980 | (I) Delivery at study hospital/(E) Chart lost | Overall TOL | 308 | Operative time (min)/maternal LOS (days) | NA/NR | No risk adjustment
| CA | Evaluate outcomes in a cohort of women with prior CD
POOR
| | | | Successful TOL | 240 | | NA/NR | All groups not compared,only RCD LOS data only reported
| | | | Failed TOL (RCD) | 68 | | 68.8 (23.9)/5.0 (1.4)
| | | | non-TOL | 544 | | NR/NR
| | | | Elective CD | 140 | | 78.2 (26.1)/5.0(1.5)
| | | | Labor&ROM | 404 | | NA/NR
| | | | Labor&ROM: RCD no TOL | 371 | | 76.9 (46.5)/4.9 (1.6)
| | | | Labor&ROM: VD | 33 | | NA/NR
Studies of Case Series
Iglesias 1991 ^161^ | Canada (Alberta) | 1985-89 | (I) Pregnant mother with prior CD eligible for TOL | 1985 | 27 | Maternal LOS (days) successful TOL/failed TOL | 5.0/none | No risk adjustment or standard deviations. Small n's
| | Success of TOL in rural hospital
POOR
| | | | 1986 | 28 | | 4.7/6.0
| | | | 1987 | 24 | | 5.6/5.0
| | | | 1988 | 25 | | 4.1/5.5
| | | | 1989 | 33 | | 3.3/6.2
Surveys
Mor-Yosef 1990 ^160^ | Israel | 3 months in 1983-84 | (I) Singleton live delivery with previous CD/(E) Delivery before 26 weeks gestation, fetal malformations, home deliveries, multiple deliveries, >1 prior CD, incomplete data | VBAC | 596 | Mean (SD) maternal LOS (days) | 3.8 (1.8) | No risk adjustment. Difference not significant
| | National survey to assess VBAC
POOR
| | | | RCD | 484 | | 7.2 (1.8)

TOL=trial of labor; ERCD=elective repeat cesarean delivery; CD=cesarean delivery;LOS=length of stay; VBAC=vaginal birth after cesarean; RCD=repeat cesarean delivery; SD=standard deviation; HMO=health maintenance organization; ROM=rupture of membranes

Evidence Table 11. Individual factors - good or fair quality studies

Author Year Quality | Country Setting | Study category Years of study Research objective | Population | Exclusion criteria | Eligible/attempting TOL VB | Factors adjusted for through Multivariate Analysis
Randomized Controlled Trials
Fraser 1997 ^106^ | Canada/USA | Nonclinical | Women with one PCD. | Previous VBAC, a classic CD or myomectomy scar, multiple gestation. | 1284/905 | RCT - assumed equal distribution of confounding factors
| 11 Canadian hospitals | 1992-1994
FAIR | | To assess whether, for women with PCD, a prenatal education and support program promoting VBAC delivery increases the probability of VD. | Stratified by motivational level (low or high), and then randomly assigned | | 649
| 1 US hospital
| | | Group 1: verbal
| | | Group 2: document
Prospective Cohort
Flamm 1997 ^36^ | USA | Predictive tool | Women with a PCD. | ERCD, incomplete data | 7229/5003 | Age, VD history, PCD indication, cervical effacement/dilation at admission
| 10 Southern California Kaiser Permanente hospitals | 1990-1992
GOOD | | To develop a scoring system to predict the likelihood of vaginal birth in patients undergoing a TOL after PCD using factors known at the time of hospital admission. | | | 3746
Stronge 1996 ^109^ | Ireland | Characteristics | Women with one PCD | ERCD, NR | 239/195 | Head engagement, dilation of cervix of more than 2cm, the use of oxytocin for augmentation
| National Maternity Hospital Dublin | 1992-1994
FAIR | | To determine if routine measured clinical factors were associated with mode of delivery. | | | 150
Retrospective Cohort
Caughey 1998 ^112^ | USA | Characteristics | Women with exactly one PCD and one previous VD. | Unavailable chart information, no previous VD, more than one previous VD or CD. | NR/800 | Maternal age, epidural use, induction, birth weight, gestational age, and previous indication for CD
| Brigham and Women's Hospital Boston, MA | 1984-1996
GOOD | | To examine the effects of order of previous modes of delivery on the rate of CD and duration of a TOL among women with a history of one PCD and one previous VD. | | | 700
| | | Compared:
| | | Group 1: PCD followed by VD (VD last)
| | | Group 2: VD followed by PCD (CD last)
Jakobi 1993 ^37^ | Israel | Predictive tool | Women with one PCD. | Unknown scar, scar other than LTCS, nonvertex presentation, multiple gestation, ruptured membranes >16hrs and without contractions or >42wks. | NR/261 | Parity, VD history, PCD indication, cervical dilation/effacement/station at previous CD, cervical dilation/effacement/station at admission, rupture of membranes, birth weight
| Rambam Medical Center Hafia | Years NR
FAIR | | To examine 15 previously identified prognostic factors, in order to evaluate the predictive value and relative importance of these factors and whether they could be used for a better selection of patients for VBAC. | | | 215
McNally 1999 ^107^ | Ireland | Medications/characteristics | Women with one previous lower segment CD who had been induced with oxytocin and amniotomy. | Fetal distress upon induction | NR/103 | Age, parity, VD history, gestational age, cervical effacement/dilation, prostaglandin administration, epidural analgesia, certainty of dates, presence or absence of meconium at amniotomy, birth weight
| Coombe Women's Hospital Dublin | 1993-1994
FAIR | | The aim of this study was, after induction of labor in women with a PCD, to compare the outcome in women with a history of VD with women who had never had a VD. | | | 82
| | | Compared:
| | | Group 1: previous VD
| | | Group 2: no previous VD
Weinstein 1996 ^42^ | Israel | Predictive tool | Women with one PCD. | ERCD, incomplete records, classic or unknown scar, hx of rupture, absolute CPD, previa, fetal malpresentation incompatible with a safe VD | 572/471 | Maternal age, VD history, bishop score, fetal weight at CD, fetal weight, PCD indication
| Hebrew University Jerusalem | 1981-1990
FAIR | | To evaluate the relative weight of the different variables that may influence the chances of vaginal birth after one PCD, with the aim of developing a predictive score for success of such a trial. | | | 368
Zelop (a)2001^110^ | USA | (a) characteristics | Women with one PCD | ERCD, preterm, multiple gestation, more than one PCD. | NR/2775 | PCD indication, birth weight
| Brigham and Women's Hospital Boston, MA | 1984-1996
FAIR | | To compare the outcomes in women with PCD at or before 40 weeks' gestation with those delivering after weeks. | Compared: | | 1923
| | | Group 1: 37 to 40 weeks gestation.
| | | Group 2: after 40 weeks gestation.
Zelop (b)2001^111^ | USA | (b) characteristics | Women with one PCD undergoing a TOL after 24 weeks. | ERCD, preterm | NR/2749 | Epidurals, maternal age, race, receiving public assistance, year of delivery, PCD indication, type of uterine hysterotomy
| Brigham and Women's Hospital Boston, MA | 1984-1996
FAIR | | To compare the outcomes at term of a TOL in women with PCD who delivered neonates weight >4000g versus women with those weighing <4000g. | | | 1912
| | | Compared:
| | | Group 1: >4000g
| | | Group 2: <4000g
Case Control
Macones 2001 ^38^ | USA | Predictive tools | Women with PCD. | Unknown scar, vertical scar | NR/400 | Substance abuse, parity, prior VBAC, weight gain during pregnancy, prepreganancy BMI, years since last delivery, cervical dilation at admission, need for augmentation
| University of Pennsylvania Philadelphia, PA | 1994-1998
FAIR | | To assess the utility and effectiveness of a neural network for predicting the likelihood of success of a TOL, relative to standard multivariate predictive models. | Compared: | | 300
| | | Group 1: VBAC
| | | Group 2: Failed TOL
Pickhardt 1992^39^ | USA | predictive tools | Women with a PCD. | Incomplete data or unobtainable charts | NR/312 | Race, age, height, weight, gravidity, parity, estimated fetal weight, number of PCD, cervical dilation/effacement/station at admission, modified bishop score, estimated gestational age, number of previous VD, PCD indication, spontaneous rupture of membranes, placental grade, fluid status, spontaneous uterine activity
| Mississippi Medical Center Jackson, MS | 1989
FAIR | | To determine if there useful and valid predictors before parturition, of successful or unsuccessful vaginal birth after previous cesarean birth that could be used to enhance the obstetric care of a patient and her pregnancy. | Compared: | | 212
| | | Group 1: VBAC
| | | Group 2: Failed TOL
Case series
de Meeus 1998 ^104^ | France | characteristics | 43 women with one PCD and current singleton pregnancy in breech presentation, attempting ecv. | ERCD, <36weeks, rupture membranes, suspected IUGR, third-trimester bleeding, vertical uterine scar, obvious macrosomia, abnormal placental insertion, uterine malformation, or abnormal FHT on admission. | 43/38
| Poitiers University Hospital | 1988-1995
FAIR | | To determine if external cephalic version (ECV) is a reasonable alternative to repeat CD in case of breech presentation. | | | 19
Flamm 1991 ^105^ | USA | characteristics | Women undergoing external cephalic version for breech presentation. | ERCD, ruptured membranes, labor, suspected IUGR, third-trimester bleeding, oligohydramnios, previous classical or vertical incision, or suspicious fetal monitoring pattern on admission. | NR/56
| Kaiser Permanente Centers (Los Angeles, Anaheim, Riverside) | 1985-1990
FAIR | | To examine external cephalic version in those with breech presentation following one or more PCD. | | | 30
| | | Compared:
| | | Group 1: with one or more PCD
| | | Group 2: no PCD
Schacter 1994^108^ | Israel | characteristics | Women with a PCD who at 36–37weeks gestation have malpresentation (breech or transverse lie), for which they undergo ECV. | Previous metroplasty, low lying placenta, oligohydramnion, ruptured membranes | 20/11
| Kaplan Hospital Jerusalem | 24 month period - Years NR
GOOD | | To describe our limited experience with external cephalic version (ECV) from breech to vertex presentation at term, with the use of ritodrine tocolysis, in women who had undergone a PCD. | | | 6

TOL=trial of labor; VBAC=vaginal birth after cesarean; CD=cesarean delivery; PCD=previous cesarean delivery; ERCD=elective repeat cesarean delivery; NR=not reported; RCT=randomized controlled trial

Evidence Table 12a. Patient preferences - good or fair quality studies

Author Year Quality | Country Setting | Study design Intervention Years of study Research objective | Eligibility Population | Education about VBAC? | Delivery Decisions/Attempt TOL/Eligible | VBAC/TOL | ERCD | Reasons or factors for elective repeat CD | Information sources for elective repeat CD
Randomized Controlled Trial
Fraser 1997 ^106^ | CANADA & USA | RCT | All women with CD, single low transverse scar, gestational age >28 weeks. Read, write English or French. | Document group: VBAC pamphlet at 21 weeks. Verbal group: Research nurse assessed the patient's motivation for VBAC and the attitudes of her physician and of her social network (husband, friends etc.) at 21 weeks. Addressed questions about pain and sterilization. 4–8 wks later, resource person provided support, etc. | Document Group: | Document Group: | Document Group | No differences between treatment groups. Women with low motivation for VBAC at baseline (21 weeks) were 3 times more likely to have an ERCD than those with high motivation. Women with low motivation were more likely to have already experienced labor, were less likely to be planning future pregnancies, were more likely to be seeking a tubal ligation. | Collected but not reported.
| 11 Canadian hospitals | Randomized to receive pamphlet on VBAC benefits or prenatal education & support program. Questionnaire 1–3 days after delivery | | | 440/634 (69.4%)
GOOD | | | | | Verbal Group: | 310/440 (70.5%) | (150/634 (23.7%)
| 1 US hospital | | | | 465/641 (72.5%)
| VBAC rate 39.3%. | | Recruited 1275/1301 | | | Verbal Group: | Verbal Group:
| | | TOL: Average age 31 (SD 5 yrs) | | | | 137/641 (21.4%)
| | | | | | 339/465 (72.8%)
| | 1992-1994 | ERCD: Average age 31 (SD 5 yrs)
| | Assess the effect of a prenatal education program on proportion of women attempting TOL
Cohort
Kirk 1990^118^ | USA | Nonrandomized trial | NR | NR but 55% of TOL patients knew about VBAC before current pregnancy; 49% of ERCD also knew. | NR | NR | NR | Reasons: 12/48 (25%) danger of TOL to mother; 14/48 (29.2%) danger of TOL to baby; 19/48 (39.6%) avoid labor pain; 13/48 (27.1%) convenience; 25/48 (52.1%) low chance of vaginal delivery; 18/48 (37.5%) knew what to expect. 15% of patients selected ERCD in before pregnancy. Another 25% decided in first half of pregnancy. 20% of patients thought they had at least a 75% chance of a vaginal delivery with a TOL. | 52% of women made decision although most women (79%) rated the physician as a strong influence. Another 31% of women and physicians together made decision. 72% of women rated their husbands as a strong influence.
| 1 teaching hospital (a) (primary CD rate 14.8%, repeat 3%) | Questionnaire during postpartum stay. Mailed follow-up to nonresponders. | TOL: Mean age 27.6 yrs
FAIR | | | Hospital a: 20% nonwhite
| | | Hospital b: 2.4% nonwhite
| | | ERCD: Mean age 30.6 years
| | 1988-1989 | Hospital a: 20% nonwhite
| | Determine who makes decisions for CD and why those decisions are made. | Hospital b: 2.4% nonwhite
| 1 metropolitan hospital (b) (primary CD rate 13.6%, repeat 5.4%)
Kline 1993 ^119^ | USA | Prospective cohort | Women with 1+ prior CD. | NR | 205/584 (35.1%) | 153/205 (74.6%) | 873/1078 (80.9%) | For 120 patients: 31.6% patient desire; 13.3% MD advice; 9.1% Patient & MD; 45.8% medical reason. | NR
| Private nonteaching hospital in MO CD rate 28.5% (18.3% primary, 10.2% repeat) | Patients interviewed before delivery and delivery data collected afterward from records | Consecutive patients (when PI was chief resident on call) first then recruited elective repeat patients. Refused not reported.
FAIR
| | 1988-1990
| | Determine the reasons for the birth choice. | TOL: Mean 30.2 yrs (SD 5.0) (n=121 successful TOL)
| | | ECRD: Mean 30.1 years (SD 4.6) (n=120)
McClain 1985;1987;1990^120^ | USA | Prospective cohort. | Women with prior CD at one of three hospitals. Recruited 102 of 125 (80%) | Education on TOL. | 65/100 (65%). Also, 4/100 (4%) undecided but who had TOL. | 39/69 (56.5%) | 28/100 (28%). Also 3/100 (3%) who were undecided but had elective repeat CD. | 19/41 (46.3%) of nonwhite women didn't want to experience labor again. 10/45 (22.2%) of white women didn't want to experience labor again. 29/40 (72.5%) of nonwhite women had positive feelings about prior CD. 21/41 (51.2%) of white women had positive feelings. 22/56 (39%) of all women having CD had decided to have no more children and had their tubes tied at delivery time. Some women chose repeat CD to spare husband the long labor process. | For all patients:
| 3 hospitals in San Francisco Bay area | Tape recorded semi-structured interview with women at home during last month of pregnancy & about two months postpartum | | | | | | | 36/100 (36%) patients influenced by friends.
FAIR | | | 23/43 nonwhite patients | | | | | | 15/92 (16.3%) patients influenced by relatives.
| | | 42/50 white patients
| | | ERCD: | | | | | | Only 28/100 (28%) of women knew someone else who attempted a TOL after prior CD.
| | 1983-1986 | 20/43 nonwhite patients
| | Examine in depth the women's choice of ERCD or TOL. | 8/50 white patients.
Martin, 1983 ^24^ | USA | Prospective cohort | All women with one or more prior CD. Recruited 717/789 | NR | 162/717 (22.6%) | 101/162 (62.4%) | 555/717 (77.4%) | 245/547 (44.8%) wanted tubal sterilization (p<.001). | NR
| Two teaching hospitals in Mississippi and Alabama. | Interviewed women during pregnancy, reviewed medical charts after delivery
FAIR | | | TOL: 22.0 yrs (SD .9 yrs)
| | | ERCD: 23.3 years (SD .3 years)
| | 1981-1982
| | Examine choices, reasons, outcomes for women choosing TOL or ERCD.
Meier 1982 ^57^ | USA | Prospective cohort | Women with single prior CD, low-transverse scar. | NR | Inferred 207/658 (31.5%) | 175/207 (84.5%) | inferred 451/658 (68.5%) | 9/13 patients cited fear of difficult labor, fail to deliver and require a repeat CD. Convenience was second reason. | NR
| Kaiser Hospital in CA Before study primary CD rate 9.8%. Repeat CD 7.1%. | Patients and physicians completed questionnaires.
FAIR | | | Considered some patients with more than one prior CD
| | 1980-1981 | TOL: NR
| | Report proportion of patients attempting and completing VBAC | ERCD: NR
Melnikow 2001 ^121^ | USA | Retrospective cohort | Randomly selected 1662 charts of deliveries. 369 charts of women with prior CD at 51 hospitals | Abstracted any counseling notes from charts. No cases of VBAC without documentation of counseling. | Hospitals with high CD rate (42%); intermediate (56%); low (90%) | Hospital with high CD rate (73.8%); intermediate (69.6%); low (78.9%) | Hospitals with high CD rate (58%); intermediate (44%); low (10%) | Hospitals with high risk adjusted CD rates were more likely than hospitals with low CD rates to schedule ERCD without documentation of counseling for TOL (21% vs .3%, p<.01). Hospitals with high CD rates had higher proportion of women who were counseled and refused than hospitals with low CD rates (36% vs. 10%, p<.01). | NR
| 3 groups of nonfederal acute-care hospitals with high (30%), intermediate (21%), low (15%) CD rates. | Chart review
FAIR
| | 1992-1993
| | Estimate rates at which women were offered and attempted TOL. | TOL & ERCD: Mean age 30.6 yrs. 47.4% nonwhite
Cross-Sectional
Lau 1996 ^123^ | CHINA | Cross-sectional | Group 1: 50 patients who just had first CD interviewed during postnatal hospital stay | NR. But implied that some education occurs since all patients were asked what the lowest success rate of VBAC they would consider and still have a VBAC. | INVALID: | NA | INVALID: | More patients who chose ERCD 20/46 (43.5%) had a fear of vaginal delivery compared with 2/53 (3.8%) (p=.000).
| Tertiary teaching hospital in Hong Kong CD 21.4%. 30% of women with prior CD attempt TOL. 80% succeed | Structured interview during pregnancy or after first CD | | | Assuming a 50–70% success rate. 24/50 (48%) of Group 1 would choose TOL for next. 29/50 (58%) Group 2. Overall: 53/100 (53%). | | Assuming a 50–70% success rate. 26/50 (52%) of Group 1 would choose ERCD for next. 21/50 (42%) Group 2. Overall 47/100 (47%).
GOOD
| | | 29.7 yrs (SD 3.6 yrs).
| | 1994 | Group 2: 50 pregnant patients with history of CD
| | Investigate how much chance of vaginal delivery influences patient's acceptance or resistance to TOL.
| | | 32.8 yrs (SD 4.1 yrs).
| | | Recruited 100/101
| | | TOL & ERCD: NR
Murphy 1989 ^124^ | USA | Cross-sectional | Recruited all women with a prior CD who had delivered a infant of at least 30 weeks gestation; had no psychiatric condition; could read and speak fluent English. | NR | INVALID: 33/50 (66.0%) | INVALID: 21/33 (63.4%) | 12/50 (34%) | None of the patients had chosen an ERCD before pregnancy began. 5/12 (41.7%) chose ERCD before 4 months. 6/12 (50%) women wanted to avoid an unsuccessful labor and another 4/12 felt that a repeat CD was a safer method. 6/12 (50%) wanted to avoid the effect of the prolonged, painful labor. | None of the patients had chosen an ERCD before pregnancy began. 5/12 (41.7%) chose ERCD before 4 months. 9/12 (75%) felt the health care provider was the most influential source. 3/12 (25%) felt the health care provider was the major source of support.
| Two hospitals in Pacific Northwest | 20 minute phone interview within 1 month of delivery
GOOD
| | 6 month period in the late 1980s.
| | Assess women's contribution to CD or TOL decision, determine reasons.
| | | Recruited 50/53
| | | TOL: Mean age 28 yrs.
| | | ERCD: Mean age 29 yrs.
Gamble 2001 ^122^ | USA | Cross-sectional | Women between 36–40 weeks gestation, at least 18 years old. Read and write in English. | NR | 17/40 (67.5%) | NR | 13/40 (32.5%) | Predominant reasons: safety of baby. Women who were very disappointed with last delivery were more like to chose CD. | NR
| Major metropolitan teaching hospital | Completed questionnaire during last month of pregnancy
FAIR
| | | Recruited 301/310
| | 1998-1999 | TOL & ERCD: NR for women with prior CD. Whole group: 79.7% under age 3; 11.7% nonwhite.
| | Determine incidence of birth choice and reasons.
Fawcett 1994 ^84^ | USA | Cross-sectional | Women who completed a VBAC. Not clear if all eligible patients were recruited and number who refused | NR but 71% knew abut VBAC before current pregnancy; 48% had decided for a TOL before current pregnancy. Another 39% decided by 2nd trimester. | NA. Only recruited VBAC patients. | 100%. Study only recruited VBAC patients. NA | NA | NA | NA
| General hospital in small town in PA. | BEQ 12–48 hrs after delivery
FAIR
| | Inferred 1991-1992
| | Compare women's VBAC reactions to their previous CD experience. | TOL: Mean age 28.8 yrs (SD 5.5 yrs)
| | | ERCD: NA

BEQ=birth experience questionnaire; VBAC=vaginal birth after cesarean; TOL=trial of labor; NR=not reported; ERCD=elective repeat cesarean delivery; DD=delivery decision; CD=cesarean delivery

Evidence Table 12b. Patient preferences - poor quality studies

Author Year Quality | Country Setting | Study Design Intervention Years of Study Research Objective | Population | Exclusion criteria | Delivery decisions Reasons or factors for TOL Attempt TOL/Eligible VBAC/TOL | Delivery decisions Reasons or factors for ERCD
Cohort
Quinlivan 1996^125^ POOR | Austria | Prospective cohort | All public patients who delivered by CD | Private patients | NR | DD:INVALID:
| Teaching hospital in Western Austria | | | | | 103 & another 47 deliveries partially attributed to mother's request
| | Physician who performed the surgery completed a computerized audit sheet
| | | | | | 147 with more than 1 prior CD
| | | Age and race NR
| | | | | | Reasons: INVALID:
| CD rate was 17.8% | 1995-1997 | | | | Women with more than 1 prior CD advised to have elective repeat.
| | To determine reasons for emergency & ERCD, examine role of anesthesia in these
Mould 1996 ^86^ POOR | USA | Prospective cohort | 102/104 women who had an emergency CD 26/102 had prior CD | NR | DD: INVALID: For next delivery, 44/87 (51%) of women would choose TOL | DD:
| University college hospital | | | | | INVALID: For next delivery, 43/87 (49%) of women would choose ERCD.
| | Clinicians interviewed women 2–3 days after delivery and at 6 week checks
| | | | | Reasons, numbers NR | Reasons: INVALID:
| CD rate of 18%. | | | | | Reasons for current CD:
| | | | | Age and race NR | - 9/34 had fetal distress; - 4/12 with mal presentation; - 11/14 with prior CD/myomectomy; - 7/19 failed to progress; - 1/5 failed induction; - 2/6 pregnancy induced hypertension; - 1/1 patient desire.
| | 1994
| | To assess extent to which women contribute to CD decision and their satisfaction
Abitbol 1993 ^85^ POOR | USA | Prospective cohort | Prior CD who met ACOG guidelines | Didn't meet ACOG standards | DD: NR | DD: 125/312 (40%)
| VBAC program in NY hospital | | | | Reasons:INVALID:
| | Clinician and social worker interviewed women before and 2–3 days after delivery | | | For all TOL patients: | Reasons:INVALID:
| | | Refused NR | 38/364 (10.4%) | - Main reason, wanted “natural birth”; - 49% health of baby; - 38% negative feeling toward CD (can't bond, felt failure); - 13% feared major surgery | - 71.2% avoidance; - 36.8% baby's health; - 60.0% mom's work schedule; - 20.8% med lay literature; - 8.8% mom's health concerns.
| 62% service patients 38% private | | Age and race NR
| | 18 month collection, no dates
| | | | | Attempt/Eligible:
| | To investigate reasons for TOL or ERCD | | | 187/312 (60%)
| | | | | VBAC/TOL:
| | | | | 122/187 (65%)
Joseph 1991^126^ POOR | USA | Prospective cohort | One prior CD | - More than one prior CD; - Classic scar; - Abnormal presentation at term; - Multiple gestation; - Abnormal antepartum testing; - Lumbar disc disease precluding epidural use; - Medical complications; - Fetal heart rate concerns. | DD, reasons: NR | DD: 92/143 (64.3%)
| Private Hospital in LA | The patient's and MD's birth choice (and reasons) recorded and updated throughout pregnancy | All women with one prior CD | | Attempt/Eligible: | Reasons:INVALID:
| | | | | | - 28/92 (30.4%) MD advised diminished chance of vaginal delivery; - 24/92 (26.1%) patients had fear of labor; - 22/92 (23.9%) patients chose for convenience; - 12/92 (13.0%) patients eligible but considered “poor candidates”; - 6/92 (6.5%) had a fear of recurrent outcome
| | | | | 85/143 (59.4%)
| | | Age and race NR | | VBAC/TOL:
| | | | | 30/85 (35.2%)
| | 1989
| | To determine if resistance from patient or MD prevents greater utilization of a VBAC program
Cross-Sectional
Dilks 1997 ^126^ POOR | USA Northeast | Cross-sectional | At least 28 weeks gestation | Read and write English | DD: NR | DD: NA
| | Convenience sample. Childbirth Self-efficiency Inventory during pregnancy | 74/225 (32.9%) | | Reasons:INVALID: | Reasons:INVALID:
| Clinician's offices, childbirth classes, hospital-based clinics that served a tertiary care center | | | | The group electing for a TOL had similar expectation of the outcomes and similar self-efficacy as the primigravida group | Group electing for a ERCD had lower expectation of the outcomes (p=.011) than the primigravida group.
| | | Mean age:
| | | 32.3 yrs (SD 4.4 yrs)
| | Inferred early to mid 1990s | Nonwhite:
| | | 12/74 (16.2%) | | Numbers NR
| | To compare self-efficacy of primigravidas and multigravidas with prior CD

VBAC=vaginal birth after cesarean; TOL=trial of labor; NR=not reported; ERCD=elective repeat cesarean delivery; DD=delivery decision; CD=cesarean delivery

Evidence Table 13. Legal and legislative factors - good quality studies

Author Year Quality | Country Setting | Years of study Research objective | Subject Eligibility: Included (I) / Excluded (E) | Study Group | Sample Size (enrolled/ complete) | Measure | Estimate | Notes
Retrospective Cohort
Studnicki 1997 ^132^ | USA | 1992-1993 | (I) Birth at non-federal, acute-care hospital / (E) <30 deliveries paid for by state or state-administered funds | 1992 (pre-rule) | 22,938 | VBAC rate: 1992 | 26.70% | Stratified by maternal age, insurance payor, race, timing of adoption of law, RCD vs. primary CD
| FL | Florida law mandates Obstetricianss receive guidelines and hospitals use peer review to enforce. This study is to evaluate outcomes.
GOOD
| | | | 1993 (post-rule) | 23,127 | 1993 | 30.90% | Of 54 categories with RCD, 12 found significant decreases in RCD (without adjusting for multiple comparisons).
King 1994 ^115^ | USA | 1989 | (I) Birth in NY hospital to NY resident with prior CD | Hospital paid loss | | Adjusted odds ratio (CI) with / without NYC | 1.01 (0.99, 1.03)/0.96 (0.95, 0.98) | Results adjusted for risk and confounders
| NY | Determine effects of hospital characteristics on VBAC rate
GOOD
| | | | Physician premiums for a $5000 annual increase | | | 0.98 (0.97, 0.99)/1.01 (1.00, 1.08)

VBAC=vaginal birth after cesarean; CD=cesarean delivery; RCD=repeat cesarean delivery; CI=confidence interval

Evidence Table 14a. Guidelines - good or fair quality studies

Author Year Quality | Country Setting | Years of study Research objective | Guideline used | Subject Eligibility: Included (I)/Excluded (E) | Study Group | Sample Size (enrolled/ complete) | Measure | Estimate | Notes
Randomized Trial Designs
Lomas 1991 ^133^ | Canada | 1988-89 | Society of Obstetricians and Gynecologists of Canada and Ontario Hospital Association (1986) | (I) Women with prior CD (including not more than one and with no vertical uterine scar) in one of participating hospitals/(E) Not eligible for TOL | Control | 8 hospitals (1233 women) | Offered TOL/underwent TOL | 51.3%/28.3% | P-values+N3=0.002/0.007
| | Randomized trial of audit/feedback, opinion leaders, and no intervention to improve clinical outcomes
GOOD
| | | | | Audit/feedback | 4 hospitals (524 women) | | 56.3%/21.4% | Small number of hospitals. No adjustment for potential confounders but no differences in baseline variables reported
| | | | | Opinion leader | 4 hospitals (739 women) | | 74.2%/38.2%
| | | | | Control | | VBAC rate/ERCD rate | 14.5%/66.8% | P-value=0.003/0.001
| | | | | Audit/feedback | | | 11.8%/69.7%
| | | | | Opinion leader | | | 25.3%/53.7%
| | | | | Control | | Dehiscence/rupture of uterus | " 2/1
| | | | | Audit/feedback | | | 0/0
| | | | | Opinion leader | | | " 4/1
Bickell 1996 ^134^ | US | 1988 | Unclear: NY State Health Department and State ACOG Chapter collaborated | (I) Hospital with active delivery services/(E) If hospital refused, replacement hospital randomly selected | Reviewed hospitals | 45 | VBAC rates (SD): 1988/1993 | 10.1% (1.4%)/24.8% (2.0%) | 1988 value, 1993 value. No difference if models adjusted for other factors. Overall CD rate differ in 1988; all other differences not significant.
| NY | 1993
| | Test effectiveness of joint statewide peer review by specialty society and health department
FAIR
| | | | | Control hospitals | 120 | | 12.1% (0.9%)/24.8% (1.1%) | Limited impact on rates. This strategy may not be effective. Small number of hospitals in intervention group but may not matter.
| | | | | Reviewed hospitals | 45 | RCD rate (SD): 1988/1993 | 10.9% (0.5%)/10.2% (0.5%) | No adjustment of VBAC rates for potential confounding variables evident.
| | | | | Control hospitals | 120 | | 9.8% (0.3%)/9.2% (0.2%)
Retrospective Cohort Design
Santerre 1996 ^136^ | US (MA) | 1985-93 | ACOG (1988) | (I) Data in panel of 55 hospitals | 1985 | | Unadjusted VBAC rate | 6.60% | Regression model predicts about 5.6% “permanent” increase in VBAC rate.
| | Assess impact of ACOG guidelines (published 10/88) on VBAC rate
FAIR
| | | | | 1986 | | | 8.50% | Minimum chi-square regression model used. Adjusted for some risk predictors (low birth weight, race, and payment source).
| | | | | 1987 | | | 9.80% | Nature of panel of hospitals not defined.
| | | | | 1988 | | | 12.60% | Denominator of VBAC rates unclear.
| | | | | 1989 | | | 18.50%
| | | | | 1990 | | | 20.40%
| | | | | 1991 | | | 24.20%
| | | | | 1992 | | | 25.10%
| | | | | 1993 | | | 25.40%
Lomas 1989 ^135^ | Canada (Ontario) | 1982-88 | Society of Obstetricians and Gynecologists of Canada and Ontario Hospital Association (1986) | (I) All deliveries in hospitals | 6 years before guidelines published | | Mean (SD) monthly rate of change of rate of RCD per 100 patients from linear regression model | -0.041 (0.008) | Other variables in regression models not specified so unclear if controlled for confounders. Survey response rate 76% to 98% across samples.
| | Assess effect of publication of guidelines
FAIR
| | | | | 2 years after guidelines published | | | -0.113 (0.023) | Survey results not cited as contained self-reported attitudes not quantitative data.

TOL=trial of labor; VBAC=vaginal birth after cesarean; ERCD=elective repeat cesarean delivery SD=standard deviation

Evidence Table 14b. Guidelines - poor quality studies

Author Year Quality | Country Setting | Years of study Research objective | Guideline used | Subject eligibility: included (I)/excluded (E) | Study group | Sample size (enrolled/complete) | Measure | Estimate | Notes
Prospective Cohort Study Designs
Myers 1988 ^139^ | USA | 1985-87 | Local: 2nd opinion; dystocia, fetal distress, breech delivery criteria defined; comprehensive peer review | (I) Birth at hospital; no other criteria stated | 1985 | 122 prior CDs | ERCD rate/TOL rate (after VBAC) | 55%/53% | No adjusting for potential confounders. Single hospital for short time period.
| IL | Assess impact of program to reduce rates of CD at inner city hospital (established in 1986)
POOR
| | | | | 1986 | 193 | | 32%/80% | Unclear if true prospective cohort.
| | | | | 1987 | 271 | | 14%/70%
Porreco 1985 ^140^ | USA | 1982-83 | Local: 8 “principles” to guide decision of TOL versus ERCD | (I) Birth at hospital; no other criteria stated | OB management (clinic service) | 1058 total deliveries | ERCD rate/Total RCD rate/VBAC rate | 0.7%/1.4%/84.3% | No adjusting for potential confounders or description of baseline risk factors. Single hospital for short time period.
| CO | Assess impact of CD manage-ment phil-osophy
POOR
| | | | | Usual care (private service) | 2459 | | 5.7%/6.6%/77.6% | Denominators of rates: all births for ERCD rate and total RCD rate; TOL patients for VBAC rate. Unclear if true prospective cohort.
Retrospective Cohort Study Designs
Myers 1993 ^137^ | USA | 1985-91 | Local hospital guidelines (implemented 1986) | (I) All deliveries in data base | 1985 | | ERCD rate/VBAC after TOL rate | 55%/53% | No risk adjustment or other potential confounders
| IL | Assess long-term impact of CD guidelines including RCD
POOR
Sanchez-Ramos 1990^138^ | USA | 1986-89 100 | Local hospital guidelines (1987) | (I) All deliveries with prior low transverse or low vertical CD./(E) Patients with other indications for RCD. | 1986 | | VBAC rate (among TOL)/RCD rate (among all births) | 64.7%/8.0% | Difference 1989 rate - 1986 rate: VBAC rate p-value<0.0001, RCD rate p-value<0.0001
| FL | Assess impact of new RCD guidelines (implemented in 7/87)
POOR
| | | | | 1987 | | | 73.6%/7.4% | No adjustment for baseline risk or other potential confounders
| | | | | 1988 | | | 85%/3.9%
| | | | | 1989 | | | 82.7%/3.3%
Coulter 1995 ^141^ | USA | Date NR | Various | (I) Member of American College of Physician Executives/(E) Incomplete forms | 159 surveys | 64 (41%) returned surveys | VBAC rates: HMO with/without VBAC policy | 39%/40% | 63% [47%] of HMO's [hospitals] have VBAC policy. 74% [87%] monitor performance. 28% [36%] hold provider accountable.
| IL | Survey of TOL guidelines and VBAC rates among physician executives
POOR
| | | | | | | VBAC rates: hospital with/without VBAC policy | 37%/47% | Among high VBAC organizations (50%+): 66% [60%] VBAC rate
| | | | | | | VBAC rates: HMO with/without confor-mance monitoring | 42%/36% | 33 HMOs and 21 hospitals
| | | | | | | VBAC rates: hospital with/without conformance monitoring | 48%/2% | No adjustment for risk or potential confounders.
| | | | | | | VBAC rates: HMO with/without provider account-ability | 46%/39% | Self-reported data with very poor response rate for survey.
| | | | | | | VBAC rates: hospital with/without provider account-ability | 59%/30%
| | | | | | | VBAC rates: HMO with/without removal of incentives for surgery | 46%/33%

TOL=trial of labor; VBAC=vaginal birth after cesarean; ERCD=elective repeat cesarean delivery SD=standard deviation

Evidence Table 15. Provider characteristics - poor quality studies

Author Year Quality | Country Setting | Years of study Research objective | Subject Eligibility: Included (I)/Excluded (E) | Study Group | Sample size (enrolled/complete) | Group | Measure | Estimate | Notes
Prospective Cohort Study Design
Sinusas 2000 ^144^ | US (CT) | 1996 | (I) Family practice MD with OB privileges | | 32 MDs (of 32 eligible), 478 deliveries | | VBAC rate | 1.7% of all deliveries (8 cases) | 9% of family physicians in CT. No multivariable adjustment.
| | Describe deliveries by family physicians
POOR
Davis 1994 ^149^ | US (IL) | 1987-90 | (I) Women with low risk pregnancy not at risk of CD/(E) ERCD and indications of high-risk pregnancy | Obstetricians | 455 | | Rate of CD after unsuccessful TOL | 23.90% | P-value<0.05
| | Comparison of obstetrician and nurse-midwife rates of ERCD
POOR
| | | | Nurse-midwives | 20 | | | 5% | Multivariable model predicted rate of CD not RCD; no risk adjustment.
Retrospective Cohort Study Design
Coco 2000 ^148^ | US (PA) | 1986-95 | (I) Delivery with Family Health Service (family physician residency) | 1986-1989 (attendings all obstetricians) | | | RCD rate | 8.00% | Odds ratio 0.362 (.250, .524)
| | Does change in specialty change rates of CD?
POOR
| | | | 1992-1995 (attendings all family physicians) | | | | 2.90% | P-value<0.001. No risk adjustment across time periods.
Harrington 1997 ^152^ | US (CA) | 1988-92 | (I) Gestational age 36–43 weeks, in active labor, singleton cephalic presentation, estimated fetal weight 2500–4000 grams/(E) Medical complications other than diet-controlled gestational diabetes, records unavailable. | Matched cases (prior CD) and controls (no prior CD). | | Prior CD | VD rate: uncomplicated (spontaneous VD?)/total (includes operative VD) | 91.3%/98.3% | One asymptomatic cesarean rupture (0.3%). 84% of prior CD women had successful vaginal delivery.
| | Evaluate safety and efficacy of nurse-midwife delivery in low-risk patients
POOR
| | | | | 298 | no prior CD | | 89.6%/99.0% | Oxytocin use 1.2% [12.2%] in women with [without] prior vaginal delivery
Stone 1996 ^151^ | US (NY) | Describe outcomes for a nurse-midwife service (physicians comanage high risk cases) in a rural setting | (I) Women with prior CD using this service | Prior CD | | | VBAC Rate (1989 and 1994) | 68% and 94% | No risk adjustment. Denominator for VBAC rate was TOL attempted. No adverse events reported.
Deutchman 1995 ^145^ | US (TN) | Compare low-risk pregnancies managed by family practice and OB at teaching hospital | (I) Non-high-risk pregnancy/(E) No prenatal care, twins, various maternal high-risk comorbidities. | Family physicians | 578 | | Number of VBAC/RCD (rate) | 9(1.6%)/14 (2.4%) | Very small numbers of women with prior CD. No evidence of adjustment for VBAC rate
POOR
| | | | OB | 1364 | | | 10 (0.7%)/122 (8.9%) | Outcome assigned to FP or OB who provided prenatal care and labor management not necessarily delivery. Denominator all pregnancies. P-values (for comparisons of rates by provider) <0.001.
Hueston 1995 ^150^ | US | Compare obstetrics residence program to family practice residence program pregnancy manage-ment across 5 states | (I) Monthly random sample of hospital deliveries/(E) Women who transferred in labor or who received care from a non-staff provider | Obstetrics supervised | 2804 | Prior CD 14% | Number of RCD | 438 | No risk adjustment for RCD rate included. No denominator for RCD rate.
POOR
| | | | Family physician supervised | 1754 | Prior CD 4% | | 63 | 14% of OB patients had prior CD but 15.6% had RCD. Practices are very heterogeneous.
Hueston 1994 ^154^ | US | 1990-91 | (I) Random sample of up to 80 deliveries per month at 1 of 5 hospitals | Women who started care or began delivery with family practice physicians | 2568 began care/2648 began delivery | Referred to ObGyn early in care | Proportion with uterine scar | 32% | Differences between those referred and those not referred significant (P<0.001) in both early labor and delivery.
| | Assess predictors of referral patterns for obstetrics.
POOR
| | | | | | Not referred to ObGyn early in care | | 3% | Independent predictor in multivariable model predicting probability of referral.
| | | | | | Referred to ObGyn in labor | | 10% | No risk adjustment
| | | | | | Not referred to ObGyn in labor | | 2%
Berkowitz 1989 ^153^ | US (NY) | 1983-85 | (I) Physicians who delivered at hospital (private patients only)/(E) 2 physicians with same surname and 4 who managed only high risk patients | | 48 physicians | | Correlation of age with repeat CD rate | 0.18 (p>0.05) | Small sample size. 37 physicians male and 23 in solo practice.
| | Evaluate effect of physician character-istics on CD rates
POOR
| | | | | | | Repeat CD rate: male physician/female physician | 22.6/15.9 (p=0.46) | No risk adjustment (males were both older and more experienced).
| | | | | | | Repeat CD rate: solo practice/group practice | 18.1/23.8 (p=0.27) | Data from logbook (reliability?)
Case-Control Study Design
Goldman 1993 ^143^ | Canada (Quebec) | 1985-88 | (I) Births in Quebec with prior CD/(E) Medical diagnosis, missing data on attending MD | VBAC | 635 of 635 | MD CD rate: 20–40% | Adjusted odds ratio (95% CI) | OR = 0.48 (0.38, 0.61) | Non-significant variables:
| | Determine factors associated with VBAC
POOR
| | | | RCD | Random sample 2593/12,473 | MD CD rate: >40% | | OR = 0.25 (0.17, 0.38) | MD referral rate, gender, specialty OB, number annual deliveries
| | | | | | MD age 35 – 54 | | OR = 0.86 (0.64, 1.17) | Patient's age, location (urban, intermediate, rural)
| | | | | | MD age >54 | | OR = 0.66 (0.44, 0.97) | Hospital OB resource capacity and CD rate
| | | | | | MD at risk patients: 5–10% | | OR = 0.67 (0.52, 0.87) | Adjustment included only age and provincial region not baseline risk.
| | | | | | MD at risk patients: >10% | | OR = 0.92 (0.67, 1.24) | Possible confounder: patient self-selection for CD
| | | | | | MD gender: male (female reference) | | OR = 0.93 (0.67, 1.30)
| | | | | | MD Specialty: OB (general practice reference) | | OR = 0.99 (0.65, 1.48)
| | | | | | Degree of hospital's neonatal & OB specialization: intermediate | | OR = 2.46 (1.81, 3.34)
| | | | | | Degree of hospital's neonatal & OB specialization: high | | OR = 3.32 (2.17, 5.23)
| | | | | | Referral rate: 10%–30% | | OR=0.81 (0.64,1.03)
| | | | | | Referral rate: >30% | | OR=0.80 (0.61, 1.06)
| | | | | | Annual deliveries: 50–150 | | OR=1.18 (0.79, 1.77)
| | | | | | Annual deliveries: >150 | | OR=1.28 (0.83, 1.99)
Goldman 1990 ^114^ | Canada (Quebec) | 1985-87 | (I) Birth recorded in provincial data base/(E) Medical diagnosis (e.g. dystocia or fetal distress) for CD or incomplete data. | | 400 cases and 1600 unmatched controls | | Odds ratio (95% CI) for VBAC versus RCD: physician gender (female reference) | 1.08 (0.71, 1.64) | No risk adjustment (other than age). Odds ratios from multivariable predictive model.
| | Identify provider characteristics and other predictors of probability of VBAC following prior CD.
POOR
| | | | | | | Age 35–54 (<35 reference) | 0.83 (0.58, 1.20) | Number of variables in predictive model suggests multicollinearity may be a problem.
| | | | | | | Age >54 (<35 reference) | 0.60 (0.37, 0.97) | Odds ratio >1 denotes higher probability of VBAC than reference group
| | | | | | | Ob/Gyn specialty (general practice reference) | 1.32 (0.79, 2.19) | Control group includes some potentially not eligible for VBAC
| | | | | | | Annual number of deliveries 50–150 (<50 reference) | 0.51 (0.30, 0.89)
| | | | | | | Annual number of deliveries >150 (<50 reference) | 0.76 (0.44, 1.31)
| | | | | | | High-risk pregnancies 5–10% (<5% reference) | 0.76 (0.55, 1.05)
| | | | | | | High-risk pregnancies >10% (<5% reference) | 1.19 (0.84, 1.68)
| | | | | | | Referral rate 10–30% (<10% reference) | 0.48 (0.36, 0.64)
| | | | | | | Referral rate >30% (<10% reference) | 0.50 (0.36, 0.70)
| | | | | | | CD rate 20–40% (<20% reference) | 0.49 (0.36, 0.66)
| | | | | | | CD rate >40% (<20% reference) | 0.17 (0.10, 0.27)
Case Series
Miller 1995 ^146^ | US (PA) | 1988-92 | (I) Women with 2 or fewer prior CD/(E) Women with prior classical or low vertical CD, breech, twins with A non-vertex, active genital Herpes | | 98 (11 of these excluded) | | Repeat CD, Attempt VBAC, VBAC delivery | 56%, 57% 77% | 85% of those who failed TOL had cephalopelvic disproportion. No comparison group
| | Estimate VBAC rate in FP residency program in community hospital
POOR
Hangsleben 1989 ^155^ | US (MN) | 1982-1987 5.5 years) | (I) Women requesting VBAC in nurse-midwife service. (E) 15 women who requested ERCD. | | 53 | | VBAC rate | 83% | Data on ERCD would have been interesting. Population may be highly selected but details not provided.
| | Describe VBAC experience over 5 years in midwife service
POOR
Surveys
Barnsley 1990 ^147^ | Canada | NR | (I) Physician a member of Ontario Medical Association Section on Obstetrics and Gynecology | | 192 returned surveys | | | | 30% reported ERCD in <50% of patients but 77% noted TOL in hypothetical case
POOR

TOL=trial of labor; VBAC=vaginal birth after cesarean; ERCD=elective repeat cesarean delivery SD=standard deviation

Evidence Table 16a. Hospital characteristics - good or fair quality studies

Author Year Quality | Country Setting | Years of study Research objective | Subject eligibility: included (I)/excluded (E) | Study group | Sample size (enrolled/complete) | Measure | Estimate | Notes
Retrospective Cohort Study Designs
Gregory 1999 ^164^ | USA | 1991 | (I) Medicaid patients delivering in Los Angeles County/(E) Inconsistent ICD-9 codes (N=2) | Number of hospitals (patients): Private non-teaching hospitals | 65 (5016) | Unadjusted RCD rate/adjusted RCD rate | 85.7%/85.7% (reference group) | Adjusted RCD rates similar to unadjusted rates. All differences with reference group are significant (P<0.001)
| CA | Compare CD rates in Medicaid patients
GOOD
| | | | Public hospitals
| | | | | 4 (2625) | | 44.2%/43.0% | Adjustment for maternal and fetal clinical conditions
| | | | Private teaching hospital
| | | | | 4 (883) | | 43.3%/40.0%
| | | | HMOs
| | | | | 5 (84) | | 60.7%/59.0%
McMahon 1996 ^5^ | Canada | 1986-92 | (I) Women who gave birth in Nova Scotia hospitals with at least 1 prior CD/(E) Nonvertex presentation, multiple gestation, prior CD with vertical to T-shaped incision, placenta previa, maternal Herpes simplex infection, previous uterine surgery. | Tertiary care | 3,725 | TOL rate/adjusted odds ratio (CI) | 60.1%/1.0 (reference) | Adjusted for both baseline risk and other confounders. Cohort is population-based.
| Nova Scotia | Compare outcomes of TOL versus ERCD
GOOD
| | | | Regional | 1,956 | | 43.1%/0.5 (0.5, 0.6)
| | | | Community | 457 | | 36.3%/0.4 (0.3, 0.5)
| | | | Tertiary care | 2,239 | Successful TOL rate/adjusted odds ratio (CI) | 63.6%/1.0 (reference)
| | | | Regional | 844 | | 53.4%/0.7 (0.6, 0.8)
| | | | Community | 166 | | 53.0%/0.7 (0.5, 0.9)
King 1994 ^115^ | USA | 1989 | (I) Birth in NY hospital to NY resident with prior CD | Hospital ownership: voluntary | 10,636 | Unadjusted VBAC rate/adjusted odds ratio (CI) | 21.8%/1.0 (reference) | Odds ratio is for VBAC compared to ERCD. The following list results without New York City if CI changes with respect to no association (odds ratio=1.0)
| NY | Determine effects of hospital characteristics on VBAC rate
GOOD
| | | | Church | 2,526 | | 23.6%/1.13 (1.01, 1.26) | 1.07 (.95, 1.21)
| | | | Government | 782 | | 19.7%/0.77 (0.63, 0.94)
| | | | Level I care | 7,030 | | 18.7%/1.0 (reference)
| | | | Level II care | 3,754 | | 24.2%/1.30 (1.18, 1.44)
| | | | Level III care | 3,160 | | 26.6%/1.55 (1.34, 1.81)
| | | | Teaching hospital | 1,065 | | 25.8%/1.11 (0.99, 1.24) | 1.36 (1.21, 1.54) if New York City hospitals excluded
Santerre 1996 ^136^ | USA | 1987-91 | (I) Data in panel of 55 hospitals | | | | | Regression model predicted lower VBAC rate at hospitals with higher proportion of low-birth-weight and Hispanic babies and non-teaching hospitals (VBAC rate average about 24% higher at teaching hospital than non-teaching hospital. Minimum chi-square regression model used. Results from model with supply-side and demand-side factors although models that exclude one of these in favor of the others explain more variability.
| MA | Assess impact of ACOG guidelines (published 10/88) on VBAC rate
FAIR
| | | | | | | | Volume of births, presence of neonatal ICU, ownership status, and urban location did not predict VBAC rate in model.
Case Series
Raynor 1993 ^29^ | USA | 1988-91 | (I) 1 or more prior CDs, low transverse or unknown scar cephalic or breech presenta-tion/(E) Other malpresentations, vertical uterine scars | | | TOL rate/VBAC rate | 51 of 67 (76%)/31 of 51 (61%) | Rates unadjusted. Small series. 2 uterine scar dehiscences in 67 patients. Level I nursery.
| NC | Evaluate outcomes of VBAC in small rural practice
FAIR
Walton 1993 ^157^ | USA | 1988-89 | (I) Pregnant women with prior CD/(E) Failure to meet ACOG criteria | Trial of labor | 62 Women with prior CD | VBAC rate | 28 of 32 (88%) | 79% of 62 patients agreed to a TOL initially but 14 failed to meet guidelines for TOL. 3 decided to undergo ERCD in late pregnancy. Change of criteria after 10/98 (women with >2 prior CD offered TOL).
| (military hospital in Japan) | Summarize VBAC experience in rural military hospital
FAIR
Schimmel 1992 ^162^ | USA | 1990 | (I) Women with at least 1 prior CD | | 37 | VBAC rate | 32 of 37 (87%) | Rates unadjusted. Small series. Many Medicaid women refused care by obstetricians.
| CA | Summarize outcomes for midwife service for low income (Medicaid) women
FAIR
Surveys
Stafford 1991170 | USA | 1986 | (I) Delivery by woman with prior CD in non-military hospital | Proprietary | 7,511 Births | VBAC rate/Adjusted odds ratio (CI) | 4.9%/1.0 (reference)
| CA | Estimate rates of VBAC with adjustment for potential confounders
GOOD
| | | | Private non-profit | 27,846 | | 8.2%/1.4 (1.2, 1.6)
| | | | Kaiser Permanente with Kaiser payment | 4,506 (includes next row) | | /3.9 (3.3, 4.6) | VBAC rate 19.8% across Kaiser
| | | | Kaiser Permanente without Kaiser payment | | | /2.6 (1.4, 4.6)
| | | | University of California | 1,166 | | 29.2%/3.7 (3.0, 4.6)
| | | | County with indigent payment | 4396 (includes next row) | | /2.5 (2.1, 2.9) | VBAC rate 23.6% across county
| | | | County without indigent payment | | | /2.7 (2.1, 3.5)
| | | | Non-teaching | 25,935 births | | 7.1%/1.0 (reference)
| | | | Non-medical school-affiliated teaching | 4,046 | | 9.8%/0.7 (0.6, 0.8)
| | | | Medical school-affiliated teaching | 7,807 | | 12.1%/0.9 (0.8, 1.0)
| | | | Council of Teaching Hospitals member | 7,367 | | 23.3%/1.7 (1.5, 1.9)
| | | | Neonatal ICU in hospital | 25,039 | | 14.2%/0.9 (0.8, 1.0)
| | | | No neonatal ICU | 20,386 | | 6.8%/1.0 (reference)
| | | | Number of annual births < 1000 | 7,995 | | 5.4%/1.0 (reference)
| | | | 1000–1999 | 11,900 | | 7.8%/1.4 (1.4, 1.5)
| | | | 2000–3499 | 13,833 | | 11.8%/1.8 (1.7, 1.9)
| | | | 3500 or more | 11,687 | | 16.6%/2.7 (2.4, 3.0)
| | | | Median family income by zip code in $1000: 24.5 or more | 9,064 | | 10.1%/1.0 (reference)
| | | | 20.8–24.5 | 8,620 | | 10.4%/0.8 (0.7, 0.9)
| | | | 17.5–20.7 | 9,648 | | 10.4%/0.9 (0.8, 1.0)
| | | | 13.0–17.4 | 8,860 | | 10.3%/0.9 (0.8, 1.0)
| | | | <13.0 | 9,233 | | 13.0%/0.9 (0.8, 1.0)
Shiono 1987 ^163^ | USA | 1984 | (I) 550 randomly selected hospitals (87% response rate)/(E) 12 hospitals outside of 50 states and DC.s | Neonatal ICU in hospital | 174 hospitals | TOL rate (adjusted for size of delivery service) | 12.50% | Results weighted to all US acute care hospitals. Not adjusted for patient level characteristics. Denominators for rates not clearly defined.
| | Appraisal of obstetrical services at US hospitals
FAIR
| | | | No neonatal ICU | 248 | | 6.50% | P-value<0.001 comparing neonatal ICU to none.
| | | | OB residency | 119 | | 14.60%
| | | | No OB residency | 303 | | 6.60% | P-value<0.001 comparing OB residency to none.
| | | | <500 annual deliveries | 145 | TOL rate/TOL Success rate/VBAC rate | 1.8%/57.8%/2.4% | VBAC rate is rate of TOL times success rate of TOL. These rates may be adjusted as the definition does not hold with simple multiplication.
| | | | 500–999 | 93 | | 8.1%/44%/4.1%
| | | | 1000–1999 | 84 | | 12.5%/49.1%/9.0%
| | | | 2000–4999 | 135 | | 22.0%/49.9%/13.1%
| | | | 5000 or more | 36 | | 8r25.4%/62.8%/16.4% | Test for trend significant at p-value<0.0.5.

TOL=trial of labor; VBAC=vaginal birth after cesarean; ERCD=elective repeat cesarean deliverySD=standard deviation

Evidence Table 16b. Hospital characteristics- poor quality studies

Author Year Quality | Country Setting | Years of study Research objective | Subject Eligibility: Included (I)/Excluded (E) | Study Group | Sample size (enrolled/ complete) | Measure | Estimate | Notes
Retrospective Cohort Study Designs
Whitsel 2000 ^158^ | USA | 1997-98 (6 months of 1999 for university hospital) | (I) Pregnancies of 20+ week duration with prior CD | University hospital (level III NICU) | 4358 deliveries (total deliveries) | Repeat CD rate | 5.8% (estimated from graph) | P-value=0.02 across 3 hospitals for RCD overall. University CD rates stratified by 6 risk categories. RCD rate 43.2% in delivery>=36 weeks without medical risks, 54.2% with risks, 56.4% if delivery<36 weeks, 66.7% if multiple gestation, 100% if malpresentation, and 92.6% if not TOL permitted.
| VT
POOR | | Compare university and community hospitals RCD rate
| | | | 2 community hospitals | 1167deliveries | | 3.8% (estimated from graph) | Risk-adjusted results for RCD for community hospitals not reported for community hospitals.
Gregory 1999 ^164^ | USA | 1995 | (I) History of prior CD | Hospital with low VBAC rate | | VBAC rate/rupture rate/relative risk (CI) | 55.6%/0.056%/reference | Unadjusted rates of rupture. Artificial classes of low and high rates of VBAC (derived after exclusions of hospitals with <200 deliveries per year or no women with prior CD)
| CA | Assess rates of rupture in women with prior CD
POOR
| | | | Hospital with high VBAC rate (60%+) | | 65.0%/ 0.088%/1.56 (1.27, 1.92)
Curtin 1997 ^167^ | USA | 1995 | (I) Pregnancy in non-federal short-stay hospital | Hospital ownership: non-profit | 29,000 pregnancy discharges in survey | VBAC rate (SE) | 38.1 (1.6) | Exact number of women with prior CD not reported.
| | Summarize data from 1995 National Hospital Discharge Survey
POOR
| | | | State or local government | | | 30 (5.5) | Total CD not just RCD.
| | | | Proprietary | | | 25.7 (8.2) [based on <60 cases in sample]
| | | | Hospital number of beds: <100 | | | 28.5 (5.2)
| | | | 100–499 | | | 36.9 (1.9)
| | | | >499 | | | 38.7 (2.8)
Sieck 1997 ^168^ | USA | 1993-96 | (I) All deliveries | Rural | 3170 deliveries | TOL rate/VBAC rate/RCD rate | 30.1%/60.2%/13.3% | No risk adjustment. No statistical analyses. Not population-based (ignores deliveries at other hospitals.
| OK | Compare VBAC rates in rural and urban hospitals
POOR
| | | | Urban | 13,954 deliveries | | 46.6%/77.3%/6.5% | Denominators are eligible for VBAC for TOL rate, attempted TOL for VBAC rate, and total deliveries for RCD rate. Eligible for VBAC is estimate based on constant (85%) of successful VBAC and RCD. Method of selection of 4 hospitals not stated (possible selection bias).
Paterson 1991 ^165^ | UK | 1988 | (I) Prior CD with no other deliveries, singleton cephalic presentation, >36 weeks gestation | | 1059 women, 664 with TOL | Correlation: rate of TOL with rate of VBAC | r = -0.09 (p>0.05) | Descriptive (no comparison) study of correlations at level of hospital unit unadjusted for potential confounders.
| England | Audit of obstetric management of women with prior CD
POOR
| | | | | | Correlation: rate of VBAC with longer labor allowed | r = 0.51 (p<0.05) | Retrospective cohort study of a regional data base. Maternity unit is sample unit.
| | | | | | Correlation: rate of VBAC with rate of oxytocin use | = 0.31 (p>0.05)
Placek 1988 ^169^ | USA | 1980-85 | (I) Patients in non-federal general and special short-stay hospitals | Hospital size: <100 beds | | VBAC rate | 4.4% (may lack precision) | No risk adjustment. National data base.
| | National survey estimates (National Hospital Discharge Survey)
POOR
| | | | 100–499 beds | | | 4.70% | Potential lack of precision is due to small sample size for numerators.
| | | | >499 beds | | | 5.70%
| | | | Hospital ownership: proprietary | | | 4.4% (may lack precision)
| | | | Government | | | 5.80%
| | | | Voluntary | | | 4.70%
Case-Control Study Designs
Goldman 1993 ^143^ | Canada (Quebec) | 1985-88 | (I) Births in Quebec with prior CSx/(E) Medical Dx justifying RCD, missing data on MD | | 635 cases and 2593 controls | Adjusted odds ratio (95% CI): | 0.44 (0.32, 0.59) | Adjusted for patient characteristics (age and provincial region) and provider and hospital characteristics. Does not adjust for clinical variables.
| | Determine factors associated with VBAC
| | | | | | Degree of education of served population: intermediate
POOR
| | | | | | Degree of education of served population: high | 0.92 (0.64, 1.32) | Odds ratio is odds of VBAC compared to RCD.
| | | | | | OB resource capacity: inter-mediate | 0.90 (0.66, 1.22)
| | | | | | OB resource capacity: high | 1.12 (0.78, 1.61)
| | | | | | Hospital CD rate: 15%–20% | 1.01 (0.72, 1.40)
| | | | | | Hospital CD rate: >20% | 0.90 (0.62, 1.31)
| | | | | | Degree of hospital's neonatal & obstetrical specialization: intermediate | 2.46 (1.81, 3.34)
| | | | | | Degree of hospital's neonatal & obstetrical specialization: high | 3.32 (2.17, 5.23)
Goldman 1990 ^114^ | Canada (Quebec) | 1985-87 | (I) Birth recorded in provincial data base/(E) Medical diagnosis (e.g. dystocia or fetal distress) for CD or incomplete data. | | 400 cases and 1600 unmatched controls | Odds ratio (95% CI) for VBAC versus RCD: hospital CD rate 16–20% (<16% reference) | 1.11 (0.74, 1.66) | No risk adjustment (other than age). Odds ratios from multivariable predictive model.
| | Identify hospital characteristics and other predictors of probability of VBAC following prior CD.
POOR
| | | | | | Hospital CD rate >20% (<16% reference) | 1.08 (0.98, 1.74) | Number of variables in predictive model suggests multicollinearity may be a problem.
| | | | | | Degree of specialization intermediate (general care reference) | 2.65 (1.46, 4.81) | Odds ratio >1 denotes higher probability of VBAC than reference group
| | | | | | Degree of specialization specialized (general care reference) | 3.18 (1.60, 6.28) | Specialization of care is a summary of 7 hospital characteristics
Cross-Sectional Study Designs
Skelton 1997 ^159^ | USA | 1992 | (I) 89 acute care hospitals in MO. | | | | | Significant correlations of VBAC rate with average distance to 5 closest hospitals (-), total births (+), average charge per CD (+), CD LOS (+), CD rate (-), total normal newborns (+), normal newborn LOS (-), total VD (+), average charge per VD (+), average charge all procedures (+), patient satisfaction (+), expected and observed numbers of neonatal deaths (+), bed size (+), total discharges (+) and total inpatient days (+).
| MO | Explore relationships among quality, cost, and compet-ition
POOR
Case-Series
Kumar 1996 ^166^ | Australia | 1994-96 | (I) 1 or 2 prior CD, delivery at hospital, willing to attempt TOL/(E) TOL contraindicated (no details) | | 33 women attempted TOL | Induction rate/overall and induced VBAC rates | 87.9%/87.9%/89.7% | Very small series. No adverse events. Various reasons induction preferred in this setting (including patient travel time and provider convenience).
| | Evaluate VBAC with early induction in remote-area hospital over almost 2 years
POOR
Iglesias 1991 ^161^ | Canada (Alberta) | 1985-89 | (I) Pregnant mother with prior CD eligible for VBAC | 1985 | TOL: 2 | VBAC rate | 100% | Small rural hospital. No risk-adjustment. Very small n.
| | Assess VBAC in small rural hospital
POOR
| | | | 1986 | 12 | | 75% | VBAC rate denominator is number attempting TOL
| | | | 1987 | 17 | | 76%
| | | | 1988 | 15 | | 87%
| | | | 1989 | 26 | | 81%
Surveys
Barnsley 1990 ^147^ | Canada | NR | (I) Ontario Medical Association section on obstetrics and gynecology | | 192 returned surveys | | | Used hypothetical cases. Obstetricians in community hospital more likely to perform ERCD than those in teaching hospital. Obstetricians more likely to perform ERCD if anesthesia availability >15 minutes.
POOR
Mor-Yosef 1990 ^160^ | Israel | 3 months in 1983-84 | (I) Singleton live delivery with previous CD/(E) Delivery before 26 weeks gestation, fetal malformations, home deliveries, multiple deliveries, >1 prior CD, incomplete data | Medical center | 354 | VBAC rate | 58.1% | Collected patient-level data in survey. No risk adjustment. Difference not significant
| | National survey to assess VBAC
POOR
| | | | General hospital | 542 | 50.9%
| | | | Peripheral hospital | | 61.9%

TOL=trial of labor; VBAC=vaginal birth after cesarean; ERCD=elective repeat cesarean deliverySD=standard deviation

Evidence Table 17a. Insurance Factors - good or fair quality studies

Author Year Quality | Country Setting | Years of study Research objective | Subject eligibility: Included (I)/Excluded (E) | Study Group | Sample size (enrolled/complete) | Measure | Estimate | Notes
Retrospective Cohort Design
King 1994 ^115^ | USA | 1989 | (I) Birth in NY hospital to NY resident with prior CD | Private insurance | 8,855 | VBAC rate/Adjusted odds ratio (CI) | 21.6%/1.0 (reference) | Results adjusted for risk and confounders. VBAC denominator is number of births with prior CD
| NY | Determine effects of hospital characteristics on VBAC rate
GOOD
| | | | HMO | 1,823 | | 25.2/1.15 (1.02, 1.30) | 1.03 (0.90, 1.17) without NYC
| | | | Self-pay | 616 | | 23.4%/1.19 (0.96, 1.47) | 1.28 (1.01, 1.81) without NYC
| | | | Medicaid | 2,650 | | 20.7%/1.01 (0.89, 1.15) | No major difference from with NYC
Stafford 1991 ^116^ | USA | 1986 | (I) Delivery by woman with prior CD in non-military hospital | Private insurance | 18,911 | VBAC rate/Adjusted odds ratio (CI) | 8.1%/1.0 (reference) | Adjusted for a range of potential confounders
| CA | Estimate rates of VBAC with adjustment for potential confounders
GOOD
| | | | Non-Kaiser HMO | 5,094 | | 8.4%/1.0 (0.8, 1.1) | VBAC rate denominator is women with prior CD
| | | | Medi-Cal (Medicaid) | 11,513 | | 9.4%/0.8 (0.8, 0.9)
| | | | Self-pay | 3,370 | | 18.0%/1.7 (1.5, 1.9)
| | | | Kaiser Permanente | 4,413 | | 19.9%/NR | With Kaiser payment OR 3.9 (3.3, 4.6); without OR 2.6 (1.4, 4.6)
| | | | Indigent services in non-county hospital | 666 | | 25.2%/1.9 (1.0, 3.6)
| | | | Other payers | 1,458 | | 17.0%/1.3 (1.1, 1.5)
Stafford 1990 ^170^ | USA | 1986 | (I) Non-military hospital delivery in 1986 with prior CD | Private insurance | 18,837 | VBAC rate (CI) | 8.1% (7.6% 8.6%) | Blue Cross, Blue Shield, others
| CA | Estimate rates of CD in CA
GOOD
| | | | Other HMO's | 5,064 | | 8.3% (7.3%, 9.4%) | Non-Kaiser HMO's
| | | | Medi-Cal | 11,444 | | 9.4% (8.6%, 10.1%) | California Medicaid
| | | | Kaiser Permanente | 4,385 | | 19.9% (18.3%, 21.5%) | Stratified on three potential confounders and adjusted using logistic regression: similar results but only unadjusted reported.
| | | | Self-pay | 3,353 | | 18.1% (16.3%, 19.9%)
| | | | Indigent Services | 660 | | 24.8% (20.4%, 29.3%)
| | | | Other payers | 1,445 | | 17.1% (10.5%, 19.7%)
Gregory 1999 ^164^ | USA | 1995 | (I) Pregnancy of woman with prior CD | Private insurance (excluding all government, HMO, PPO, Blue Cross/ Blue Shield non-HMO non-PPO) versus all other payment sources. | | Adjusted odds ratio (CI) for risk of uterine rupture. Model adjusted for age, ethnicity and payment sources | 1.09 (0.84, 1.29) | No significant association with binary classification of payer.
| CA | Compare outcomes of TOL
FAIR
Santerre 1996 ^136^ | USA | 1987-91 | (I) Data in panel of 55 hospitals | | | | | Regression model showed no effect of payment methods on VBAC rates. Minimum chi-square regression model used.
| MA | Assess impact of ACOG guidelines (published 10/88) on VBAC rate
FAIR

TOL=trial of labor; VBAC=vaginal birth after cesarean; ERCD=elective repeat cesarean delivery SD=standard deviation

Evidence Table 17b. Insurance factors - poor quality studies

Author Year Quality | Country Setting | Years of study Research objective | Subject Eligibility: Included (I)/Excluded (E) | Study Group | Sample Size (enrolled/complete) | Measure | Estimate | Notes
Prospective Cohort Designs
Rageth 1999 ^60^ | Switzerland | 1983-96 | (I) Women with prior CD | TOL | Of 17,613 who had a TOL, 6293 had private insurance | Unadjusted relative risk (95% CI) | 0.84 (0.82, 0.87) | P-value< 0.001. No adjustment for baseline risk or other confounders.
| | Evaluate risks of CD following prior CD
POOR
| | | | ERCD | Of 11,433 who had a ERCD, 4,862 had private insurance | | Reference
Miller 1992 ^173^ | Australia | 1989-90 | (I) Women with at least 1 prior CD who delivered in hospital | Private health insurance | 248 | ERCD rate | 62.50% | No adjustment for risk or other confounders.
| | Assess outcomes in women with prior CD
POOR
| | | | Public health insurance | 70 | | 54.30%
Retrospective Cohort Designs
Wagner 1999 ^171^ | USA | Measure association of insurance type and delivery method | (I) Prior CD, pregnancy >36 weeks, non-emergent/(E) Insurance status unclear | Medicaid/Indigent Care | 321 | TOL rate/VBAC rate (as % of total sample) | 64%/62% | Adjusted for other potential confounders. More frequent CD for fetal distress and abruption and less for failure to progress. Higher clinical risk status. Higher rates of unmarried, history of substance abuse, infection, chronic hypertension, smoking and less prenatal care. Lower mean birth rate. 20% more VBAC than TOL in report. Single institution study.
POOR
| | | | Other private insurance | 655 | | 50% (P-value<0.0001)/60% (P>0.05)
Oleske 1998 ^172^ | USA | 1993 | (I) Singleton births, weight > 500g, in non-federal hospitals with 1 of 3 insurance types | Medicaid managed care (MMC) | | VBAC rates: CA/FL | 27.42/42.29 | No adjustment for risk or other confounders
| CA,FL | Describe variation in CD rates across 3 insurance types
POOR
| | | | Medicaid fee-for-service (MFFS) | | | 22.67/34.49 | Significantly higher than for MFFS in CA and than MFFS and PMC in FL (all p<0.01)
| | | | Private managed care (PMC) | | | 27.77/28.44 | Denominator for VBAC rate unclear.
Curtin 1997 ^167^ | USA | 1995 | (I) Pregnancy in non-federal short-stay hospital | Expected payment source: Blue Cross/Blue Shield | | | | Exact number of women with prior CD not reported.
| | Summarize data from 1995 National Hospital Discharge Survey
POOR
| | | | Other private insurance
| | | | Medicaid
| | | | Other government sources
| | | | Self
| | | | Other
Placek 1988 ^169^ | US | 1980-85 | (I) Pregnancy in non-federal short-stay hospital | Blue Cross | | VBAC rates | 4.30% | No risk adjustment.
| | Summarize national survey estimates
POOR
| | | | Other private insurance | | | 4.50%
| | | | Medicaid/other government | | | 5.80%
| | | | Self-pay, no charge, other | | | 6.90%
Cross-Sectional Designs
Skelton 1997 ^159^ | US (MO) | 1992 | (I) Pregnancy in acute care hospitals in MO. | | | | | Significant positive correlations of VBAC rate with total Medicaid discharges and total with no government assistance.
| | Explore relationships among quality, cost, and competition
POOR

TOL=trial of labor; VBAC=vaginal birth after cesarean; ERCD=elective repeat cesarean delivery SD=standard deviation