# Acronyms and Abbreviations

A | Augmentation
AHRQ | Agency for Healthcare Research and Quality
AI | Augmentation/Induction
BW | Birthweight
CD | Cesarean Delivery
CI | Confidence Interval
CPD | Cephalopelvic Disporportion
CPDI | Cephalopelvic Disproportion Index
ECV | External Cephalic Version
EFW | Estimated Fetal Weight
EPC | Evidence-based Practice Center
ERCD | Elective Repeat Cesarean Delivery
FHT | Fetal Heart Tracing
FP | Family Medicine
FPI | Fetal Pelvic Index
FTOL | Failed Trial of Labor
FTP | Failure to Process
g | Grams
GA | Gestational Age
hrs | Hours
I | Induction
IUGR | Intrauterine Growth Restriction
LOS | Length of Stay
LTCS | Lower segment Transverse Cesarean Section
MD | Medical Doctor
mos | Months
NA | Not Applicable
NPV | Negative Predictive Value
NS-NR | Non-Significant/ actual p-value not reported
OR | Odds Ratio
OR(a) | Adjusted Odds Ratio
PCD | Previous Cesarean Delivery
PIH | Pregnancy Induced Hypertension
PLTCS | Previous Low Traverse Cesarean Section
PPV | Positive Predictive Value
PROM | Premature Rupture of Membranes
RCT | Randomized Clinical Trial
RR | Relative Risk
SD | Standard Deviation
SL | Spontaneous Labor
TOL | Trial of Labor
UR | Uterine Rupture
VBAC | Vaginal Birth After Cesarean Delivery
VD | Vaginal Delivery
wks | Weeks
XRP | X-ray Pelvimetry
yrs | Years