# Bibliography

Abitbol M M, Castillo I, Taylor U B, et al. Vaginal birth after cesarean section: The patient's point of view. Am Fam Physician. 1993;47(1):129-34. [pmid: 8418576].
Abitbol M M, Taylor U B, Castillo I, et al. The cephalopelvic disproportion index. Combined fetal sonography and x-ray pelvimetry for early detection of cephalopelvic disproportion. J Reprod Med. 1991;36(5):369-73. [pmid: 2061886].
Abma JC, Chandra A, Mosher WD, et al. Fertility, family planning, and women's health: new data from the 1995 National Survey of Family Growth. Vital & Health Statistics - Series 23, Data From the National Survey of Family Growth 1997(19):1–114.
Abraham R, Sadovsky E. Delay in the diagnosis of rupture of the uterus due to epidural anesthesia in labor. Gynecol Obstet Invest. 1992;33(4):239-40. [pmid: 1505814].
Abramowitz L, Sobhani I, Ganansia R, et al. Are sphincter defects the cause of anal incontinence after vaginal delivery? Results of a prospective study. Dis Colon Rectum 2000;43(5):590–6; discussion 596–8.
Abu-Ghazzeh Y M, Barqawi R. An appraisal of computed tomography pelvimetry in patients with previous caesarean section. East Medit Health J. 2000;6(23):260-4.
ACOG Committee on Obstetric Practice. Vaginal delivery after a previous cesarean birth. ACOG Committee opinion. Number 143-October 1994. Int J Gynaecol Obster 1995;48(1):127–9.
ACOG Committee on Obstetric Practice. ACOG committee opinion. Rate of vaginal births after cesarean delivery. Number 179, November 1996. Int J Gynaecol Obster 1997;57(1):89–90.
ACOG Committee on Obstetric Practice. ACOG committee opinion. Monitoring during induction of labor with dinoprostone. Number 209, October 1998. Int J Gynaecol Obster 1999;64(2):200.
Adair C D, Sanchez-Ramos L, Gaudier F L, et al. Labor induction in patients with previous cesarean section. Am J Perinatol. 1995;12(6):450-4. [pmid: 8579661].
Adair C D, Sanchez-Ramos L, Kaunitz A M, et al. A trial of labor complicated by uterine rupture following amnioinfusion. South Med J. 1995;88(8):847-8. [pmid: 7631213].
Adair C D, Sanchez-Ramos L, Whitaker D, et al. Trial of labor in patients with a previous lower uterine vertical cesarean section. Am J Obstet Gynecol. 1996;174(3):966-970. [pmid: 8633677].
Adami J, Glimelius B, Cnattingius S, et al. Maternal and perinatal factors associated with non-Hodgkin's lymphoma among children. Int J Cancer. 1996;65(6):774-7. [pmid: 8631590].
Adams D M, Druzin M L, Cederqvist L L. Intrapartum uterine rupture. Obstet Gynecol. 1989;73(3 Pt 2):471-3. [pmid: 2915876].
Adams E K, Mauldin P D, Mauldin J G, et al. Determining cost savings from attempted cephalic version in an inner city delivering population. Health Care Management Science. 2000;3(3):185-92. [pmid: 10907321].
Adolph H P, Adolph B J. Surgery on the edge of the desert. Bull Am Coll Surg. 1997;82(6):8-19. [pmid: 10173075].
Afriat C I. Vaginal birth after cesarean section: A review of the literature. J Perinat Neonat Nurs. 1990;3(3):1-13.
Ahdoot D, Van Nostrand K M, Nguyen N J, et al. The effect of route of delivery on regression of abnormal cervical cytologic findings in the postpartum period. Am J Obstet Gynecol. 1998;178(6):1116-20. [pmid: 9662288].
Akar M E, Yilmaz Z, Gokmen O. Fetal survival despite unrecognized uterine rupture resulting from previous unknown corporeal scar. Arch Gynecol Obstet. 2001;265(2):89-90. [pmid: 11409482].
Akyol D, Mungan T, Unsal A, et al. Prelabour rupture of the membranes at term - No advantage of delaying induction for 24 hours. Aust N Z J Obstet Gynaecol. 1999;39(3):291-295. [pmid: 10554936].
Al Nuaim L A, Mustafa M S. Vaginal breech delivery or a third cesarean section for intrauterine fetal demise. Int J Gynaecol Obster. 1996;52(2):183-4.
Al Sakka M, Dauleh W, Al Hassani S. Case series of uterine rupture and subsequent pregnancy outcome. Int J Fertil Womens Med. 1999;44(6):297-300. [pmid: 10617251].
Al Sakka M, Hamsho A, Khan L. Rupture of the pregnant uterus--a 21-year review. Int J Gynaecol Obster. 1998;63(2):105-8.
Al-Sibai M H, Rahman J, Rahman M S, et al. Emergency hysterectomy in obstetrics--a review of 117 cases. Aust N Z J Obstet Gynaecol. 1987;27(3):180-4. [pmid: 3501713].
Aladjem S. Twice a cesarean, always a cesarean?. Obstet Gynecol. 1989;74(1):137-8. [pmid: 2660042].
Albers L L, Savitz D A. Hospital setting for birth and use of medical procedures in low-risk women. J Nurse Midwifery. 1991;36(6):327-33. [pmid: 1757818].
Albrechtsen S, Rasmussen S, Reigstad H, et al. Evaluation of a protocol for selecting fetuses in breech presentation for vaginal delivery or cesarean section. Am J Obstet Gynecol. 1997;177(3):586-92. [pmid: 9322628].
Ales K L, Druzin M L, Santini D L. Impact of advanced maternal age on the outcome of pregnancy. Surg Gynecol Obstet. 1990;171(3):209-16. [pmid: 2385814].
Alexander J M, Ramus R, Cox S M, et al. Outcome of twin gestations with a single anomalous fetus. Am J Obstet Gynecol. 1997;177(4):849-52. [pmid: 9369832].
Alexander J M, Sharma S K, McIntire D D, et al. Intensity of labor pain and cesarean delivery. Anesth Analg. 2001;92(6):1524-8. [pmid: 11375838].
Alfirevic Z. Oral misoprostol for induction of labour. Cochrane Database of Systematic Reviews 2000(4):CD001338.
Alfirevic Z, Howarth G, Gaussmann A. Oral misoprostol for induction of labour with a viable fetus. Cochrane Database of Systematic Reviews 2000(2):CD001338.
Allenby K, Rand R J. Pregnancies in a woman with a vesico-uterine fistula following lower segment caesarean section. Br J Obstet Gynaecol. 1996;103(1):87-9. [pmid: 8608106].
Amer-Wahlin I, Hellsten C, Noren H, et al. Cardiotocography only versus cardiotocography plus ST analysis of fetal electrocardiogram for intrapartum fetal monitoring: A Swedish randomised controlled trial. Lancet. 2001;358(9281):534-8. [pmid: 11520523].
American Academy of Family Physicians. FACTS about Family Practice. Table 67. (www.aafp.org). 2001.
American College of Obstetricians and Gynecologists. News release: Court-Ordered Treatment Rarely Justified for Obstetrical Care. 1987(August).
American College of Obstetricians and Gynecologists. Vaginal birth after previous cesarean delivery: Clinical Management guidelines for obstetrician-gynecologists. Washington: The College 1999;ACOG Practice Bulletin No. 5.
Amin P, Wiener J J. Vaginal delivery after abdominal wall replacement by Marlex mesh. J Obstet Gynaecol. 1999;19(5):543. [pmid: 15512390].
Amini S B, Dierker L J, Catalano P M, et al. Trends in an obstetric patient population: An eighteen-year study. Am J Obstet Gynecol. 1994;171(4):1014-21. [pmid: 7943064].
Amir W, Peter J, Etan Z. Trial of labor without oxytocin in patients with a previous cesarean section. Am J Perinatol. 1987;4(2):140-3. [pmid: 3566882].
Amon E, Sibai B M, Anderson G D. How perinatologists manage the problem of the presenting breech. Am J Perinatol. 1988;5(3):247-50. [pmid: 3382484].
Ananth C V, Smulian J C, Vintzileos A M. The association of placenta previa with history of cesarean delivery and abortion: A metaanalysis. Am J Obstet Gynecol. 1997;177(5):1071-8. [pmid: 9396896].
Anderson G M, Lomas J. Explaining variations in cesarean section rates: Patients, facilities or policies?. Can Med Assoc J. 1985;132(3):253-6. [pmid: 3967160].
Anderson R, Greener D. A descriptive analysis of home births attended by CNMs in two nurse-midwifery services. J Nurse Midwifery. 1991;36(2):95-103. [pmid: 2037879].
Anderson R E, Anderson D A. The cost-effectiveness of home birth. J Nurse Midwifery. 1999;44(1):30-5. [pmid: 10063222].
Andreasson B, Bock J E, Larsen J. Induction of labor. A double-blind randomized controlled study of prostaglandin E2 vaginal suppositories compared with intranasal oxytocin and with sequential treatment. Acta Obstet Gynecol Scand. 1985;64(2):157-61. [pmid: 3885670].
Andres R L, Piacquadio K M, Resnik R. A reappraisal of the need for autologous blood donation in the obstetric patient. Am J Obstet Gynecol. 1990;163(5 Pt 1):1551-3. [pmid: 2240105].
Annas G J. Protecting the liberty of pregnant patients. N Engl J Med. 1987;316(19):1213-4. [pmid: 3574372].
Annibale D J, Hulsey T C, Wagner C L, et al. Comparative neonatal morbidity of abdominal and vaginal deliveries after uncomplicated pregnancies. Arch Pediatr Adolesc Med. 1995;149(8):862-7. [pmid: 7633538].
Anonymous. Caesarean childbirth. Summary of an NIH consensus statement. Br Med J (Clin Res Ed) 1981;282(6276):1600–4.
Anonymous. Cesarean childbirth: an NIH consensus development conference. Clin Pediatr 1981;20(9):555–60.
Anonymous. Cesarean Childbirth: Report of a Consensus Development Conference Sponsored by the NICHHD in Conjunction with the National Center for Health Care Technology and Assisted by the Office for Medical Applications of Research. NIH Publication 1981;82–2067.
Anonymous. The National Institutes of Health Consensus Development statement on cesarean childbirth. A summary. J Reprod Med 1981;26(3):103–12.
Anonymous. NIH Consensus Development Conference summary--Cesarean childbirth. J Tenn Med Assoc 1981;74(10):734–40.
Anonymous. NIH Consensus Development Task force statement on cesarean childbirth. Am J Obstet Gynecol 1981;139(8):902–9.
Anonymous. Panel discussion: cesarean section. March of Dimes Symposium - perinatal care in the 1980's. November 17, 1980. J Perinat Med 1981;9(4):195–9.
Anonymous. Breech: Vaginal delivery or caesarean section? Br Med J (Clin Res Ed) 1982;285(6350):1275–6.
Anonymous. Kielland or Caesar? Br Med J (Clin Res Ed) 1983;287(6392):609–11.
Anonymous. Forum on malpractice issues in childbirth. Public Health Rep 1985;100(6):629–33.
Anonymous. Vaginal delivery after cesarean section. Am Fam Physician 1985;32(3):90.
Anonymous. Indications for cesarean section: Final statement of the Panel of the National Consensus Conference on Aspects of Cesarean Birth. Can Med Assoc J 1986;134(12):1348–52.
Anonymous. Cesarean births and trial of labor rates. JAMA 1987;257(20):2757–9.
Anonymous. Court-ordered obstetrical interventions. N Engl J Med 1987;317(19):1223–5.
Anonymous. Delivery after caesarean section. Br Med J (Clin Res Ed) 1987;295(6594):388.
Anonymous. Obstetrics'87. A report of the Canadian Medical Association on obstetrical care in Canada. Can Med Assoc J 1987;Suppl:1–26.
Anonymous. Births by cesarean: cost changes, 1982-83 to 1986. Stat Bull Metrop Insur Co 1988;1988(69):18–25.
Anonymous. Costs of normal births: Regional variations, 1986. Stat Bull Metrop Insur Co 1988;69(4):24–32.
Anonymous. The costs of maternity care and childbirth in the United States. Health Insurance Association of America. Research Bulletin 1989;1 (R1589).
Anonymous. Practice parameters: Cesarean birth. Minnesota Clinical Comparison and Assessment Project. QA Rev 1991;3(5):6.
Anonymous. Charges for a cesarean section: United States, 1990. Stat Bull Metrop Insur Co 1992;73(1):12–8.
Anonymous. Induction and augmentation of labor: ACOG Technical bulletin number 157. International Journal of Gynecology & Obstetrics 1992;39(2):139–142.
Anonymous. Improving the timeliness of emergency C-sections at Southwestern Vermont Medical Center leads to improved patient care and increased physician satisfaction. Qual Lett Healthc Lead 1993;5(1):6–8.
Anonymous. Mothers who use nurse midwives have shorter hospital stays and fewer cesarean sections and episiotomies. J Nurs Adm 1993;23(7–8):11, 40.
Anonymous. Rates of cesarean delivery-United States, 1991. MMWR Morb Mortal Wkly Rep 1993;42:285–289.
Anonymous. Health care guideline: Vaginal birth after cesarean. In: Institute for Clinical Systems Integration 1993/1994 health care guidelines 1994;Bloomington(MN):ICSI.
Anonymous. AAFP Task Force on Clinical Policies for Patient Care. Trial of labor vs. elective repeat cesarean section for the woman with a previous cesarean section. American Academy of Family Physicians 1995.
Anonymous. Australia's mothers and babies. Aust Health Rev 1995;18(3):137–8.
Anonymous. Obstetrical stays--IMS, AMA policy. Iowa Med 1995;85(9):358.
Anonymous. Trial of labor vs. elective repeat cesarean section. AAFP Task Force on Clinical Policies for Patient Care. Am Fam Physician 1995;52(6):1763–5.
Anonymous. Vaginal delivery after previous cesarean birth. ACOG Prac Pat 1995;1:1–8.
Anonymous. Average postpartum length of stay for uncomplicated deliveries--New Jersey, 1995. MMWR Morb Mortal Wkly Rep 1996;45(32):700–4.
Anonymous. Health care guideline: Vaginal birth after cesarean. In: Institute for Clinical Systems Integration 1996;1996:577–90.
Anonymous. Multimillion dollar verdict in missed uterine rupture case. Obstet Gynecol Malpract Prev 1996;3(6):41–43.
Anonymous. Vaginal birth after previous caesarean birth. In: The Society of Obstetricians and Gynaecologists of Canada: policy statement, committee opinion, clinical practice guidelines. Ottawa, ON : SOGC 1996;4.
Anonymous. Vaginal delivery after previous cesarean birth. Number 1--August 1995. Committee on Practice Patterns. American College of Obstetricians and Gynecologists. Int J Gynaecol Obster 1996;52(1):90–8.
Anonymous. VBAC (Vaginal Birth After Cesareans): Are cost concerns outweighing possible safety risks? Hosp Case Manag 1996;4(11):161–4.
Anonymous. 1998 ACOG Socioeconomic Survey of Fellows (unpublished.). ACOG NET 1997;www.acog.com.
Anonymous. ACOG practice patterns. External cephalic version. Number 4, July 1997. American College of Obstetricians and Gynecologists. Int J Gynaecol Obster 1997;59(1):73–80.
Anonymous. Electronic fetal heart rate monitoring: Research guidelines for interpretation. National Institute of Child Health and Human Development Research Planning Workshop. American Journal of Obstetrics & Gynecology 1997;177(6):1385–90.
Anonymous. Approach VBAC deliveries cautiously, experts say. Hosp Peer Rev 1998;23(10):189.
Anonymous. C-sections give way to VBACs and better quality. Hosp Peer Rev 1998;23(10):184, 189.
Anonymous. Case records of the Massachusetts General Hospital. Weekly clinicopathological exercises. Case 9-1998. Cardiovascular collapse after vaginal delivery in a patient with a history of cesarean section. N Engl J Med 1998;338(12):821–6.
Anonymous. Charges and LOS for deliveries vary widely by geographic region, analysis concludes. Data Strat Benchmarks 1998;2(10):154–7.
Anonymous. Outreach program slashes Florida health network's rate of cesarean sections. Health Care Cost Reeng Rep 1998;3(9):137–8.
Anonymous. ACOG practice bulletin. Vaginal birth after previous cesarean delivery. Number 2, October 1998. Clinical management guidelines for obstetrician-gynecologists. American College of Obstetricians and Gynecologists. Int J Gynaecol Obster 1999;64(2):201–8.
Anonymous. Misoprostol for cervical ripening: Is it a safe, cost-effective alternative to dinoprostone? Formulary 1999;34(1):77–78.
Anonymous. When the patient changed her mind. Schreiber vs. Physicians Ins. Co. Hosp Law Newsl 1999;16(5):1–3.
Anonymous. From the Centers for Disease Control and Prevention. Use of hospital discharge data to monitor uterine rupture--Massachusetts, 1990-1997. JAMA 2000;283(16):2098–100.
Anonymous. ACOG committee opinion: number 265, December 2001. Mode of term single breech delivery. Obstet Gynecol 2001;98(6):1189–90.
Anonymous. Stats & facts. Vaginal births after cesarean sections: A need to revisit. Manag Care Interface 2001;14(11):34–5.
Appleby J. Data briefing. Caesarean births. Health Serv J. 2001;111(5756):31.
Appleton B, Targett C, Rasmussen M, et al. Knowledge and attitudes about vaginal birth after Caesarean section in Australian hospitals. VBAC Study Group. Vaginal Birth After Caesarean. Aust N Z J Obstet Gynaecol. 2000;40(2):195-9. [pmid: 10925909].
Appleton B, Targett C, Rasmussen M, et al. Vaginal birth after caesarean section: an Australian multicentre study. VBAC Study Group. Aust N Z J Obstet Gynaecol. 2000;40(1):87-91. [pmid: 10870788].
Apuzzio J J, Pelosi M, Frisoli G, et al. Bacterial colonization of amniotic fluid in patients with intact membranes during labor. South Med J. 1984;77(9):1133-5. [pmid: 6484681].
Arkutu A A. Spontaneous uterine rupture with placenta percreta: a case report. Int J Gynaecol Obster. 1980;17(5):485-7.
Arnold M. Midwifery care on trial?. Midwife Health Visit Community Nurse. 1986;22(6):207-8. [pmid: 3637606].
Artinian B M. Collaborative planning of patient care in the prenatal, labor and delivery, and neonatal settings. JOGN Nurs. 1984;13(2):105-10. [pmid: 6562252].
Arulkumaran S, Chua S, Ratnam S S. Symptoms and signs with scar rupture--value of uterine activity measurements. Aust N Z J Obstet Gynaecol. 1992;32(3):208-12. [pmid: 1445128].
Arulkumaran S, Gibb D M, Ingemarsson I, et al. Uterine activity during spontaneous labour after previous lower-segment caesarean section. Br J Obstet Gynaecol. 1989;96(8):933-8. [pmid: 2775690].
Arulkumaran S, Ingemarsson I, Ratnam S S. Oxytocin augmentation in dysfunctional labour after previous caesarean section. Br J Obstet Gynaecol. 1989;96(8):939-941. [pmid: 2775691].
Asaad K, Alaily B. Oxytocin use and delivery outcome in women with one previous caesarean section and pre-labour rupture of the membranes at term. J Obstet Gynaecol. 1994;14(6):420-422.
Asakura H, Myers S A. More than one previous cesarean delivery: a 5-year experience with 435 patients. Obstet Gynecol. 1995;85(6):924-9. [pmid: 7770261].
Asakura H, Nakai A, Ishikawa G, et al. Prediction of uterine dehiscence by measuring lower uterine segment thickness prior to the onset of labor: Evaluation by transvaginal ultrasonography. Nippon Ika Daigaku Zasshi - Journal of the Nippon Medical School. 2000;67(5):352-6.
Atalla R K, Thompson J R, Oppenheimer C A, et al. Reactive thrombocytosis after caesarean section and vaginal delivery: Implications for maternal thromboembolism and its prevention. BJOG. 2000;107(3):411-4. [pmid: 10740340].
Atiba E O, Adeghe A J, Murphy P J, et al. Patients' expectation and caesarean section rate. Lancet. 1993;341(8839):246. [pmid: 8093530].
Austin S E. Childbirth classes for couples desiring VBAC (Vaginal Birth After Cesarean). MCN Am J Matern Child Nurs. 1986;11(4):250-5. [pmid: 3088369].
Awad I T, Shorten G D. Amniotic fluid embolism and isolated coagulopathy: Atypical presentation of amniotic fluid embolism. Eur J Anaesthesiol. 2001;18(6):410-3. [pmid: 11412296].
Ayhan A, Yuce K, Kisnisci H A. Analysis of 20,291 deliveries in a Turkish institution. Int J Gynaecol Obster. 1989;29(2):131-4.
Ayres A W, Johnson T R, Hayashi R. Characteristics of fetal heart rate tracings prior to uterine rupture. Int J Gynaecol Obster. 2001;74(3):235-40.
Azem F, Jaffa A, Lessing J B, et al. Uterine rupture with the use of a low-dose vaginal PGE2 tablet. Acta Obstet Gynecol Scand. 1993;72(4):316-7. [pmid: 8389523].
Baird A G, Jewell D, Walker J J. Management of labour in an isolated rural maternity hospital. BMJ. 1996;312(7025):223-6. [pmid: 8563590].
Bais J M, van dre Borden D M, Pel M, et al. Vaginal birth after caesarean section in a population with a low overall caesarean section rate. Eur J Obstet Gynecol Reprod Biol. 2001;96(2):158-62. [pmid: 11384799].
Baker K. Vaginal delivery after lower uterine cesarean section. Surg Gynecol Obstet. 1955;100:690. [pmid: 14373378].
Bakshi S, Meyer B A. Indications for and outcomes of emergency peripartum hysterectomy. A five-year review. J Reprod Med. 2000;45(9):733-7. [pmid: 11027082].
Balaban D, McCall N, Jones-Bauer E. Quality of Medicaid Managed Care: An evaluation of the Arizona Health Care Cost Containment System (AHCCCS). San Francisco: Laguna Research Associates; 1994.
Baldwin L M, Hart L G, Lloyd M, et al. Defensive medicine and obstetrics. JAMA. 1995;274(20):1606-10. [pmid: 7474245].
Barclay A M, Knapp D P, Kallail K J. The provision of labor and delivery services by graduates of four Kansas family practice residencies. Kans Med. 1996;97(1):19-23. [pmid: 8676586].
Barclay L, Andre C A, Glover P A. Women's business: the Challenge of childbirth. Midwifery. 1989;5(3):122-33. [pmid: 2685513].
Barnhart RJ. Cesarean section: Changing indications, 1968--1977. J Kans Med Soc 1980;81(2):57–62, 78.
Barnsley J M, Vayda E, Lomas J, et al. Cesarean section in Ontario: Practice patterns and responses to hypothetical cases. Can J Surg. 1990;33(2):128-32. [pmid: 2268812].
Barratt K, von Briesen J D. The continued vitality of a patient's informed consent, or, when the patient says ‘no’. Wis Med J. 1999;98(2):60-1.
Barros F C, Vaughan J P, Victora C G, et al. Epidemic of caesarean sections in Brazil. Lancet. 1991;338(8760):167-9. [pmid: 1677075].
Barton A. Caesarean section and litigation. Lancet. 2001;357(9255):556. [pmid: 11229694].
Baskett T F, McMillen R M. Cesarean section: Trends and morbidity. Can Med Assoc J. 1981;125(7):723-6. [pmid: 7326654].
Bassett K L, Iyer N, Kazanjian A. Defensive medicine during hospital obstetrical care: a Byproduct of the technological age. Soc Sci Med. 2000;51(4):523-37. [pmid: 10868668].
Baumann P, Blackwell S C, Schild C, et al. Mathematic modeling to predict abruptio placentae. Am J Obstet Gynecol. 2000;183(4):815-22. [pmid: 11035319].
Beall M, Eglinton G S, Clark S L, et al. Vaginal delivery after cesarean section in women with unknown types of uterine scar. J Reprod Med. 1984;29(1):31-5. [pmid: 6708018].
Beckett V A, Regan L. Vaginal birth after cesarean: The European experience. Clin Obstet Gynecol. 2001;44(3):594-603. [pmid: 11685883].
Beckley S, Gee H, Newton J R. Scar rupture in labour after previous lower uterine segment caesarean section: The role of uterine activity measurement. Br J Obstet Gynaecol. 1991;98(3):265-9. [pmid: 2021565].
Bedoya C, Bartha J L, Rodriguez I, et al. A trial of labor after cesarean section in patients with or without a prior vaginal delivery. Int J Gynaecol Obster. 1992;39(4):285-9.
Beebe L A, Rayburn W F, Beaty C M, et al. Indications for labor induction. Differences between university and community hospitals. J Reprod Med. 2000;45(6):469-75. [pmid: 10900580].
Benedetti T J. Birth injury and method of delivery. N Engl J Med. 1999;341(23):1758-9. [pmid: 10580076].
Benedetti T J, Platt L, Druzin M. Vaginal delivery after previous cesarean section for a nonrecurrent cause. Am J Obstet Gynecol. 1982;142(3):358-9. [pmid: 7065029].
Bennett B B. Uterine rupture during induction of labor at term with intravaginal misoprostol. Obstet Gynecol. 1997;89(5 Pt 2):832-3. [pmid: 9166339].
Bennett K A, Butt K, Crane J M G, et al. A masked randomized comparison of oral and vaginal administration of misoprostol for labor induction. Obstet Gynecol. 1998;92(4 I):481-486. [pmid: 9764615].
Bennett M J, Laurence D T. Induction of labour with prostaglandin E2 vaginal pessaries in high risk pregnancies. J Obstet Gynaecol. 1981;2(2):71-73.
Bennetts A B, Lubic R W. The free-standing birth centre. Lancet. 1982;1(8268):378-80. [pmid: 6120357].
Benson M D. Therapeutic equivalents in clinical practice. Int J Fertil Womens Med. 2001;46(2):89-94. [pmid: 11374660].
Berard J, Dufour P, Vinatier D, et al. Fetal macrosomia: risk factors and outcome. A study of the outcome concerning 100 cases >4500 g. Eur J Obstet Gynecol Reprod Biol. 1998;77(1):51-9. [pmid: 9550201].
Berchuck A, Sokol R J. Previous cesarean section, placenta increta, and uterine rupture in second-trimester abortion. Am J Obstet Gynecol. 1983;145(6):766-7. [pmid: 6829668].
Berg A, Yuval D, Ivancovsky M, et al. Patient perception of involvement in medical care during labor and delivery. Isr Med Assoc J. 2001;3(5):352-6. [pmid: 11411200].
Berghella V, Rogers R A, Lescale K. Stripping of membranes as a safe method to reduce prolonged pregnancies. Obstet Gynecol. 1996;87(6):927-931. [pmid: 8649700].
Bergman A, Henderson M, Cline J L. Technology and outpatient review: a Preliminary evaluation. Qrb. Quality Review Bulletin. 1990;16(6):234-9. [pmid: 2120661].
Bergsjo P, Denman D W 3rd, Hoffman H J, et al. Duration of human singleton pregnancy. A population-based study. Acta Obstet Gynecol Scand. 1990;69(3):197-207. [pmid: 2220340].
Bergsjo P, Schmidt E, Pusch D. Differences in the reported frequencies of some obstetrical interventions in Europe. Br J Obstet Gynaecol. 1983;90(7):628-32. [pmid: 6871130].
Berkman H. A discussion of medical malpractice and cesarean section. Spec Law Dig Health Care Law 1993(170):9–30.
Berkowitz G S, Fiarman G S, Mojica M A, et al. Effect of physician characteristics on the cesarean birth rate. Am J Obstet Gynecol. 1989;161(1):146-9. [pmid: 2750795].
Berkowitz G S, Skovron M L, Lapinski R H, et al. Delayed childbearing and the outcome of pregnancy. N Engl J Med. 1990;322(10):659-64. [pmid: 2304491].
Berkus M D, Ramamurthy R S, O'Connor P S, et al. Cohort study of Silastic obstetric vacuum cup deliveries: II Unsuccessful vacuum extraction. Obstet Gynecol. 1986;68(5):662-6. [pmid: 3763080].
Bernstein P, Leyland N, Gurland P, et al. Cervical ripening and labor induction with prostaglandin E2 gel: a Placebo-controlled study. Am J Obstet Gynecol. 1987;156(2):336-40. [pmid: 3548368].
Bertollini R, DiLallo D, Spadea T, et al. Cesarean section rates in Italy by hospital payment mode: An analysis based on birth certificates. Am J Public Health. 1992;82(2):257-61. [pmid: 1739159].
Bex P, Gunasekera P C, Phipps J H. Difficulties with controlled release prostaglandin E2 pessaries (II). Lancet. 1990;336(8707):119. [pmid: 1975301].
Bhal P S, Sharma A, Asaad K. Vaginal delivery after caesarean section: factors influencing success rates. Aust N Z J Obstet Gynaecol. 1996;36(4):497-8. [pmid: 9006850].
Bianco A, Stone J, Lynch L, et al. Pregnancy outcome at age 40 and older. Obstet Gynecol. 1996;87(6):917-22. [pmid: 8649698].
Bick D E, MacArthur C. Attendance, content and relevance of the six week postnatal examination. Midwifery. 1995;11(2):69-73. [pmid: 7616861].
Bickell N A, Zdeb M S, Applegate M S, et al. Effect of external peer review on cesarean delivery rates: a statewide program. Obstet Gynecol. 1996;87(5 Pt 1):664-7. [pmid: 8677064].
Bique C, Bugalho A, Bergstrom S. Labor induction by vaginal misoprostol in grand multiparous women. Acta Obstet Gynecol Scand. 1999;78(3):198-201. [pmid: 10078580].
Biran G, Mazor M, Shoham I, et al. Premature delivery of small versus appropriate-for-gestational-age neonates. A comparative study of maternal characteristics. J Reprod Med. 1994;39(1):39-44. [pmid: 8169915].
Blackwell S C, Hassan S S, Wolfe H M, et al. Vaginal birth after cesarean in the diabetic gravida. J Reprod Med. 2000;45(12):987-90. [pmid: 11153259].
Blakemore K J, Qin N G, Petrie R H, et al. A prospective comparison of hourly and quarter-hourly oxytocin dose increase intervals for the induction of labor at term. Obstet Gynecol. 1990;75(5):757-61. [pmid: 2325960].
Blanchette H, Blanchette M, McCabe J, et al. Is vaginal birth after cesarean safe? Experience at a community hospital. Am J Obstet Gynecol 2001;184(7):1478–84; discussion 1484–7.
Blanchette H A, Nayak S, Erasmus S, et al. Comparison of the safety and efficacy of intravaginal misoprostol (prostaglandin e1) with those of dinoprostone (prostaglandin E2) for cervical ripening and induction of labor in a community hospital. Am J Obstet Gynecol. 1999;180(6 Pt I):1551-1559. [pmid: 10368503].
Blanco J D, Collins M, Willis D, et al. Prostaglandin E2 gel induction of patients with a prior low transverse cesarean section. Am J Perinatol. 1992;9(2):80-3. [pmid: 1590872].
Blegen M A, Reiter R C, Goode C J, et al. Outcomes of hospital-based managed care: a Multivariate analysis of cost and quality. Obstet Gynecol. 1995;86(5):809-14. [pmid: 7566854].
Blickstein I, Lancet M, Kessler I. Re-evaluation of the obstetrical risk for the older primipara. Int J Gynaecol Obster. 1987;25(2):107-12.
Blumenthal P D, Gaffikin L, Atad J, et al. Nonpharmaceutical ripening of the unfavorable cervix and induction of labor by a novel double balloon device [8]. Obstet Gynecol. 1991;77(6):967-968. [pmid: 2030880].
Boivin J. Baby and me--out 1,2,3. Nursing Spectrum (D.C./Baltimore Metro Edition). 1995;5(17):3.
Bolaji II, Meehan F P. Caesarean section survey in Galway--1973 through 1987. Eur J Obstet Gynecol Reprod Biol. 1993;48(1):1-8. [pmid: 8449255].
Bonham D G. Caesarean birth. N Z Med J. 1983;96(728):205-6. [pmid: 6572825].
Bonnar J, Norris L A, Greene R. Low molecular weight heparin for thromboprophylaxis during caesarean section. Thromb Res. 1999;96(4):317-22. [pmid: 10593435].
Bors-Koefoed R, Zylstra S, Resseguie L J, et al. Statistical models of outcome in malpractice lawsuits involving death or neurologically impaired infants. J Matern Fetal Med. 1998;7(3):124-31. [pmid: 9642609].
Bortolus R. Determinants of response to intracervical prostaglandin E2 for cervical ripening. Eur J Obstet Gynecol Reprod Biol. 1999;87(2):137-141. [pmid: 10597962].
Bossert R, Rayburn W F, Stanley J R, et al. Early postpartum discharge at a university hospital. Outcome analysis. J Reprod Med. 2001;46(1):39-43. [pmid: 11209630].
Bottoms S F, Hirsch V J, Sokol R J. Medical management of arrest disorders of labor: a Current overview. Am J Obstet Gynecol. 1987;156(4):935-9. [pmid: 3578404].
Boucher M, Tahilramaney M P, Eglinton G S, et al. Maternal morbidity as related to trial of labor after previous cesarean delivery. A quantitative analysis. J Reprod Med. 1984;29(1):12-6. [pmid: 6708013].
Boulot P, Hoffet M, Bachelard B, et al. Late vaginal induced abortion after a previous cesarean birth: Potential for uterine rupture. Gynecol Obstet Invest. 1993;36(2):87-90. [pmid: 8225053].
Boulvain M, Fraser W D, Brisson-Carroll G, et al. Trial of labour after caesarean section in sub-Saharan Africa: a Meta-analysis. Br J Obstet Gynaecol. 1997;104(12):1385-90. [pmid: 9422017].
Boulvain M, Irion O. Stripping/sweeping the membranes for inducing labour or preventing post-term pregnancy. Cochrane Database of Systematic Reviews 2000(2):CD000451.
Boulvain M, Irion O, Marcoux S, et al. Sweeping of the membranes to prevent post-term pregnancy and to induce labour: a Systematic review. Br J Obstet Gynaecol. 1999;106(5):481-5. [pmid: 10430199].
Boulvain M, Stan C, Irion O. Elective delivery in diabetic pregnant women. Cochrane Database of Systematic Reviews 2000(2):CD001997.
Bowers S K, MacDonald H M, Shapiro E D. Prevention of iatrogenic neonatal respiratory distress syndrome: Elective repeat cesarean section and spontaneous labor. Am J Obstet Gynecol. 1982;143(2):186-9. [pmid: 7081331].
Boyce P M, Todd A L. Increased risk of postnatal depression after emergency caesarean section. Med J Aust. 1992;157(3):172-4. [pmid: 1635490].
Boyd M E, Usher R H, McLean F H, et al. Obstetric consequences of postmaturity. Am J Obstet Gynecol. 1988;158(2):334-8. [pmid: 3277431].
Boyers S P, Gilbert W M. Elective repeat caesarean section versus trial of labour: the neonatologist's view. Lancet. 1998;351(9097):155. [pmid: 9449865].
Brady K, Read J A. Vaginal delivery of twins after previous cesarean section. N Engl J Med. 1988;319(2):118-9. [pmid: 3380126].
Brahams D. Caesarean sections by court order. Lancet. 1996;348(9030):770. [pmid: 8813981].
Bramadat I J, Driedger M. Satisfaction with childbirth: Theories and methods of measurement. Birth. 1993;20(1):22-9. [pmid: 8503963].
Brandsma C, Calhoun B C, Vannatta J E. Uncomplicated pregnancy: Clinical pathway genesis based on the nursing process. Mil Med. 2000;165(11):839-43. [pmid: 11143430].
Braveman P, Egerter S, Edmonston F, et al. Racial/ethnic differences in the likelihood of cesarean delivery, California. Am J Public Health. 1995;85(5):625-30. [pmid: 7733420].
Braveman P A. Short hospital stays for mothers and newborns. J Fam Pract. 1996;42(5):523-5. [pmid: 8642372].
Bredfeldt R C, Thomas J M, Massie M. Pregnancy care in family practice: Medical student perspectives on specialty and residency selection. Fam Med. 1994;26(3):145-8. [pmid: 8026657].
Bremme K, Bygdeman M. A comparative study of uterine activity and fetal heart rate pattern in labor induced with oral prostaglandin E2 or oxytocin. Acta Obstet Gynecol Scand Suppl. 1980;92:23-9. [pmid: 7004051].
Bremme K, Bygdeman M. Induction of labor by oxytocin or prostaglandin E2. Acta Obstet Gynecol Scand Suppl. 1980;92:11-21. [pmid: 7004050].
Brengman S L, Burns M K. Vaginal delivery after C-section. Am J Nurs. 1983;83(11):1544-7. [pmid: 6556884].
Bretelle F, Cravello L, Shojai R, et al. Vaginal birth following two previous cesarean sections. Eur J Obstet Gynecol Reprod Biol. 2001;94(1):23-6. [pmid: 11134821].
Bricker L, Luckas M. Amniotomy alone for induction of labour. Cochrane Database of Systematic Reviews 2000(4):CD002862.
Brink S. C-sections rise but may not be the kindest cut. US News & World Report. 2000;129(9):63.
Brisson-Carroll G, Fraser W, Breart G, et al. The effect of routine early amniotomy on spontaneous labor: a Meta-analysis. Obstet Gynecol. 1996;87(5 Pt 2):891-6. [pmid: 8677130].
Britton J R. Postpartum early hospital discharge and follow-up practices in Canada and the United States. Birth. 1998;25(3):161-8. [pmid: 9767218].
Brody C Z, Kosasa T S, Nakayama R T, et al. Vaginal birth after cesarean section in Hawaii. Experience at Kapiolani Medical Center for Women and Children. Hawaii Med J. 1993;52(2):38-42. [pmid: 8468182].
Broe S, Khoo S K. How safe is caesarean section in current practice? A survey of mortality and serious morbidity. Aust N Z J Obstet Gynaecol. 1989;29(2):93-8. [pmid: 2803134].
Bromham D R, Anderson R S. Uterine scar rupture in labour induced with vaginal prostaglandin E2. Lancet. 1980;2(8192):485-486. [pmid: 6106134].
Brooten D, Roncoli M, Finkler S, et al. A randomized trial of early hospital discharge and home follow-up of women having cesarean birth. Obstet Gynecol. 1994;84(5):832-8. [pmid: 7936522].
Brow C S, Garcia J I, Pellegrini J E. Comparison of the length of stage II labor and incidence of forceps and cesarean delivery after epidural infusion of 0.125% bupivacaine with 2 mu/mL fentanyl as compared with 0.0625% bupivacaine with 2 mu/mL fentanyl. CRNA. 2000;11(2):51-6. [pmid: 11271039].
Brown C E, Stettler R W, Twickler D, et al. Puerperal septic pelvic thrombophlebitis: incidence and response to heparin therapy. Am J Obstet Gynecol. 1999;181(1):143-8. [pmid: 10411810].
Brown S. Mothers who use nurse midwives have fewer C-sections, episiotomies and shorter hospital stays. Penn Nurse. 1993;48(4):9.
Brown S. Women's views of care in labour and birth: Is anyone listening? Proceedings of the 2nd Annual Conference of the Perinatal Society of Autralia and New Zealand 1998.
Brown S, Lumley J. Satisfaction with care in labor and birth: a Survey of 790 Australian women. Birth. 1994;21(1):4-13. [pmid: 8155224].
Brown S, Lumley J. Changing childbirth: Lessons from an Australian survey of 1336 women. Br J Obstet Gynaecol. 1998;105(2):143-55. [pmid: 9501778].
Brown S, Lumley J. Maternal health after childbirth: Results of an Australian population based survey. Br J Obstet Gynaecol. 1998;105(2):156-61. [pmid: 9501779].
Bryan H, Hawrylyshyn P, Hogg-Johnson S, et al. Perinatal factors associated with the respiratory distress syndrome. Am J Obstet Gynecol. 1990;162(2):476-81. [pmid: 2309834].
Bryant D R, Leonardi M R, Landwehr J B, et al. Limited usefulness of fetal weight in predicting neonatal brachial plexus injury. Am J Obstet Gynecol. 1998;179(3 Pt 1):686-9. [pmid: 9757972].
Buechner J S. Rate of vaginal births among women with previous cesarean deliveries. Med Health Rhode Island. 1997;80(2):63-4.
Buist R, Brown J, McNamara T. For whom is the caesarean section rate high?. N Z Med J. 1999;112(1101):469-71. [pmid: 10678212].
Bujold E, Gauthier R J. Neonatal morbidity associated with uterine rupture: What are the risk factors?. Am J Obstet Gynecol. 2002;186(2):311-4. [pmid: 11854656].
Burke M S, Porreco R P. Obstetric factors causing early periventricular-intraventricular hemorrhage. Obstet Gynecol. 1985;65(6):858-9. [pmid: 4000575].
Burns L R, Chilingerian J A, Wholey D R. The effect of physician practice organization on efficient utilization of hospital resources. Health Serv Res. 1994;29(5):583-603. [pmid: 8002351].
Burns L R, Geller S E, Wholey D R. The effect of physician factors on the cesarean section decision. Med Care. 1995;33(4):365-82. [pmid: 7731278].
Burns L R, Wholey D R, Abeln M O. Hospital utilization and mortality levels for patients in the Arizona Health Care Cost Containment System. Inquiry. 1993;30(2):142-56. [pmid: 8314603].
Burrows J. The parturient woman: Can there be room for more than ‘one person with full and equal rights inside a single human skin’?. J Adv Nurs. 2001;33(5):689-95. [pmid: 11298206].
Burt R D, Vaughan T L, Daling J R. Evaluating the risks of cesarean section: Low Apgar score in repeat C-section and vaginal deliveries. Am J Public Health. 1988;78(10):1312-4. [pmid: 3421386].
Bussinger E K. Vaginal birth after cesarean section in a rural private setting. Nebr Med J. 1993;78(11):358-60.
Butler J, Abrams B, Parker J, et al. Supportive nurse-midwife care is associated with a reduced incidence of cesarean section. Am J Obstet Gynecol. 1993;168(5):1407-13. [pmid: 8166781].
Byrne J P, Crowther C A, Moss J R. A randomised controlled trial comparing birthing centre care with delivery suite care in Adelaide, Australia. Aust N Z J Obstet Gynaecol. 2000;40(3):268-74. [pmid: 11065032].
Cadet J J. Occult uterine rupture: Role of ultrasonography. J Natl Med Assoc. 1998;90(6):374-6. [pmid: 9640909].
Cain M. Choice of plan in Michigan Medicaid and cesarean section delivery. AHSR FSHR Annu Meet Abstr Book;13:2a–4a.
Callahan C, Chescheir N, Steiner B D. Safety and efficacy of attempted vaginal birth after cesarean beyond the estimated date of delivery. J Reprod Med. 1999;44(7):606-10. [pmid: 10442323].
Carey T S, Weis K, Homer C. Prepaid versus traditional Medicaid plans: Lack of effect on pregnancy outcomes and prenatal care. Health Serv Res. 1991;26(2):165-81. [pmid: 2061055].
Carlan S J, Bouldin S, O'Brien W F. Extemporaneous preparation of misoprostol gel for cervical ripening: a Randomized trial. Obstet Gynecol. 1997;90(6):911-5. [pmid: 9397101].
Carley M E, Turner R J, Scott D E, et al. Obstetric history in women with surgically corrected adult urinary incontinence or pelvic organ prolapse. J Am Assoc Gynecol Laparosc. 1999;6(1):85-9. [pmid: 9971858].
Carlomagno G, Candussi G, Conforti B R, et al. Vaginal birth after caesarean section: Further contribution to counteract caesarean section epidemic. Ann Ig. 1992;4(4):199-202. [pmid: 1284577].
Carlsson C, Nybell-Lindahl G, Ingemarsson I. Extradural block in patients who have previously undergone caesarean section. Br J Anaesth. 1980;52(8):827-30. [pmid: 7426260].
Caron A, Neuhauser D. The effect of public accountability on hospital performance: Trends in rates for cesarean sections and vaginal births after cesarean section in Cleveland, Ohio. Qual Manag Health Care. 1999;7(2):1-10. [pmid: 10346457].
Carpenter M W, Soule D, Yates W T, et al. Practice environment is associated with obstetric decision making regarding abnormal labor. Obstet Gynecol. 1987;70(4):657-62. [pmid: 3627632].
Carr C J, Patton R. A comparison of varying doses of vaginal prostaglandin E2 for induction of labour. Ir Med J. 1984;77(3):70-2. [pmid: 6706529].
Carr C J, Winckworth T, Finneran E. Trial of vaginal prostaglandin pessary for induction of labour. Ir J Med Sci. 1987;156(9):265-7. [pmid: 3316113].
Carroll S G, Turner M J, Stronge J M, et al. Management of antepartum spontaneous membrane rupture after one previous caesarean section. Eur J Obstet Gynecol Reprod Biol. 1990;35(23):173-8. [pmid: 2335251].
Carter L V, Dooley D J, Elliott C E, et al. Obstetrics in small hospitals. Med J Aust. 1980;1(8):359-62. [pmid: 7393071].
Carty E M, Tier T. Birth planning. A reality-based script for building confidence. J Nurse Midwifery. 1989;34(3):111-4. [pmid: 2732798].
Caspi B, Lancet M, Kessler I. Sinusoidal pattern of uterine contractions in abruptio placentae. Int J Gynaecol Obster. 1980;17(6):615-6.
Castledine G, Oliver J, Turton P, et al. Fact-finding mission. Nurs Times. 1985;81(21):23.
Catanese M L. Vaginal birth after cesarean: Recommendations, risks, realities, and the client's right to know. Holist Nurs Pract. 1987;2(1):35-43. [pmid: 3667729].
Catanzarite V A. Risk of vaginal delivery after a prior cesarean section. Am J Obstet Gynecol. 1987;157(1):213. [pmid: 3605259].
Catanzarite V A, Foster E, Robinette P, et al. Maternal death due to rupture of a low transverse cesarean section incision during labor at home. West J Med. 1992;157(4):454-5. [pmid: 1462547].
Catanzarite V A, Mehalek K E, Wachtel T, et al. Sonographic diagnosis of traumatic and later recurrent uterine rupture. Am J Perinatol. 1996;13(3):177-80. [pmid: 8688111].
Catlin A J. When pregnant women and their physicians disagree on the need for cesarean section: No simple solution. Adv Pract Nurs Q. 1998;4(2):23-9. [pmid: 9874946].
Caughey A B, Shipp T D, Repke J T, et al. Trial of labor after cesarean delivery: The effect of previous vaginal delivery. Am J Obstet Gynecol. 1998;179(4):938-41. [pmid: 9790374].
Caughey A B, Shipp T D, Repke J T, et al. Rate of uterine rupture during a trial of labor in women with one or two prior cesarean deliveries. Am J Obstet Gynecol. 1999;181(4):872-6. [pmid: 10521745].
Cavero C M, Fullerton J T, Bartlome J A. Assessment of the process and outcomes of the first 1,000 births of a nurse-midwifery service. J Nurse Midwifery. 1991;36(2):104-10. [pmid: 2037871].
Cepicky P, Stembera Z, Zeman J, et al. When is it possible to meet the wish of a woman to terminate her labour by caesarean section?. Eur J Obstet Gynecol Reprod Biol. 1991;38(2):109-12. [pmid: 1995378].
Chalmers B, Meyer D. What women say about their birth experiences: a Cross-cultural study. Journal of Psychosomatic Obstetrics & Gynecology. 1994;15(4):211-8. [pmid: 7881507].
Chambliss L R, Daly C, Medearis A L, et al. The role of selection bias in comparing cesarean birth rates between physician and midwifery management. Obstet Gynecol. 1992;80(2):161-5. [pmid: 1635724].
Chan B C, Lao T T. Influence of parity on the obstetric performance of mothers aged 40 years and above. Hum Reprod. 1999;14(3):833-7. [pmid: 10221722].
Chan C C, To W W. Antepartum hemorrhage of unknown origin--What is its clinical significance?. Acta Obstet Gynecol Scand. 1999;78(3):186-90. [pmid: 10078578].
Chang C. Trial of labor with prior vertical cesarean incision. J Fam Pract. 1997;45(5):380-1. [pmid: 9374961].
Chang M Y, Tsieh T T, Chu K K, et al. An analysis of 121 trial labors following a previous cesarean section. Changgeng Yi Xue Za Zhi. 1987;10(1):28-36. [pmid: 3455272].
Chanrachakul B, Chaturachinda K, Phuapradit W, et al. Cesarean and postpartum hysterectomy. Int J Gynaecol Obster. 1996;54(2):109-13.
Chanrachakul B, Herabutya Y, Punyavachira P. Potential efficacy of nitric oxide for cervical ripening in pregnancy at term. Int J Gynaecol Obster. 2000;71(3):217-9.
Chanrachakul B, Herabutya Y, Udomsubpayakul U. Epidemic of cesarean section at the general, private and university hospitals in Thailand. Journal of Obstetrics & Gynaecology Research. 2000;26(5):357-61. [pmid: 11147723].
Chapman DJ, Perez-Escamilla R. Identification of risk factors for delayed onset of lactation. J Am Diet Assoc 1999;99(4):450–4; quiz 455–6.
Chapman K, Meire H, Chapman R. The value of serial ultrasounds in the management of recurrent uterine scar rupture. Br J Obstet Gynaecol. 1994;101(6):549-51. [pmid: 8018651].
Chapman R H, Stone P W, Sandberg E A, et al. A comprehensive league table of cost-utility ratios and a sub-table of “panel-worthy” studies. Med Decis Making. 2000;20(4):451-67. [pmid: 11059478].
Chapman S J, Owen J, Hauth J C. One- versus two-layer closure of a low transverse cesarean: the Next pregnancy. Obstet Gynecol. 1997;89(1):16-8. [pmid: 8990429].
Chaska B W, Mellstrom M S, Grambsch P M, et al. Influence of site of obstetric care and delivery on pregnancy management and outcome. J Am Board Fam Pract. 1988;1(3):152-63. [pmid: 3177013].
Chattopadhyay K, Sengupta B S, Edress Y B, et al. Vaginal birth after cesarean section: Management debate. Int J Gynaecol Obster. 1988;26(2):189-96.
Chattopadhyay S K, Sherbeeni M M, Anokute C C. Planned vaginal delivery after two previous caesarean sections. Br J Obstet Gynaecol. 1994;101(6):498-500. [pmid: 8018637].
Chauhan S P, Magann E F, Carroll C S, et al. Mode of delivery for the morbidly obese with prior cesarean delivery: Vaginal versus repeat cesarean section. Am J Obstet Gynecol. 2001;185(2):349-54. [pmid: 11518890].
Chauhan S P, Troyer L R, Hendrix N W, et al. Neonatal acidemia with trial of labor among parturients with prior cesarean delivery: a Case-control study. J Matern Fetal Med. 2000;9(5):278-81. [pmid: 11132582].
Chazotte C, Cohen W R. Catastrophic complications of previous cesarean section. Am J Obstet Gynecol. 1990;163(3):738-42. [pmid: 2403155].
Chazotte C, Madden R, Cohen W R. Labor patterns in women with previous cesareans. Obstet Gynecol. 1990;75(3 Pt 1):350-5. [pmid: 2304706].
Chelmow D, Kilpatrick S J, Laros R K. Maternal and neonatal outcomes after prolonged latent phase. Obstet Gynecol. 1993;81(4):486-91. [pmid: 8459953].
Chelmow D, Laros R K. Maternal and neonatal outcomes after oxytocin augmentation in patients undergoing a trial of labor after prior cesarean delivery. Obstet Gynecol. 1992;80(6):966-71. [pmid: 1448265].
Chen C H, Wang S Y, Chang M Y. Women's perceptions of helpful and unhelpful nursing behaviors during labor: a Study in Taiwan. Birth. 2001;28(3):180-5. [pmid: 11552966].
Chen D C, Nommsen-Rivers L, Dewey K G, et al. Stress during labor and delivery and early lactation performance. Am J Clin Nutr. 1998;68(2):335-44. [pmid: 9701191].
Chen H Y, Chen S J, Hsieh F J. Observation of cesarean section scar by transvaginal ultrasonography. Ultrasound Med Biol. 1990;16(5):443-7. [pmid: 2238250].
Chen K C, Hsieh T T. Rupture of gravid uterus: a Eight-year clinical analysis and review of the literature. Changgeng Yi Xue Za Zhi. 1992;15(1):15-22. [pmid: 1581835].
Chen L H, Tan K H, Yeo G S. A ten-year review of uterine rupture in modern obstetric practice. Ann Acad Med Singapore. 1995;24(6):830-5. [pmid: 8838990].
Cheng M, Hannah M. Breech delivery at term: a Critical review of the literature. Obstet Gynecol. 1993;82(4 Pt 1):605-18. [pmid: 8377990].
Chervenak F A, Herslinger R, Freedman R, et al. Current perspectives on iatrogenic neonatal respiratory distress syndrome. J Reprod Med. 1986;31(1):53-7. [pmid: 3512821].
Chervenak F A, McCullough L B. An ethically justified algorithm for offering, recommending, and performing cesarean delivery and its application in managed care practice. Obstet Gynecol. 1996;87(2):302-5. [pmid: 8559543].
Chetty V K. Stochastic technology, production organization and costs. J Health Econ. 1998;17(2):187-210. [pmid: 10180915].
Cheung T H, Leung A, Chang A. Macrosomic babies. Aust N Z J Obstet Gynaecol. 1990;30(4):319-22. [pmid: 2082887].
Chew S, Biswas A. Caesarean and postpartum hysterectomy. Singapore Med J. 1998;39(1):9-13. [pmid: 9557096].
Chew S Y. Uterine rupture in labour. A 10-year review. Singapore Med J. 1984;25(1):24-9. [pmid: 6463658].
Chez R A. Vaginal birth after cesarean section. Am J Obstet Gynecol. 1989;160(5 Pt 1):1251. [pmid: 2729403].
Chez R A. Cervical ripening and labor induction after previous cesarean delivery. Clin Obstet Gynecol. 1995;38(2):287-92. [pmid: 7554596].
Chez R A, Droegemueller W, Gant N F Jr, et al. Clinical experience reported by candidates for the American Board of Obstetrics and Gynecology 1995 and 1997 oral examinations. Am J Obstet Gynecol. 2001;185(6):1429-32. [pmid: 11744920].
Choy-Hee L, Raynor B D. Misoprostol induction of labor among women with a history of cesarean delivery. Am J Obstet Gynecol. 2001;184(6):1115-7. [pmid: 11349173].
Chua S, Arulkumaran S, Kurup A, et al. Oxytocin titration for induction of labour: a Prospective randomized study of 15 versus 30 minute dose increment schedules. Aust N Z J Obstet Gynaecol. 1991;31(2):134-7. [pmid: 1930035].
Chua S, Arulkumaran S, Singh P, et al. Trial of labour after previous caesarean section: Obstetric outcome. Aust N Z J Obstet Gynaecol. 1989;29(1):12-7. [pmid: 2562593].
Chua S, Kurup A, Arulkumaran S, et al. Augmentation of labor: Does internal tocography result in better obstetric outcome than external tocography?. Obstet Gynecol. 1990;76(2):164-7. [pmid: 2196493].
Chuang JH, Jenders RA. Trial of labor versus elective repeat cesarean section for the women with a previous cesarean section: a Decision analysis. Proceedings / AMIA Annual Symposium 1999:226–30.
Chuck F J, Huffaker B J. Labor induction with intravaginal misoprostol versus intracervical prostaglandin E2 gel (Prepidil gel): Randomized comparison. Am J Obstet Gynecol. 1995;173(4):1137-42. [pmid: 7485307].
Chung A, Macario A, El-Sayed Y Y, et al. Cost-effectiveness of a trial of labor after previous cesarean. Obstet Gynecol. 2001;97(6):932-41. [pmid: 11384699].
Clark J F, Westney L S, Lawyer C J. Adolescent pregnancy: a 25-year review. J Natl Med Assoc. 1987;79(4):377-80. [pmid: 3586034].
Clark L, Mugford M, Paterson C. How does the mode of delivery affect the cost of maternity care?. Br J Obstet Gynaecol. 1991;98(6):519-23. [pmid: 1873239].
Clark S L. Rupture of the scarred uterus. Obstetrics & Gynecology Clinics of North America. 1988;15(4):737-44. [pmid: 3226674].
Clark S L, Eglinton G S, Beall M, et al. Effect of indication for previous cesarean section on subsequent delivery outcome in patients undergoing a trial of labor. J Reprod Med. 1984;29(1):22-5. [pmid: 6708015].
Clark SL, Hankins GD, Dudley DA, et al. Amniotic fluid embolism: Analysis of the national registry. Am J Obstet Gynecol 1995;172(4 Pt 1):1158–67; discussion 1167–9.
Clark S L, Scott J R, Porter T F, et al. Is vaginal birth after cesarean less expensive than repeat cesarean delivery?. Am J Obstet Gynecol. 2000;182(3):599-602. [pmid: 10739514].
Clark S L, Yeh S Y, Phelan J P, et al. Emergency hysterectomy for obstetric hemorrhage. Obstet Gynecol. 1984;64(3):376-80. [pmid: 6462567].
Clarke S C, Taffel S. Changes in cesarean delivery in the United States, 1988 and 1993. Birth. 1995;22(2):63-7. [pmid: 7779224].
Clarke S C, Taffel S M. Rates of cesarean and VBAC delivery, United States, 1994. Birth. 1996;23(3):166-8. [pmid: 8924103].
Clarke S C, Taffel S M. State variation in rates of cesarean and VBAC delivery: 1989 and 1993. Stat Bull Metrop Insur Co. 1996;77(1):28-36. [pmid: 8744893].
Cnattingius S, Forman M R, Berendes H W, et al. Delayed childbearing and risk of adverse perinatal outcome. A population-based study. JAMA. 1992;268(7):886-90. [pmid: 1640617].
Coco A S, Gates T J, Gallagher M E, et al. Association of attending physician specialty with the cesarean delivery rate in the same patient population. Fam Med. 2000;32(9):639-44. [pmid: 11039152].
Cohen M, Carson B S. Respiratory morbidity benefit of awaiting onset of labor after elective cesarean section. Obstet Gynecol. 1985;65(6):818-24. [pmid: 4000571].
Cohen NW, LaLeike S. What factors cause unnecessary cesareans? Midwifery Today Childbirth Educ 1992(23):16–7.
Cohen R L. Factors influencing maternal choice of childbirth alternatives. J Am Acad Child Psychiatry. 1981;20(1):1-15. [pmid: 7217542].
Cohen S, Mitchell J L, Marx G F. Severe systemic reactions following administration of different uterotonic drugs. N Y State J Med. 1983;83(810):1060-1061. [pmid: 6579406].
Coleman T L, Randall H, Graves W, et al. Vaginal birth after cesarean among women with gestational diabetes. Am J Obstet Gynecol. 2001;184(6):1104-7. [pmid: 11349170].
Coltart T M, Davies J A, Katesmark M. Outcome of a second pregnancy after a previous elective caesarean section. Br J Obstet Gynaecol. 1990;97(12):1140-3. [pmid: 2279020].
Combs C A, Murphy E L, Laros R K. Cost-benefit analysis of autologous blood donation in obstetrics. Obstet Gynecol. 1992;80(4):621-5. [pmid: 1407883].
Combs C A, Singh N B, Khoury J C. Elective induction versus spontaneous labor after sonographic diagnosis of fetal macrosomia. Obstet Gynecol. 1993;81(4):492-6. [pmid: 8459954].
Comried L A. Cost analysis: Initiation of HBMC and first CareMap. Nurs Econ. 1996;14(1):34-9. [pmid: 8700246].
Connolly G A, Razak A R A, Conroy R, et al. A five year review of scar dehiscence in the Rotunda Hospital Dublin. Ir Med J. 2001;94(6):176-178. [pmid: 11495235].
Coody D, Yetman R J, Montgomery D, et al. Early hospital discharge and the timing of newborn metabolic screening. Clin Pediatr. 1993;32(8):463-6.
Coonrod D V, Bay R C, Kishi G Y. The epidemiology of labor induction: Arizona, 1997. Am J Obstet Gynecol. 2000;182(6):1355-62. [pmid: 10871449].
Cotzias C S, Paterson-Brown S, Fisk N M. Obstetricians say yes to maternal request for elective caesarean section: a Survey of current opinion. Eur J Obstet Gynecol Reprod Biol. 2001;97(1):15-6. [pmid: 11435000].
Coulter C H, Lehrfeld R. When push comes to shove: Implementing VBAC practice guidelines. Physician Exec. 1995;21(6):30-5. [pmid: 10161334].
Cowan R K, Kinch R A, Ellis B, et al. Trial of labor following cesarean delivery. Obstet Gynecol. 1994;83(6):933-6. [pmid: 8190434].
Cragin E B, et al. Conservatism in obstetrics. N Y Med J. 1916;104(1):1-3.
Crane S, Chun B, Acker D. Treatment of obstetrical hemorrhagic emergencies. Curr Opin Obstet Gynecol. 1993;5(5):675-82. [pmid: 8241446].
Cranley MS, Hedahl KJ, Pegg SH. Women's perceptions of vaginal and cesarean deliveries. Nurs Res 1983;32(10–15).
Creedy D K, Shochet I M, Horsfall J. Childbirth and the development of acute trauma symptoms: Incidence and contributing factors. Birth. 2000;27(2):104-11. [pmid: 11251488].
Cronk M. Home birth after LSCS. Midwives Chronicle. 1991;104(1239):110. [pmid: 2027319].
Crowley P. Interventions for preventing or improving the outcome of delivery at or beyond term. Cochrane Database of Systematic Reviews 2000(2):CD000170.
Cunha M, Bugalho A, Bique C, et al. Induction of labor by vaginal misoprostol in patients with previous cesarean delivery. Acta Obstet Gynecol Scand. 1999;78(7):653-4. [pmid: 10422915].
Cunningham J D. Experiences of Australian mothers who gave birth either at home, at a birth centre, or in hospital labour wards. Soc Sci Med. 1993;36(4):475-83. [pmid: 8434272].
Curet L B, Zachman R D, Rao A V, et al. Effect of mode of delivery on incidence of respiratory distress syndrome. Int J Gynaecol Obster. 1988;27(2):165-70.
Curtin SC. Rates of cesarean birth and vaginal birth after previous cesarean, 1991-1995. Natl Vital Stat Rep 1997;45(11):Suppl 3.
Curtin S C. Recent changes in birth attendant, place of birth, and the use of obstetric interventions, United States, 1989-1997. J Nurse Midwifery. 1999;44(4):349-54. [pmid: 10466281].
Curtin S C, Kozak L J. Cesarean delivery rates in 1995 continue to decline in the United States. Birth. 1997;24(3):194-6. [pmid: 9355279].
Curtin S C, Martin J A. Births: Preliminary data for 1999. Natl Vital Stat Rep. 2000;48(14):1-20.
Curtin S C, Mathews T J. U.S. obstetric procedures, 1998. Birth. 2000;27(2):136-8. [pmid: 11251492].
Curtin S C, Park M M. Trends in the attendant, place, and timing of births, and in the use of obstetric interventions: United States, 1989-97. Natl Vital Stat Rep. 1999;47(27):1-12.
Cyr R M, Usher R H, McLean F H. Changing patterns of birth asphyxia and trauma over 20 years. Am J Obstet Gynecol. 1984;148(5):490-8. [pmid: 6702907].
d'Orsi E, Chor D, Giffin K, et al. Factors associated with vaginal birth after cesarean in a maternity hospital of Rio de Janeiro. Eur J Obstet Gynecol Reprod Biol. 2001;97(2):152-7. [pmid: 11451540].
Dagher A P, Fishman E K. Uterine and bladder rupture during vaginal delivery in a patient with a prior cesarean section: Case report. Urol Radiol. 1992;14(3):200-1. [pmid: 1290212].
Dainer M, Hall C D, Choe J, et al. Pregnancy following incontinence surgery. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(6):385-90. [pmid: 9891960].
Dani C, Reali M F, Bertini G, et al. Risk factors for the development of respiratory distress syndrome and transient tachypnoea in newborn infants. Italian Group of Neonatal Pneumology. Eur Respir J. 1999;14(1):155-9. [pmid: 10489844].
Dannenbring D, Stevens M J, House A E. Predictors of childbirth pain and maternal satisfaction. J Behav Med. 1997;20(2):127-42. [pmid: 9144036].
Darby M. Reimbursement has small impact on c-section rates. In: Report on Medical Guidelines and Outcome Research. Alexandria, VA: Capitol Publications; 1992. p. 8–10.
Darling M R. Elective or selective caesarean delivery of the small baby?. Lancet. 1997;349(9053):666. [pmid: 9078196].
Daus K M. Spontaneous rupture of low transverse cesarean scar. South Med J. 1995;88(5):600. [pmid: 7732458].
Davies G A, Hahn P M, McGrath M M. Vaginal birth after cesarean. Physicians' perceptions and practice. J Reprod Med. 1996;41(7):515-20. [pmid: 8829065].
Davis L G, Riedmann G L, Sapiro M, et al. Cesarean section rates in low-risk private patients managed by certified nurse-midwives and obstetricians. J Nurse Midwifery. 1994;39(2):91-7. [pmid: 8027851].
Davis-Floyd R, Davis E. Intuition as authoritative knowledge in midwifery and homebirth. Med Anthropol Q. 1996;10(2):237-69. [pmid: 8744086].
Daviss B A. Vaginal delivery after caesarean section. Study's focus on induction v spontaneous labour neglects spontaneous deliver. BMJ. 2001;323(7324):1307. [pmid: 11764759].
Dawson N V, Acheson L S. Trade-offs in clinical policy making. Arch Fam Med. 1997;6(2):127-8. [pmid: 9075446].
Day A, MacLennan A, Green R. A comparison of intravaginal PGF2 alpha and intravenous oxytocin to stimulate labour after membrane rupture. Aust N Z J Obstet Gynaecol. 1985;25(4):252-5. [pmid: 3914885].
de Jong P. Trial of labor following cesarean section--a Study of 212 patients. Int J Gynaecol Obster. 1987;25(5):405-11.
de Meeus J B, Ellia F, Magnin G. External cephalic version after previous cesarean section: a Series of 38 cases. Eur J Obstet Gynecol Reprod Biol. 1998;81(1):65-8. [pmid: 9846717].
de Mello e Souza C. C-sections as ideal births: the Cultural constructions of beneficence and patients' rights in Brazil. Camb Q Healthc Ethics. 1994;3(3):358-66. [pmid: 7994459].
De Muylder X. Vaginal delivery after caesarean section: Is it safe in a developing country?. Aust N Z J Obstet Gynaecol. 1988;28(2):99-102. [pmid: 3228417].
de Vries L S, Regev R, Dubowitz L M, et al. Perinatal risk factors for the development of extensive cystic leukomalacia. Am J Dis Child. 1988;142(7):732-5. [pmid: 3289372].
DeJoy S, O'Grady JP, Burkman RT. The risks of lowering the cesarean-delivery rate. N Engl J Med 1999;341(1):53–4; discussion 54–5.
Del Valle G O, Adair C D, Sanchez-Ramos L, et al. Cervical ripening in women with previous cesarean deliveries. International Journal of Gynecology & Obstetrics. 1994;47(1):17-21. [pmid: 7813746].
Delarue T, Pele P. Prevention of rupture of the uterus before or during birth in women with previous caesarian sections: Report on 14 cases. J Gynecol Obstet Biol Reprod 1981;10(3):259–67.
Delarue T, Pele P, Pelletier P, et al. Prognosis for delivery in women with previous cesarean section. Apropos of 209 cases. J Gynecol Obstet Biol Reprod. 1983;12(2):193-206.
Dellinger E H, Boehm F H, Crane M M. Electronic fetal heart rate monitoring: early neonatal outcomes associated with normal rate, fetal stress, and fetal distress. Am J Obstet Gynecol. 2000;182(1 Pt 1):214-20. [pmid: 10649181].
Delpapa E H, Mueller-Heubach E. Pregnancy outcome following ultrasound diagnosis of macrosomia. Obstet Gynecol. 1991;78(3 Pt 1):340-3. [pmid: 1876361].
DeMaio H, Edwards R K, Euliano T Y, et al. Vaginal birth after cesarean delivery: An historic cohort cost analysis. Am J Obstet Gynecol. 2002;186:890-2. [pmid: 12015504].
Demianczuk N N, Hunter D J, Taylor D W. Trial of labor after previous cesarean section: Prognostic indicators of outcome. Am J Obstet Gynecol. 1982;142(6 Pt 1):640-2. [pmid: 7065036].
DeMott RK, Sandmire HF.The Green Bay cesarean section study. I. The physician factor as a determinant of cesarean birth rates. Am J Obstet Gynecol 1990;162(6):1593–9; discussion 1599–602.
Deutchman M E, Sills D, Connor P D. Perinatal outcomes: a Comparison between family physicians and obstetricians. J Am Board Fam Pract. 1995;8(6):440-7. [pmid: 8585401].
Devlin R. Childbirth on trial. Nurs Times. 1986;82(9):19-20. [pmid: 3634385].
Devoe L D, Croom C S, Youssef A A, et al. The prediction of “controlled” uterine rupture by the use of intrauterine pressure catheters. Obstet Gynecol. 1992;80(4):626-9. [pmid: 1407884].
Devoe L D, Samuel S, Prescott P, et al. Predicting the duration of the first stage of spontaneous labor using a neural network. J Matern Fetal Med. 1996;5(5):256-61. [pmid: 8930796].
Dhall K, Mittal S C, Grover V, et al. Childbirth following primary cesarean section--Evaluation of a scoring system. Int J Gynaecol Obster. 1987;25(3):199-205.
Diani F, Venanzi S, Zanconato G, et al. Fetal macrosomia and management of delivery. Clin Exp Obstet Gynecol. 1997;24(4):212-4. [pmid: 9478322].
Dickson M J. Vaginal delivery after previous caesarean section for failure of second stage of labour. Br J Obstet Gynaecol. 1999;106(7):749. [pmid: 10428537].
Dildy G A, Jackson G M, Fowers G K, et al. Very advanced maternal age: Pregnancy after age 45. Am J Obstet Gynecol. 1996;175(3 Pt 1):668-74. [pmid: 8828432].
Dilks F M, Beal J A. Role of self-efficacy in birth choice. J Perinat Neonat Nurs. 1997;11(1):1-9.
DiMatteo M R, Morton S C, Lepper H S, et al. Cesarean childbirth and psychosocial outcomes: a Meta-analysis. Health Psychol. 1996;15(4):303-14. [pmid: 8818678].
Dishman R K, Buckworth J. Increasing physical activity: a Quantitative synthesis. Med Sci Sports Exerc. 1996;28(6):706-19. [pmid: 8784759].
Donnelly J P, Franzoni K T. Uterine rupture. A 30-year survey. Obstet Gynecol. 1964;23:774. [pmid: 14196410].
Donnelly V, Fynes M, Campbell D, et al. Obstetric events leading to anal sphincter damage. Obstet Gynecol. 1998;92(6):955-61. [pmid: 9840557].
Drummond M, O'Brien B, Stoddart G, et al. Methods for the Economic Evaluation of Health Care Programmes, 2nd Ed. New York: Oxford University Press; 1997.
Dubay L, Kaestner R, Waidmann T. The impact of malpractice fears on cesarean section rates. J Health Econ. 1999;18(4):491-522. [pmid: 10539619].
Duff C, Sinclair M. Exploring the risks associated with induction of labour: a Retrospective study using the NIMATS database. Northern Ireland Maternity System. J Adv Nurs. 2000;31(2):410-7. [pmid: 10672100].
Duff P, Southmayd K, Read J A. Outcome of trial of labor in patients with a single previous low transverse cesarean section for dystocia. Obstet Gynecol. 1988;71(3 Pt 1):380-4. [pmid: 3347423].
Dulitzki M, Soriano D, Schiff E, et al. Effect of very advanced maternal age on pregnancy outcome and rate of cesarean delivery. Obstet Gynecol. 1998;92(6):935-9. [pmid: 9840553].
Durik A M, Hyde J S, Clark R. Sequelae of cesarean and vaginal deliveries: psychosocial outcomes for mothers and infants. Dev Psychol. 2000;36(2):251-60. [pmid: 10749082].
Dyack C, Hughes P F, Simbakalia J B. Vaginal birth after cesarean section in the grand multipara with a previous lower segment scar. Int J Gynaecol Obster. 1996;55(2):167-8.
Dyack C, Hughes P F, Simbakalia J B. Vaginal delivery in the grand multipara following previous lower segment cesarian section. Journal of Obstetrics & Gynaecology Research. 1997;23(2):219-22. [pmid: 9158312].
Eakes M. Economic considerations for epidural anesthesia in childbirth. Nurs Econ. 1990;8(5):329-32. [pmid: 2234140].
Eakins P S, O'Reilly W B, May L J, et al. Obstetric outcomes at the birth place in Menlo Park: the First seven years. Birth. 1989;16(3):123-9. [pmid: 2789561].
Eddy D M. Clinical decision making: from Theory to practice. Guidelines for policy statements: the Explicit approach. JAMA. 1990;263(16):2239-40. [pmid: 2319689].
Edelin K C, Oellerich D, Larrieux J R. The effect of induced abortion on the risks and outcome of a trial of labor after a previous cesarean birth. J Natl Med Assoc. 1988;80(9):993-5. [pmid: 3241315].
Eden R D, Parker R T, Gall S A, et al. Rupture of the pregnant uterus: a 53-year review. Obstet Gynecol. 1986;68(5):671-4. [pmid: 3763082].
Edwards D R, Porter S A, Stein G S. A pilot study of postnatal depression following caesarean section using two retrospective self-rating instruments. J Psychosom Res. 1994;38(2):111-7. [pmid: 8189400].
Egarter C, Kofler E, Fitz R, et al. Is induction of labor indicated in prolonged pregnancy? Results of a prospective randomised trial. Gynecol Obstet Invest. 1989;27(1):6-9. [pmid: 2646187].
Eglinton G S, Phelan J P, Yeh S, et al. Outcome of a trial of labor after prior cesarean delivery. J Reprod Med. 1984;29(1):3-8. [pmid: 6708017].
Eidelman A I, Schimmel M S, Bromiker R, et al. Pediatric coverage of the delivery room: an Analysis of manpower utilization. J Perinatol. 1998;18(2):131-4. [pmid: 9605304].
Eisenberg J M, et al. Sociological influences on the decision-making by clinicians. Ann Intern Med. 1979;90:957. [pmid: 443692].
Eisenberg JM. Doctors' Decisions and the Cost of Medical Care. Ann Arbor, Mich: Health Administration Press; 1986
Ekblad U, Erkkola R. Intracervical prostaglandin E2 gel for cervical ripening. Ann Chir Gynaecol Suppl. 1987;202:23-5. [pmid: 3477983].
Ekblad U, Vilpa T. Pregnancy in women over forty. Ann Chir Gynaecol Suppl. 1994;208:68-71. [pmid: 8092778].
Ekeocha C E, Jackson P. The ‘birth plan’ experience. Br J Obstet Gynaecol. 1985;92(1):97-101. [pmid: 3966995].
Ekman G, Granstrom L, Ulmsten U. Induction of labor with intravenous oxytocin or vaginal PGE2 suppositories. A randomized study. Acta Obstet Gynecol Scand. 1986;65(8):857-9. [pmid: 3548209].
el Gammal N A, Jallad K B, O'Deh H M. Breech vaginal delivery after one cesarean section: a Retrospective study. Int J Gynaecol Obster. 1990;33(2):99-102.
Elferink-Stinkens P M, Brand R, le C essie S, et al. Large differences in obstetrical intervention rates among Dutch hospitals, even after adjustment for population differences. Eur J Obstet Gynecol Reprod Biol. 1996;68(12):97-103. [pmid: 8886689].
Elferink-Stinkens P M, Brand R, Van Hemel O J. Trends in caesarean section rates among high- and medium-risk pregnancies in The Netherlands 1983-1992. Eur J Obstet Gynecol Reprod Biol. 1995;59(2):159-67. [pmid: 7657010].
Elferink-Stinkens P M, Van H emel O J, Brand R, et al. The Perinatal Database of the Netherlands. Eur J Obstet Gynecol Reprod Biol. 2001;94(1):125-38. [pmid: 11134838].
Elkady A A, Bayomy H M, Bekhiet M T, et al. A review of 126 cases of ruptured gravid uterus. Int Surg. 1993;78(3):231-5. [pmid: 8276548].
Elkins T, Onwuka E, Stovall T, et al. Uterine rupture in Nigeria. J Reprod Med. 1985;30(3):195-9. [pmid: 3999069].
Elliott J P, Flaherty J F. The use of breast stimulation to ripen the cervix in term pregnancies. Am J Obstet Gynecol. 1983;145(5):553-6. [pmid: 6338721].
Elliott J P, Flaherty J F, et al. The use of breast stimulation to prevent postdate pregnancy. Am J Obstet Gynecol. 1984;149(6):628-32. [pmid: 6377899].
Elliott J P, Russell M M, Dickason L A. The labor-adjusted cesarean section rate--a more informative method than the cesarean section “rate” for assessing a practitioner's labor and delivery skills. Am J Obstet Gynecol. 1997;177(1):139-43. [pmid: 9240597].
Emerson M V, Pieramici D J, Stoessel K M, et al. Incidence and rate of disappearance of retinal hemorrhage in newborns. Ophthalmology. 2001;108(1):36-9. [pmid: 11150261].
Engelsen I B, Albrechtsen S, Iversen O E. Peripartum hysterectomy-incidence and maternal morbidity. Acta Obstet Gynecol Scand. 2001;80(5):409-12. [pmid: 11328216].
Enkin M. Labour and Delivery follwing previous Caesarean Section. In: Chalmers I, Enkin M, Kierse MJNC, editors. Effective Care in Pregnancy and Childbirth. Oxford: Oxford University Press; 1989. p. 1196–1215.
Enthoven A, Kronick R. A consumer-choice health plan for the 1990s. Universal health insurance in a system designed to promote quality and economy (2). N Engl J Med. 1989;320(2):94-101. [pmid: 2492082].
Erb L, Hill G, Houston D, et al. A survey of parent's attitudes toward their cesaran births in Manitoba hospitals. Birth. 1983;10(2):85-92. [pmid: 6552195].
Eriksen N L, Buttino L, et al. Vaginal birth after cesarean: a Comparison of maternal and neonatal morbidity to elective repeat cesarean section. Am J Perinatol. 1989;6(4):375-9. [pmid: 2789534].
Esposito M A, Menihan C A, Malee M P. Association of interpregnancy interval with uterine scar failure in labor: a Case-control study. Am J Obstet Gynecol. 2000;183(5):1180-3. [pmid: 11084563].
Evans M I, Dougan M B, Moawad A H, et al. Ripening of the human cervix with porcine ovarian relaxin. Am J Obstet Gynecol. 1983;147(4):410-4. [pmid: 6353927].
Evans M I, Richardson D A, Sholl J S, et al. Cesarean section. Assessment of the convenience factor. J Reprod Med. 1984;29(9):670-6. [pmid: 6541697].
Ewen S P, Notley R G, Coats P M. Bladder laceration associated with uterine scar rupture during vaginal delivery. Br J Urol. 1994;73(6):712-3. [pmid: 8032844].
Fanaroff A A, Wright L L, Stevenson D K, et al. Very-low-birth-weight outcomes of the National Institute of Child Health and Human Development Neonatal Research Network, May 1991 through December 1992. Am J Obstet Gynecol. 1995;173(5):1423-31. [pmid: 7503180].
Farmakides G, Duvivier R, Schulman H, et al. Vaginal birth after two or more previous cesarean sections. Am J Obstet Gynecol. 1987;156(3):565-6. [pmid: 3826201].
Farmer K C, Schwartz W J, Rayburn W F, et al. A cost-minimization analysis of intracervical prostaglandin E2 for cervical ripening in an outpatient versus inpatient setting. Clin Ther. 1996;18(4):747-56; discussion 702. [pmid: 8879901].
Farmer R M, Kirschbaum T, Potter D, et al. Uterine rupture during trial of labor after previous cesarean section. Am J Obstet Gynecol. 1991;165(4 Pt 1):996-1001. [pmid: 1951569].
Fawcett J, Henklein J C. Antenatal education for cesarean birth: Extension of a field test. J Obstet Gynecol Neonat Nurs. 1987;16(1):61-5.
Fawcett J, Knauth D. The factor structure of the perception of birth scale. Nurs Res. 1996;45(2):83-6. [pmid: 8604369].
Fawcett J, Pollio N, Tully A. Women's perceptions of cesarean and vaginal delivery: Another look. Res Nurs Health. 1992;15(6):439-46. [pmid: 1448575].
Fawcett J, Tulman L, Spedden J. Responses to vaginal birth after cesarean section. J Obstet Gynecol Neonat Nurs. 1994;23(3):253-9.
Faxelius G, Hagnevik K, Lagercrantz H, et al. Catecholamine surge and lung function after delivery. Arch Dis Child. 1983;58(4):262-6. [pmid: 6847229].
Fedorkow D M, Nimrod C A, Taylor P J. Ruptured uterus in pregnancy: a Canadian hospital's experience. Can Med Assoc J. 1987;137(1):27-9. [pmid: 3594331].
Feldman G B, Freiman J A. Prophylactic cesarean section at term?. N Engl J Med. 1985;312(19):1264-7. [pmid: 3990727].
Ferguson J E 2nd, Newberry Y G, DeAngelis G A. The fetal-pelvic index has minimal utility in predicting fetal-pelvic disproportion. Am J Obstet Gynecol. 1998;179(5):1186-92. [pmid: 9822498].
Field M A. Controlling the woman to protect the fetus. Law Med Health Care. 1989;17(2):114-29. [pmid: 2755204].
Finkelstein BS, Harper DL, Rosenthal GE. Assessing variation, validity, and reproducibility in patient satisfaction with hospital obstetrical care. AHSR FSHR Annu Meet Abstr Book;13.
Finkelstein B S, Harper D L, Rosenthal G E. Does length of hospital stay during labor and delivery influence patient satisfaction? Results from a regional study. Am J Manag Care. 1998;4(12):1701-8. [pmid: 10339102].
Finkelstein B S, Harper D L, Rosenthal G E. Patient assessments of hospital maternity care: a Useful tool for consumers?. Health Serv Res. 1999;34(2):623-40. [pmid: 10357293].
Finkelstein B S, Singh J, Silvers J B, et al. Patient and hospital characteristics associated with patient assessments of hospital obstetrical care. Med Care. 1998;36(8 Suppl):AS68-78. [pmid: 9708584].
Finkler M D, Wirtschafter D D. Cost-effectiveness and obstetric services. Med Care. 1991;29(10):951-63. [pmid: 1921528].
Finkler M D, Wirtschafter D D. Why pay extra for cesarean-section deliveries?. Inquiry. 1993;30(2):208-15. [pmid: 8314609].
Finkler M D, Wirtschafter D D. One health maintenance organization's experience: Obstetric costs depend more on staffing patterns than on mode of delivery. J Perinatol. 1997;17(2):148-55. [pmid: 9134516].
Finkler S A. The distinction between cost and charges. Ann Intern Med. 1982;96(1):102-9. [pmid: 7053682].
Finley B E, Gibbs C E. Emergent cesarean delivery in patients undergoing a trial of labor with a transverse lower-segment scar. Am J Obstet Gynecol. 1986;155(5):936-9. [pmid: 3777070].
Firth P A, Chu J, Bell M A, et al. Changing practice habits of King County obstetricians. Obstet Gynecol. 1988;72(3 Pt 1):419-22. [pmid: 3405558].
Flamm B, Mac D onald D, Shearer E, et al. Should the electronic fetal monitor always be used for women in labor who are having a vaginal birth after a previous cesarean section?. Birth. 1992;19(1):31-5. [pmid: 1558585].
Flamm B L. Vaginal birth after cesarean section: Controversies old and new. Clin Obstet Gynecol. 1985;28(4):735-44. [pmid: 4075626].
Flamm BL. The patient who demands cesarean delivery. In: EJ Q, Flamm B, editors. Cesarean section: Guidelines for appropriate utilization. New York: Springer-Verlag; 1995. p. 207–21.
Flamm B L. Once a cesarean, always a controversy. Obstet Gynecol. 1997;90(2):312-5. [pmid: 9241315].
Flamm B L, Anton D, Goings J R, et al. Prostaglandin E2 for cervical ripening: a Multicenter study of patients with prior cesarean delivery. Am J Perinatol. 1997;14(3):157-60. [pmid: 9259919].
Flamm B L, Dunnett C, Fischermann E, et al. Vaginal delivery following cesarean section: Use of oxytocin augmentation and epidural anesthesia with internal tocodynamic and internal fetal monitoring. Am J Obstet Gynecol. 1984;148(6):759-763. [pmid: 6702945].
Flamm B L, Fried M W, Lonky N M, et al. External cephalic version after previous cesarean section. Am J Obstet Gynecol. 1991;165(2):370-2. [pmid: 1872341].
Flamm B L, Geiger A M. Vaginal birth after cesarean delivery: an Admission scoring system. Obstet Gynecol. 1997;90(6):907-10. [pmid: 9397100].
Flamm B L, Goings J R. Vaginal birth after cesarean section: is Suspected fetal macrosomia a contraindication? [see comments]. Obstet Gynecol. 1989;74(5):694-7. [pmid: 2638575].
Flamm B L, Goings J R, Fuelberth N J, et al. Oxytocin during labor after previous cesarean section: Results of a multicenter study. Obstet Gynecol. 1987;70(5):709-12. [pmid: 3309751].
Flamm B L, Goings J R, Liu Y, et al. Elective repeat cesarean delivery versus trial of labor: a Prospective multicenter study. Obstet Gynecol. 1994;83(6):927-32. [pmid: 8190433].
Flamm B L, Lim O W, Jones C, et al. Vaginal birth after cesarean section: Results of a multicenter study. Am J Obstet Gynecol. 1988;158(5):1079-84. [pmid: 3369487].
Flamm B L, Newman L A, Thomas S J, et al. Vaginal birth after cesarean delivery: Results of a 5-year multicenter collaborative study. Obstet Gynecol. 1990;76(5 Pt 1):750-4. [pmid: 2216218].
Flanagan T A, Mulchahey K M, Korenbrot C C, et al. Management of term breech presentation. Am J Obstet Gynecol. 1987;156(6):1492-502. [pmid: 3109245].
Fleissig A. Are women given enough information by staff during labour and delivery?. Midwifery. 1993;9(2):70-5. [pmid: 8332094].
Fleissig A. Prevalence of procedures in childbirth. BMJ. 1993;306(6876):494-5. [pmid: 8448462].
Fletcher H, McCaw-Binns A. Rupture of the uterus with misoprostol (prostaglandin E1) used for induction of labour. J Obstet Gynaecol. 1998;18(2):184-187. [pmid: 15512047].
Fogarty J P. Twin vaginal delivery after a previous cesarean delivery for twins. J Am Board Fam Pract. 1993;6(6):600-3. [pmid: 8285101].
Foote A J, Giles W B. Review of obstetric operative intervention rates. Asia Oceania J Obstet Gynaecol. 1992;18(3):195-8. [pmid: 1449417].
Forsnes E V, Browning J E, Gherman R B. Bladder rupture associated with uterine rupture. A report of two cases occurring during vaginal birth after cesarean. J Reprod Med. 2000;45(3):240-2. [pmid: 10756505].
Francis K T. Status of the year 2000 health goals for physical activity and fitness. Phys Ther. 1999;79(4):405-14. [pmid: 10201546].
Franco S. VBAC: the Lesson of labor. Midwifery Today 2000(53):41.
Fraser W, Maunsell E, Hodnett E, et al. Randomized controlled trial of a prenatal vaginal birth after cesarean section education and support program. Childbirth Alternatives Post-Cesarean Study Group. Am J Obstet Gynecol. 1997;176(2):419-25. [pmid: 9065192].
Fraser W, Usher R H, McLean F H, et al. Temporal variation in rates of cesarean section for dystocia: Does “convenience” play a role?. Am J Obstet Gynecol. 1987;156(2):300-4. [pmid: 3826164].
French L. Trial of labor after cesarean section. J Fam Pract. 1996;43(6):538-9. [pmid: 8969698].
Fribourg S. Previous cesarean delivery and trial of labor. Am J Obstet Gynecol. 1987;157(4 Pt 1):1014-5. [pmid: 3674149].
Friedman E A. Correlation between maximum cervical dilatation at cesarean delivery and subsequent vaginal birth after cesarean delivery. Obstet Gynecol. 1997;90(2):316-7. [pmid: 9241317].
Frigoletto FD, Jr., Lieberman E, Lang JM, et al. A clinical trial of active management of labor. [erratum appears in N Engl J Med 1995 Oct 26;333(17):1163.]. N Engl J Med 1995;333(12):745–50.
Fruchter O. Trial of labor compared with an elective second cesarean section. N Engl J Med 1997;336(9):658; discussion 659.
Fujii T, Kozuma S, Unno N, et al. Successful pregnancy following antenatal closure of uterine wall defect. Int J Gynaecol Obster. 2000;68(3):261-2.
Gaffney G, Flavell V, Johnson A, et al. Cerebral palsy and neonatal encephalopathy. Arch Dis Child Fetal Neonatal Ed. 1994;70(3):F195-200. [pmid: 7802763].
Gafni A, Goeree R, Myhr T L, et al. Induction of labour versus expectant management for prelabour rupture of the membranes at term: an Economic evaluation. TERMPROM Study Group. Term Prelabour Rupture of the Membranes. Can Med Assoc J. 1997;157(11):1519-25. [pmid: 9400406].
Galbraith R S. Incidence of neonatal sixth nerve palsy in relation to mode of delivery. Am J Obstet Gynecol. 1994;170(4):1158-9. [pmid: 8166202].
Gamble J A, Creedy D K. Women's request for a cesarean section: a Critique of the literature. Birth. 2000;27(4):256-63. [pmid: 11251511].
Gamble J A, Creedy D K. Women's preference for a cesarean section: Incidence and associated factors. Birth. 2001;28(2):101-10. [pmid: 11380381].
Garcia F A, Miller H B, Huggins G R, et al. Effect of academic affiliation and obstetric volume on clinical outcome and cost of childbirth. Obstet Gynecol. 2001;97(4):567-76. [pmid: 11275029].
Gardeil F, Daly S, Turner M J. Uterine rupture in pregnancy reviewed. Eur J Obstet Gynecol Reprod Biol. 1994;56(2):107-10. [pmid: 7805960].
Garel M, Lelong N, Marchand A, et al. Psychosocial consequences of caesarean childbirth: a Four-year follow-up study. Early Hum Dev. 1990;21(2):105-14. [pmid: 2318122].
Garite T J, Freeman R K, Nageotte M P. Fetal maturity cascade: a Rapid and cost-effective method for fetal lung maturity testing. Obstet Gynecol. 1986;67(5):619-22. [pmid: 3754319].
Gates P E. Think globally, act locally: an Approach to implementation of clinical practice guidelines. Jt Comm J Qual Improv. 1995;21(2):71-84. [pmid: 7735381].
Geary M, Fanagan M, Boylan P. Maternal satisfaction with management in labour and preference for mode of delivery. J Perinat Med. 1997;25(5):433-9. [pmid: 9438948].
Gee H. Delivery following previous Caesarean section. Curr Obstet Gynaecol. 2000;10(2):86-90.
Gellman E, Goldstein M S, Kaplan S, et al. Vaginal delivery after cesarean section. Experience in private practice. JAMA. 1983;249(21):2935-7. [pmid: 6842808].
Gemer O, Kopmar A, Sassoon E, et al. Neglected transverse lie with uterine rupture. Arch Gynecol Obstet. 1993;252(3):159-60. [pmid: 8503708].
Gemer O, Segal S, Sassoon E. Detection of scar dehiscence at delivery in women with prior cesarean section. Acta Obstet Gynecol Scand. 1992;71(7):540-2. [pmid: 1332375].
Gerbaud L, Biolay S, Venet M, et al. [Comparative evaluation of maternity hospitals in Auvergne: from planning to contracting]. Cah Sociol Demogr Med. 1998;38(4):297-323. [pmid: 10051927].
Gherman R B, Heath T. Trial of labor after cesarean delivery: a Pilot study of oral misoprostol for preinduction cervical ripening. Obstet Gynecol. 2001;97(4 Suppl. 1):S68.
Gherman R B, McBrayer S, Browning J. Uterine rupture associated with vaginal birth after cesarean section: a Complication of intravaginal misoprostol?. Gynecol Obstet Invest. 2000;50(3):212-3. [pmid: 11014958].
Gibbs C E. Planned vaginal delivery following cesarean section. Clin Obstet Gynecol. 1980;23(2):507-15. [pmid: 7398161].
Gibson D H. Vaginal delivery after caesarean section in primigravidae. Ir J Med Sci. 1988;157(9):290-2. [pmid: 3235309].
Gifford D S, Keeler E, Kahn K L. Reductions in cost and cesarean rate by routine use of external cephalic version: a Decision analysis. Obstet Gynecol. 1995;85(6):930-6. [pmid: 7770262].
Gifford D S, Morton S C, Fiske M, et al. Lack of progress in labor as a reason for cesarean. Obstet Gynecol. 2000;95(4):589-95. [pmid: 10725495].
Gifford DS, Pearson M, Flamm B, et al. Factors which influence the decision to perform a cesarean delivery. Abstr Book Assoc Health Serv Res;14:271–2.
Gilbert W M, Nesbitt T S, Danielsen B. Childbearing beyond age 40: Pregnancy outcome in 24,032 cases. Obstet Gynecol. 1999;93(1):9-14. [pmid: 9916947].
Gillette RD. Cost of vaginal delivery vs. repeated cesarean section. Am Fam Physician 1996;53(7):2284, 2287.
Gilson G J, Izquierdo L A, Chatterjee M S, et al. Prevention of cesarean section - Does intracervical dinoprostone work?. West J Med. 1993;159(2):149-152. [pmid: 8212680].
Gilstrap L C 3rd, Hauth J C, Schiano S, et al. Neonatal acidosis and method of delivery. Obstet Gynecol. 1984;63(5):681-5. [pmid: 6717872].
Gilstrap L C 3rd, Leveno K J, Burris J, et al. Diagnosis of birth asphyxia on the basis of fetal pH, Apgar score, and newborn cerebral dysfunction. Am J Obstet Gynecol. 1989;161(3):825-30. [pmid: 2782367].
Gimovsky M L, Bayer-Zwirello L A, Plevyak M. Fetal heart rate monitoring casebook. Amnioinfusion with uterine dehiscence and fetal distress. J Perinatol. 1997;17(1):83-6. [pmid: 9069073].
Girard M. Episiotomy and faecal incontinence. Lancet. 1999;35496(91):2169. [pmid: 10609851].
Glasser M. Strategies to avoid unnecessary cesarean sections. J Fam Pract. 1988;27(5):514-8. [pmid: 3193067].
Glasser M. Cesarean section: Science or ritual surgery?. Med Hypotheses. 1991;34(1):73-80. [pmid: 2056934].
Gleicher N. Cesarean section rates in the United States. The short-term failure of the National Consensus Development Conference in 1980. JAMA. 1984;252(23):3273-6. [pmid: 6512931].
Gleicher N. The cesarean-section epidemic. Mt Sinai J Med. 1986;53(7):563-5. [pmid: 3491313].
Gleicher N. Mandatory trial of labor after cesarean delivery: an Alternative viewpoint. Obstet Gynecol. 1991;78(4):727-8. [pmid: 1923183].
Gobis L J. Recent developments in health law relevant to health care providers. Nurse Pract. 1992;17(3):77-80. [pmid: 1565304].
Goer H. Misoprostol and uterine rupture. Birth. 2000;27(3):224-5. [pmid: 11310413].
Goeree R, Hannah M, Hewson S. Cost-effectiveness of induction of labour versus serial antenatal monitoring in the Canadian Multicentre Postterm Pregnancy Trial. Can Med Assoc J. 1995;152(9):1445-50. [pmid: 7728693].
Goetzl L, Shipp T D, Cohen A, et al. Oxytocin dose and the risk of uterine rupture in trial of labor after cesarean. Obstet Gynecol. 2001;97(3):381-4. [pmid: 11239641].
Goh J T. Genital tract fistula repair on 116 women. Aust N Z J Obstet Gynaecol. 1998;38(2):158-61. [pmid: 9653850].
Gold M, Siegel J, Russell L, et al. Cost-Effectiveness in Health and Medicine. New York: Oxford University Press; 1996.
Gold R B, Kenney A M, Singh S. Paying for maternity care in the United States. Fam Plann Perspect. 1987;19(5):190-206. [pmid: 3319681].
Goldberger S B, Rosen D J, Michaeli G, et al. The use of PGE2 for induction of labor in parturients with a previous cesarean section scar. Acta Obstet Gynecol Scand. 1989;68(6):523-6. [pmid: 2520807].
Goldfarb MG. Who recieves cesareans: Patient and hospital characteristics. Hospital Cost and Utilization Project-Research Note No. 4. National Center for Health Services Research 1984.
Goldfarb M G, Coffey R M. Case-mix differences between teaching and nonteaching hospitals. Inquiry. 1987;24(1):68-84. [pmid: 2951336].
Goldfarb N I, Hillman A L, Eisenberg J M, et al. Impact of a mandatory Medicaid case management program on prenatal care and birth outcomes. A retrospective analysis. Med Care. 1991;29(1):64-71. [pmid: 1986179].
Goldman G, Pineault R, Bilodeau H, et al. Effects of patient, physician and hospital characteristics on the likelihood of vaginal birth after previous cesarean section in Quebec. Can Med Assoc J. 1990;143(10):1017-24. [pmid: 2224667].
Goldman G, Pineault R, Potvin L, et al. Factors influencing the practice of vaginal birth after cesarean section. Am J Public Health. 1993;83(8):1104-8. [pmid: 8342717].
Goldman G A, Kaplan B, Neri A, et al. The grand multipara. Eur J Obstet Gynecol Reprod Biol. 1995;61(2):105-9. [pmid: 7556829].
Goldman G A, Kaplan B, Rabinerson D, et al. Vaginal delivery following caesarean section - the use of oxytocin and prostaglandins. J Obstet Gynaecol. 1998;18(4):328-330. [pmid: 15512101].
Gonen O, Rosen D J, Dolfin Z, et al. Induction of labor versus expectant management in macrosomia: a Randomized study. Obstet Gynecol. 1997;89(6):913-7. [pmid: 9170464].
Gonzalves P E, Hardin J J. Coordinated care early discharge of postpartum patients at Irwin Army Community Hospital. Mil Med. 1993;158(12):820-2. [pmid: 8108027].
Goodlin R C. Low birth weight infants. Obstet Gynecol. 1984;64(3):446-7. [pmid: 6462580].
Goodlin R C. Uterine activity during spontaneous labour after previous lower-segment caesarean section. Br J Obstet Gynaecol. 1990;97(3):277-8. [pmid: 2334655].
Goodlin R C. Correlation between maximum cervical dilatation at cesarean delivery and subsequent vaginal birth after cesarean delivery. Obstet Gynecol. 1997;90(2):316. [pmid: 9241316].
Gordon D, Milberg J, Daling J, et al. Advanced maternal age as a risk factor for cesarean delivery. Obstet Gynecol. 1991;77(4):493-7. [pmid: 2002968].
Gordon H. Uterine rupture and its association with oxytocic drugs: The Northwick Park Hospital experience. J Obstet Gynaecol. 1988;8(SUPPL. 1):S16-S17.
Gordon N P, Walton D, McAdam E, et al. Effects of providing hospital-based doulas in health maintenance organization hospitals. Obstet Gynecol. 1999;93(3):422-6. [pmid: 10074992].
Gotoh H, Masuzaki H, Yoshida A, et al. Predicting incomplete uterine rupture with vaginal sonography during the late second trimester in women with prior cesarean. Obstet Gynecol. 2000;95(4):596-600. [pmid: 10725496].
Gough G W, Randall N J, Genevier E S, et al. Head-to-cervix forces and their relationship to the outcome of labor. Obstet Gynecol. 1990;75(4):613-8. [pmid: 2314780].
Gould J B, Davey B, Stafford R S. Socioeconomic differences in rates of cesarean section. [see comments.]. N Engl J Med. 1989;321(4):233-9. [pmid: 2747759].
Gower R H, Toraya J, Miller J M. Laminaria for preinduction cervical ripening. Obstet Gynecol. 1982;60(5):617-9. [pmid: 6755325].
Goyert G L, Bottoms S F, Treadwell M C, et al. The physician factor in cesarean birth rates. N Engl J Med. 1989;320(11):706-9. [pmid: 2922015].
Graham A R. Trial labor following previous cesarean section. Am J Obstet Gynecol. 1984;149(1):35-45. [pmid: 6720772].
Graham E M, Forouzan I, Morgan M A. A retrospective analysis of Erb's palsy cases and their relation to birth weight and trauma at delivery. J Matern Fetal Med. 1997;6(1):1-5. [pmid: 9029377].
Graham W J, Hundley V, McCheyne A L, et al. An investigation of women's involvement in the decision to deliver by caesarean section. Br J Obstet Gynaecol. 1999;106(3):213-20. [pmid: 10426639].
Granovsky-Grisaru S, Shaya M, Diamant Y Z. The management of labor in women with more than one uterine scar: is a repeat cesarean section really the only “safe” option?. J Perinat Med. 1994;22(1):13-7. [pmid: 8035290].
Grazier K L, McGuire T G. Payment systems and hospital resource use: a comparative analysis of psychiatric, medical and obstetric services. Adv Health Econ Health Serv Res Suppl. 1987;8:75-95.
Green J M. Expectations, experiences and psychological outcomes of childbirth: a prospective study of 825 women. Birth. 1990;17(1):15-24. [pmid: 2346576].
Green JM, Coupland VA, Kitzinger JV. Great expectations: A prospective study of women's expectations and experiences of childbirth. Cambridge: University of Cambridge, Childcare and Develment Group; 1988.
Green L. VBAC clinical policy: an AAFP guideline. Am Fam Physician. 1995;52(6):1655. [pmid: 7484671].
Green-Thompson R W. Antepartum haemorrhage. Clin Obstet Gynaecol. 1982;9(3):479-515. [pmid: 6756747].
Greene M F. Vaginal delivery after cesarean section - Is the risk acceptable?. N Engl J Med. 2001;345(1):54-55. [pmid: 11439949].
Greene M F. Vaginal delivery after cesarean section--is the risk acceptable? [letter; comment]. N Engl J Med. 2001;345(1):54-5. [pmid: 11439949].
Greenhalgh R, Slade P, Spiby H. Fathers' coping style, antenatal preparation, and experiences of labor and the postpartum. Birth. 2000;27(3):177-84. [pmid: 11251499].
Gregory K, Henry O, Anderson E. Vaginal birth after cesarean: what should we be monitoring. AHSR FSHR Annu Meet Abstr Book;11:92.
Gregory K D, Henry O A, Gellens A J, et al. Repeat cesareans: how many are elective?. Obstet Gynecol. 1994;84(4):574-8. [pmid: 8090395].
Gregory K D, Henry O A, Ramicone E, et al. Maternal and infant complications in high and normal weight infants by method of delivery. Obstet Gynecol. 1998;92(4 Pt 1):507-13. [pmid: 9764620].
Gregory K D, Korst L M, Cane P, et al. Vaginal birth after cesarean and uterine rupture rates in California. Obstet Gynecol. 1999;94(6):985-9. [pmid: 10576187].
Gregory KD, Ramicone E, Chan L, et al. Cesarean deliveries for Medicaid patients in public and private hospitals. Abstr Book Assoc Health Serv Res;14:125–6.
Gregory K D, Ramicone E, Chan L, et al. Cesarean deliveries for medicaid patients: a comparison in public and private hospitals in Los Angeles county. Am J Obstet Gynecol. 1999;180(5):1177-84. [pmid: 10329874].
Greis J B, Bieniarz J, Scommegna A. Comparison of maternal and fetal effects of vacuum extraction with forceps or cesarean deliveries. Obstet Gynecol. 1981;57(5):571-7. [pmid: 7219906].
Greulich B, Paine L L, McClain C, et al. Twelve years and more than 30,000 nurse-midwife-attended births: the Los Angeles County + University of Southern California women's hospital birth center experience. J Nurse Midwifery. 1994;39(4):185-96. [pmid: 7965188].
Gries D M, Phyall G, Barfield W D. Evaluation of an early discharge program for infants after childbirth in a military population. Mil Med. 2000;165(8):616-21. [pmid: 10957856].
Griffith P. Midwives' attitudes: promoting normal birth. Aust J Adv Nur. 1988;5(3):33-9.
Griffiths M L. The scarred uterus and subsequent pregnancy and delivery. S Afr Med J. 1982;62(1):5. [pmid: 7089780].
Grobman W A, Peaceman A M, Socol M L. Cost-effectiveness of elective cesarean delivery after one prior low transverse cesarean. Obstet Gynecol. 2000;95(5):745-51. [pmid: 10775741].
Gross P A, Greenfield S, Cretin S, et al. Optimal methods for guideline implementation: conclusions from Leeds Castle meeting. Med Care. 2001;39(8 Suppl 2):II85-92. [pmid: 11583124].
Groutz A, Gordon D, Wolman I, et al. Persistent postpartum urinary retention in contemporary obstetric practice. Definition, prevalence and clinical implications. J Reprod Med. 2001;46(1):44-8. [pmid: 11209631].
Grubb D K, Kjos S L, Paul R H. Latent labor with an unknown uterine scar. Obstet Gynecol. 1996;88(3):351-5. [pmid: 8752238].
Grullon K E, Grimes D A. The safety of early postpartum discharge: a review and critique. Obstet Gynecol. 1997;90(5):860-5. [pmid: 9351780].
Grzybowski S C, Cadesky A S, Hogg W E. Rural obstetrics: a 5-year prospective study of the outcomes of all pregnancies in a remote northern community. Can Med Assoc J. 1991;144(8):987-94. [pmid: 2009477].
Gudgeon C W. Uterine rupture and scar dehiscence. Anaesth Intensive Care. 1997;25(4):434. [pmid: 9288397].
Guerdan B R, McKenna J P, Wright J C. Vaginal birth after cesarean section in a community hospital: a family practice residency experience. J Am Board Fam Pract. 1989;2(3):169-71. [pmid: 2750558].
Guerresi E, Gori G, Beccari A, et al. Influence of spasmolytic treatment and amniotomy on delivery times: A factorial clinical trial. Clin Ther. 1981;3(5):382-388. [pmid: 7008940].
Guillemette J, Fraser W D. Differences between obstetricians in caesarean section rates and the management of labour. Br J Obstet Gynaecol. 1992;99(2):105-8. [pmid: 1554658].
Guldholt I, Espersen T. Maternal febrile morbidity after cesarean section. Acta Obstet Gynecol Scand. 1987;66(8):675-9. [pmid: 3448881].
Gupta U, Ganesh K. Emergency hysterectomy in obstetrics: review of 15 years. Asia Oceania J Obstet Gynaecol. 1994;20(1):1-5. [pmid: 8172519].
Guyer B, Strobino D M, Ventura S J, et al. Annual summary of vital statistics-1994. Pediatrics. 1995;96(6):1029-39. [pmid: 7491217].
Haas J S, Udvarhelyi S, Epstein A M. The effect of health coverage for uninsured pregnant women on maternal health and the use of cesarean section. JAMA. 1993;270(1):61-4. [pmid: 8510298].
Hadley C B, Mennuti M T, Gabbe S G. An evaluation of the relative risks of a trial of labor versus elective repeat cesarean section. Am J Perinatol. 1986;3(2):107-14. [pmid: 3964379].
Hadley J, Hoffman J, Feder J. Relationships between health insurance coverage and selected health and hospital use characteristics of newborns and pregnant women. Washington: Center for Health Policy Studies, George Washington University; 1989.
Hage ML, Helms MJ, Dudley A, et al. Acute childbirth morbidity: its measurement using hospital charges. Am J Obstet Gynecol 1992;166(6 Pt 1):1853–9; discussion 1859–62.
Haines C J, Rogers M S, Leung D H. Neonatal outcome and its relationship with maternal age. Aust N Z J Obstet Gynaecol. 1991;31(3):209-12. [pmid: 1804079].
Haire D B, Elsberry C C. Maternity care and outcomes in a high-risk service: the North Central Bronx Hospital experience. Birth. 1991;18(1):33-7. [pmid: 2006959].
Hale R W. Trial of labor compared with an elective second cesarean section. N Engl J Med. 1997;336(9):659. [pmid: 9036324].
Hales K A, Morgan M A, Thurnau G R. Influence of labor and route of delivery on the frequency of respiratory morbidity in term neonates. Int J Gynaecol Obster. 1993;43(1):35-40.
Hall M H. Mortality associated with elective caesarean section. BMJ. 1994;30843(69):1572. [pmid: 8019334].
Halliday H L. Elective delivery at “term”: implications for the newborn. Acta Paediatr. 1999;88(11):1180-1. [pmid: 10591416].
Halperin M E, Moore D C, Hannah W J. Classical versus low-segment transverse incision for preterm caesarean section: maternal complications and outcome of subsequent pregnancies. Br J Obstet Gynaecol. 1988;95(10):990-6. [pmid: 3191053].
Hamilton E F, Bujold E, McNamara H, et al. Dystocia among women with symptomatic uterine rupture. Am J Obstet Gynecol. 2001;184(4):620-4. [pmid: 11262462].
Hamrick-Turner J E, Cranston P E, Lantrip B S. Gravid uterine dehiscence: MR findings. Abdom Imaging. 1995;20(5):486-8. [pmid: 7580793].
Handa V L, Harris T A, Ostergard D R. Protecting the pelvic floor: obstetric management to prevent incontinence and pelvic organ prolapse. Obstet Gynecol. 1996;88(3):470-8. [pmid: 8752261].
Haney E I, Reiter J A, MacGregor S N, et al. Optional vaginal delivery rate. An informative indicator of intrapartum care. J Reprod Med. 1999;44(10):842-8. [pmid: 10554743].
Hangsleben K L, Taylor M A, Lynn N M. VBAC program in a nurse-midwifery service. Five years of experience. J Nurse Midwifery. 1989;34(4):179-84. [pmid: 2769442].
Hankins G D, Hammond T L, Snyder R R, et al. Transverse lie. Am J Perinatol. 1990;7(1):66-70. [pmid: 2131781].
Hanley M L, Smulian J C, Lake M F, et al. Analysis of repeat cesarean delivery indications: implications of heterogeneity. Am J Obstet Gynecol. 1996;175(4 Pt 1):883-8. [pmid: 8885741].
Hannah M E, Hannah W J, Hodnett E D, et al. Outcomes at 3 months after planned cesarean vs planned vaginal delivery for breech presentation at term: the international randomized Term Breech Trial. JAMA. 2002;287(14):1822-31. [pmid: 11939868].
Hannah M E, Ohlsson A, Farine D, et al. Induction of labor compared with expectant management for prelabor rupture of the membranes at term. N Engl J Med. 1996;334(16):1005-1010. [pmid: 8598837].
Hansell RS, McMurray KB, Huey GR. Vaginal birth after two or more cesarean sections: a five-year experience. Birth 1990;17(3):146–50; discussion 150–1.
Hansen J P. Older maternal age and pregnancy outcome: a review of the literature. Obstetrical & Gynecological Survey. 1986;41(11):726-42. [pmid: 2950347].
Harlass F E, Duff P. The duration of labor in primiparas undergoing vaginal birth after cesarean delivery. Obstet Gynecol. 1990;75(1):45-7. [pmid: 2296421].
Harrington L C, Miller D A, McClain C J, et al. Vaginal birth after cesarean in a hospital-based birth center staffed by certified nurse-midwives. J Nurse Midwifery. 1997;42(4):304-7. [pmid: 9277061].
Harris L H. Counselling women about choice. Best Prac Res Clin Obstet Gynaecol. 2001;15(1):93-107.
Harris R P, Helfand M, Woolf S H, et al. Methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
Hart GL, Dobie SA, Baldwin LM, et al. Rural and urban differences in physician resource use for low-risk obstetrics. Seattle: WAMI RHRC 1995;42.
Hart L G, Dobie S A, Baldwin L M, et al. Rural and urban differences in physician resource use for low-risk obstetrics. Health Serv Res. 1996;31(4):429-52. [pmid: 8885857].
Hart M A, Foster S N. Couples' attitudes toward childbirth participation: relationship to evaluation of labor and delivery. J Perinat Neonat Nurs. 1997;11(1):10-20.
Harwood M I. Are there adverse maternal and neonatal outcomes associated with induction of labor when there is no well-accepted indication?. J Fam Pract. 2001;50(2):106. [pmid: 11219552].
Haupt BJ. Deliveries in short-stay hospitals: United States, 1980. Adv Data 1982(83):1–11.
Hawe J A, Olah K S. Posterior uterine rupture in a patient with a lower segment caesarean section scar complicating prostaglandin induction of labour. Br J Obstet Gynaecol. 1997;104(7):857-8. [pmid: 9236658].
Haynes de Regt R, Minkoff H L, Feldman J. Relations of private or clinic care to the cesarean birth rate. N Engl J Med. 1986;315:619-24. [pmid: 3736601].
Heddleston L N, Watson W J. Vaginal birth after cesarean section in a small hospital. Mil Med. 1991;156(5):239-40. [pmid: 2057077].
Heidrick W P. Rupture of the gravid uterus--lessons and questions. Nebr Med J. 1983;68(7):197-8.
Heilbrunn JZ, Park E Variations in the Use of Cesarean Section: Literature Review. Santa Monica, Calif.: RAND; 1992
Helfand M, Marton K, Ueland K. Factors involved in the interpretation of fetal monitor tracings. Am J Obstet Gynecol. 1985;151(6):737-44. [pmid: 3976782].
Hemminki E. Obstetric practice in Finland, 1950-1980. Changes in technology and its relation to health. Med Care. 1983;21(12):1131-43. [pmid: 6656337].
Hemminki E. Pregnancy and birth after cesarean section: a survey based on the Swedish birth register. Birth. 1987;14(1):12-7. [pmid: 3646886].
Hemminki E. Long term maternal health effects of caesarean section. J Epidemiol Community Health. 1991;45(1):24-8. [pmid: 2045740].
Hemminki E, Kojo-Austin H, Malin M, et al. Variation in obstetric interventions by midwife. Scand J Caring Sci. 1992;6(2):81-6. [pmid: 1641536].
Henderson J, McCandlish R, Kumiega L, et al. Systematic review of economic aspects of alternative modes of delivery. BJOG. 2001;108(2):149-57. [pmid: 11236114].
Henry O A, Gregory K D, Hobel C J, et al. Using ICD-9 codes to identify indications for primary and repeat cesarean sections: agreement with clinical records. Am J Public Health. 1995;85(8 Pt 1):1143-6. [pmid: 7625515].
Heres M H, Pel M, Elferink-Stinkens P M, et al. The Dutch obstetric intervention study--variations in practice patterns. Int J Gynaecol Obster. 1995;50(2):145-50.
Heriot M J. Fetal rights versus the female body: contested domains. Med Anthropol Q. 1996;10(2):176-94. [pmid: 8744083].
Heritage C, Cunningham M. Association of elective repeat cesarean delivery and persistent pulmonary hypertension of the newborn. Am J Obstet Gynecol. 1983;152:627. [pmid: 4025421].
Hibbard J H, Weeks E C. Does the dissemination of comparative data on physician fees affect consumer use of services?. Med Care. 1989;27(12):1167-74. [pmid: 2512462].
Hibbard JU, Ismail MA, Wang Y, et al. Failed vaginal birth after a cesarean section: how risky is it? I. Maternal morbidity. Am J Obstet Gynecol 2001;184(7):1365–71; discussion 1371–3.
Hickson G B, Altemeier W A, Perrin J M. Physician reimbursement by salary or fee-for-service: effect on physician practice behavior in a randomized prospective study. Pediatrics. 1986;80:344-50. [pmid: 3627885].
Hill D A, Chez R A, Quinlan J, et al. Uterine rupture and dehiscence associated with intravaginal misoprostol cervical ripening. J Reprod Med. 2000;45(10):823-6. [pmid: 11077631].
Hill D J, Beischer N A. Hysterectomy in obstetric practice. Aust N Z J Obstet Gynaecol. 1980;20(3):151-3. [pmid: 6257222].
Hillan E M. Postoperative morbidity following Caesarean delivery. J Adv Nurs. 1995;22(6):1035-42. [pmid: 8675855].
Hillman A L. Health maintenance organizations, financial incentives, and physicians' judgments. Ann Intern Med. 1990;112(12):891-3. [pmid: 2339854].
Hoffmann R A M, Anthony J, Fawcus S. Oral misoprostol vs. placebo in the management of prelabor rupture of membranes at term. Int J Gynecol Obstet. 2001;72(3):215-221.
Hofmeyr G J, Alfirevic Z, Matonhodze B, et al. Titrated oral misoprostol solution for induction of labour: A multi-centre, randomised trial. Br J Obstet Gynaecol. 2001;108(9):952-959.
Hofmeyr GJ, Kulier R. Operative versus conservative management for ‘fetal distress’ in labour. Cochrane Database of Systematic Reviews 2000(2):CD001065.
Holden D, Vere M, Manyonda I. Vesico-uterine fistula occurring in a woman with a previous caesarean section and two subsequent normal vaginal deliveries. Br J Obstet Gynaecol. 1994;101(4):354-6. [pmid: 8199088].
Holland J G, Dupre A R, Blake P G, et al. Trial of labor after cesarean delivery: experience in the non-university level II regional hospital setting. Obstet Gynecol. 1992;79(6):936-9. [pmid: 1579317].
Holmes P, Oppenheimer L W, Wen S W. The relationship between cervical dilatation at initial presentation in labour and subsequent intervention. BJOG. 2001;108(11):1120-4. [pmid: 11762649].
Holt V L, Mueller B A. Attempt and success rates for vaginal birth after caesarean section in relation to complications of the previous pregnancy. Paediatr Perinat Epidemiol. 1997;11(Suppl 1):63-72. [pmid: 9018716].
Hook B, Kiwi R, Amini S B, et al. Neonatal morbidity after elective repeat cesarean section and trial of labor. Pediatrics. 1997;100(3 Pt 1):348-53. [pmid: 9282704].
Horenstein J M, Eglinton G S, Tahilramaney M P, et al. Oxytocin use during a trial of labor in patients with previous cesarean section. J Reprod Med Obstet Gynecol. 1984;29(1):26-30.
Horenstein J M, Phelan J P. Previous cesarean section: the risks and benefits of oxytocin usage in a trial of labor. Am J Obstet Gynecol. 1985;151(5):564-9. [pmid: 3976755].
Hornbrook M C, Goldfarb M G. Patterns of obstetrical care in hospitals. Med Care. 1981;19(1):55-67. [pmid: 7464311].
Horowitz B J, Edelstein S W, Lippman L. Once a cesarean, always a cesarean. Obstet Gynecol Survey. 1981;36:592.
Hoskins I A, Gomez J L. Correlation between maximum cervical dilatation at cesarean delivery and subsequent vaginal birth after cesarean delivery. Obstet Gynecol. 1997;89(4):591-3. [pmid: 9083318].
Hourvitz A, Alcalay M, Korach J, et al. A prospective study of high- versus low-dose oxytocin for induction of labor. Acta Obstet Gynecol Scand. 1996;75(7):636-41. [pmid: 8822656].
Hsiao W C, Braun P, Dunn D, et al. Results and policy implications of the resource-based relative-value study. N Engl J Med. 1988;319(13):881-8. [pmid: 3045557].
Hsu C D, Chen S, Feng T I, et al. Rupture of uterine scar with extensive maternal bladder laceration after cocaine abuse. Am J Obstet Gynecol. 1992;167(1):129-30. [pmid: 1442913].
Hueston W J. Obstetric referral in family practice. Factors Affecting Cesarean Section (FACS) Study Group. J Fam Pract. 1994;38(4):368-72. [pmid: 8163961].
Hueston W J, Applegate J A, Mansfield C J, et al. Practice variations between family physicians and obstetricians in the management of low-risk pregnancies. J Fam Pract. 1995;40(4):345-51. [pmid: 7699347].
Hueston W J, Rudy M. A comparison of labor and delivery management between nurse midwives and family physicians. J Fam Pract. 1993;37(5):449-54. [pmid: 8228856].
Hueston W J, Rudy M. Factors predicting elective repeat cesarean delivery. Obstet Gynecol. 1994;83(5 Pt 1):741-4. [pmid: 8164936].
Hueston W J, Rudy M. Differences in labor and delivery experience in family physician- and obstetrician-supervised teaching services. Fam Med. 1995;27(3):182-7. [pmid: 7774778].
Hughes E G, Kelly A J, Kavanagh J. Dinoprostone vaginal insert for cervical ripening and labor induction: a meta-analysis. Obstet Gynecol. 2001;97(5 Pt 2):847-55. [pmid: 11336776].
Hundley V A, Milne J M, Glazener C M, et al. Satisfaction and the three C's: continuity, choice and control. Women's views from a randomised controlled trial of midwife-led care. Br J Obstet Gynaecol. 1997;104(11):1273-80. [pmid: 9386028].
Hunter I W, Cato E, Ritchie J W. Induction of labor using high-dose or low-dose prostaglandin vaginal pessaries. Obstet Gynecol. 1984;63(3):418-20. [pmid: 6366660].
Hurst M, Summey P S. Childbirth and social class: the case of cesarean delivery. Soc Sci Med. 1984;18(8):621-31. [pmid: 6374910].
Hutchins V, Kessel S S, Placek P J. Trends in maternal and infant health factors associated with low infant birth weight, United States, 1972 and 1980. Public Health Rep. 1984;99(2):162-72. [pmid: 6424165].
Iglesias S, Burn R, Saunders L D. Reducing the cesarean section rate in a rural community hospital. Can Med Assoc J. 1991;145(11):1459-64. [pmid: 1959105].
Iloabachie G C, Njoku O. Vesico-uterine fistula. Br J Urol. 1985;57(4):438-9. [pmid: 4027516].
Impey L, O'Herlihy C. First delivery after cesarean delivery for strictly defined cephalopelvic disproportion. Obstet Gynecol. 1998;92(5):799-803. [pmid: 9794672].
Ingemarsson E, Ingemarsson I, Svenningsen N W. Impact of routine fetal monitoring during labor on fetal outcome with long-term follow-up. Am J Obstet Gynecol. 1981;141(1):29-38. [pmid: 7270619].
Innes G, Rosen P. An unusual cause of abdominal pain and shock in pregnancy: case report and review of the literature. J Emerg Med. 1985;2(5):361-6. [pmid: 3910716].
Irion O, Hirsbrunner Almagbaly P, Morabia A. Planned vaginal delivery versus elective caesarean section: a study of 705 singleton term breech presentations. Br J Obstet Gynaecol. 1998;105(7):710-7. [pmid: 9692410].
Ito M, Nawa T, Mikamo H, et al. Lower segment uterine rupture related to early pregnancy by in vitro fertilization and embryo transfer after a previous cesarean delivery. J Med. 1998;29(12):85-91. [pmid: 9704295].
Jackson DJ, Lang J, Swartz W, et al. Outcomes from the San Diego Birth Center Study: Examining an alternative model of perinatal service delivery. Abstr Book Assoc Health Serv Res;15:95.
Jackson D J, Lang J M, Ganiats T G. Epidemiological issues in perinatal outcomes research. Paediatr Perinat Epidemiol. 1999;13(4):392-404. [pmid: 10563358].
Jackson R L A. County learns costly lesson on mandated labor guidelines. Qual Lett Healthc Lead. 1998;10(4):18-9. [pmid: 10184893].
Jacoby A. Women's preferences for and satisfaction with current procedures in childbirth--findings from a national study. Midwifery. 1987;3(3):117-24. [pmid: 3670108].
Jacoby I, Meyer G S, Haffner W, et al. Modeling the future workforce of obstetrics and gynecology. Obstet Gynecol. 1998;92(3):450-6. [pmid: 9721788].
Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
Jagani N, Schulman H, Chandra P, et al. The predictability of labor outcome from a comparison of birth weight and x-ray pelvimetry. Am J Obstet Gynecol. 1981;139(5):507-11. [pmid: 7468717].
Jain M, Pandey S, Pandey L K, et al. Obstetric prospects after caesarean section. J Indian Med Assoc. 1987;85(11):324-6. [pmid: 3448134].
Jakobi P, Weissman A, Paldi E. Uniform presentation of data concerning cesarean sections. Acta Obstet Gynecol Scand. 1987;66(7):657-8. [pmid: 3439450].
Jakobi P, Weissman A, Peretz B A, et al. Evaluation of prognostic factors for vaginal delivery after cesarean section. J Reprod Med. 1993;38(9):729-33. [pmid: 8254598].
Jakobi P, Zimmer E Z, Weissman A. Oxytocin administration and uterine exploration in the management of vaginal birth after cesarean--not routine procedures. Am J Obstet Gynecol. 1989;160(6):1538-40. [pmid: 2735373].
Jakobi P, Zimmer E Z, Weissman A, et al. Oxytocin administration and uterine exploration in the management of vaginal birth after cesarean - Not routine procedures. Am J Obstet Gynecol. 1989;160(6):1538-1540. [pmid: 2735373].
Jamelle R N. Outcome of unplanned vaginal deliveries after two previous caesarean sections. J Obstet Gynaecol Res. 1996;22(5):431-6. [pmid: 8987324].
Janke J R. Breastfeeding duration following cesarean and vaginal births. J Nurse Midwifery. 1988;33(4):159-64. [pmid: 3404279].
Janowitz B, Higgins J E, Clopton D C, et al. Access to postpartum sterilization in southeast Brazil. Med Care. 1982;20(5):526-34. [pmid: 7098591].
Janowitz B, Wallace S, Araujo G, et al. Method of payment and the cesarean birth rate in a hospital in northeast Brazil. J Health Polit Policy Law. 1984;9(3):515-26. [pmid: 6512225].
Janssen P A, Klein M C, Soolsma J H. Differences in institutional cesarean delivery rates-the role of pain management. J Fam Pract. 2001;50(3):217-23. [pmid: 11252209].
Jarrell M A, Ashmead G G, Mann L I. Vaginal delivery after cesarean section: a five-year study. Obstet Gynecol. 1985;65(5):628-32. [pmid: 3982739].
Jarvelin M R, Hartikainen-Sorri A L, Rantakallio P. Labour induction policy in hospitals of different levels of specialisation. Br J Obstet Gynaecol. 1993;100(4):310-5. [pmid: 8494831].
Johanson R, Burr R, Leighton N, et al. Informed choice? Evidence of the persuasive power of professionals. J Public Health Med. 2000;22(3):439-40. [pmid: 11077922].
Johanson R B, Heycock E, Carter J, et al. Maternal and child health after assisted vaginal delivery: five-year follow up of a randomised controlled study comparing forceps and ventouse. Br J Obstet Gynaecol. 1999;106(6):544-9. [pmid: 10426611].
Johnson C, Oriol N. The role of epidural anesthesia in trial of labor. Reg Anesth. 1990;15(6):304-8. [pmid: 2291886].
Johnson C, Oriol N, Flood K. Trial of labor: a study of 110 patients. J Clin Anesth 1991;3(3):216–8; discussion 214–5.
Johnson K C, Gaskin I M. Vaginal delivery after caesarean section. Safety of single-layer suturing in caesarean sections must be proved. BMJ. 2001;32324(73):1307-8. [pmid: 11764760].
Johnson N, Ansell D. Variation in caesarean and instrumental delivery rates in New Zealand hospitals. Aust N Z J Obstet Gynaecol. 1995;35(1):6-11. [pmid: 7772003].
Johnson S R, Elkins T E, Strong C, et al. Obstetric decision-making: responses to patients who request cesarean delivery. Obstet Gynecol. 1986;67(6):847-50. [pmid: 3703409].
Jolly J, Walker J, Bhabra K. Subsequent obstetric performance related to primary mode of delivery. Br J Obstet Gynaecol. 1999;106(3):227-32. [pmid: 10426641].
Jones L, LoGerfo J, Shy K, et al. StORQS: Washington's Statewide Obstetrical Review and Quality System: overview and provider evaluation. Qrb. Quality Review Bulletin. 1993;19(4):110-8. [pmid: 8493025].
Jones R O, Nagashima A W, Hartnett-Goodman M M, et al. Rupture of low transverse cesarean scars during trial of labor. Obstet Gynecol. 1991;77(6):815-7. [pmid: 2030848].
Jongen V H, Halfwerk M G, Brouwer W K. Vaginal delivery after previous caesarean section for failure of second stage of labour. Br J Obstet Gynaecol. 1998;105(10):1079-81. [pmid: 9800930].
Joseph GF, Stedman CM, Robichaux AG. Vaginal birth after cesarean section: the impact of patient resistance to a trial of labor. Am J Obstet Gynecol 1991;164(6 Pt 1):1441–4; discussion 1444–7.
Kafkas S, Taner C E. Ruptured uterus. Int J Gynaecol Obster. 1991;34(1):41-4.
Kahn K, Fiske M, DiMatteo R, et al. Mother's thoughts about cesarean as compared with vaginal deliveries and the effect of those thoughts on method of delivery. AHSR FSHR Annu Meet Abstr Book;11:23.
Kaplan B, Rabinerson D, Harel L, et al. Multiple repeat cesarean sections. Int J Gynaecol Obster. 1996;55(2):173-4.
Kaplan B, Royburt M, Peled Y, et al. Routine revision of uterine scar after prior cesarean section. Acta Obstet Gynecol Scand. 1994;73(6):473-475. [pmid: 8042459].
Kattan S A. Maternal urological injuries associated with vaginal deliveries: change of pattern. Int Urol Nephrol. 1997;29(2):155-61. [pmid: 9241541].
Kazandjian V A, Thomson R G, Law W R, et al. Do performance indicators make a difference?. Jt Comm J Qual Improv. 1996;22(7):482-91. [pmid: 8858419].
Keeler E B, Brodie M. Economic incentives in the choice between vaginal delivery and cesarean section. Milbank Q. 1993;71(3):365-404. [pmid: 8413067].
Keeler E B, Fok T. Equalizing physician fees had little effect on cesarean rates. Med Care Res Rev. 1996;53(4):465-71. [pmid: 10162961].
Keirse M, De Koning Gans H J. Randomized comparison of the effects of endocervical and vaginal prostaglandin E2 gel in women with various degrees of cervical ripeness. Am J Obstet Gynecol. 1995;173(6):1859-1864. [pmid: 8610776].
Keirse M J. Amniotomy or oxytocin for induction of labor. Re-analysis of a randomized controlled trial. Acta Obstet Gynecol Scand. 1988;67(8):731-5. [pmid: 3074604].
Keirse M J. Prostaglandins in preinduction cervical ripening. Meta-analysis of worldwide clinical experience. J Reprod Med. 1993;38(1 Suppl):89-100. [pmid: 8429533].
Kennedy C M, Peleg D, Syrop C, et al. Antenatal diagnosis of vesicouterine fistula. Obstet Gynecol. 1999;94(5 Pt 2):808-9. [pmid: 10546736].
Kennedy E K. VBAC trend put in reverse. Hosp Peer Rev. 1997;22(9):129-31. [pmid: 10170343].
Kennedy J H, Stewart P, Barlow D H, et al. Induction of labour: a comparison of a single prostaglandin E2 vaginal tablet with amniotomy and intravenous oxytocin. Br J Obstet Gynaecol. 1982;89(9):704-7. [pmid: 7052115].
Kennell J, Klaus M, McGrath S, et al. Continuous emotional support during labor in a US hospital. A randomized controlled trial. JAMA. 1991;265(17):2197-201. [pmid: 2013951].
Khan K S, Rizvi A. The partograph in the management of labor following cesarean section. Int J Gynaecol Obster. 1995;50(2):151-7.
Khan K S, Rizvi A, Rizvi J H. Risk of uterine rupture after the partographic ‘alert’ line is crossed--an additional dimension in the quest towards safe motherhood in labour following caesarean section. JPMA J Pak Med Assoc. 1996;46(6):120-2. [pmid: 8991366].
Khanna S. Inversion of uterus through an upper segment scar. Br J Obstet Gynaecol. 1999;106(11):1225-6. [pmid: 10549974].
Kieback D G, Zahradnik H P, Quaas L, et al. Clinical evaluation of endocervical prostaglandin E2-triacetin-gel for preinduction cervical softening in pregnant women at term. Prostaglandins. 1986;32(1):81-5. [pmid: 3532209].
Kildea S. Trial of scar--team midwifery makes a difference. J Aust Coll Midwives. 1996;9(3):21-2. [pmid: 8920421].
Kilpatrick S J, Safford K L. Repeat external cephalic version. Is it worth the effort?. J Reprod Med. 1995;40(11):775-8. [pmid: 8592311].
Kimball F A, Ruppel P L, Noah M L, et al. The effect of endocervical PGE2-gel (Prepidil) gel on plasma levels of 13,14-dihydro-15-keto-PGE2 (PGEM) in women at term. Prostaglandins. 1986;32(4):527-37. [pmid: 3541062].
Kindig M, Cardwell M, Lee T. Delayed postpartum uterine dehiscence. A case report. J Reprod Med. 1998;43(7):591-2. [pmid: 9693410].
King D E, Lahiri K. Socioeconomic factors and the odds of vaginal birth after cesarean delivery. JAMA. 1994;272(7):524-9. [pmid: 8046806].
Kirk EP, Doyle KA, Leigh J, et al. Vaginal birth after cesarean or repeat cesarean section: medical risks or social realities? Am J Obstet Gynecol 1990;162(6):1398–403; discussion 403–5.
Kishor T, Singh C, Barman S D, et al. Study of vaginal delivery in patients with one previous lower segment caesarean section. Aust N Z J Obstet Gynaecol. 1986;26(4):245-8. [pmid: 3469988].
Kitzinger S. Sheila Kitzinger's letter from Europe: awake, aware--and action!. Birth. 2001;28(3):210-2. [pmid: 11552971].
Kizer K W, Ellis A. C-section rate related to payment source. Am J Public Health. 1988;78(1):96-7. [pmid: 3337319].
Klein M, Rosen A, Beck A. Diagnostic potential of cardiotocography (CTG) for silent uterine rupture. Acta Obstet Gynecol Scand. 1989;68(7):653-6. [pmid: 2631533].
Klein M C, Gauthier R J, Robbins J M, et al. Relationship of episiotomy to perineal trauma and morbidity, sexual dysfunction, and pelvic floor relaxation. Am J Obstet Gynecol. 1994;171(3):591-8. [pmid: 8092203].
Kline J, Arias F. Analysis of factors determining the selection of repeated cesarean section or trial of labor in patients with histories of prior cesarean delivery. J Reprod Med. 1993;38(4):289-92. [pmid: 8501737].
Knight R, Fynes M, Permezel M. Faecal incontinence after vaginal delivery: a review. Aust N Z J Obstet Gynaecol. 2001;41(2):161-6. [pmid: 11453264].
Kolder V E, Gallagher J, Parsons M T. Court-ordered obstetrical interventions. N Engl J Med. 1987;316(19):1192-6. [pmid: 3574370].
Koska M T. Survey: lower cesarean rate reveal cost-quality tradeoffs. Trustee. 1989;42(4):16.
Kotagal U R, Atherton H D, Eshett R, et al. Safety of early discharge for Medicaid newborns. JAMA. 1999;282(12):1150-6. [pmid: 10501118].
Kozak L J. Surgical and nonsurgical procedures associated with hospital delivery in the United States: 1980-1987. Birth. 1989;16(4):209-13. [pmid: 2610787].
Kramer R L, Gilson G J, Morrison D S, et al. A randomized trial of misoprostol and oxytocin for induction of labor: safety and efficacy. Obstet Gynecol. 1997;89(3):387-91. [pmid: 9052591].
Krantz M E, Wennergren M, Bengtson L G, et al. Epidemiological analysis of the increased risk of disturbed neonatal respiratory adaptation after caesarean section. Acta Paediatr Scand. 1986;75(5):832-9. [pmid: 3564950].
Kraus J F, Bulterys M, Greenland S. A nested case-control study of oxytocin and sudden infant death syndrome. Am J Obstet Gynecol. 1990;162(2):604-605. [pmid: 2309851].
Krieger N. Analyzing socioeconomic and racial/ethnic patterns in health and health care. Am J Public Health. 1993;83(8):1086-7. [pmid: 8342712].
Krikke E H, Bell N R. Relation of family physician or specialist care to obstetric interventions and outcomes in patients at low risk: a western Canadian cohort study. Can Med Assoc J. 1989;140(6):637-43. [pmid: 2920337].
Krishnamurthy S, Fairlie F, Cameron A D, et al. The role of postnatal x-ray pelvimetry after caesarean section in the management of subsequent delivery. Br J Obstet Gynaecol. 1991;98(7):716-8. [pmid: 1883799].
Kumar S, Maouris P. Induction of labour for trial of vaginal birth after caesarean section in a remote district hospital. Aust N Z J Obstet Gynaecol. 1996;36(4):417-20. [pmid: 9006824].
Kwon J S, Davies G A L, Mackenzie V P. A comparison of oral and vaginal misoprostol for induction of labour at term: A randomised trial. Br J Obstet Gynaecol. 2001;108(1):23-26.
Lagrew D C Jr, Adashek J A. Lowering the cesarean section rate in a private hospital: comparison of individual physicians' rates, risk factors, and outcomes. Am J Obstet Gynecol. 1998;178(6):1207-14. [pmid: 9662303].
Lagrew D C, Morgan M A. Decreasing the cesarean section rate in a private hospital: success without mandated clinical changes. Am J Obstet Gynecol. 1996;174(1 Pt 1):184-91. [pmid: 8572004].
Lai S F, Sidek S. Delivery after a lower segment caesarean section. Singapore Med J. 1993;34(1):62-6. [pmid: 8266134].
Laken MP, Ager J. Use of the postpartum survey for program planing and ongoing evaluation. Abstr Book Assoc Health Serv Res;14:347–8
Land R, Parry E, Rane A, et al. Personal preferences of obstetricians towards childbirth. Aust N Z J Obstet Gynaecol. 2001;41(3):249-52. [pmid: 11592537].
Lange A P, Secher N J, Nielsen F H, et al. Stimulation of labor in cases of premature rupture of the membranes at or near term. A consecutive randomized study of prostaglandin E2-tablets and intravenous oxytocin. Acta Obstet Gynecol Scand. 1981;60(2):207-10. [pmid: 7018166].
Lantinen A J. Labor following previous cesarean section. Am J Obstet Gynecol. 1980;137(4):517. [pmid: 7386540].
Lao T T, Chin R K, Leung B F. Is X-ray pelvimetry useful in a trial of labour after caesarean section?. Eur J Obstet Gynecol Reprod Biol. 1987;24(4):277-83. [pmid: 3582716].
Lao T T, Leung B F. Rupture of the gravid uterus. Eur J Obstet Gynecol Reprod Biol. 1987;25(3):175-80. [pmid: 3609432].
Lao T T, Leung B F H. Labor induction for planned vaginal delivery in patients with previous cesarean section. Acta Obstet Gynecol Scand. 1987;66(5):413-416. [pmid: 3425241].
Lau T K, Chan F. Unknown uterine scars, unknown risks. Aust N Z J Obstet Gynaecol. 1994;34(2):216-7. [pmid: 7980320].
Lau T K, MRCOG, Wong S H, et al. A study of patient's acceptance towards vaginal birth after cesarean section. Aust N Z J Obstet Gynaecol. 1996;36(2):155-158. [pmid: 8798303].
Laube D W, Zlatnik F J, Pitkin R M. Preinduction cervical ripening with prostaglandin E2 intracervical gel. Obstet Gynecol. 1986;68(1):54-7. [pmid: 3523330].
Laufer A, Hodenius V, Friedman L, et al. Vaginal birth after cesarean section Nurse-midwifery management. J Nurse Midwifery. 1987;32(1):41-7. [pmid: 3644883].
Lavender T, Wallymahmed A H, Walkinshaw S A. Managing labor using partograms with different action lines: a prospective study of women's views. Birth. 1999;26(2):89-96. [pmid: 10687572].
Lavin J P, Stephens R J, Miodovnik M, et al. Vaginal delivery in patients with a prior cesarean section. Obstet Gynecol. 1982;59(2):135-48. [pmid: 7078857].
Law Y Y, Lam K Y. A randomized controlled trial comparing midwife-managed care and obstetrician-managed care for women assessed to be at low risk in the initial intrapartum period. J Obstet Gynaecol Res. 1999;25(2):107-12. [pmid: 10379125].
Lawler P E, Bulfin M J, Lawler F C, et al. A review of vainal delivery follwoing cesarean section, from private practice. Am J Obstet Gynecol. 1956;72:252. [pmid: 13339856].
Le Coutour X, Infante-Rivard C, Danzon A. [Regionalization of health care and obstetric practice]. Rev Epidemiol Sante Publique. 1990;38(3):211-20. [pmid: 2396034].
Leaphart W L, Meyer M C, Capeless E L. Labor induction with a prenatal diagnosis of fetal macrosomia. J Matern Fetal Med. 1997;6(2):99-102. [pmid: 9086425].
Learman L A, Evertson L R, Shiboski S. Predictors of repeat cesarean delivery after trial of labor: do any exist?. J Am Coll Surg. 1996;182(3):257-62. [pmid: 8603247].
Lee A H, Xiao J, Vemuri S R, et al. A discordancy test approach to identify outliers of length of hospital stay. Stat Med. 1998;17(19):2199-206. [pmid: 9802178].
Lee J Y, Cass A S. Spontaneous bladder and uterine rupture with attempted vaginal delivery after cesarean section. J Urol. 1992;147(3):691-2. [pmid: 1538460].
Lehmann D K, Chism J. Pregnancy outcome in medically complicated and uncomplicated patients aged 40 years or older. Am J Obstet Gynecol. 1987;157(3):738-42. [pmid: 3631175].
Lelaidier C, Baton C, Benifla J L, et al. Mifepristone for labour induction after previous caesarean section. Br J Obstet Gynaecol. 1994;101(6):501-3. [pmid: 8018638].
Lenke R, Osterkamp T. A prolapsed umbilical cord into the abdominal cavity in a woman with a previous cesarean section. Am J Obstet Gynecol. 1980;138(8):1224-5. [pmid: 7446634].
Lescale K B, Inglis S R, Eddleman K A, et al. Conflicts between physicians and patients in non-elective cesarean delivery: incidence and the adequacy of informed consent. Am J Perinatol. 1996;13(3):171-6. [pmid: 8688110].
Leung A S, Farmer R M, Leung E K, et al. Risk factors associated with uterine rupture during trial of labor after cesarean delivery: A case-control study. Am J Obstet Gynecol. 1993;168(5):1358-1363. [pmid: 8498412].
Leung A S, Leung E K, Paul R H. Uterine rupture after previous cesarean delivery: maternal and fetal consequences. Am J Obstet Gynecol. 1993;169(4):945-50. [pmid: 8238154].
Leung K M, Elashoff R M, Rees K S, et al. Hospital- and patient-related characteristics determining maternity length of stay: a hierarchical linear model approach. Am J Public Health. 1998;88(3):377-81. [pmid: 9518967].
Leung T Y, Lau T K, Lo K W, et al. A survey of pregnant women's attitude towards breech delivery and external cephalic version. Aust N Z J Obstet Gynaecol. 2000;40(3):253-9. [pmid: 11065030].
Leuthard J L, Davison M, Lorenz D. Obstetrical practice survey report. Healthy Futures Program, May 2, 1991. J Oklahoma State Med Assoc. 1991;84(12):607-11.
Leveno K J, Cunningham F G, Nelson S, et al. A prospective comparison of selective and universal electronic fetal monitoring in 34,995 pregnancies. N Engl J Med. 1986;315(10):615-9. [pmid: 3736600].
Leveno K J, Cunningham F G, Pritchard J A. Cesarean section: the House of Horne revisited. Am J Obstet Gynecol. 1989;160(1):78-9. [pmid: 2912105].
Leyland A. Socioeconomic and racial differences in obstetric procedures. [letter; comment]. Am J Public Health. 1993;83(8):1178-9. [pmid: 8342735].
Li W J, Li Z L, Ha K W. Effect of hyaluronidase on cervical ripening. Chin Med J. 1994;107(7):552-3. [pmid: 7956505].
Lieberman E. Risk factors for uterine rupture dining a trial of labor after cesarean. Clin Obstet Gynecol. 2001;44(3):609-621. [pmid: 11685885].
Lieberman E. Risk factors for uterine rupture during a trial of labor after cesarean. Clin Obstet Gynecol. 2001;44(3):609-621. [pmid: 11685885].
Lieberman E, Lang J M, Heffner L J, et al. Assessing the role of case mix in cesarean delivery rates. Obstet Gynecol. 1998;92(1):1-7. [pmid: 9649082].
Lilford R J, van Coeverden de Groot H A, Moore P J, et al. The relative risks of caesarean section (intrapartum and elective) and vaginal delivery: a detailed analysis to exclude the effects of medical disorders and other acute pre-existing physiological disturbances. Br J Obstet Gynaecol. 1990;97(10):883-92. [pmid: 2223678].
Lim R. A window to Bali. Midwifery Today Childbirth Educ 1993(28):22–3.
Lind B, Hoel T M. Alleviation of labor pain in Norway An interview investigation in 1969 and 1986. Acta Obstet Gynecol Scand. 1989;68(2):125-9. [pmid: 2589040].
Lipscomb K R, Gregory K, Shaw K. The outcome of macrosomic infants weighing at least 4500 grams: Los Angeles County + University of Southern California experience. Obstet Gynecol. 1995;85(4):558-64. [pmid: 7898833].
Lipson J G. Repeat cesarean births Social and psychological issues. JOGN Nurs. 1984;13(3):157-62. [pmid: 6563200].
Lledo R, Rodriguez T, Trilla A, et al. Perceived quality of care in pregnancy assessment before and after delivery. Eur J Obstet Gynecol Reprod Biol. 2000;88(1):35-42. [pmid: 10659914].
Localio A R, Lawthers A G, Bengtson J M, et al. Relationship between malpractice claims and cesarean delivery. JAMA. 1993;269(3):366-73. [pmid: 8418343].
Lomas J, Anderson G, Enkin M, et al. The role of evidence in the consensus process Results from a Canadian consensus exercise. JAMA. 1988;259(20):3001-5. [pmid: 3367477].
Lomas J, Anderson G M, Domnick-Pierre K, et al. Do practice guidelines guide practice? The effect of a consensus statement on the practice of physicians. N Engl J Med. 1989;321(19):1306-11. [pmid: 2677732].
Lomas J, Enkin M. Variations in operative delivery rates. Effictive care in pregnancy and childbirth, In: Chalmers I, Enkin M, Keirse MJNC, editors. 1989;2(Childbirth):1182-95.
Lomas J, Enkin M, Anderson G M, et al. Opinion leaders vs audit and feedback to implement practice guidelines. Delivery after previous cesarean section. JAMA. 1991;265(17):2202-7. [pmid: 2013952].
Lonky N M, Worthen N, Ross M G. Prediction of cesarean section scars with ultrasound imaging during pregnancy. J Ultrasound Med. 1989;8(1):15-9. [pmid: 2644438].
Lopez-Zeno J A, Peaceman A M, Adashek J A, et al. A controlled trial of a program for the active management of labor. N Engl J Med. 1992;326(7):450-4. [pmid: 1732771].
Lorenz R P, Botti J J, Chez R A, et al. Variations of biologic activity of low-dose prostaglandin E2 on cervical ripening. Obstet Gynecol. 1984;64(1):123-7. [pmid: 6377145].
Lovell R. Vaginal delivery after Caesarean section: factors influencing success rates. Aust N Z J Obstet Gynaecol. 1996;36(1):4-8. [pmid: 8775239].
Lucas V A. Birth: nursing's role in today's choices. RN. 1993;56(6):38-44. [pmid: 8516644].
Luckas M, Bricker L. Intravenous prostaglandin for induction of labour. Cochrane Database of Systematic Reviews 2000(4):CD002864.
Lumley J. Assessing satisfaction with childbirth. Birth. 1985;12:141-145. [pmid: 3850745].
Lurie S, Hagay Z, Goldschmit R, et al. Routine previous cesarean scar exploration following successful vaginal delivery. Is it necessary?. Eur J Obstet Gynecol Reprod Biol. 1992;45(3):185-6. [pmid: 1511765].
Lydon-Rochelle M, Holt V L, Easterling T R, et al. Cesarean delivery and postpartum mortality among primiparas in Washington State, 1987-1996(1). Obstet Gynecol. 2001;97(2):169-74. [pmid: 11165576].
Lydon-Rochelle M, Holt V L, Easterling T R, et al. Risk of uterine rupture during labor among women with a prior cesarean delivery. N Engl J Med. 2001;345(1):3-8. [pmid: 11439945].
Lydon-Rochelle M, Holt V L, Martin D P, et al. Association between method of delivery and maternal rehospitalization. JAMA. 2000;283(18):2411-6. [pmid: 10815084].
Lydon-Rochelle MT, Holt VL, Martin D. The association between method of delivery and maternal rehospitalization among primiparous women: Washington State 1987-1996. Abstr Book Assoc Health Serv Res;16:116.
Lydon-Rochelle M T, Holt V L, Martin D P. Delivery method and self-reported postpartum general health status among primiparous women. Paediatr Perinat Epidemiol. 2001;15(3):232-40. [pmid: 11489150].
Lynch J C, Pardy J P. Uterine rupture and scar dehiscence. A five-year survey. Anaesth Intensive Care. 1996;24(6):699-704. [pmid: 8971320].
MacDonald D. Previous obstetrical or gynaecological surgery. Clin Obstet Gynaecol. 1982;9(1):147-69. [pmid: 7105609].
Macfarlane A. At last--maternity statistics for England. BMJ. 1998;316(7131):566-7. [pmid: 9518893].
Macfarlane A, Chamberlain G. What is happening to caesarean section rates?. Lancet. 1993;342(8878):1005-6. [pmid: 8105260].
MacKenzie I Z, Bradley S, Embrey M P. Vaginal prostaglandins and labour induction for patients previously delivered by caesarean section. Br J Obstet Gynaecol. 1984;91(1):7-10. [pmid: 6581835].
MacLennan A H, Chan F Y, Eckert K. The safety of vaginal prostaglandin F2alpha for the stimulation of labour. Aust N Z J Obstet Gynaecol. 1994;34(2):154-158. [pmid: 7980303].
MacLennan A H, Green R C. A double blind dose trial of intravaginal prostaglandin F2 alpha for cervical ripening and the induction of labour. Aust N Z J Obstet Gynaecol. 1980;20(2):80-3. [pmid: 6932207].
MacLennan A H, Green R C, Bryant-Greenwood G D, et al. Ripening of the human cervix and induction of labour with purified porcine relaxin. Lancet. 1980;1(8162):220-3. [pmid: 6101676].
MacLennan A H, Green R C, Bryant-Greenwood G D, et al. Cervical ripening with combinations of vaginal prostaglandin F2-alpha estradiol, and relaxin. Obstet Gynecol. 1981;58(5):601-4. [pmid: 7029370].
MacLennan A H, Green R C, Grant P, et al. Ripening of the human cervix and induction of labor with intracervical purified porcine relaxin. Obstet Gynecol. 1986;68(5):598-601. [pmid: 3531936].
Macones G A. The utility of clinical tests of eligibility for a trial of labour following a caesarean section: a decision analysis. Br J Obstet Gynaecol. 1999;106(7):642-6. [pmid: 10428518].
Macones G A, Hausman N, Edelstein R, et al. Predicting outcomes of trials of labor in women attempting vaginal birth after cesarean delivery: a comparison of multivariate methods with neural networks. Am J Obstet Gynecol. 2001;184(3):409-13. [pmid: 11228495].
Magann E F, Nolan T E. Pregnancy outcome in an active-duty population. Obstet Gynecol. 1991;78(3 Pt 1):391-3. [pmid: 1876371].
Maher C F, Cave D G, Haran M V. Caesarean section rate reduced. Aust N Z J Obstet Gynaecol. 1994;34(4):389-92. [pmid: 7848224].
Mahmood T. The role of radiological pelvimetry in the management of patients who have had a previous caesarean section. J Obstet Gynaecol. 1987;8(8):24-28.
Mahmood T A. Maternal height, birthweight, obstetric conjugate and their influence on the management of parturients with a previous cesarean scar. Acta Obstet Gynecol Scand. 1989;68(7):595-8. [pmid: 2631526].
Makinen J I, Meltomaa S S, Ekblad U U. Hospital stay due to various hysterectomies, caesarean section and normal delivery in Turku University Central Hospital area from 1983 to 1992. Ann Chir Gynaecol Suppl. 1994;208:54-7. [pmid: 8092774].
Maouris P. Successful vaginal delivery after caesarean scar rupture: a case report. Clin Exp Obstet Gynecol. 1989;16(1):1-2. [pmid: 2713988].
Marchesoni D, Franco F, Mozzanega B, et al. Vaginal delivery after previous cesarean section. Clin Exp Obstet Gynecol. 1984;11(4):150-1. [pmid: 6499189].
Marcus S, Cheng E, Goff B. Extrauterine pregnancy resulting from early uterine rupture. Obstet Gynecol. 1999;94(5 Pt 2):804-5. [pmid: 10546734].
Mardon R E, Shafer K D, Hinton S A. Cesarean deliveries in Florida: current trends and related factors. J Fla Med Assoc. 1997;84(5):310-5. [pmid: 9260435].
Marieskind H I. Cesarean section in the United States: has it changed since 1979?. Birth. 1989;16(4):196-202. [pmid: 2610785].
Marta MR. Current topics in obstetrical risk management--Part I. J Healthc Qual 1994;16(5):6–9, quiz 9, 19.
Marta MR. Current topics in obstetrical risk management--Part II. J Healthc Qual 1994;16(6):6–9; quiz 16, 48.
Martin J A, Hamilton B E, Ventura S J, et al. Births: final data for 2000. Natl Vital Stat Rep. 2002;50(5):1-101.
Martin J A, Smith B L, Mathews T J, et al. Births and deaths: preliminary data for 1998. Natl Vital Stat Rep. 1999;47(25):1-45.
Martin J N, Harris B A, Huddleston J F, et al. Vaginal delivery following previous cesarean birth. Am J Obstet Gynecol. 1983;146(3):255-63. [pmid: 6859134].
Martin J N Jr, Morrison J C. Vaginal birth after cesarean section: the demise of routine repeat abdominal delivery. Obstet Gynecol Clin North Am. 1988;15(4):719-36. [pmid: 3226673].
Maslow A S, Sweeny A L. Elective induction of labor as a risk factor for cesarean delivery among low-risk women at term. Obstet Gynecol. 2000;95(6 Pt 1):917-22. [pmid: 10831992].
Mathews J. Placenta praevia percreta with bladder penetration. Med J Aust. 1983;1(4):173-4. [pmid: 6843467].
Mathews T J. Trends in stimulation and induction of labor 1989-1995. Stat Bull Metrop Insur Co. 1997;78(4):20-6. [pmid: 9357077].
Mauldin J G, Mauldin P D, Feng T I, et al. Determining the clinical efficacy and cost savings of successful external cephalic version. Am J Obstet Gynecol. 1996;175(6):1639-44. [pmid: 8987953].
Maymon R, Haimovich L, Shulman A, et al. Third-trimester uterine rupture after prostaglandin E2 use for labor induction. J Reprod Med. 1992;37(5):449-52. [pmid: 1507193].
Mc Gurgan P, Coulter-Smith S, PJ O D. A national confidential survey of obstetrician's personal preferences regarding mode of delivery. Eur J Obstet Gynecol Reprod Biol. 2001;97(1):17-9. [pmid: 11435001].
McClain C S. Why women choose trial of labor or repeat cesarean section. J Fam Pract. 1985;21(3):210-6. [pmid: 4031794].
McClain C S. Patient decision making: the case of delivery method after a previous cesarean section. Cult Med Psychiatry. 1987;11(4):495-508. [pmid: 3691163].
McClain C S. The making of a medical tradition: vaginal birth after cesarean. Soc Sci Med. 1990;31(2):203-10. [pmid: 2389156].
McCloskey L, Kosecoff J, Brook RJ. Conformity to recommendations on childbirth by cesarean delivery. In: Kanouse DE, Winkler JD, Kosecoff J, editors. Changing medical practice through technology assessment: an evaluation of the National Institutes of Health Consensus Development Program. Ann Arbor, MI: Health Administration Press; 1989. p. 28.
McCloskey L, Petitti D B, Hobel C J. Variations in the use of cesarean delivery for dystocia: lessons about the source of care. Med Care. 1992;30(2):126-35. [pmid: 1736018].
McGurgan P, Coulter-Smith S, PJ O D. A national confidential survey of obstetrician's personal preferences regarding mode of delivery. Eur J Obstet Gynecol Reprod Biol. 2001;97(1):17-9. [pmid: 11435001].
McIntosh D G, Rayburn W F. Patient-controlled analgesia in obstetrics and gynecology. Obstet Gynecol. 1991;78(6):1129-35. [pmid: 1945222].
McIntosh I D. Hospital effects of maternity early discharge. Med Care. 1984;22(7):611-9. [pmid: 6748779].
McKenna J P, Guerdan B R, Wright J C. Vaginal birth after cesarean section A safe option in carefully selected patients. Postgrad Med. 1988;84(6):211-5. [pmid: 3054847].
McKenzie L, Stephenson P A. Variation in cesarean section rates among hospitals in Washington State. Am J Public Health. 1993;83(8):1109-12. [pmid: 8342718].
McMahon M J. Vaginal birth after cesarean. Clin Obstet Gynecol. 1998;41(2):369-81. [pmid: 9646969].
McMahon M J, Luther ER, Bowes WA, et al. Comparison of a trial of labor with an elective second cesarean section. N Engl J Med. 1996;335(10):689-95. [pmid: 8703167].
McNally O M, Turner M J. Induction of labour after 1 previous Caesarean section. Aust N Z J Obstet Gynaecol. 1999;39(4):425-9. [pmid: 10687757].
McNellis D, Medearis A L, Fowler S, et al. A clinical trial of induction of labor versus expectant management in postterm pregnancy: The National Institute of Child Health and Human Development Network of Maternal-Fetal Medicine Units. Am J Obstet Gynecol. 1994;170(3):716-723. [pmid: 7710467].
Meehan F P. Delivery following prior cesarean section: an obstetrician's dilemma?. Obstet Gynecol Survey. 1988;43(10):582-9.
Meehan F P. Trial of scar with induction/oxytocin in delivery following prior section. Clin Exp Obstet Gynecol. 1988;15(4):117-123. [pmid: 3233752].
Meehan F P, Burke G. Trial of labour following prior section; a 5 year prospective study (1982-1987). Eur J Obstet Gynecol Reprod Biol. 1989;31(2):109-17. [pmid: 2759320].
Meehan F P, Burke G, Casey C, et al. Delivery following cesarean section and perinatal mortality. Am J Perinatol. 1989;6(1):90-4. [pmid: 2910325].
Meehan F P, Burke G, Kehoe J T. Update on delivery following prior cesarean section: a 15-year review 1972-1987. Int J Gynaecol Obster. 1989;30(3):205-12.
Meehan F P, Burke G, Kehoe J T, et al. True rupture/scar dehiscence in delivery following prior section. Int J Gynaecol Obster. 1990;31(3):249-55.
Meehan F P, Magani I M. True rupture of the caesarean section scar (a 15 year review, 1972-1987). Eur J Obstet Gynecol Reprod Biol. 1989;30(2):129-35. [pmid: 2703100].
Meehan F P, Moolgaoker A S, Stallworthy J. Vaginal delivery under caudal analgesia after caesarean section and other major uterine surgery. BMJ. 1972;2(816):740-2. [pmid: 5036881].
Megafu U. Factors influencing maternal survival in ruptured uterus. Int J Gynaecol Obster. 1985;23(6):475-80.
Meier P R, Porreco R P. Trial of labor following cesarean section: a two-year experience. Am J Obstet Gynecol. 1982;144(6):671-8. [pmid: 7137251].
Melchior J, Bernard N. Incidence and pattern of fetal heart rate alterations during labor. In: Kunzel W, editor. Heart rate monitoring: clinical practice and physiology. Berlin: Springer-Verlag; 1985.
Melnikow J, Romano P, Gilbert W M, et al. Vaginal birth after cesarean in California. Obstet Gynecol. 2001;98(3):421-6. [pmid: 11530123].
Menacker F, Curtin S C. Trends in Cesarean Birth and Vaginal Birth After Previous Cesarean, 1991-99. Natl Vital Stat Rep. 2001;49(13):1-16.
Menihan C A. Uterine rupture in women attempting a vaginal birth following prior cesarean birth. J Perinatol. 1998;18(6 Pt 1):440-3. [pmid: 9848757].
Menihan C A. The effect of uterine rupture on fetal heart rate patterns. J Nurse Midwifery. 1999;44(1):40-6. [pmid: 10063224].
Menticoglou S M, Manning F A, Morrison I, et al. Must macrosomic fetuses be delivered by a caesarean section? A review of outcome for 786 babies greater than or equal to 4,500 g. Aust N Z J Obstet Gynaecol. 1992;32(2):100-3. [pmid: 1520190].
Merrill D C, Zlatnik F J. Randomized, double-masked comparison of oxytocin dosage in induction and augmentation of labor. Obstet Gynecol. 1999;94(3):455-63. [pmid: 10472877].
Mesleh R A, Kurdi A M, Algwiser A A. Intrapartum rupture of the uterus 19 Years' experience. Int J Gynecol Obstet. 1999;64(3):311-312.
Metcalfe J. Midwives' Journal An image restored. Nurs Times. 1986;82(22):66. [pmid: 3636889].
Michaels W H, Thompson H O, Boutt A, et al. Ultrasound diagnosis of defects in the scarred lower uterine segment during pregnancy. Obstet Gynecol. 1988;71(1):112-20. [pmid: 3275907].
Miklos J R, Sze E, Parobeck D, et al. Vesicouterine fistula: a rare complication of vaginal birth after cesarean. Obstet Gynecol. 1995;86(4 Pt 2):638-9. [pmid: 7675394].
Miksovsky P, Watson W J. Obstetric vacuum extraction: state of the art in the new millennium. Obstet Gynecol Survey. 2001;56(11):736-51.
Miles A M, Monga M, Waller K, et al. Risk factors for symptomatic uterine rupture during a trial of labor: The 1990s. Am J Perinatol. 2000;17(7):385-389. [pmid: 12141526].
Miller C F, Sutter C S. Vaginal birth after cesarean. J Obstet Gynecol Neonat Nurs. 1985;14(5):383-9.
Miller D A, Diaz F G, Paul R H. Vaginal birth after cesarean: a 10-year experience. Obstet Gynecol. 1994;84(2):255-8. [pmid: 8041542].
Miller D A, Goodwin T M, Gherman R B, et al. Intrapartum rupture of the unscarred uterus. Obstet Gynecol. 1997;89(5 Pt 1):671-3. [pmid: 9166298].
Miller D A, Mullin P, Hou D, et al. Vaginal birth after cesarean section in twin gestation. Am J Obstet Gynecol. 1996;175(1):194-8. [pmid: 8694051].
Miller E S, Partezana J, Montgomery R L. Vaginal birth after cesarean: a 5-year experience in a family practice residency program. J Am Board Fam Pract. 1995;8(5):357-60. [pmid: 7484222].
Miller J. The role of the legal system in the cesarean childbirth controversy. Nurs Law Ethics 1980;1(10):1–2, 6, 8.
Miller J. The role of the legal system in the cesarean childbirth controversy. Nurs Law Ethics. 1988;15(4):629-38.
Miller M, Leader L R. Vaginal delivery after caesarean section. Aust N Z J Obstet Gynaecol. 1992;32(3):213-6. [pmid: 1445129].
Minor AF. The cost of maternity care and childbirth in the United States, 1989. Washington: Health Insurance Association of America, Research Bulletin 1989;December.
Misra M, Vavre S. Labour induction with intracervical prostaglandin E2 gel and intravenous oxytocin in women with a very unfavourable cervix. Aust N Z J Obstet Gynaecol. 1994;34(5):511-515.
Mocanu E V, Greene R A, Byrne B M, et al. Obstetric and neonatal outcome of babies weighing more than 4.5 kg: an analysis by parity. Eur J Obstet Gynecol Reprod Biol. 2000;92(2):229-33. [pmid: 10996687].
Moller M, Thomsen A C, Sorensen J, et al. Oxytocin- or low-dose prostaglandin F2 alpha-infusion for stimulation of labor after primary rupture of membranes A prospective, randomized trial. Acta Obstet Gynecol Scand. 1987;66(2):103-6. [pmid: 3303813].
Molloy B G, Sheil O, Duignan N M. Delivery after caesarean section: review of 2176 consecutive cases. Br Med J (Clin Res Ed). 1987;294(6588):1645-7.
Moore T R, Origel W, Key T C, et al. The perinatal and economic impact of prenatal care in a low-socioeconomic population. Am J Obstet Gynecol. 1986;154(1):29-33. [pmid: 3946500].
Mootabar H, Dwyer J F, Surur F, et al. Vaginal delivery following previous cesarean section in 1983. Int J Gynaecol Obstet. 1984;22(2):155-60. [pmid: 6145641].
Mor-Yosef S, Zeevi D, Samueloff A, et al. Vaginal delivery following one previous cesarean birth: nation wide survey. Asia Oceania J Obstet Gynaecol. 1990;16(1):33-7. [pmid: 2344309].
Moran C, Carranza-Lira S, Ochoa R, et al. Gastrin levels in mothers and neonates at delivery in various perinatal conditions. Acta Obstet Gynecol Scand. 1996;75(7):608-11. [pmid: 8822651].
Morewood G A, O'sullivan M J, McConney J. Vaginal delivery after cesarean section. Obstet Gynecol. 1973;42(4):589-95. [pmid: 4742663].
Morgan M A, Thurnau G R. Efficacy of the fetal-pelvic index for delivery of neonates weighing 4000 grams or greater: a preliminary report. Am J Obstet Gynecol. 1988;158(5):1133-7. [pmid: 3285685].
Morgan M A, Thurnau G R, Fishburne J I. The fetal-pelvic index as an indicator of fetal-pelvic disproportion: a preliminary report. Am J Obstet Gynecol. 1986;155(3):608-13. [pmid: 3529966].
Moriya M, Kusaka H, Shimizu K, et al. Spontaneous rupture of the uterus caused by placenta percreta at 28 weeks of gestation: a case report. J Obstet Gynaecol Res. 1998;24(3):211-4. [pmid: 9714992].
Morrison J J, Rennie J M, Milton P J. Neonatal respiratory morbidity and mode of delivery at term: influence of timing of elective caesarean section. Br J Obstet Gynaecol. 1995;102(2):101-6. [pmid: 7756199].
Moskovitz H, O'Grady J P, Gimovsky M. Fetal heart rate monitoring casebook. Uterine rupture and sinusoidal heart rate. J Perinatol. 1994;14(2):154-8. [pmid: 8014702].
Mould T A, Chong S, Spencer J A, et al. Women's involvement with the decision preceding their caesarean section and their degree of satisfaction. Br J Obstet Gynaecol. 1996;103(11):1074-7. [pmid: 8916991].
Mousa H A, Mahmood T A. Do practice guidelines guide practice? A prospective audit of induction of labor three years experience. Acta Obstet Gynecol Scand. 2000;79(12):1086-92. [pmid: 11130093].
Mozurkewich E L, Hutton E K. Elective repeat cesarean delivery versus trial of labor: a meta-analysis of the literature from 1989 to 1999. Am J Obstet Gynecol. 2000;183(5):1187-97. [pmid: 11084565].
Mullings A M, Hall J S. Rupture of uterus and bladder in vaginal delivery following previous caesarean section. West Indian Med J. 1987;36(1):51-3. [pmid: 3590754].
Mundle W R, Young D C. Vaginal misoprostol for induction of labor: a randomized controlled trial. Obstet Gynecol. 1996;88(4 Pt 1):521-5. [pmid: 8841210].
Murphy M C, Harvey S M. Choice of a childbirth method after cesarean. Women Health. 1989;15(2):67-85. [pmid: 2781811].
Murray TM. Case 9-1998: uterine rupture. N Engl J Med 1998;339(4):268; discussion 269.
Mushinski M. Average charges for uncomplicated cesarean and vaginal deliveries, United States, 1993. Stat Bull Metrop Insur Co. 1994;75(4):27-36. [pmid: 7817268].
Mushinski M. Average charges for uncomplicated vaginal, cesarean and VBAC deliveries: regional variations, United States, 1996. Stat Bull Metrop Insur Co. 1998;79(3):17-28. [pmid: 9691358].
Myers S A, Gleicher N. Breech delivery: why the dilemma?. Am J Obstet Gynecol. 1986;156(1):6-10. [pmid: 3799770].
Myers S A, Gleicher N. A successful program to lower cesarean-section rates. N Engl J Med. 1988;319(23):1511-6. [pmid: 3185675].
Myers S A, Gleicher N. A program to lower cesarean section rates [letter]. N Engl J Med. 1989;320:1693.
Myers S A, Gleicher N. 1988 U.S. cesarean-section rate: good news or bad?. N Engl J Med. 1990;323(3):200. [pmid: 2362615].
Myers S A, Gleicher N. Implementation of a cesarean section program: the quality assurance process. QRB. Qual Rev Bull. 1991;17(5):162-166. [pmid: 2052351].
Myers S A, Gleicher N. The Mount Sinai cesarean section reduction program: an update after 6 years. Soc Sci Med. 1993;37(10):1219-22. [pmid: 8272900].
Myerscough P. Systematic reviews: insufficient evidence on which to base medicine. Br J Obstet Gynaecol 1998;105(11):1235; discussion 1236.
Myles T. Vaginal birth of twins after a previous Cesarean section. J Matern Fetal Med. 2001;10(3):171-4. [pmid: 11444785].
Nachman KL, Oleske DM, Linn ES, et al. The effect of obstetrical quality process initiatives on the likelihood of newborn birth trauma in Medicaid managed care, Medicaid fee-for-service, and private managed care. Abstr Book Assoc Health Serv Res;15:198.
Naef RW, Ray MA, Chauhan SP, et al. Trial of labor after cesarean delivery with a lower-segment, vertical uterine incision: is it safe? Am J Obstet Gynecol 1995;172(6):1666–73; discussion 1673–4.
Naeye R L. Maternal age, obstetric complications, and the outcome of pregnancy. Obstet Gynecol. 1983;61(2):210-6. [pmid: 6823362].
Nagarkatti R S, Ambiye V R, Vaidya P R. Ruptured uterus: changing trends in etiology and management. J Postgrad Med. 1991;37:136-139. [pmid: 1784024].
Naiden J, Deshpande P. Using active management of labor and vaginal birth after previous cesarean delivery to lower cesarean delivery rates: aA 10-year experience. Am J Obstet Gynecol 2001;184(7):1535–41; discussion 1541–3.
National Institute of Child Health & Human Development Research Planning Workshop. Electronic fetal heart rate monitoring: research guidelines for interpretation. Am J Obstet Gynecol. 1997;177(6):1385-90. [pmid: 9423739].
Neilson D R, Prins R P, Bolton R N, et al. A comparison of prostaglandin E2 gel and prostaglandin F2 alpha gel for preinduction cervical ripening. Am J Obstet Gynecol. 1983;146(5):526-32. [pmid: 6344644].
Nelson L J. Legal dimensions of maternal-fetal conflict. Clin Obstet Gynecol. 1992;35(4):738-48. [pmid: 1451357].
Nelson L J, Milliken N. Compelled medical treatment of pregnant women Life, liberty, and law in conflict. JAMA. 1988;259(7):1060-6. [pmid: 3276942].
Nesbitt T S, Tanji J L, Scherger J E, et al. Obstetric care, Medicaid, and family physicians. How policy changes affect physicians' attitudes. West J Med. 1991;155(6):653-7. [pmid: 1812644].
Newton E R, Higgins C S. Factors associated with hospital-specific cesarean birth rates. J Reprod Med. 1989;34(6):407-11. [pmid: 2738872].
Ngu A, Quinn M A. Vaginal delivery following caesarean section. Aust N Z J Obstet Gynaecol. 1985;25(1):41-3. [pmid: 3899089].
Nguyen T V, Dinh T V, Suresh M S, et al. Vaginal birth after cesarean section at the University of Texas. J Reprod Med. 1992;37(10):880-2. [pmid: 1479573].
Nielsen T F, Hokegard K H. Postoperative cesarean section morbidity: a prospective study. Am J Obstet Gynecol. 1983;146(8):911-5. [pmid: 6881224].
Nielsen T F, Hokegard K H. The course of subsequent pregnancies after previous cesarean section. Acta Obstet Gynecol Scand. 1984;63(1):13-6. [pmid: 6720254].
Nielsen T F, Hokegard K H. The incidence of acute neonatal respiratory disorders in relation to mode of delivery. Acta Obstet Gynecol Scand. 1984;63(2):109-14. [pmid: 6730922].
Nielsen T F, Hokegard K H, Moldin P G. X-ray pelvimetry and trial of labor after previous cesarean section A prospective study. Acta Obstet Gynecol Scand. 1985;64(6):485-90. [pmid: 4061065].
Nielsen T F, Ljungblad U, Hagberg H. Rupture and dehiscence of cesarean section scar during pregnancy and delivery. Am J Obstet Gynecol. 1989;160(3):569-73. [pmid: 2929675].
Nimrod C, Currie J, Yee J, et al. Cervical ripening and labor induction with intracervical triacetin base prostaglandin E2 gel: a placebo-controlled study. Obstet Gynecol. 1984;64(4):476-9. [pmid: 6384844].
Nissen E, Gustavsson P, Widstrom A M, et al. Oxytocin, prolactin, milk production and their relationship with personality traits in women after vaginal delivery or Cesarean section. J Psychosomat Obstet Gynecol. 1998;19(1):49-58.
Noah M L, DeCoster J M, Fraser T J, et al. Preinduction cervical softening with endocervical PGE2 gel A multi-center trial. Acta Obstet Gynecol Scand. 1987;66(1):3-7. [pmid: 3300135].
Nordin A J, Richardson J A. Lower segment uterine scar rupture during induction of labour with vaginal prostaglandin E2 [1]. Postgrad Med J. 1993;69(813):592. [pmid: 8415353].
Norman M, Ekman G. Preinductive cervical ripening with prostaglandin E2 in women with one previous cesarean section. Acta Obstet Gynecol Scand. 1992;71(5):351-355. [pmid: 1326210].
Norman P. Vaginal birth after caesarean section. Lancet. 1995;345(8943):142. [pmid: 7823667].
Norman P, Kostovcik S, Lanning A. Elective repeat cesarean sections: how many could be vaginal births?. Can Med Assoc J. 1993;149(4):431-5. [pmid: 8348425].
Notzon F C. International differences in the use of obstetric interventions. JAMA. 1990;263(24):3286-91. [pmid: 2348539].
Notzon F C, Cnattingius S, Bergsjo P, et al. Cesarean section delivery in the 1980s: international comparison by indication. Am J Obstet Gynecol. 1994;170(2):495-504. [pmid: 8116703].
Novas J, Myers S A, Gleicher N. Obstetric outcome of patients with more than one previous cesarean section. Am J Obstet Gynecol. 1989;160(2):364-7. [pmid: 2916619].
O'Boyle A L, Woodman P J, O'Boyle J D, et al. Pelvic organ support in nulliparous pregnant and nonpregnant women: a case control study. Am J Obstet Gynecol. 2002;187(1):99-102. [pmid: 12114895].
O'Brien J M, Barton J R, Donaldson E S. The management of placenta percreta: conservative and operative strategies. Am J Obstet Gynecol. 1996;175(6):1632-8. [pmid: 8987952].
O'Bryant C. QQ: VBAC waterbirth. Midwifery Today 2000(54):34.
O'Connor K M. How safe is induction of labour following a previous caesarean section?. J Obstet Gynaecol. 1983;4(2):86-87.
O'Connor R A, Gaughan B. Pregnancy following simple repair of the ruptured gravid uterus. Br J Obstet Gynaecol. 1989;96(8):942-4. [pmid: 2775692].
O'Driscoll K, Foley M, MacDonald D, et al. Cesarean section and perinatal outcome: response from the House of Horne. Am J Obstet Gynecol. 1988;158(3 Pt 1):449-52. [pmid: 3348301].
O'Flaherty L. Oral misoprostol and intracervical dinoprostone for cervical ripening and labor induction: a randomized comparison. J Midwifery Womens Health. 2001;46(3):203-4. [pmid: 11480753].
O'Meara C. An evaluation of consumer perspectives of childbirth and parenting education. Midwifery. 1993;9(4):210-9. [pmid: 8283953].
O'Neil JD, Gilbert P, Kusugak N, et al. Obstetric policy for the Keewatin Region, N.W.T.: results of the childbirth experience survey. Arctic Med Res 1991;Suppl:572–6.
O'Sullivan M J, Fumia F, Holsinger K, et al. Vaginal delivery after cesarean section. Clin Perinatol. 1981;8(1):131-43. [pmid: 7237886].
Obara H, Minakami H, Koike T, et al. Vaginal birth after cesarean delivery: results in 310 pregnancies. Journal of Obstetrics & Gynaecology Research. 1998;24(2):129-34. [pmid: 9631601].
Oberer D, Auckerman L. Best practice: clinical pathways for uncomplicated births. Best Pract Benchmarking Healthc. 1996;1(1):43-50. [pmid: 9192590].
Oberman L H. Obstetrics: reducing C-sections without financial ruin. Trustee. 1989;42(4):20. [pmid: 10292726].
Obst T E, Nauenberg E, Buck G M. Maternal health insurance coverage as a determinant of obstetrical anesthesia care. Journal of Health Care for the Poor & Underserved. 2001;12(2):177-91. [pmid: 11370186].
Odeh M, Tarazova L, Wolfson M, et al. Evidence that women with a history of cesarean section can deliver twins safely. Acta Obstet Gynecol Scand. 1997;76(7):663-6. [pmid: 9292641].
Odibo A O, O'Coigligh J, Selinger M. Planned vaginal delivery after two previous caesarean sections. Br J Obstet Gynaecol. 1995;102(3):262-3. [pmid: 7794857].
Ohel G, Haddad S, Linder N. Fetal urine production after induction of labor with prostaglandin E2. Am J Obstet Gynecol. 1994;171(5):1242-1243. [pmid: 7977527].
Ojo V A, Okwerekwu F O. Vaginal delivery in first pregnancy following a primary caesarean section. Asia Oceania J Obstet Gynaecol. 1989;15(2):121-6. [pmid: 2757570].
Oleske D M, Glandon G L, Giacomelli G J, et al. The cesarean birth rate: influence of hospital teaching status. Health Serv Res. 1991;26(3):325-37. [pmid: 1869443].
Oleske D M, Glandon G L, Tancredi D J, et al. Information dissemination and the cesarean birth rate. The Illinois experience. Int J Technol Assess Health Care. 1992;8(4):708-18. [pmid: 1464490].
Oleske D M, Linn E S, Nachman K L, et al. Effect of Medicaid managed care on pregnancy complications. Obstet Gynecol. 2000;95(1):6-13. [pmid: 10636493].
Oleske D M, Linn E S, Nachman K L, et al. Cesarean and VBAC delivery rates in Medicaid managed care, Medicaid fee-for-service, and private managed care. Birth. 1998;25(2):125-7. [pmid: 9668747].
Ollendorff D A, Goldberg J M, Minogue J P, et al. Vaginal birth after cesarean section for arrest of labor: is success determined by maximum cervical dilatation during the prior labor?. Am J Obstet Gynecol. 1988;159(3):636-9. [pmid: 3421262].
Onuora V C, al Ariyan R, Koko A H, et al. Major injuries to the urinary tract in association with childbirth. East Afr Med J. 1997;74(8):523-6. [pmid: 9487420].
Ophir E, Oettinger M, Yagoda A, et al. Breech presentation after cesarean section: always a section?. Am J Obstet Gynecol. 1989;161(1):25-8. [pmid: 2750812].
Ophir E, Yagoda A, Rojansky N, et al. Trial of labor following cesarean section: dilemma. Obstet Gynecol Survey. 1989;44(1):19-24.
Osmers R, Ulbrich R, Schauer A, et al. Sonographic detection of an asymptomatic rupture of the uterus due to necrosis during the third trimester. Int J Gynaecol Obster. 1988;26(2):279-84.
Ottinger W S, Menard M K, Brost B C, et al. A randomized clinical trial of prostaglandin E2 intracervical gel and a slow release vaginal pessary for preinduction cervical ripening. Am J Obstet Gynecol. 1998;179(2):349-353. [pmid: 9731837].
Oumachigui A, Rajagopalan G, Reddy R, et al. Placenta accreta and percreta: a review of 5 cases. Int J Gynaecol Obster. 1981;19(4):337-40.
Ouzounian J G, Miller D A, Paul R H. Amnioinfusion in women with previous cesarean births: a preliminary report. Am J Obstet Gynecol. 1996;174(2):783-6. [pmid: 8623822].
Oyelese Y, Landy H J, Collea J V. Cervical laceration associated with misoprostol induction. Int J Gynaecol Obster. 2001;73(2):161-2.
Ozumba B C, Nwabue R. Spontaneous uterine rupture following low upper segment transverse incision. Trop Doct. 1997;27(2):111-2. [pmid: 9133802].
Paech M J. The King Edward Memorial Hospital 1,000 mother survey of methods of pain relief in labour. Anaesth Intensive Care. 1991;19(3):393-9. [pmid: 1767909].
Paraskevaides E, Stuart B, Gardeil F. Secondary postpartum haemorrhage from nondehisced lower caesarean section scar: a case for hysteroscopy. Aust N Z J Obstet Gynaecol. 1993;33(4):427. [pmid: 8179561].
Parrish K M, Holt V L, Connell F A, et al. Variations in the accuracy of obstetric procedures and diagnoses on birth records in Washington State, 1989. Am J Epidemiol. 1993;138(2):119-27. [pmid: 8342530].
Parrish K M, Holt V L, Easterling T R, et al. Effect of changes in maternal age, parity, and birth weight distribution on primary cesarean delivery rates. JAMA. 1994;271(6):443-7. [pmid: 8295319].
Paterson C M, Saunders N J. Mode of delivery after one caesarean section: audit of current practice in a health region. BMJ. 1991;303(6806):818-21. [pmid: 1932972].
Paterson C M, Saunders N S. The fetal maturity and mode of delivery of a woman's first baby influences the characteristics of her next labour. Eur J Obstet Gynecol Reprod Biol. 1991;42(3):187-93. [pmid: 1773872].
Pauerstein C J. Labor after cesarean section: from precept to practice. J Reprod Med. 1981;26(8):409-12. [pmid: 7277351].
Pauerstein C J, Karp L, Muher S. Trial of labor after low segment cesarean section. South Med J. 1969;62(8):925-8. [pmid: 5798330].
Paul R H. Cesarean section: at term on request [editorial]. Perinatol Neonatol. 1988;12(4):7.
Paul R H. Toward fewer cesarean sections--the role of a trial of labor. N Engl J Med. 1996;335(10):735-6. [pmid: 8703175].
Paul R H, Phelan J P, Yeh S Y. Trial of labor in the patient with a prior cesarean birth. Am J Obstet Gynecol. 1985;151(3):297-304. [pmid: 3970097].
Pauly M V, Redisch M. The not-for-profit hospital as a physicians' cooperative. Am Econ Rev. 1973;63(1):87-99.
Peaceman A M, Lopez-Zeno J A, Minogue J P, et al. Factors that influence route of delivery--active versus traditional labor management. Am J Obstet Gynecol. 1993;169(4):940-4. [pmid: 8238153].
Pearl M L, Escamilla G, Karpel B M, et al. Conservative management of placenta percreta with involvement of the ileum. Arch Gynecol Obstet. 1996;258(3):147-50. [pmid: 8781703].
Pel M, Heres M H, Hart A A, et al. Provider-associated factors in obstetric interventions. Eur J Obstet Gynecol Reprod Biol. 1995;61(2):129-34. [pmid: 7556833].
Peleg D, Hannah M E, Hodnett E D, et al. Predictors of cesarean delivery after prelabor rupture of membranes at term. Obstet Gynecol. 1999;93(6):1031-5. [pmid: 10362176].
Pello L C, Rosevear S K, Dawes G S, et al. Computerized fetal heart rate analysis in labor. Obstet Gynecol. 1991;78(4):602-10. [pmid: 1923162].
Pelosi M A. Vesicouterine fistula: a rare complication of vaginal birth after cesarean. Obstet Gynecol. 1996;87(1):160-2. [pmid: 8532257].
Penso C. Vaginal birth after cesarean section: An update on physician trends and patient perceptions. Curr Opin Obstet Gynecol. 1994;6(5):417-425. [pmid: 7827271].
Perveen F, Shah Q. Obstetric outcome after one previous caesarean section. J Obstet Gynaecol Res. 1997;23(4):341-6. [pmid: 9311174].
Peters C, Cowley M, Standiford L. The process of outcomes management in an acute care facility. Nurs Adm Q. 1999;24(1):75-89. [pmid: 10765248].
Petitti D. Maternal mortality and morbidity in cesarean section. Clin Obstet Gynecol. 1985;28(4):763-69. [pmid: 4075629].
Petitti D B, Cefalo R C, Shapiro S, et al. In-hospital maternal mortality in the United States: time trends and relation to method of delivery. Obstet Gynecol. 1982;59(1):6-12. [pmid: 7078850].
Petrikovsky B M. Endoscopic assessment of the integrity of the postcesarean uterine wall before a trial of labor. Transcervical Endoscopy Registry. J Reprod Med. 1994;39(6):464-6. [pmid: 7932401].
Petrikovsky B M. Rupture of the scarred uterus: prediction and diagnosis. Lancet. 1996;347(9004):838-9. [pmid: 8622376].
Petrou S, Henderson J, Glazener C. Economic aspects of caesarean section and alternative modes of delivery. Best Prac Res Clin Obstet Gynaecol. 2001;15(1):145-63.
Phelan J P. Delivery following cesarean section and perinatal mortality. Am J Perinatol. 1989;6(1):95-6. [pmid: 2910326].
Phelan J P. VBAC: Time to reconsider?. Obstet Gynecol Manag. 1996;11:62-68.
Phelan J P, Ahn M O, Diaz F, et al. Twice a cesarean, always a cesarean?. Obstet Gynecol. 1989;73(2):161-5. [pmid: 2911420].
Phelan J P, Ahn M O, Korst L, et al. Intrapartum fetal asphyxial brain injury with absent multiorgan system dysfunction. J Matern Fetal Med. 1998;7(1):19-22. [pmid: 9502665].
Phelan J P, Boucher M, Mueller E, et al. The nonlaboring transverse lie. A management dilemma. J Reprod Med. 1986;31(3):184-6. [pmid: 3701717].
Phelan J P, Clark S L, Diaz F, et al. Vaginal birth after cesarean. Am J Obstet Gynecol. 1987;157(6):1510-5. [pmid: 3425654].
Phelan J P, Eglinton G S, Horenstein J M, et al. Previous cesarean birth. Trial of labor in women with macrosomic infants. J Reprod Med. 1984;29(1):36-40. [pmid: 6708019].
Phelan J P, Korst L M, Settles D K. Uterine activity patterns in uterine rupture: a case-control study. Obstet Gynecol. 1998;92(3):394-7. [pmid: 9721777].
Phibbs C S, Mark D H, Luft H S, et al. Choice of hospital for delivery: a comparison of high-risk and low-risk women. Health Serv Res. 1993;28(2):201-22. [pmid: 8514500].
Phillips R N, Thornton J, Gleicher N. Physician bias in cesarean sections. JAMA. 1982;248(9):1082-4. [pmid: 7109201].
Pickhardt MG, Martin JN, Meydrech EF, et al. Vaginal birth after cesarean delivery: are there useful and valid predictors of success or failure? Am J Obstet Gynecol 1992;166(6 Pt 1):1811–5; discussion 1815–9.
Placek P J, Taffel S M. Recent patterns in cesarean delivery in the United States. Obstet Gynecol Clin North Am. 1988;15(4):607-27. [pmid: 3226670].
Placek P J, Taffel S M. Vaginal birth after cesarean (VBAC) in the 1980s. Am J Public Health. 1988;78(5):512-5. [pmid: 3354732].
Placek P J, Taffel S M, Moien M. 1986 C-sections rise; VBACs inch upward. Am J Public Health. 1988;78(5):562-3. [pmid: 3354740].
Plauche W C, Von Almen W, Muller R. Catastrophic uterine rupture. Obstet Gynecol. 1984;64(6):792-7. [pmid: 6390278].
Plaut M M, Schwartz M L, Lubarsky S L, et al. Uterine rupture associated with the use of misoprostol in the gravid patient with a previous cesarean section. Am J Obstet Gynecol. 1999;180(6 Pt I):1535-1542. [pmid: 10368501].
Poma P A. Effects of obstetrician characteristics on cesarean delivery rates. A community hospital experience. Am J Obstet Gynecol. 1999;180(6 Pt 1):1364-72. [pmid: 10368473].
Poma P A. Rupture of a cesarean-scarred uterus: a community hospital experience. J Natl Med Assoc. 2000;92(6):295-300. [pmid: 10918765].
Porreco R P. High cesarean section rate: a new perspective. Obstet Gynecol. 1985;65(3):307-11. [pmid: 4038791].
Porreco R P, Klaus M H, Shearer E, et al. Commentaries: the cesarean section rate is 25 percent and rising. Why? What can be done about it?. Birth. 1989;16(3):118-22. [pmid: 2789560].
Porreco R P, Meier P R. Trial of labor in patients with multiple previous cesarean sections. J Reprod Med. 1983;28(11):770-2. [pmid: 6655634].
Prabulos A M, Philipson E H. Umbilical cord prolapse. Is the time from diagnosis to delivery critical?. J Reprod Med. 1998;43(2):129-32. [pmid: 9513874].
Prasad R N, Ratnam S S. Uterine rupture after induction of labour for intrauterine death using the prostaglandin E2 analogue sulprostone. Aust N Z J Obstet Gynaecol. 1992;32(3):282-3. [pmid: 1445147].
Prendergast M S, Anderle L J. Experience with vaginal delivery after prior cesarean birth in a community hospital. J Am Osteopath Assoc. 1985;85(4):238-40. [pmid: 4044319].
Press F, Katz M, Leiberman J R, et al. Obstetric performance in Ethiopian immigrants compared with Israeli parturients. Isr J Med Sci. 1993;29(67):403-7. [pmid: 8349462].
Pridjian G. Labor after prior cesarean section. Clin Obstet Gynecol. 1992;35(3):445-456. [pmid: 1521374].
Pridjian G, Hibbard J U, Moawad A H. Cesarean: changing the trends. Obstet Gynecol. 1991;77(2):195-200. [pmid: 1988880].
Proctor S. What determines quality in maternity care? Comparing the perceptions of childbearing women and midwives. Birth. 1998;25(2):85-93. [pmid: 9668742].
Pruett K M, Kirshon B, Cotton D B. Unknown uterine scar and trial of labor. Am J Obstet Gynecol. 1988;159(4):807-10. [pmid: 3177527].
Pruett K M, Kirshon B, Cotton D B, et al. Is vaginal birth after two or more cesarean sections safe?. Obstet Gynecol. 1988;72(2):163-5. [pmid: 3393359].
Prysak M, Castronova F C. Elective induction versus spontaneous labor: a case-control analysis of safety and efficacy. Obstet Gynecol. 1998;92(1):47-52. [pmid: 9649091].
Purdie F R, Nieto J M, Summerson D J, et al. Rupture of the uterus with DIC. Ann Emerg Med. 1983;12(3):174-6. [pmid: 6829998].
Puza S, Roth N, Macones G A, et al. Does cesarean section decrease the incidence of major birth trauma?. J Perinatol. 1998;18(1):9-12. [pmid: 9527937].
Quilligan E J. Vaginal birth after Cesarean section: 270 degrees. Journal of Obstetrics & Gynaecology Research. 2001;27(4):169-73. [pmid: 11721726].
Quinlivan J A, Petersen R W, Nichols C N. Patient preference the leading indication for elective Caesarean section in public patients--results of a 2-year prospective audit in a teaching hospital. Aust N Z J Obstet Gynaecol. 1999;39(2):207-14. [pmid: 10755782].
Quirk JG, Jr., Fortney J, Collins HB, 2nd, et al. Outcomes of newborns with gastroschisis: the effects of mode of delivery, site of delivery, and interval from birth to surgery. Am J Obstet Gynecol 1996;174(4):1134–8; discussion 1138–40.
Rabinerson D, Rafael Z B, Dekel A. Vaginal birth after cesarean delivery?. Am J Obstet Gynecol. 2001;184(4):780. [pmid: 11262495].
Rachagan S P, Raman S, Balasundram G, et al. Rupture of the pregnant uterus--a 21-year review. Aust N Z J Obstet Gynaecol. 1991;31(1):37-40. [pmid: 1872771].
Rageth J C, Juzi C, Grossenbacher H. Delivery after previous cesarean: a risk evaluation. Swiss Working Group of Obstetric and Gynecologic Institutions. Obstet Gynecol. 1999;93(3):332-7. [pmid: 10074973].
Rajaram P, Oumachigui A. Trial of labor after cesarean section. Am J Obstet Gynecol. 1984;149(4):471-2. [pmid: 6731528].
Ramsey P S, Johnston B W, Welter V E, et al. Artifactual fetal electrocardiographic detection using internal monitoring following intrapartum fetal demise during VBAC trial. J Matern Fetal Med. 2000;9(6):360-1. [pmid: 11243295].
Ranzinger M, Fuentes A, Smyk L V. Spontaneous rupture of a low transverse cesarean scar. South Med J. 1994;87(10):1001-2. [pmid: 7939908].
Raskin K S, Dachauer J D, Doeden A L, et al. Uterine rupture after use of a prostaglandin E2 vaginal insert during vaginal birth after cesarean: A report of two cases. J Reprod Med Obstet Gynecol. 1999;44(6):571-574.
Ratten G J. Medicolegal matters involving a major obstetric and gynaecological teaching hospital. Aust N Z J Obstet Gynaecol. 1997;37(2):192-4. [pmid: 9222466].
Raube K, Merrell K, Gomberg MC. Maternal minimum-stay legislation: cost and policy implications. Abstr Book Assoc Health Serv Res;14:302.
Ravasia D J, Brain P H, Pollard J K. Incidence of uterine rupture among women with mullerian duct anomalies who attempt vaginal birth after cesarean delivery. Am J Obstet Gynecol. 1999;181(4):877-81. [pmid: 10521746].
Ravasia D J, Wood S L, Pollard J K. Uterine rupture during induced trial of labor among women with previous cesarean delivery. Am J Obstet Gynecol. 2000;183(5):1176-9. [pmid: 11084562].
Rayburn W, Gosen R, Ramadei C, et al. Outpatient cervical ripening with prostaglandin E2 gel in uncomplicated postdate pregnancies. Am J Obstet Gynecol. 1988;158(6 Pt 1):1417-23. [pmid: 3289398].
Rayburn W F. Prostaglandin E2 gel for cervical ripening and induction of labor: a critical analysis. Am J Obstet Gynecol. 1989;160(3):529-34. [pmid: 2648830].
Rayburn WF Clinical experience with a controlled-release, prostaglandin E2 intravaginal insert in the USA. Br J Obstet Gynaecol 1997 104 (Suppl 15):8–12; discussion 20–5.
Rayburn W F, Gittens L N, Lucas M J, et al. Weekly administration of prostaglandin E2 gel compared with expectant management in women with previous cesareans. Obstet Gynecol. 1999;94(2):250-254. [pmid: 10432137].
Raynor B D. The experience with vaginal birth after cesarean delivery in a small rural community practice. Am J Obstet Gynecol. 1993;168(1 Pt 1):60-2. [pmid: 8420350].
Read A W, Waddell V P, Prendiville W J, et al. Trends in caesarean section in Western Australia, 1980-1987. Med J Aust. 1990;153(6):318-23. [pmid: 2233449].
Read J A. The scheduling of repeat cesarean section operations: prospective management protocol experience. Am J Obstet Gynecol. 1985;151(5):557-63. [pmid: 3883779].
Reddy U M, DiVito M M, Armstrong J C, et al. Population adjustment of the definition of the vaginal birth after cesarean rate. Am J Obstet Gynecol. 2000;183(5):1166-9. [pmid: 11084560].
Redwine D B. Vaginal delivery in patients with a prior cesarean section. Obstet Gynecol. 1983;61(3):399-400. [pmid: 6823386].
Reid A J, Carroll J C, Ruderman J, et al. Differences in intrapartum obstetric care provided to women at low risk by family physicians and obstetricians. Can Med Assoc J. 1989;140(6):625-33. [pmid: 2920336].
Reid M C. Use of methodological standards in diagnostic testing research. JAMA. 1995;274:645-57. [pmid: 7637146].
Resick L K, Erlen J A. Vaginal birth after cesarean: issues and implications. J Am Acad Nurs Pract. 1990;2(3):100-6.
Resnick M B, Ariet M, Carter R L, et al. Prospective pricing system by diagnosis-related groups: comparison of federal diagnosis-related groups with high-risk obstetric care groups. Am J Obstet Gynecol. 1987;156(3):567-73. [pmid: 3103450].
Reynolds J L. Post-traumatic stress disorder after childbirth: the phenomenon of traumatic birth. Can Med Assoc J. 1997;156(6):831-5. [pmid: 9084390].
Rhodes M K. Early discharge of mothers and infants following vaginal childbirth at the United States Air Force Academy: A three-year study. Mil Med. 1994;159(3):227-30. [pmid: 8041470].
Rice D P, Kleinman J C. National health data for policy and planning. Health Policy Educ. 1980;1(2):129-41. [pmid: 10316949].
Rieger N, Schloithe A, Saccone G, et al. The effect of a normal vaginal delivery on anal function. Acta Obstet Gynecol Scand. 1997;76(8):769-72. [pmid: 9348256].
Riva H L, Teich J C. Vaginal delivery after cesarean section. Am J Obstet Gynecol. 1961;81(3):501-10. [pmid: 13741925].
Roberts L J, Beardsworth S A, Trew G. Labour following caesarean section: current practice in the United Kingdom. Br J Obstet Gynaecol. 1994;101(2):153-5. [pmid: 8305391].
Roberts M, Nordin A J. Posterior uterine rupture in a patient with a lower segment caesarean section scar complicating prostaglandin induction of labour. Br J Obstet Gynaecol. 1997;104(12):1421. [pmid: 9422029].
Robert R G, Bell H S, Wall E M, et al. Trial of labor or repeated cesarean section. The woman's choice. Arch Fam Med. 1997;6(2):120-5. [pmid: 9075445].
Rochat R W, Koonin L M, Atrash H K, et al. Maternal mortality in the United States: report from the Maternal Mortality Collaborative. Obstet Gynecol. 1988;72(1):91-7. [pmid: 3380512].
Rock S M. Malpractice premiums and primary cesarean section rates in New York and Illinois. Public Health Rep. 1988;103(5):459-63. [pmid: 3140270].
Rockner G, Jonasson A, Olund A. The effect of mediolateral episiotomy at delivery on pelvic floor muscle strength evaluated with vaginal cones. Acta Obstet Gynecol Scand. 1991;70(1):51-4. [pmid: 1858497].
Rodriguez M H, Masaki D I, Phelan J P, et al. Uterine rupture: are intrauterine pressure catheters useful in the diagnosis?. Am J Obstet Gynecol. 1989;161(3):666-9. [pmid: 2782349].
Rodriguez M H, Wang R, Clark S L, et al. Previous cesarean birth: management considerations in the patient with acute puerperal uterine inversion. Am J Obstet Gynecol. 1984;150(4):433-5. [pmid: 6486207].
Rogers R G, Gardner M O, Tool K J, et al. Active management of labor: a cost analysis of a randomized controlled trial. West J Med. 2000;172(4):240-3. [pmid: 10778374].
Roland E H, Poskitt K, Rodriguez E, et al. Perinatal hypoxic-ischemic thalamic injury: clinical features and neuroimaging. Ann Neurol. 1998;44(2):161-6. [pmid: 9708537].
Rooks J P, Weatherby N L, Ernst E K. The National Birth Center Study. Part III--Intrapartum and immediate postpartum and neonatal complications and transfers, postpartum and neonatal care, outcomes, and client satisfaction. J Nurse Midwifery. 1992;37(6):361-97. [pmid: 1460528].
Rooks J P, Weatherby N L, Ernst E K, et al. Outcomes of care in birth centers. The National Birth Center Study. N Engl J Med. 1989;321(26):1804-11. [pmid: 2687692].
Rose V. ACOG urges a cautious approach to vaginal birth after cesarean delivery. Am Fam Physician. 1999;59(2):474. [pmid: 9930134].
Rose V L. ACOG urges a cautious approach to vaginal birth after cesarean delivery. Am Fam Physician. 1999;60(4):1245-6. [pmid: 10507750].
Rosen M G, Bilenker R M, Thompson K. Assessment of developmental time periods and risks of brain damage in the fetus and neonate. J Reprod Med. 1986;31(5):297-303. [pmid: 3746779].
Rosen M G, Dickinson J C. Vaginal birth after cesarean: a meta-analysis of indicators for success. Obstet Gynecol. 1990;76(5 Pt 1):865-9. [pmid: 2145531].
Rosen M G, Dickinson J C, Westhoff C L. Vaginal birth after cesarean: a meta-analysis of morbidity and mortality. Obstet Gynecol. 1991;77(3):465-70. [pmid: 1825136].
Rothstein E P, Faccenda D R, Rubenstein S D. Neonatal morbidity of abdominal and vaginal deliveries after uncomplicated pregnancies. Arch Pediatr Adolesc Med. 1996;150(6):653-4. [pmid: 8646325].
Roumen F J, Janssen A A, Vrouenraets F P. The course of delivery after previous cesarean section. Eur J Obstet Gynecol Reprod Biol. 1990;34(12):15-20. [pmid: 2303149].
Rourke J T. Trends in small hospital obstetric services in Ontario. Can Fam Physician. 1998;44:2117-24. [pmid: 9805166].
Rouse D J, Owen J, Goldenberg R L, et al. The effectiveness and costs of elective cesarean delivery for fetal macrosomia diagnosed by ultrasound. JAMA. 1996;276(18):1480-6. [pmid: 8903259].
Rowbottom S J, Critchley L A, Gin T. Uterine rupture and epidural analgesia during trial of labour. Anaesthesia. 1997;52(5):486-8. [pmid: 9165971].
Rowlands S, Bell R, Donath S, et al. Misoprostol versus dinoprostone for cervical priming prior to induction of labour in term pregnancy: A randomised controlled trial. Aust N Z J Obstet Gynaecol. 2001;41(2):145-152. [pmid: 11453262].
Rozenberg P, Goffinet F, Philippe H J, et al. Thickness of the lower uterine segment: its influence in the management of patients with previous cesarean sections. Eur J Obstet Gynecol Reprod Biol. 1999;87(1):39-45. [pmid: 10579615].
Rozenberg P, Goffinet F, Philippe H J, et al. Ultrasonographic measurement of lower uterine segment to assess risk of defects of scarred uterus. Lancet. 1996;347(8997):281-4. [pmid: 8569360].
Rubin G L, Peterson H B, Rochat R W, et al. Maternal death after cesarean section in Georgia. Am J Obstet Gynecol. 1981;139(6):681-5. [pmid: 7211974].
Ruderman J, Carroll J C, Reid A J, et al. Are physicians changing the way they practise obstetrics?. Can Med Assoc J. 1993;148(3):409-15. [pmid: 8439912].
Rudick V, Niv D, Hetman-Peri M, et al. Epidural analgesia for planned vaginal delivery following previous cesarean section. Obstet Gynecol. 1984;64(5):621-3. [pmid: 6493654].
Rust O A, Place J C, Melendez D, et al. Lowering the cesarean rate at a small USAF hospital. Mil Med. 1993;158(1):22-6. [pmid: 8437736].
Ryding E L. Psychosocial indications for cesarean section. A retrospective study of 43 cases. Acta Obstet Gynecol Scand. 1991;70(1):47-9. [pmid: 1858495].
Saad AH. Trial of labor compared with an elective second cesarean section. N Engl J Med 1997;336(9):658–9; discussion 659.
Sachs B P. A program to lower cesarean-section rates [letter]. N Engl J Med. 1989;320:1694. [pmid: 2725623].
Sachs B P, Kobelin C, Castro M A, et al. The risks of lowering the cesarean-delivery rate. N Engl J Med. 1999;340(1):54-7. [pmid: 9878648].
Sack R A. The effect of utilization on health care costs. Am J Obstet Gynecol. 1980;137(2):270-5. [pmid: 7377246].
Saglamtas M, Vicdan K, Yalcin H, et al. Rupture of the uterus. Int J Gynaecol Obster. 1995;49(1):9-15.
Saisto T, Salmela-Aro K, Nurmi J E, et al. Psychosocial characteristics of women and their partners fearing vaginal childbirth. BJOG. 2001;108(5):492-8. [pmid: 11368135].
Saisto T, Salmela-Aro K, Nurmi J E, et al. Psychosocial predictors of disappointment with delivery and puerperal depression. A longitudinal study. Acta Obstet Gynecol Scand. 2001;80(1):39-45. [pmid: 11167187].
Saisto T, Salmela-Aro K, Nurmi J E, et al. A randomized controlled trial of intervention in fear of childbirth. Obstet Gynecol. 2001;98(5 Pt 1):820-6. [pmid: 11704175].
Saisto T, Ylikorkala O, Halmesmaki E. Factors associated with fear of delivery in second pregnancies. Obstet Gynecol. 1999;94(5 Pt 1):679-82. [pmid: 10546709].
Sakala C. Midwifery care and out-of-hospital birth settings: how do they reduce unnecessary cesarean section births?. Soc Sci Med. 1993;37(10):1233-50. [pmid: 8272902].
Sakala E P, Erhard L N, White J J. Elective cesarean section improves outcomes of neonates with gastroschisis. Am J Obstet Gynecol. 1993;169(4):1050-3. [pmid: 8238118].
Sakala E P, Kaye S, Murray R D, et al. Epidural analgesia. Effect on the likelihood of a successful trial of labor after cesarean section. J Reprod Med. 1990;35(9):886-90. [pmid: 2231564].
Sakala E P, Kaye S, Murray R D, et al. Oxytocin use after previous cesarean: Why a higher rate of failed labor trial?. Obstet Gynecol. 1990;75(3 I):356-359. [pmid: 2304707].
Saldana L R, Schulman H, Reuss L. Management of pregnancy after cesarean section. Am J Obstet Gynecol. 1979;135(5):555-61. [pmid: 500774].
Samueloff A, Mor-Yosef S, Seidman D S, et al. The 1984 national perinatal census: design, organization and uses for assessing obstetric services in Israel. Isr J Med Sci. 1989;25(11):629-34. [pmid: 2592178].
Sanchez-Ramos L. Dinoprostone vaginal insert for cervical ripening and labor induction: a meta-analysis. Obstet Gynecol. 2001;98(3):519-20. [pmid: 11547789].
Sanchez-Ramos L, Farah L A, Kaunitz A M, et al. Preinduction cervical ripening with commercially available prostaglandin E2 gel: a randomized, double-blind comparison with a hospital-compounded preparation. Am J Obstet Gynecol. 1995;173(4):1079-84. [pmid: 7485297].
Sanchez-Ramos L, Gaudier F L, Kaunitz A M. Cervical ripening and labor induction after previous cesarean delivery. Clin Obstet Gynecol. 2000;43(3):513-23. [pmid: 10949755].
Sanchez-Ramos L, Kaunitz A M. Misoprostol for cervical ripening and labor induction: a systematic review of the literature. Clin Obstet Gynecol. 2000;43(3):475-88. [pmid: 10949752].
Sanchez-Ramos L, Kaunitz A M. Uterine rupture associated with the use of prostaglandin E1 in patients with previous cesarean delivery. Am J Obstet Gynecol. 2000;182(4):990-1. [pmid: 10764490].
Sanchez-Ramos L, Kaunitz A M, Connor P M. Hygroscopic cervical dilators and prostaglandin E2 gel for preinduction cervical ripening. A randomized, prospective comparison. J Reprod Med. 1992;37(4):355-9. [pmid: 1593561].
Sanchez-Ramos L, Kaunitz A M, Delke I, et al. Cervical ripening and labor induction with a controlled-release dinoprostone vaginal insert: a meta-analysis. Obstet Gynecol. 1999;94(5 Pt 2):878-83. [pmid: 10546777].
Sanchez-Ramos L, Kaunitz AM, Peterson HB, et al. Reducing cesarean sections at a teaching hospital. Am J Obstet Gynecol 1990;163(3):1081–7; discussion 1087–8.
Sanchez-Ramos L, Kaunitz A M, Wears R L, et al. Misoprostol for cervical ripening and labor induction: a meta-analysis. Obstet Gynecol. 1997;89(4):633-42. [pmid: 9083326].
Sandmire H F. Whither ultrasonic prediction of fetal macrosomia?. Obstet Gynecol. 1993;82(5):860-2. [pmid: 8414339].
Sandmire H F. The labor-adjusted cesarean section: a more informative method than the cesarean section “rate” for assessing a practitioner's labor and delivery skills. Am J Obstet Gynecol. 1998;178(1 Pt 1):196-7. [pmid: 9465833].
Sandmire HF, DeMott RK. The Green Bay cesarean section study. III. Falling cesarean birth rates without a formal curtailment program. Am J Obstet Gynecol 1994;170(6):1790–9; discussion 1799–802.
Sandmire H F, DeMott R K. The Green Bay cesarean section study. IV. The physician factor as a determinant of cesarean birth rates for the large fetus. Am J Obstet Gynecol. 1996;174(5):1557-64. [pmid: 9065129].
Santerre R E. The effect of the ACOG guideline on vaginal births after cesarean. Med Care Res Rev. 1996;53(3):315-29. [pmid: 10159931].
Sarah R. Power, certainty, and the fear of death. Women Health. 1987;13(12):59-71. [pmid: 3332835].
Sarno A P Jr, Phelan J P, Ahn M O, et al. Vaginal birth after cesarean delivery. Trial of labor in women with breech presentation. J Reprod Med. 1989;34(10):831-3. [pmid: 2795566].
Satin A J, Hankins G D, Yeomans E R. A prospective study of two dosing regimens of oxytocin for the induction of labor in patients with unfavorable cervices. Am J Obstet Gynecol. 1991;165(4 Pt 1):980-4. [pmid: 1951567].
Satin A J, Leveno K J, Sherman M L, et al. High-dose oxytocin: 20- versus 40-minute dosage interval. Obstet Gynecol. 1994;83(2):234-8. [pmid: 8290186].
Sato K, Takahashi K, Shioda K. Uterine rupture during a trial of labor in a case with a unicornuate uterus and a previous cesarean section. Gynecol Obstet Invest. 1993;36(2):124-6. [pmid: 8225047].
Sato T, Konishi F, Minakami H, et al. Pelvic floor disturbance after childbirth: vaginal delivery damages the upper levels of sphincter innervation. Dis Colon Rectum. 2001;44(8):1155-61. [pmid: 11535856].
Savage W. Midwives' Journal. Changing attitudes to intervention. Nurs Times. 1986;82(22):63-4. [pmid: 3636887].
Schachter M, Kogan S, Blickstein I. External cephalic version after previous cesarean section--a clinical dilemma. Int J Gynaecol Obster. 1994;45(1):17-20.
Schauberger C W, Rooney B L, Beguin E A, et al. Evaluating the thirty minute interval in emergency cesarean sections. J Am Coll Surg. 1994;179(2):151-5. [pmid: 8044383].
Schimmel L M, Hogan P, Boehler B, et al. The Yolo County Midwifery Service. A descriptive study of 496 singleton birth outcomes, 1990. J Nurse Midwifery. 1992;37(6):398-403. [pmid: 1460529].
Schimmel L M, Schimmel L D, DeJoseph J. Toward lower cesarean birth rates and effective care: five years' outcomes of joint private obstetric practice. Birth. 1997;24(3):181-7. [pmid: 9355277].
Schiotz H A. Rupture of the uterus in labour. An unusual case followed with sonography. Arch Gynecol Obstet. 1991;249(1):43-5. [pmid: 1892424].
Schneider A. Delivery after caesarean section. Br Med J (Clin Res Ed). 1987;295(6597):554-5.
Schneider G. Palpation of the uterine scar after vaginal delivery. Can Med Assoc J. 1989;141(2):98. [pmid: 2743236].
Schneider J, Gallego D, Benito R. Trial of labour in patients with a prior caesarean section and an intervening vaginal delivery. Aust N Z J Obstet Gynaecol. 1987;27(3):178-9. [pmid: 3435355].
Schneider J, Gallego D, Benito R. Trial of labor after an earlier cesarean section. A conservative approach. J Reprod Med. 1988;33(5):453-6. [pmid: 3385700].
Schneider K T M, Luftner D, Rath W. Efficacy and safety of a 2-tier prostaglandin labor induction scheduIe. J Perinat Med. 1994;22(5):399-407. [pmid: 7791015].
Schnitker K A. Uterine rupture during trial of labor: risk management recommendations. J Healthc Risk Manag. 1999;19(4):12-6. [pmid: 10620900].
Schuitemaker N, van Roosmalen J, Dekker G, et al. Maternal mortality after cesarean section in The Netherlands. Acta Obstet Gynecol Scand. 1997;76(4):332-4. [pmid: 9174426].
Schussman L C, Lutz L J. Hazards and uses of prenatal diagnostic X-radiation. J Fam Pract. 1982;14(3):473-80. [pmid: 7061957].
Sciscione A C, Nguyen L, Manley J, et al. A randomized comparison of transcervical Foley catheter to intravaginal misoprostol for preinduction cervical ripening. Obstet Gynecol. 2001;97(4):603-7. [pmid: 11275035].
Sciscione A C, Nguyen L, Manley J S, et al. Uterine rupture during preinduction cervical ripening with misoprostol in a patient with a previous Caesarean delivery. Aust N Z J Obstet Gynaecol. 1998;38(1):96-7. [pmid: 9521403].
Scott J R. Mandatory trial of labor after cesarean delivery: an alternative viewpoint. Obstet Gynecol. 1991;77(6):811-4. [pmid: 2030847].
Scott J R. Avoiding labor problems during vaginal birth after cesarean delivery. Clin Obstet Gynecol. 1997;40(3):533-41. [pmid: 9328733].
Sebitloane M H, Moodley J. Emergency peripartum hysterectomy. East Afr Med J. 2001;78(2):70-4. [pmid: 11682949].
Secher N J, Lange A P, Nielsen F H, et al. Induction of labor with and without primary amniotomy. A randomized study of prostaglandin E2 tablets and intravenous oxytocin. Acta Obstet Gynecol Scand. 1981;60(3):237-41. [pmid: 7023173].
Seffah J D, Amaniampong K, Wilson J B. The use of the partograph in monitoring labor in a prior cesarean section. Int J Gynaecol Obster. 1994;45(3):281.
Segal S, Gemer O, Zohav E, et al. Evaluation of breast stimulation for induction of labor in women with a prior cesarean section and in grandmultiparas. Acta Obstet Gynecol Scand. 1995;74(1):40-1. [pmid: 7856430].
Seguin L, Therrien R, Champagne F, et al. The components of women's satisfaction with maternity care. Birth. 1989;16(3):109-13. [pmid: 2789558].
Seidman D S, Laor A, Gale R, et al. Long-term effects of vacuum and forceps deliveries. Lancet. 1991;337(8757):1583-5. [pmid: 1675719].
Seitchik J. Cesarean delivery in nulliparous women for failed oxytocin-augmented labor: route of delivery in subsequent pregnancy. Am J Obstet Gynecol. 1982;143(4):393-7. [pmid: 7091203].
Setubal A, Clode N, Bruno-Paiva J L, et al. Vesicouterine fistula after manual removal of placenta in a woman with previous cesarean section. Eur J Obstet Gynecol Reprod Biol. 1999;84(1):75-6. [pmid: 10413231].
Sewell JE. Cesarean Section--A Brief History. Washington, DC: Historian Librarian, The American College of Obstetricians and Gynecologists; 1993.
Shalev E, Battino S, Giladi Y, et al. External cephalic version at term--using tocolysis. Acta Obstet Gynecol Scand. 1993;72(6):455-7. [pmid: 8394624].
Shaver D C, Bada H S, Korones S B, et al. Early and late intraventricular hemorrhage: the role of obstetric factors. Obstet Gynecol. 1992;80(5):831-7. [pmid: 1407923].
Shearer E L. Cesarean section: medical benefits and costs. Soc Sci Med. 1993;37(10):1223-31. [pmid: 8272901].
Shearer M H. Commentary:Pondering the Study of Women's Psychosocial Outcomes. Birth. 1990;17(1):24.
Sherman S J, Greenspoon J S, Nelson J M, et al. Obstetric hemorrhage and blood utilization. J Reprod Med. 1993;38(12):929-34. [pmid: 8120849].
Shimonovitz S, Botosneano A, Hochner-Celnikier D. Successful first vaginal birth after cesarean section: a predictor of reduced risk for uterine rupture in subsequent deliveries. Isr Med Assoc J. 2000;2(7):526-8. [pmid: 10979328].
Shin Y K. Shoulder pain in a trial of labor after cesarean delivery. South Med J. 1989;82(10):1320. [pmid: 2799457].
Shiono P H, Fielden J G, McNellis D, et al. Recent trends in cesarean birth and trial of labor rates in the United States. JAMA. 1987;257(4):494-7. [pmid: 3795432].
Shiono P H, McNellis D, Rhoads G G. Reasons for the rising cesarean delivery rates: 1978-1984. Obstet Gynecol. 1987;69(5):696-700. [pmid: 3574796].
Shipp T D, Zelop C M, Repke J T, et al. Intrapartum uterine rupture and dehiscence in patients with prior lower uterine segment vertical and transverse incisions. Obstet Gynecol. 1999;94(5 Pt 1):735-40. [pmid: 10546720].
Shipp T D, Zelop C M, Repke J T, et al. Labor after previous cesarean: influence of prior indication and parity. Obstet Gynecol. 2000;95(6 Pt 1):913-6. [pmid: 10831991].
Shipp T D, Zelop C M, Repke J T, et al. Interdelivery Interval and risk of asymptomatic uterine rupture. Obstet Gynecol. 2001;97(2):175-7. [pmid: 11165577].
Shipp T D, Zelop C M, Repke J T, et al. Interdelivery Interval and Risk of Symptomatic Uterine Rupture. Obstet Gynecol. 2001;97(2):175-7. [pmid: 11165577].
Shorten A, Lewis D E, Shorten B. Trial of labour versus elective repeat caesarean section: a cost-effectiveness analysis. Aust Health Rev. 1998;21(1):8-28. [pmid: 10181675].
Shy K K, Frost F, Ullom J. Out-of-hospital delivery in Washington State, 1975 to 1977. Am J Obstet Gynecol. 1980;137(5):547-52. [pmid: 7386548].
Shy K K, LoGerfo J P, Karp L E. Evaluation of elective repeat cesarean section as a standard of care: an application of decision analysis. Am J Obstet Gynecol. 1981;139(2):123-9. [pmid: 7457528].
Siddiqui D, Stiller R J, Collins J, et al. Pregnancy outcome after successful external cephalic version. Am J Obstet Gynecol. 1999;181(5 Pt 1):1092-5. [pmid: 10561624].
Sieck C C. Vaginal birth after cesarean section: a comparison of rural and metropolitan rates in Oklahoma. J Oklahoma State Med Assoc. 1997;90(8):444-9.
Silberstein T, Wiznitzer A, Katz M, et al. Routine revision of uterine scar after cesarean section: has it ever been necessary?. Eur J Obstet Gynecol Reprod Biol. 1998;78(1):29-32. [pmid: 9605445].
Silver R K, Gibbs R S. Predictors of vaginal delivery in patients with a previous cesarean section, who require oxytocin. Am J Obstet Gynecol. 1987;156(1):57-60. [pmid: 3799769].
Silver R K, Minogue J. When does a statistical fact become an ethical imperative? [see comments]. Am J Obstet Gynecol. 1987;157(2):229-33. [pmid: 3618663].
Sims E J, Newman R B, Hulsey T C. Vaginal birth after cesarean: to induce or not to induce. Am J Obstet Gynecol. 2001;184(6):1122-4. [pmid: 11349175].
Sims P D, Cabral D, Daley W, et al. The incentive plan: an approach for modification of physician behavior. Am J Public Health. 1984;74(2):150-2. [pmid: 6691527].
Sinusas K. Deliveries by family physicians in Connecticut: results of a practice-based research network. Arch Fam Med. 2000;9(5):434-8. [pmid: 10810948].
Sjogren B. Reasons for anxiety about childbirth in 100 pregnant women. J Psychosomat Obstet Gynecol. 1997;18(4):266-72.
Skelton A G. The relationship among cost, quality, and competition: an analysis of obsterics services in Missouri hospitals. J Health Care Finance. 1997;24(1):30-44. [pmid: 9327357].
Skinner G. Action: promoting normal birth. Pract Midwife. 2002;5(3):4. [pmid: 11915425].
Skupski D W, Chervenak F A, McCullough L B, et al. Cesarean delivery for intrapartum fetal heart rate abnormalities: incorporating survey data into clinical judgment. Obstet Gynecol. 1996;88(1):60-4. [pmid: 8684764].
Slavin R. Best-evidence synthesis: An alternative to meta-analytic and traditional reviews. Educ Res. 1986;15:5-11.
Small R, Lumley J, Donohue L, et al. Randomised controlled trial of midwife led debriefing to reduce maternal depression after operative childbirth. BMJ. 2000;321(7268):1043-7. [pmcid: 27510]. [pmid: 11053173].
Smith D W, Murphy N J. Alaska's obstetrical delivery systems: a descriptive epidemiologic study. Alaska Med. 2000;42(3):78-84. [pmid: 11042940].
Smith G C S, Pell J P, Cameron A D, et al. Risk of perinatal death associated with labor after previous cesarean delivery in uncomplicated term pregnancis. JAMA. 2002;287(20):2684-90. [pmid: 12020304].
Smith L F. Development of a multidimensional labour satisfaction questionnaire: dimensions, validity, and internal reliability. Quality in Health Care. 2001;10(1):17-22. [pmid: 11239139].
Smith L P, DeLeon A, Funnell W R, et al. A research-oriented system for McGill obstetrical and noenatal data (Mond). Acta Obstet Gynecol Scand. 1982;109(Supplement):49-50.
Smith L P, Nagourney B A, McLean F H, et al. Hazards and benefits of elective induction of labor. Am J Obstet Gynecol. 1984;148(5):579-85. [pmid: 6538386].
Socol ML, Garcia PM, Peaceman AM, et al. Reducing cesarean births at a primarily private university hospital. Am J Obstet Gynecol 1993;168(6 Pt 1):1748–54; discussion 1754–8.
Socol M L, Peaceman A M. Vaginal birth after cesarean: an appraisal of fetal risk. Obstet Gynecol. 1999;93(5 Pt 1):674-9. [pmid: 10912965].
Soliman S R, Burrows R F. Cesarean section: analysis of the experience before and after the National Consensus Conference on Aspects of Cesarean Birth. Can Med Assoc J. 1993;148(8):1315-20. [pmid: 8462053].
Soltan M H, Khashoggi T, Adelusi B. Pregnancy following rupture of the pregnant uterus. Int J Gynaecol Obster. 1996;52(1):37-42.
Somell C. Induction of labor and cervical ripening with oral PGE2 in risk pregnancies. A placebo-controlled study. Acta Obstet Gynecol Scand 1987;66(7):633–7.
Somell C, Larsson B. Priming and induction of labor with oral PGE2 in patients with low Bishop score. Acta Obstet Gynecol Scand. 1983;62(4):315-20. [pmid: 6356770].
Sorensen S S, Brocks V, Lenstrup C. Induction of labor and cervical ripening by intracervical prostaglandin E2. Obstet Gynecol. 1985;65(1):110-4. [pmid: 3880877].
Sox H C Jr. Evaluation of diagnostic testing. Ann Rev Med. 1996;47:463-71. [pmid: 8712795].
Spaulding L B. Delivery through the maternal bladder during trial of labor. Obstet Gynecol. 1992;80(3 Pt 2):512-4. [pmid: 1495725].
Spellacy W N. Vaginal birth after cesarean: a reward/penalty system for national implementation. Obstet Gynecol. 1991;78(2):316-7. [pmid: 2067781].
Spellacy W N, Miller S J, Winegar A. Pregnancy after 40 years of age. Obstet Gynecol. 1986;68(4):452-4. [pmid: 3748489].
Spiegelhalter D, Thomas A, Best N. WinBUGS Version 1.2 User Manual. In. 1.2 ed. Cambridge: MRC Biostatistics Unit; 1999.
Spong F W. Deliveries, readmission rates and practice guidelines to reduce variations in obstetrical practice. Health Care Innov. 1997;7(1):18-23. [pmid: 10165127].
Springen K. The right to choose. Cesarean sections are on the rise again. Public-health officials want to limit them, but many patients and doctors are resisting. Newsweek. 2000;136(23):73-4. [pmid: 11126067].
Stafford R S. Alternative strategies for controlling rising cesarean section rates. JAMA. 1990;263(5):683-7. [pmid: 2296123].
Stafford R S. Cesarean section use and source of payment: an analysis of California hospital discharge abstracts. Am J Public Health. 1990;80(3):313-5. [pmid: 2305912].
Stafford R S. The impact of nonclinical factors on repeat cesarean section. JAMA. 1991;265(1):59-63. [pmid: 1984126].
Stafford R S, Sullivan S D, Gardner L B. Trends in cesarean section use in California, 1983 to 1990. Am J Obstet Gynecol. 1993;168(4):1297-302. [pmid: 8475978].
Stalnaker BL, Maher JE, Kleinman GE, et al. Characteristics of successful claims for payment by the Florida Neurologic Injury Compensation Association Fund. Am J Obstet Gynecol 1997;177(2):268–71; discussion 271–3.
Stanco L M, Schrimmer D B, Paul R H, et al. Emergency peripartum hysterectomy and associated risk factors. Am J Obstet Gynecol. 1993;168(3 Pt 1):879-83. [pmid: 8456896].
Stark C M, Smith R S, Lagrandeur R M, et al. Need for urgent delivery after third-trimester amniocentesis. Obstet Gynecol. 2000;95(1):48-50. [pmid: 10636501].
Steer P J, Carter M C, Choong K, et al. A multicentre prospective randomized controlled trial of induction of labour with an automatic closed-loop feedback controlled oxytocin infusion system. Br J Obstet Gynaecol. 1985;92(11):1127-33. [pmid: 3904817].
Steer P J, Kennedy J H, Calder A A, et al. Induction of labour: A comparison of a single prostaglandin E2 vaginal tablet with amniotomy and intravenous oxytocin. Br J Obstet Gynaecol. 1983;90(2):186-187. [pmid: 6572069].
Stein Z A. A woman's age: childbearing and child rearing. Am J Epidemiol. 1985;121(3):327-42. [pmid: 3893099].
Stone C, Halliday J, Lumley J, et al. Vaginal births after Caesarean (VBAC): a population study. Paediatr Perinat Epidemiol. 2000;14(4):340-8. [pmid: 11101021].
Stone J, Lockwood C J, Berkowitz G S, et al. Morbidity of failed labor in patients with prior cesarean section. Am J Obstet Gynecol. 1992;167(6):1513-7. [pmid: 1471656].
Stone J L, Lockwood C J, Berkowitz G, et al. Use of cervical prostaglandin E2 gel in patients with previous cesarean section. Am J Perinatol. 1994;11(4):309-12. [pmid: 7945629].
Stone S E, Brown M P, Westcott J P. Nurse-midwifery service in a rural setting. J Nurse Midwifery. 1996;41(5):377-82. [pmid: 8916678].
Stovall T G, Shaver D C, Solomon S K, et al. Trial of labor in previous cesarean section patients, excluding classical cesarean sections. Obstet Gynecol. 1987;70(5):713-717. [pmid: 3658277].
Strong T H Jr, Brown W L Jr, Brown W L, et al. Experience with early postcesarean hospital dismissal. Am J Obstet Gynecol. 1993;169(1):116-9. [pmid: 8333434].
Strong T H, Phelan J P, Ahn M O, et al. Vaginal birth after cesarean delivery in the twin gestation. Am J Obstet Gynecol. 1989;161(1):29-32. [pmid: 2750818].
Strong T H, Vega J S, O'shaughnessy M J, et al. Amnioinfusion among women attempting vaginal birth after cesarean delivery. Obstet Gynecol. 1992;79(5 Pt 1):673-4. [pmid: 1565348].
Stronge J. Factors Affecting Mode of Delivery In Labour Following A Single Previous Birth by Caesarean Section. J Obstet Gynaecol. 1996;16(5):353-7.
Stuart K A, Krakauer H, Schone E, et al. Labor epidurals improve outcomes for babies of mothers at high risk for unscheduled cesarean section. J Perinatol. 2001;21(3):178-85. [pmid: 11503105].
Studnicki J, Remmel R, Campbell R, et al. The impact of legislatively imposed practice guidelines on cesarean section rates: the Florida experience. Am J Med Qual. 1997;12(1):62-8. [pmid: 9116534].
Sturdee D W, Rushton D I. Caesarean and post-partum hysterectomy 1968-1983. Br J Obstet Gynaecol. 1986;93(3):270-4. [pmid: 3485995].
Suk Wai N, Wing Kee T, Lao T, et al. Cervical priming with oral misoprostol in pre-labor rupture of membranes at term. Obstet Gynecol. 1996;87(6):923-926. [pmid: 8649699].
Sultan A H, Kamm M A. Faecal incontinence after childbirth. Br J Obstet Gynaecol. 1997;104(9):979-82. [pmid: 9307520].
Sultan A H, Kamm M A, Hudson C N. Pudendal nerve damage during labour: prospective study before and after childbirth. Br J Obstet Gynaecol. 1994;101(1):22-8. [pmid: 8297863].
Sultan A H, Kamm M A, Hudson C N, et al. Anal-sphincter disruption during vaginal delivery. N Engl J Med. 1993;329(26):1905-11. [pmid: 8247054].
Sultan A H, Stanton S L. Preserving the pelvic floor and perineum during childbirth--elective caesarean section?. Br J Obstet Gynaecol. 1996;103(8):731-4. [pmid: 8760699].
Sun M S, Hseu S S, Chang D S, et al. Anesthetic management in parturients with uterine rupture preoperatively--report of two cases. Acta Anaesthesiol Sin. 1997;35(3):167-70. [pmid: 9407681].
Suner S, Jagminas L, Peipert J F, et al. Fatal spontaneous rupture of a gravid uterus: case report and literature review of uterine rupture. J Emerg Med. 1996;14(2):181-5. [pmid: 8740749].
Suonio S, Saarikoski S, Kaariainen J, et al. Intrapartum rupture of uterus diagnosed by ultrasound: a case report. Int J Gynaecol Obster. 1984;22(5):411-3.
Sutcliffe E. Factors predicting elective repeat cesarean delivery. Obstet Gynecol. 1994;84(4):641-2. [pmid: 8090411].
Suzuki S, Sawa R, Yoneyama Y, et al. Preoperative diagnosis of dehiscence of the lower uterine segment in patients with a single previous Caesarean section. Aust N Z J Obstet Gynaecol. 2000;40(4):402-4. [pmid: 11194423].
Swaim L S, Holste C S, Waller D K. Umbilical cord blood pH after prior cesarean delivery. Obstet Gynecol. 1998;92(3):390-3. [pmid: 9721776].
Sweeten KM, Graves WK, Athanassiou A. Spontaneous rupture of the unscarred uterus. Am J Obstet Gynecol 1995;172(6):1851–5; discussion 1855–6.
Sykes G S, Molloy P M, Johnson P, et al. Fetal distress and the condition of newborn infants. Br Med J (Clin Res Ed). 1983;287(6397):943-5.
Taffel S M. Cesarean section in America: dramatic trends, 1970 to 1987. Stat Bull Metrop Insur Co. 1989;70(4):2-11. [pmid: 2609247].
Taffel S M, Placek P J. Complications in cesarean and non-cesarean deliveries: United States, 1980. Am J Public Health. 1983;73(8):856-60. [pmid: 6869637].
Taffel S M, Placek P J, Liss T. Trends in the United States cesarean section rate and reasons for the 1980-85 rise. Am J Public Health. 1987;77(8):955-9. [pmid: 3605474].
Taffel S M, Placek P J, Moien M, et al. 1989 U.S. cesarean section rate steadies--VBAC rate rises to nearly one in five. Birth. 1991;18(2):73-7. [pmid: 1930436].
Tahilramaney M P, Boucher M, Eglinton G S, et al. Previous cesarean section and trial of labor. Factors related to uterine dehiscence. J Reprod Med. 1984;29(1):17-21. [pmid: 6708014].
Tamale-Sali E G, Iskandar M N. Is thre a risk of lower segment scar rupture in pregnancy after multiple caesarean sections?. J Obstet Gynaecol. 1992;12:19-21.
Tammelleo AD. “Asleep on duty” record impacts delay in delivery case. Case in point: St. Paul Medical Center v. Cecil (842 S.W.2d 808--TX [1992]). Regan Rep Nurs Law 1993;33(10):2.
Tammelleo AD. Failure to “fully communicate”: catastrophic results. Case in point: Baptist Medical Center v. Wilson 618 So. 2d 1335--AL (1993). Regan Rep Nurs Law 1993;34(3):2.
Tammelleo A D. Nurse opines on non-natural childbirth: freedom of speech. Regan Rep Nurs Law. 1993;34(2):1.
Tanik A, Ustun C, Cil E, et al. Sonographic evaluation of the wall thickness of the lower uterine segment in patients with previous cesarean section. J Clin Ultrasound. 1996;24(7):355-7. [pmid: 8873858].
Targett C. Caesarean section and trial of scar. Aust N Z J Obstet Gynaecol. 1988;28(4):249-62. [pmid: 3074775].
Tauer C A. Lives at stake. How to respond to a woman's refusal of cesarean surgery when she risks losing her child or her life. Health Prog. 1992;73(7):18-27.
Tauer C A. When pregnant patients refuse interventions. AWHONNS. 1993;4(4):596-605.
Taylor A V G, Sellers S, Ah-Moye M, et al. A prospective random allocation trial to compare vaginal prostaglandin E2 with intravenous oxytocin for labour induction in women previously delivered by caesarean section. J Obstet Gynaecol. 1993;13(5):333-336.
Taylor H A, Hayes S M, McGowan L M. The maternity care practice of Navy family practice residency graduates while on active duty. Mil Med. 1997;162(9):620-2. [pmid: 9290299].
Tetzschner T, Sorensen M, Jonsson L, et al. Delivery and pudendal nerve function. Acta Obstet Gynecol Scand. 1997;76(4):324-31. [pmid: 9174425].
Tews G, Ebner T, Yaman C, et al. Maternal ascites into the abdomen in a patient with status post adnexectomy and uterine rupture. Acta Obstet Gynecol Scand. 2001;80(5):474-5. [pmid: 11328229].
Thacker S B, Peterson H B, Stroup D F. Metaanalysis for the obstetrician-gynecologist. Am J Obstet Gynecol. 1996;174(5):1403-7. [pmid: 9065103].
Thacker SB, Stroup DF. Continuous electronic heart rate monitoring for fetal assessment during labor. Cochrane Database of Systematic Reviews 2000(2):CD000063.
Thiery M, Decoster J M, Parewijck W, et al. Endocervical prostaglandin E2 gel for preinduction cervical softening. Prostaglandins. 1984;27(3):429-39. [pmid: 6374766].
Thomas I L, Chenoweth J N, Tronc G N, et al. Preparation for induction of labour of the unfavourable cervix with Foley catheter compared with vaginal prostaglandin. Aust N Z J Obstet Gynaecol. 1986;26(1):30-5. [pmid: 3524549].
Thompson MS, Cohen AB. Should we measure personal valuations of perinatal outcomes? Mead Johnson Symp Perinat Dev Med 1982(20):47–52.
Thorp J M, Bowes W A. Vaginal birth after abdominal delivery. Am J Obstet Gynecol. 1990;163(3):1101-2. [pmid: 2403146].
Thubisi M, Ebrahim A, Moodley J, et al. Vaginal delivery after previous caesarean section: is X-ray pelvimetry necessary? [see comments]. Br J Obstet Gynaecol. 1993;100(5):421-4. [pmid: 8518240].
Thurnau G R, Scates D H, Morgan M A. The fetal-pelvic index: a method of identifying fetal-pelvic disproportion in women attempting vaginal birth after previous cesarean delivery. Am J Obstet Gynecol. 1991;165(2):353-8. [pmid: 1872337].
Tomlinson A J, Archer P A, Hobson S. Induction of labour: A comparison of two methods with particular concern to patient acceptability. J Obstet Gynaecol. 2001;21(3):239-241. [pmid: 12521850].
Torres A, Reich M R. The shift from home to institutional childbirth: a comparative study of the United Kingdom and The Netherlands. Int J Health Serv. 1989;19(3):405-14. [pmid: 2753577].
Traynor J D, Peaceman A M. Maternal hospital charges associated with trial of labor versus elective repeat cesarean section. Birth. 1998;25(2):81-4. [pmid: 9668741].
Trofatter K F, Bowers D, Gall S A, et al. Preinduction cervical ripening with prostaglandin E2 (Prepidil) gel. Am J Obstet Gynecol. 1985;153(3):268-71. [pmid: 3901764].
Troyer L R, Parisi V M. Obstetric parameters affecting success in a trial of labor: designation of a scoring system. Am J Obstet Gynecol. 1992;167(4 Pt 1):1099-104. [pmid: 1415398].
Tucker J M, Hauth J C, Hodgkins P, et al. Trial of labor after a one- or two-layer closure of a low transverse uterine incision. Am J Obstet Gynecol. 1993;168(2):545-6. [pmid: 8438925].
Tulman L, Fawcett J, Groblewski L, et al. Changes in functional status after childbirth. Nurs Res. 1990;39:70-75. [pmid: 2315069].
Tuncer R, Erkaya S, Sipahi T, et al. Emergency postpartum hysterectomy. Journal of Gynecologic Surgery. 1995;11(4):209-13. [pmid: 10172732].
Turan C, Kutlay B. Cesarean section rates and perinatal outcomes in resident and midwife attended low risk deliveries. Eur J Obstet Gynecol Reprod Biol. 1995;62(1):3-5. [pmid: 7493704].
Turnbull D, Holmes A, Shields N, et al. Randomised, controlled trial of efficacy of midwife-managed care. Lancet. 1996;348(9022):213-8. [pmid: 8684197].
Turnbull D A, Wilkinson C, Yaser A, et al. Women's role and satisfaction in the decision to have a caesarean section. Med J Aust. 1999;170(12):580-3. [pmid: 10416426].
Turner M J. Delivery after one previous cesarean section. Am J Obstet Gynecol. 1997;176(4):741-4. [pmid: 9125596].
Turner MJ, McNally O, Gardeil F. Trial of labor compared with an elective second cesarean section. N Engl J Med 1997;336(9):658; discussion 659.
Turnquest M A, James T, Marcell C, et al. Vaginal birth after cesarean section in a university setting. J Ky Med Assoc. 1994;92(6):216-21. [pmid: 8051495].
Tussing A D, Wojtowycz M A. The cesarean decision in New York State, 1986. Economic and noneconomic aspects. Med Care. 1992;30(6):529-40. [pmid: 1593918].
Tyson H. Outcomes of 1001 midwife-attended home births in Toronto, 1983-1988. Birth. 1991;18(1):14-9. [pmid: 2006954].
U.S. Department of Health and Human Services. Healthy People 2010. In: Office of Disease Prevention and Health Promotion; 2000.
Udo-Inyang A, Lee C, Evans E. Gravid uterine rupture following cesarean section and intervening vaginal delivery. Henry Ford Hosp Med J. 1986;34(3):215-7. [pmid: 3804778].
Udom N U, Betley C L. Effects of maternity-stay legislation on ‘drive-through deliveries’. Health Aff. 1998;17(5):208-15.
Udvarhelyi I S, et al. Colditz G A. Rai A. Cost-effectiveness and cost-benefit analyses in the medical literature. Are the methods being used correctly?. Ann Intern Med. 1992;116(3):238-44. [pmid: 1530808].
Uppington J. Epidural analgesia and previous caesarean section. Anaesthesia. 1983;38(4):336-41. [pmid: 6846763].
van Alten D. Eskes M. Treffers P E. Midwifery in The Netherlands. The Wormerveer study; selection, mode of delivery, perinatal mortality and infant morbidity. Br J Obstet Gynaecol. 1989;96(6):656-62. [pmid: 2803988].
van Amerongen D. Vaginal birth after cesarean section in an HMO. HMO Pract. 1989;3(3):104-7. [pmid: 10313505].
van Amerongen D. Vaginal birth after cesarean section. Experience in a community-based practice. J Reprod Med. 1989;34(8):531-4. [pmid: 2810241].
van der Walt W A, Cronje H S, Bam R H. Vaginal delivery after one cesarean section. Int J Gynaecol Obster. 1994;46(3):271-7.
Van Gelderen C J, et al. England M J. Naylor G A. Labour in patients with a caesarean section scar. The place of oxytocin augmentation. S Afr Med J. 1986;70(9):529-32. [pmid: 3775598].
Van Tuinen I, Wolfe SM. Unnecessary Cesarean Sections: halting a National Epidemic. Washington: Public Citizens Health Research Group; 1992.
Vandevusse L. Decision making in analyses of women's birth stories. Birth. 1999;26(1):43-50. [pmid: 10352055].
Varma A, Gunn J, Gardiner A, et al. Obstetric anal sphincter injury: prospective evaluation of incidence. Dis Colon Rectum. 1999;42(12):1537-43. [pmid: 10613471].
Varma T R, Norman J. A comparison of three dosages of prostaglandin E2 pessaries for ripening the unfavourable cervix prior to induction of labor. Acta Obstet Gynecol Scand. 1984;63(1):17-21. [pmid: 6372360].
Vause S, Macintosh M. Evidence based case report: use of prostaglandins to induce labour in women with a caesarean section scar. BMJ. 1999;318(7190):1056-8. [pmid: 10205107].
Vedat A, Hasan B, Ismail A. Rupture of the uterus in labor: a review of 150 cases. Isr J Med Sci. 1993;29(10):639-43. [pmid: 8244663].
Veridiano N P, Thorner N S, Ducey J. Vaginal delivery after cesarean section. Int J Gynaecol Obster. 1989;29(4):307-11.
Vestermark V, Hogdall C K, Birch M, et al. Influence of the mode of delivery on initiation of breast-feeding. Eur J Obstet Gynecol Reprod Biol. 1991;38(1):33-8. [pmid: 1988324].
Videla F L, Satin A J, Barth W H, et al. Trial of labor: a disciplined approach to labor management resulting in a high rate of vaginal delivery. Am J Perinatol. 1995;12(3):181-4. [pmid: 7612091].
Vimercati A, Greco P, Kardashi A, et al. Choice of cesarean section and perception of legal pressure. J Perinat Med. 2000;28(2):111-7. [pmid: 10875095].
Vintzileos A M, Gaffney S E, Salinger L M, et al. The relationship between fetal biophysical profile and cord pH in patients undergoing cesarean section before the onset of labor. Obstet Gynecol. 1987;70(2):196-201. [pmid: 3601282].
Vintzileos A M, Nochimson D J, Guzman E R, et al. Intrapartum electronic fetal heart rate monitoring versus intermittent auscultation: a meta-analysis. Obstet Gynecol. 1995;85(1):149-55. [pmid: 7800313].
Vinueza C A, Chauhan S P, Barker L, et al. Predicting the success of a trial of labor with a simple scoring system. J Reprod Med. 2000;45(4):332-6. [pmid: 10804491].
Vroman S, Sian A Y L, Thiery M, et al. Elective induction of labor conducted under lumbar epidural block I. Labor induction by anniotomy and intravenous oxytocin. Eur J Obstet Gynecol Reprod Biol. 1977;7:159-80. [pmid: 264052].
Wadhawan S, Narone J N. Outcome of labor following previous cesarean section. Int J Gynaecol Obster. 1983;21(1):7-10.
Wagner C L, Metts A K. Rates of successful vaginal delivery after cesarean for patients with private versus public insurance. J Perinatol. 1999;19(1):14-8. [pmid: 10685196].
Waldenstrom U. Experience of labor and birth in 1111 women. J Psychosom Res. 1999;47(5):471-82. [pmid: 10624845].
Wall E M. “But doctor, I'd prefer to have a cesarean section”: when public policy conflicts with patient preference. J Am Board Fam Pract. 1995;8(5):414-6. [pmid: 7484232].
Walmsley K, Hobbs L. Vaginal birth after lower segment caesarean section. Modern Midwife. 1994;4(4):20-1. [pmid: 7788367].
Walton D L, Ludlow D, Willis D C. Vaginal birth after cesarean section. Acceptance and outcome at a rural hospital. J Reprod Med. 1993;38(9):716-8. [pmid: 8254595].
Wang P H, Yuan C C, Chao H T, et al. Posterior uterine wall rupture during labour. Hum Reprod. 2000;15(5):1198-9. [pmid: 10783378].
Wang P H, Yuan C C, Chao H T, et al. Posterior uterine wall rupture during labour. Hum Reprod. 2000;15(5):1198-9. [pmid: 10783378].
Ware JE, Snow KK, Kosinski MA, et al. SF-36 health Survey Manual and Interpretation Guide. Boston: The Health Institute, New England Medical Center; 1997.
Watson K M. Induction of labour by prostaglandin tablets in a general practitioner maternity unit. Practitioner. 1981;225(1354):545-549. [pmid: 7279841].
Wax J R, Philput C, Mather J, et al. Twin vaginal birth after cesarean. Conn Med. 2000;64(4):205-8. [pmid: 10812766].
Wax J R, Sutula K, Lerer T, et al. Labor and delivery following successful external cephalic version. Am J Perinatol. 2000;17(4):183-6. [pmid: 11041439].
Wear A. Problems in labor. Nursing - Oxford. 1986;3(2):46-51.
Wearing M P. Comparison of vaginal delivery and cesarean section in breech presentation. Am J Obstet Gynecol. 1980;136(8):1083. [pmid: 7369264].
Webb J C, Gilson G, Gordon L. Late second stage rupture of the uterus and bladder with vaginal birth after cesarean section: a case report and review of the literature. J Matern Fetal Med. 2000;9(6):362-5. [pmid: 11243296].
Weber D O. At Saddleback Memorial, care maps detail birth process interventions, cutting C-section rate and raising VBACs. Strategies for Healthcare Excellence. 1997;10(5):7-9.
Weeks J W, Pitman T, Spinnato J A. Fetal macrosomia: does antenatal prediction affect delivery route and birth outcome?. Am J Obstet Gynecol. 1995;173(4):1215-9. [pmid: 7485323].
Weerasekera D S, Grant J M. Sweeping of the membranes is an effective method of induction of labour in prolonged pregnancy: A report of a randomised trial [2]. Br J Obstet Gynaecol. 1993;100(2):193-194. [pmid: 8476819].
Weinstein D, Benshushan A, Ezra Y, et al. Vaginal birth after cesarean section: current opinion. Int J Gynaecol Obster. 1996;53(1):1-10.
Weinstein D, Benshushan A, Tanos V, et al. Predictive score for vaginal birth after cesarean section. Am J Obstet Gynecol. 1996;174(1 Pt 1):192-8. [pmid: 8572005].
Weiss J, Nannini A, Fogerty S, et al. Use of hospital discharge data to monitor uterine rupture--Massachusetts, 1990-1997; US Department of Health & Human Services. MMWR Morb Mortal Wkly Rep. 2000;49(12):245-8. [pmid: 10774544].
Weiss RR. Case 9-1998: uterine rupture. N Engl J Med 1998;339(4):268; discussion 269.
Wen S W, Liu S, Marcoux S, et al. Trends and variations in length of hospital stay for childbirth in Canada. Can Med Assoc J. 1998;158(7):875-80. [pmid: 9559012].
Wennberg J E, Barnes B A, Zubkoff M. Professional uncertainty and the problem of supplier-induced demand. Soc Sci Med. 1982;16(7):811-24. [pmid: 7100999].
Westgate J, Williams J A. Evaluation of a controlled release vaginal prostaglandin E2 pessary with a retrieval system for the induction of labour. J Obstet Gynaecol. 1994;14(3):146-150.
Westgren M, Ingemarsson E, Ingemarsson I, et al. Intrapartum electronic fetal monitoring in low-risk pregnancies. Obstet Gynecol. 1980;56(3):301-4. [pmid: 7422168].
Whiteside D C, Mahan C S, Cook J C. Factors associated with successful vaginal delivery after cesarean section. J Reprod Med. 1983;28(11):785-8. [pmid: 6655637].
Whitford H M, Hillan E M. Women's perceptions of birth plans. Midwifery. 1998;14(4):248-53. [pmid: 10076320].
Whitsel A I, Capeless E C, Abel D E, et al. Adjustment for case mix in comparisons of cesarean delivery rates: university versus community hospitals in Vermont. Am J Obstet Gynecol. 2000;183(5):1170-5. [pmid: 11084561].
Wijma K, Soderquist J, Wijma B. Posttraumatic stress disorder after childbirth: a cross sectional study. J Anxiety Disord. 1997;11(6):587-97. [pmid: 9455721].
Wilf R T, Franklin J B. Six years' experience with vaginal births after cesareans at Booth Maternity Center in Philadelphia. Birth. 1984;11(1):5-9. [pmid: 6561037].
Wilkinson C, McIlwaine G, Patel N. Vaginal birth after caesarean section. Scottish Caesarean Section Audit Group. Lancet 1995;345(8951):725.
Williams J K, Lewis M L, Cohen G R, et al. The sequential use of estradiol and prostaglandin E2 topical gels for cervical ripening in high-risk term pregnancies requiring induction of labor. Am J Obstet Gynecol. 1988;158(1):55-8. [pmid: 3276201].
Williams J K, Wilkerson W G, O'Brien W F, et al. Use of prostaglandin E2 topical cervical gel in high-risk patients: a critical analysis. Obstet Gynecol. 1985;66(6):769-73. [pmid: 3906461].
Williams L S. Relations between Alberta midwives, MDs appear to be thawing despite high-profile trial. Can Med Assoc J. 1991;145(5):497-50. [pmid: 1878832].
Williams M A, Luthy D A, Zingheim R W, et al. Preinduction prostaglandin E2 gel prior to induction of labor in women with a previous cesarean section. Gynecol Obstet Invest. 1995;40(2):89-93. [pmid: 8575698].
Williams M C, Knuppel R A, O'Brien W F, et al. A randomized comparison of assisted vaginal delivery by obstetric forceps and polyethylene vacuum cup. Obstet Gynecol. 1991;78(5 Pt 1):789-94. [pmid: 1923198].
Williams R L, Chen P M. Identifying the sources of the recent decline in perinatal mortality rates in California. N Engl J Med. 1982;306(4):207-14. [pmid: 7054683].
Williams R L, Chen P M. Controlling the rise in cesarean section rates by the dissemination of information from vital records. Am J Public Health. 1983;73(8):863-7. [pmid: 6869639].
Wilner S, Schoenbaum S C, Monson R R, et al. A comparison of the quality of maternity care between a health-maintenance organization and fee-for-service practices. N Engl J Med. 1981;304(13):784-7. [pmid: 7464889].
Wilson P D, Herbison R M, Herbison G P. Obstetric practice and the prevalence of urinary incontinence three months after delivery. Br J Obstet Gynaecol. 1996;103(2):154-61. [pmid: 8616133].
Wing D A, Lovett K, Paul R H. Disruption of prior uterine incision following misoprostol for labor induction in women with previous cesarean delivery. Obstet Gynecol. 1998;91(5 Pt 2):828-30. [pmid: 9572178].
Wing D A, Paul R H. Induction of labor with misoprostol for premature rupture of membranes beyond thirty-six weeks' gestation. Am J Obstet Gynecol. 1998;179(1):94-9. [pmid: 9704771].
Wing D A, Paul R H. Vaginal birth after cesarean section: selection and management. Clin Obstet Gynecol. 1999;42(4):836-48. [pmid: 10572697].
Winslow R. Patient data may reshape health care. Efforst to cut costs, pinpoint treatment gain. Wall Street Journal 1989(April 17).
Wiqvist I, Norstrom A, Wiqvist N. Induction of labor by intra-cervical PGE2 in viscous gel. Mechanism of action and clinical treatment routines. Acta Obstet Gynecol Scand. 1986;65(5):485-92. [pmid: 3535364].
Witlin A G, Mattar F, Sibai B M. Postpartum stroke: a twenty-year experience. Am J Obstet Gynecol. 2000;183(1):83-8. [pmid: 10920313].
Witter F R, Rocco L E, Johnson T R. A randomized trial of prostaglandin E2 in a controlled-release vaginal pessary for cervical ripening at term. Am J Obstet Gynecol. 1992;166(3):830-4. [pmid: 1550148].
Wittich A C. Uterine scar separation in patients undergoing trial of labor (TOL) in one army hospital. Mil Med. 2000;165(10):730-2. [pmid: 11050867].
Woo G M, Twickler D M, Stettler R W, et al. The pelvis after cesarean section and vaginal delivery: normal MR findings. AJR Am J Roentgenol. 1993;161(6):1249-52. [pmid: 8249736].
Woods J R, Saywell R M Jr, Benson J T. Comparative costs of a cooperative care program versus inpatient hospital care for obstetric patients. Med Care. 1988;26(6):596-606. [pmid: 3379990].
Woolbright L A. Why is the cesarean delivery rate so high in Alabama? An examination of risk factors, 1991-1993. Birth. 1996;23(1):20-5. [pmid: 8703253].
Woolery W. Informed consent issues throughout the birthing process. J Leg Med. 2000;21(2):241-55. [pmid: 10911697].
Wright C H, Gardin T H, Wright C L. Obstetric care in a health maintenance organization and a private fee-for-service practice: a comparative analysis. Am J Obstet Gynecol. 1984;149(8):848-56. [pmid: 6465249].
Wright J B, Wright A L, Simpson N A, et al. A survey of trainee obstetricians preferences for childbirth. Eur J Obstet Gynecol Reprod Biol. 2001;97(1):23-5. [pmid: 11435003].
Wright M. The value of X-ray pelvimetry in previous caesarean section pregnancies. S Afr Med J. 1985;68(6):409-11. [pmid: 4035514].
Wynn P. Hospitals, health plans and employers unite to reduce cesarean deliveries. Manag Care. 1996;5(12):57-8. [pmid: 10164024].
Xenakis E-J, Langer O, Piper J M, et al. Low-dose versus high-dose oxytocin augmentation of labor - A randomized trial. Am J Obstet Gynecol. 1995;173(6):1874-1878. [pmid: 8610779].
Yamani T Y, Rouzi A A. Induction of labor with vaginal prostaglandin-E2 in grand multiparous women. International Journal of Gynecology & Obstetrics. 1998;62(3):255-259.
Yamani T Y, Rouzi A A. Induction of labor with vaginal prostaglandin-E2 in grand multiparous women with one previous cesarean section. Int J Gynaecol Obster. 1999;65(3):251-3.
Yan J S, Chang Y K, Yin C S. Elective cesarean section for macrosomia?. Chin Med J. 1994;53(3):141-5.
Yang J Y, Fang L J, Tsou Yau K I. Labor pain before elective cesarean section reduces neonatal respiratory distress. Chung-Hua Min Kuo Hsiao Erh Ko i Hsueh Hui Tsa Chih. 1997;38(1):38-43. [pmid: 9066188].
Yanover M J, Jones D, Miller M D. Perinatal care of low-risk mothers and infants. Early discharge with home care. N Engl J Med. 1976;294(13):702-5. [pmid: 1250282].
Yap O W, Kim E S, Laros R K Jr. Maternal and neonatal outcomes after uterine rupture in labor. Am J Obstet Gynecol. 2001;184(7):1576-81. [pmid: 11408884].
Yasumizu T, Nozawa A, Kinoshita T, et al. Trial of Labor in the Patient with a Prior Cesarean Section. Yamanashi Med J. 1993;8(3):113-119.
Yasumizu T, Nozawa A, Kinoshita T, et al. Trial of vaginal birth following cesarean section for arrest disorders of labor: analysis of patients with well-documented medical records. Asia Oceania J Obstet Gynaecol. 1994;20(4):407-13. [pmid: 7832674].
Yeast J D, Jones A, Poskin M. Induction of labor and the relationship to cesarean delivery: A review of 7001 consecutive inductions. [see comments.]. Am J Obstet Gynecol. 1999;180(3 Pt 1):628-33. [pmid: 10076139].
Yeh S, Huang X, Phelan J P. Postterm pregnancy after previous cesarean section. J Reprod Med. 1984;29(1):41-4. [pmid: 6708020].
Yetman T J, Nolan T E. Vaginal birth after cesarean section: a reappraisal of risk. Am J Obstet Gynecol. 1989;161(5):1119-23. [pmid: 2486193].
Yip S K, Fung H Y, Wong W S, et al. Vesico-uterine fistula--a rare complication of vacuum extraction in a patient with previous caesarean section. Br J Urol. 1997;80(3):502-3. [pmid: 9313682].
Yla-Outinen A, Heinonen P K, Tuimala R. Predisposing and risk factors of umbilical cord prolapse. Acta Obstet Gynecol Scand. 1985;64(7):567-70. [pmid: 4082931].
Young D. A new push to reduce cesareans in the United States. Birth. 1997;24(1):1-3. [pmid: 9271960].
Young D. Confrontation in Kansas City: elective cesareans and maternal choice. Birth. 2000;27(3):153-5. [pmid: 11251495].
Yudkin P. Identifying the sources of the recent decline in perinatal mortality rates in California: two commentaries and a reply. Birth. 1983;10(1):39-46. [pmid: 6551175].
Zahniser S C, Kendrick J S, Franks A L, et al. Trends in obstetric operative procedures, 1980 to 1987. Am J Public Health. 1992;82(10):1340-4. [pmid: 1415856].
Zakut H, Blankstein J, Kramer J, et al. The outcome of pregnancy following abdominal surgery during pregnancy. Clin Exp Obstet Gynecol. 1981;8(2):45-9. [pmid: 7337947].
Zelop C M, Shipp T D, Cohen A, et al. Trial of labor after 40 weeks' gestation in women with prior cesarean. Obstet Gynecol. 2001;97(3):391-3. [pmid: 11239643].
Zelop C M, Shipp T D, Repke J T, et al. Uterine rupture during induced or augmented labor in gravid women with one prior cesarean delivery. Am J Obstet Gynecol. 1999;181(4):882-6. [pmid: 10521747].
Zelop C M, Shipp T D, Repke J T, et al. Effect of previous vaginal delivery on the risk of uterine rupture during a subsequent trial of labor. Am J Obstet Gynecol. 2000;183(5):1184-6. [pmid: 11084564].
Zelop C M, Shipp T D, Repke J T, et al. Outcomes of trial of labor following previous cesarean delivery among women with fetuses weighing >4000 g. Am J Obstet Gynecol. 2001;185(4):903-5. [pmid: 11641675].
Zhang J, Klebanoff M A, DerSimonian R. Epidural analgesia in association with duration of labor and mode of delivery: a quantitative review. Am J Obstet Gynecol. 1999;180(4):970-7. [pmid: 10203666].
Zhou S W, Chi I C. Immediate postpartum IUD insertions in a Chinese hospital--a two year follow-up. Int J Gynaecol Obster. 1991;35(2):157-64.
Ziadeh S M, El-Jallad M F, Sunn'a E I. Obstetric uterine rupture: a four-year clinical analysis. Gynecol Obstet Invest. 1999;48(3):176-8. [pmid: 10545741].
Zinberg S. Vaginal delivery after previous cesarean delivery: A continuing controversy. Clin Obstet Gynecol. 2001;44(3):561-570. [pmid: 11685880].
Zisow D L. Uterine rupture as a cause of shoulder dystocia. Obstet Gynecol. 1996;87(5 Pt 2):818-9. [pmid: 8677099].
Zorlu C G, Danisman N, Caglar T, et al. Vaginal birth following unmonitored labor in patients with prior cesarean section. Gynecol Obstet Invest. 1996;42(4):222-6. [pmid: 8979091].
Zorlu C G, Turan C, Isik A Z, et al. Emergency hysterectomy in modern obstetric practice. Changing clinical perspective in time. Acta Obstet Gynecol Scand. 1998;77(2):186-90. [pmid: 9512325].
Zweig S, Kruse J, LeFevre M. Patient satisfaction with obstretric care. J Fam Pract. 1986;23:131-136. [pmid: 3734717].