# References

1 Cragin E B. Conservatism in obstetrics. N Y Med J. 1916;104(1):1-3.
2 Martin J A, Hamilton B E, Ventura S J, et al. Births: final data for 2000. Natl Vital Stat Rep. 2002;50(5):1-101.
3 U.S. Department of Health and Human Services. Healthy People 2010. In: Office of Disease Prevention and Health Promotion; 2000.
4 Lydon-Rochelle M, Holt V L, Easterling T R, et al. Risk of uterine rupture during labor among women with a prior cesarean delivery. N Engl J Med. 2001;345(1):3-8. [pmid: 11439945].
5 McMahon M J, Luther E R, Bowes W A, et al. Comparison of a trial of labor with an elective second cesarean section. N Engl J Med. 1996;335(10):689-95. [pmid: 8703167].
6 Smith G C S, Pell J P, Cameron A D, et al. Risk of perinatal death associated with labor after previous cesarean delivery in uncomplicated term pregnancies. JAMA. 2002;287(20):2684-90. [pmid: 12020304].
7 Menacker F, Curtin S C. Trends in Cesarean Birth and Vaginal Birth After Previous Cesarean, 1991-99. Natl Vital Stat Rep. 2001;49(13):1-16.
8 Clarke S C, Taffel S M. State variation in rates of cesarean and VBAC delivery: 1989 and 1993. Stat Bull Metrop Insur Co. 1996;77(1):28-36. [pmid: 8744893].
9 Jacoby I, Meyer G S, Haffner W, et al. Modeling the future workforce of obstetrics and gynecology. Obstet Gynecol. 1998;92(3):450-6. [pmid: 9721788].
10 1998 American College of Obstetricians & Gynocologists. Socioeconomic Survey of Fellows (unpublished.). ACOG NET 1997;www.acog.com.
11 American Academy of Family Practitioners. FACTS about Family Practice. Table 67. (www.aafp.org). 2001.
12 Hannah M E, Hannah W J, Hodnett E D, et al. Outcomes at 3 months after planned cesarean vs planned vaginal delivery for breech presentation at term: the international randomized Term Breech Trial. JAMA. 2002;287(14):1822-31. [pmid: 11939868].
13 O'Boyle A L, Woodman P J, O'Boyle J D, et al. Pelvic organ support in nulliparous pregnant and nonpregnant women: a case control study. Am J Obstet Gynecol. 2002;187(1):99-102. [pmid: 12114895].
14 Morrison J J, Rennie J M, Milton P J. Neonatal respiratory morbidity and mode of delivery at term: influence of timing of elective caesarean section. Br J Obstet Gynaecol. 1995;102(2):101-6. [pmid: 7756199].
15 Plaut M M, Schwartz M L, Lubarsky S L, et al. Uterine rupture associated with the use of misoprostol in the gravid patient with a previous cesarean section. Am J Obstet Gynecol. 1999;180(6 Pt I):1535-1542. [pmid: 10368501].
16 Udvarhelyi I S, Colditz G A, Rai A, et al. Cost-effectiveness and cost-benefit analyses in the medical literature. Are the methods being used correctly? [see comments.]. Annals of Internal Medicine. 1992;116(3):238-44. [pmid: 1530808].
17 Slavin, R. Best-evidence synthesis: An alternative to meta-analytic and traditional reviews. Educational Researcher 1986;155–11.
18 Reid, MC. Use of methodological standards in diagnostic testing research. JAMA 1995;274645–57.
19 Sox, HC, Jr. Evaluation of diagnostic testing. Ann Rev Med 1996;47463–71.
20 Flamm B L, Goings J R, Liu Y, et al. Elective repeat cesarean delivery versus trial of labor: a Prospective multicenter study. Obstet Gynecol. 1994;83(6):927-32. [pmid: 8190433].
21 Flamm B L, Lim O W, Jones C, et al. Vaginal birth after cesarean section: Results of a multicenter study. Am J Obstet Gynecol. 1988;158(5):1079-84. [pmid: 3369487].
22 Flamm B L, Newman L A, Thomas S J, et al. Vaginal birth after cesarean delivery: Results of a 5-year multicenter collaborative study. Obstet Gynecol. 1990;76(5 Pt 1):750-4. [pmid: 2216218].
23 Phelan J P, Clark S L, Diaz F, et al. Vaginal birth after cesarean. Am J Obstet Gynecol. 1987;157(6):1510-5. [pmid: 3425654].
24 Martin J N, Harris B A, Huddleston J F, et al. Vaginal delivery following previous cesarean birth. Am J Obstet Gynecol. 1983;146(3):255-63. [pmid: 6859134].
25 Cowan R K, Kinch R A, Ellis B, et al. Trial of labor following cesarean delivery. Obstet Gynecol. 1994;83(6):933-6. [pmid: 8190434].
26 Duff P, Southmayd K, Read J A. Outcome of trial of labor in patients with a single previous low transverse cesarean section for dystocia. Obstet Gynecol. 1988;71(3 Pt 1):380-4. [pmid: 3347423].
27 Stovall T G, Shaver D C, Solomon S K, et al. Trial of labor in previous cesarean section patients, excluding classical cesarean sections. Obstet Gynecol. 1987;70(5):713-717. [pmid: 3658277].
28 Flamm B L, Goings J R, Fuelberth N J, et al. Oxytocin during labor after previous cesarean section: Results of a multicenter study. Obstet Gynecol. 1987;70(5):709-12. [pmid: 3309751].
29 Raynor B D. The experience with vaginal birth after cesarean delivery in a small rural community practice. Am J Obstet Gynecol. 1993;168(1 Pt 1):60-2. [pmid: 8420350].
30 Paul R H, Phelan J P, Yeh S Y. Trial of labor in the patient with a prior cesarean birth. Am J Obstet Gynecol. 1985;151(3):297-304. [pmid: 3970097].
31 Lao T T, Leung B F H. Labor induction for planned vaginal delivery in patients with previous cesarean section. Acta Obstet Gynecol Scand. 1987;66(5):413-416. [pmid: 3425241].
32 Rayburn W F, Gittens L N, Lucas M J, et al. Weekly administration of prostaglandin E2 gel compared with expectant management in women with previous cesareans. Obstet Gynecol. 1999;94(2):250-254. [pmid: 10432137].
33 Flamm B L, Anton D, Goings J R, et al. Prostaglandin E2 for cervical ripening: a Multicenter study of patients with prior cesarean delivery. Am J Perinatol. 1997;14(3):157-60. [pmid: 9259919].
34 Blanco J D, Collins M, Willis D, et al. Prostaglandin E2 gel induction of patients with a prior low transverse cesarean section. Am J Perinatol. 1992;9(2):80-3. [pmid: 1590872].
35 Lelaidier C, Baton C, Benifla J L, et al. Mifepristone for labour induction after previous caesarean section. Br J Obstet Gynaecol. 1994;101(6):501-3. [pmid: 8018638].
36 Flamm B L, Geiger A M. Vaginal birth after cesarean delivery: an Admission scoring system. Obstet Gynecol. 1997;90(6):907-10. [pmid: 9397100].
37 Jakobi P, Weissman A, Peretz B A, et al. Evaluation of prognostic factors for vaginal delivery after cesarean section. J Reprod Med. 1993;38(9):729-33. [pmid: 8254598].
38 Macones G A, Hausman N, Edelstein R, et al. Predicting outcomes of trials of labor in women attempting vaginal birth after cesarean delivery: a comparison of multivariate methods with neural networks. Am J Obstet Gynecol. 2001;184(3):409-13. [pmid: 11228495].
39 Pickhardt, MG, Martin, JN, Meydrech, EF, et al. Vaginal birth after cesarean delivery: are there useful and valid predictors of success or failure? Am J Obstet Gynecol 1992;166(6 Pt 1):1811–5; discussion 1815–9.
40 Troyer L R, Parisi V M. Obstetric parameters affecting success in a trial of labor: designation of a scoring system. Am J Obstet Gynecol. 1992;167(4 Pt 1):1099-104. [pmid: 1415398].
41 Vinueza C A, Chauhan S P, Barker L, et al. Predicting the success of a trial of labor with a simple scoring system. J Reprod Med. 2000;45(4):332-6. [pmid: 10804491].
42 Weinstein D, Benshushan A, Tanos V, et al. Predictive score for vaginal birth after cesarean section. Am J Obstet Gynecol. 1996;174(1 Pt 1):192-8. [pmid: 8572005].
43 Abitbol M M, Taylor U B, Castillo I, et al. The cephalopelvic disproportion index. Combined fetal sonography and x-ray pelvimetry for early detection of cephalopelvic disproportion. J Reprod Med. 1991;36(5):369-73. [pmid: 2061886].
44 Lao T T, Chin R K, Leung B F. Is X-ray pelvimetry useful in a trial of labour after caesarean section?. Eur J Obstet Gynecol Reprod Biol. 1987;24(4):277-83. [pmid: 3582716].
45 Mahmood T. The role of radiological pelvimetry in the management of patients who have had a previous caesarean section. J Obstet Gynaecol. 1987;8(8):24-28.
46 Morgan M A, Thurnau G R. Efficacy of the fetal-pelvic index for delivery of neonates weighing 4000 grams or greater: a preliminary report. Am J Obstet Gynecol. 1988;158(5):1133-7. [pmid: 3285685].
47 Thubisi M, Ebrahim A, Moodley J, et al. Vaginal delivery after previous caesarean section: is X-ray pelvimetry necessary?. Br J Obstet Gynaecol. 1993;100(5):421-4. [pmid: 8518240].
48 Thurnau G R, Scates D H, Morgan M A. The fetal-pelvic index: a method of identifying fetal-pelvic disproportion in women attempting vaginal birth after previous cesarean delivery. Am J Obstet Gynecol. 1991;165(2):353-8. [pmid: 1872337].
49 Wright M. The value of X-ray pelvimetry in previous caesarean section pregnancies. S Afr Med J. 1985;68(6):409-11. [pmid: 4035514].
50 Meehan F P, Burke G. Trial of labour following prior section; a 5 year prospective study (1982-1987). Eur J Obstet Gynecol Reprod Biol. 1989;31(2):109-17. [pmid: 2759320].
51 Segal S, Gemer O, Zohav E, et al. Evaluation of breast stimulation for induction of labor in women with a prior cesarean section and in grandmultiparas. Acta Obstet Gynecol Scand. 1995;74(1):40-1. [pmid: 7856430].
52 Blanchette, H, Blanchette, M, McCabe, J, et al. Is vaginal birth after cesarean safe? Experience at a community hospital. Am J Obstet Gynecol 2001;184(7):1478–84; discussion 1484–7.
53 Connolly G A, Razak A R A, Conroy R, et al. A five year review of scar dehiscence in the Rotunda Hospital Dublin. Ir Med J. 2001;94(6):176-178. [pmid: 11495235].
54 Leung A S, Farmer R M, Leung E K, et al. Risk factors associated with uterine rupture during trial of labor after cesarean delivery: A case-control study. Am J Obstet Gynecol. 1993;168(5):1358-1363. [pmid: 8498412].
55 Leung A S, Leung E K, Paul R H. Uterine rupture after previous cesarean delivery: maternal and fetal consequences. Am J Obstet Gynecol. 1993;169(4):945-50. [pmid: 8238154].
56 Bujold E, Gauthier R J. Neonatal morbidity associated with uterine rupture: What are the risk factors?. Am J Obstet Gynecol. 2002;186(2):311-4. [pmid: 11854656].
57 Meier P R, Porreco R P. Trial of labor following cesarean section: a two-year experience. Am J Obstet Gynecol. 1982;144(6):671-8. [pmid: 7137251].
58 Stone C, Halliday J, Lumley J, et al. Vaginal births after Caesarean (VBAC): a population study. Paediatr Perinat Epidemiol. 2000;14(4):340-8. [pmid: 11101021].
59 Holt V L, Mueller B A. Attempt and success rates for vaginal birth after caesarean section in relation to complications of the previous pregnancy. Paediatr Perinat Epidemiol. 1997;11(Suppl 1):63-72. [pmid: 9018716].
60 Rageth J C, Juzi C, Grossenbacher H. Delivery after previous cesarean: a risk evaluation. Swiss Working Group of Obstetric and Gynecologic Institutions. Obstet Gynecol. 1999;93(3):332-7. [pmid: 10074973].
61 Gregory K D, Ramicone E, Chan L, et al. Cesarean deliveries for medicaid patients: a comparison in public and private hospitals in Los Angeles county. Am J Obstet Gynecol. 1999;180(5):1177-84. [pmid: 10329874].
62 Weiss J, Nannini A, Fogerty S, et al. Use of hospital discharge data to monitor uterine rupture--Massachusetts, 1990-1997; US Department of Health & Human Services. MMWR Morb Mortal Wkly Rep. 2000;49(12):245-8. [pmid: 10774544].
63 Farmer R M, Kirschbaum T, Potter D, et al. Uterine rupture during trial of labor after previous cesarean section. Am J Obstet Gynecol. 1991;165(4 Pt 1):996-1001. [pmid: 1951569].
64 Eden R D, Parker R T, Gall S A. Rupture of the pregnant uterus: a 53-year review. Obstet Gynecol. 1986;68(5):671-4. [pmid: 3763082].
65 Scott J R. Mandatory trial of labor after cesarean delivery: an alternative viewpoint. Obstet Gynecol. 1991;77(6):811-4. [pmid: 2030847].
66 Plauche W C, Von Almen W, Muller R. Catastrophic uterine rupture. Obstet Gynecol. 1984;64(6):792-7. [pmid: 6390278].
67 Blanchette H A, Nayak S, Erasmus S, et al. Comparison of the safety and efficacy of intravaginal misoprostol (prostaglandin e1) with those of dinoprostone (prostaglandin E2) for cervical ripening and induction of labor in a community hospital. Am J Obstet Gynecol. 1999;180(6 Pt I):1551-1559. [pmid: 10368503].
68 Electronic fetal heart rate monitoring: Research guideline for interpretation. National Institute of Child Health and Human Development Research Planning Workshop. American Journal of Obstetrics & Gynecology. 1997;177(6):1385–90.
69 Melchior, J, Bernard, N. Incidence and pattern of fetal heart rate alterations during labor. In: Kunzel, W, editor. Heart rate monitoring: clinical practice and physiology. Berlin: Springer-Verlag; 1985.
70 Vroman, S, Sian, AYL, Thiery, M, et al. Elective induction of labor conducted under lumbar epidural block I. Labor induction by anniotomy and intravenous oxytocin. Eur J Obstet Gynecol Reprod Biol 1977;7159–80.
71 DiMatteo M R, Morton S C, Lepper H S, et al. Cesarean childbirth and psychosocial outcomes: a Meta-analysis. Health Psychol. 1996;15(4):303-14. [pmid: 8818678].
72 Lydon-Rochelle M T, Holt V L, Martin D P. Delivery method and self-reported postpartum general health status among primiparous women. Paediatr Perinat Epidemiol. 2001;15(3):232-40. [pmid: 11489150].
73 Ware, JE, Snow, KK, Kosinski, MA, et al. SF-36 health Survey Manual and Interpretation Guide. Boston: The Health Institute, New England Medical Center; 1997.
74 Tulman, L, Fawcett, J, Groblewski, L, et al. Changes in functional status after childbirth. Nurs Res 1990;3970–75.
75 Durik A M, Hyde J S, Clark R. Sequelae of cesarean and vaginal deliveries: psychosocial outcomes for mothers and infants. Dev Psychol. 2000;36(2):251-60. [pmid: 10749082].
76 Green J M. Expectations, experiences and psychological outcomes of childbirth: a prospective study of 825 women. Birth. 1990;17(1):15-24. [pmid: 2346576].
77 Shearer M H. Commentary: Pondering the Study of Women's Psychosocial Outcomes. Birth. 1990;17(1):24.
78 Bramadat I J, Driedger M. Satisfaction with childbirth: Theories and methods of measurement. Birth. 1993;20(1):22-9. [pmid: 8503963].
79 Proctor S. What determines quality in maternity care? Comparing the perceptions of childbearing women and midwives. Birth. 1998;25(2):85-93. [pmid: 9668742].
80 Gamble J A, Creedy D K. Women's request for a cesarean section: a Critique of the literature. Birth. 2000;27(4):256-63. [pmid: 11251511].
81 Geary M, Fanagan M, Boylan P. Maternal satisfaction with management in labour and preference for mode of delivery. J Perinat Med. 1997;25(5):433-9. [pmid: 9438948].
82 Seguin L, Therrien R, Champagne F, et al. The components of women's satisfaction with maternity care. Birth. 1989;16(3):109-13. [pmid: 2789558].
83 Erb L, Hill G, Houston D. A survey of parent's attitudes toward their cesaran births in Manitoba hospitals. Birth. 1983;10(2):85-92. [pmid: 6552195].
84 Fawcett J, Tulman L, Spedden J. Responses to vaginal birth after cesarean section. J Obstet Gynecol Neonat Nurs. 1994;23(3):253-9.
85 Abitbol M M, Castillo I, Taylor U B, et al. Vaginal birth after cesarean section: The patient's point of view. Am Fam Physician. 1993;47(1):129-34. [pmid: 8418576].
86 Mould T A, Chong S, Spencer J A, et al. Women's involvement with the decision preceding their caesarean section and their degree of satisfaction. Br J Obstet Gynaecol. 1996;103(11):1074-7. [pmid: 8916991].
87 Chung A, Macario A, El-Sayed Y Y, et al. Cost-effectiveness of a trial of labor after previous cesarean. Obstet Gynecol. 2001;97(6):932-41. [pmid: 11384699].
88 Grobman W A, Peaceman A M, Socol M L. Cost-effectiveness of elective cesarean delivery after one prior low transverse cesarean. Obstet Gynecol. 2000;95(5):745-51. [pmid: 10775741].
89 Finkler M D, Wirtschafter D D. One health maintenance organization's experience: Obstetric costs depend more on staffing patterns than on mode of delivery. J Perinatol. 1997;17(2):148-55. [pmid: 9134516].
90 Keeler E B, Fok T. Equalizing physician fees had little effect on cesarean rates. Med Care Res Rev. 1996;53(4):465-71. [pmid: 10162961].
91 Spellacy W N. Vaginal birth after cesarean: a reward/penalty system for national implementation. Obstet Gynecol. 1991;78(2):316-7. [pmid: 2067781].
92 Shy K K, LoGerfo J P, Karp L E. Evaluation of elective repeat cesarean section as a standard of care: an application of decision analysis. Am J Obstet Gynecol. 1981;139(2):123-9. [pmid: 7457528].
93 Chuang, JH, Jenders, RA. Trial of labor versus elective repeat cesarean section for the women with a previous cesarean section: a Decision analysis. Proceedings / AMIA Annual Symposium 1999226-30.
94 Clark S L, Scott J R, Porter T F, et al. Is vaginal birth after cesarean less expensive than repeat cesarean delivery?. Am J Obstet Gynecol. 2000;182(3):599-602. [pmid: 10739514].
95 Traynor J D, Peaceman A M. Maternal hospital charges associated with trial of labor versus elective repeat cesarean section. Birth. 1998;25(2):81-4. [pmid: 9668741].
96 Shorten A, Lewis D E, Shorten B. Trial of labour versus elective repeat caesarean section: a cost-effectiveness analysis. Aust Health Rev. 1998;21(1):8-28. [pmid: 10181675].
97 Hadley C B, Mennuti M T, Gabbe S G. An evaluation of the relative risks of a trial of labor versus elective repeat cesarean section. Am J Perinatol. 1986;3(2):107-14. [pmid: 3964379].
98 Flamm B L. Vaginal birth after cesarean section: Controversies old and new. Clin Obstet Gynecol. 1985;28(4):735-44. [pmid: 4075626].
99 DeMaio, H, Edwards, RK, Euliano, TY, et al. Vaginal birth after cesarean delivery: An historic cohort cost analysis. Am J Obstet Gynecol 2002;186890–2.
100 Gold, M, Siegel, J, Russell, L, et al. Cost-Effectiveness in Health and Medicine. New York: Oxford University Press; 1996.
101 Boucher M, Tahilramaney M P, Eglinton G S, et al. Maternal morbidity as related to trial of labor after previous cesarean delivery. A quantitative analysis. J Reprod Med. 1984;29(1):12-6. [pmid: 6708013].
102 Mushinski M. Average charges for uncomplicated vaginal, cesarean and VBAC deliveries: regional variations, United States, 1996. Stat Bull Metrop Insur Co. 1998;79(3):17-28. [pmid: 9691358].
103 Charges and LOS for deliveries vary widely by geographic region, analysis concludes. Data Strat Benchmarks 1998;2(10):154–7.
104 de Meeus J B, Ellia F, Magnin G. External cephalic version after previous cesarean section: a Series of 38 cases. Eur J Obstet Gynecol Reprod Biol. 1998;81(1):65-8. [pmid: 9846717].
105 Flamm B L, Fried M W, Lonky N M, et al. External cephalic version after previous cesarean section. Am J Obstet Gynecol. 1991;165(2):370-2. [pmid: 1872341].
106 Fraser W, Maunsell E, Hodnett E, et al. Randomized controlled trial of a prenatal vaginal birth after cesarean section education and support program. Childbirth Alternatives Post-Cesarean Study Group. Am J Obstet Gynecol. 1997;176(2):419-25. [pmid: 9065192].
107 McNally O M, Turner M J. Induction of labour after 1 previous Caesarean section. Aust N Z J Obstet Gynaecol. 1999;39(4):425-9. [pmid: 10687757].
108 Schachter M, Kogan S, Blickstein I. External cephalic version after previous cesarean section--a clinical dilemma. Int J Gynaecol Obster. 1994;45(1):17-20.
109 Stronge J. Factors Affecting Mode of Delivery In Labour Following A Single Previous Birth by Caesarean Section. J Obstet Gynaecol. 1996;16(5):353-7.
110 Zelop C M, Shipp T D, Cohen A, et al. Trial of labor after 40 weeks' gestation in women with prior cesarean. Obstet Gynecol. 2001;97(3):391-3. [pmid: 11239643].
111 Zelop C M, Shipp T D, Repke J T, et al. Outcomes of trial of labor following previous cesarean delivery among women with fetuses weighing >4000 g. Am J Obstet Gynecol. 2001;185(4):903-5. [pmid: 11641675].
112 Caughey A B, Shipp T D, Repke J T, et al. Trial of labor after cesarean delivery: The effect of previous vaginal delivery. Am J Obstet Gynecol. 1998;179(4):938-41. [pmid: 9790374].
113 Socol M L, Peaceman A M. Vaginal birth after cesarean: an appraisal of fetal risk. Obstet Gynecol. 1999;93(5 Pt 1):674-9. [pmid: 10912965].
114 Goldman G, Pineault R, Bilodeau H, et al. Effects of patient, physician and hospital characteristics on the likelihood of vaginal birth after previous cesarean section in Quebec. Can Med Assoc J. 1990;143(10):1017-24. [pmid: 2224667].
115 King D E, Lahiri K. Socioeconomic factors and the odds of vaginal birth after cesarean delivery. JAMA. 1994;272(7):524-9. [pmid: 8046806].
116 Stafford R S. The impact of nonclinical factors on repeat cesarean section. JAMA. 1991;265(1):59-63. [pmid: 1984126].
117 Roberts R G, Bell H S, Wall E M, et al. Trial of labor or repeated cesarean section. The woman's choice. Arch Fam Med. 1997;6(2):120-5. [pmid: 9075445].
118 Kirk, EP, Doyle, KA, Leigh, J, et al. Vaginal birth after cesarean or repeat cesarean section: medical risks or social realities? Am J Obstet Gynecol 1990;162(6):1398–403; discussion 403–5.
119 Kline J, Arias F. Analysis of factors determining the selection of repeated cesarean section or trial of labor in patients with histories of prior cesarean delivery. J Reprod Med. 1993;38(4):289-92. [pmid: 8501737].
120 McClain C S. The making of a medical tradition: vaginal birth after cesarean. Soc Sci Med. 1990;31(2):203-10. [pmid: 2389156].
121 Melnikow J, Romano P, Gilbert W M, et al. Vaginal birth after cesarean in California. Obstet Gynecol. 2001;98(3):421-6. [pmid: 11530123].
122 Gamble J A, Creedy D K. Women's preference for a cesarean section: Incidence and associated factors. Birth. 2001;28(2):101-10. [pmid: 11380381].
123 Lau T K, MRCOG, Wong S H, et al. A study of patient's acceptance towards vaginal birth after cesarean section. Aust N Z J Obstet Gynaecol. 1996;36(2):155-158. [pmid: 8798303].
124 Murphy M C, Harvey S M. Choice of a childbirth method after cesarean. Women Health. 1989;15(2):67-85. [pmid: 2781811].
125 Quinlivan J A, Petersen R W, Nichols C N. Patient preference the leading indication for elective Caesarean section in public patients--results of a 2-year prospective audit in a teaching hospital. Aust N Z J Obstet Gynaecol. 1999;39(2):207-14. [pmid: 10755782].
126 Joseph, GF, Stedman, CM, Robichaux, AG. Vaginal birth after cesarean section: the impact of patient resistance to a trial of labor. Am J Obstet Gynecol 1991;164(6 Pt 1):1441–4; discussion 1444–7.
127 Dilks F M, Beal J A. Role of self-efficacy in birth choice. J Perinat Neonat Nurs. 1997;11(1):1-9.
128 McClain C S. Patient decision making: the case of delivery method after a previous cesarean section. Cult Med Psychiatry. 1987;11(4):495-508. [pmid: 3691163].
129 McClain C S. Why women choose trial of labor or repeat cesarean section. J Fam Pract. 1985;21(3):210-6. [pmid: 4031794].
130 DeMott, RK, Sandmire, HF. The Green Bay cesarean section study. I. The physician factor as a determinant of cesarean birth rates. Am J Obstet Gynecol 1990;162(6):1593–9; discussion 1599–602.
131 Vimercati A, Greco P, Kardashi A, et al. Choice of cesarean section and perception of legal pressure. J Perinat Med. 2000;28(2):111-7. [pmid: 10875095].
132 Studnicki J, Remmel R, Campbell R, et al. The impact of legislatively imposed practice guidelines on cesarean section rates: the Florida experience. Am J Med Qual. 1997;12(1):62-8. [pmid: 9116534].
133 Lomas J, Enkin M, Anderson G M, et al. Opinion leaders vs audit and feedback to implement practice guidelines. Delivery after previous cesarean section. JAMA. 1991;265(17):2202-7. [pmid: 2013952].
134 Bickell N A, Zdeb M S, Applegate M S, et al. Effect of external peer review on cesarean delivery rates: a statewide program. Obstet Gynecol. 1996;87(5 Pt 1):664-7. [pmid: 8677064].
135 Lomas J, Anderson G M, Domnick-Pierre K, et al. Do practice guidelines guide practice? The effect of a consensus statement on the practice of physicians. N Engl J Med. 1989;321(19):1306-11. [pmid: 2677732].
136 Santerre R E. The effect of the ACOG guideline on vaginal births after cesarean. Med Care Res Rev. 1996;53(3):315-29. [pmid: 10159931].
137 Myers S A, Gleicher N. The Mount Sinai cesarean section reduction program: an update after 6 years. Soc Sci Med. 1993;37(10):1219-22. [pmid: 8272900].
138 Sanchez-Ramos, L, Kaunitz, AM, Peterson, HB, et al. Reducing cesarean sections at a teaching hospital. Am J Obstet Gynecol 1990;163(3):1081–7; discussion 1087–8.
139 Myers S A, Gleicher N. A successful program to lower cesarean-section rates. N Engl J Med. 1988;319(23):1511-6. [pmid: 3185675].
140 Porreco R P. High cesarean section rate: a new perspective. Obstet Gynecol. 1985;65(3):307-11. [pmid: 4038791].
141 Coulter C H, Lehrfeld R. When push comes to shove: Implementing VBAC practice guidelines. Physician Exec. 1995;21(6):30-5. [pmid: 10161334].
142 Gross P A, Greenfield S, Cretin S, et al. Optimal methods for guideline implementation: conclusions from Leeds Castle meeting. Med Care. 2001;39(8 Suppl 2):II85-92. [pmid: 11583124].
143 Goldman G, Pineault R, Potvin L, et al. Factors influencing the practice of vaginal birth after cesarean section. Am J Public Health. 1993;83(8):1104-8. [pmid: 8342717].
144 Sinusas K. Deliveries by family physicians in Connecticut: results of a practice-based research network. Arch Fam Med. 2000;9(5):434-8. [pmid: 10810948].
145 Deutchman M E, Sills D, Connor P D. Perinatal outcomes: a Comparison between family physicians and obstetricians. J Am Board Fam Pract. 1995;8(6):440-7. [pmid: 8585401].
146 Miller E S, Partezana J, Montgomery R L. Vaginal birth after cesarean: a 5-year experience in a family practice residency program. J Am Board Fam Pract. 1995;8(5):357-60. [pmid: 7484222].
147 Barnsley J M, Vayda E, Lomas J, et al. Cesarean section in Ontario: Practice patterns and responses to hypothetical cases. Can J Surg. 1990;33(2):128-32. [pmid: 2268812].
148 Coco A S, Gates T J, Gallagher M E, et al. Association of attending physician specialty with the cesarean delivery rate in the same patient population. Fam Med. 2000;32(9):639-44. [pmid: 11039152].
149 Davis L G, Riedmann G L, Sapiro M, et al. Cesarean section rates in low-risk private patients managed by certified nurse-midwives and obstetricians. J Nurse Midwifery. 1994;39(2):91-7. [pmid: 8027851].
150 Hueston W J, Rudy M. Differences in labor and delivery experience in family physician- and obstetrician-supervised teaching services. Fam Med. 1995;27(3):182-7. [pmid: 7774778].
151 Stone S E, Brown M P, Westcott J P. Nurse-midwifery service in a rural setting. J Nurse Midwifery. 1996;41(5):377-82. [pmid: 8916678].
152 Harrington L C, Miller D A, McClain C J, et al. Vaginal birth after cesarean in a hospital-based birth center staffed by certified nurse-midwives. J Nurse Midwifery. 1997;42(4):304-7. [pmid: 9277061].
153 Berkowitz G S, Fiarman G S, Mojica M A, et al. Effect of physician characteristics on the cesarean birth rate. [see comments.]. Am J Obstet Gynecol. 1989;161(1):146-9. [pmid: 2750795].
154 Hueston W J. Obstetric referral in family practice. Factors Affecting Cesarean Section (FACS) Study Group. J Fam Pract. 1994;38(4):368-72. [pmid: 8163961].
155 Hangsleben K L, Taylor M A, Lynn N M. VBAC program in a nurse-midwifery service. Five years of experience. J Nurse Midwifery. 1989;34(4):179-84. [pmid: 2769442].
156 Chambliss L R, Daly C, Medearis A L, et al. The role of selection bias in comparing cesarean birth rates between physician and midwifery management. Obstet Gynecol. 1992;80(2):161-5. [pmid: 1635724].
157 Walton D L, Ludlow D, Willis D C. Vaginal birth after cesarean section. Acceptance and outcome at a rural hospital. J Reprod Med. 1993;38(9):716-8. [pmid: 8254595].
158 Whitsel A I, Capeless E C, Abel D E, et al. Adjustment for case mix in comparisons of cesarean delivery rates: university versus community hospitals in Vermont. Am J Obstet Gynecol. 2000;183(5):1170-5. [pmid: 11084561].
159 Skelton A G. The relationship among cost, quality, and competition: an analysis of obstetrics services in Missouri hospitals. J Health Care Finance. 1997;24(1):30-44. [pmid: 9327357].
160 Mor-Yosef S, Zeevi D, Samueloff A, et al. Vaginal delivery following one previous cesarean birth: nation wide survey. Asia Oceania J Obstet Gynaecol. 1990;16(1):33-7. [pmid: 2344309].
161 Iglesias S, Burn R, Saunders L D. Reducing the cesarean section rate in a rural community hospital. Can Med Assoc J. 1991;145(11):1459-64. [pmid: 1959105].
162 Schimmel L M, Hogan P, Boehler B, et al. The Yolo County Midwifery Service. A descriptive study of 496 singleton birth outcomes, 1990. J Nurse Midwifery. 1992;37(6):398-403. [pmid: 1460529].
163 Shiono P H, Fielden J G, McNellis D, et al. Recent trends in cesarean birth and trial of labor rates in the United States. JAMA. 1987;257(4):494-7. [pmid: 3795432].
164 Gregory K D, Korst L M, Cane P, et al. Vaginal birth after cesarean and uterine rupture rates in California. Obstet Gynecol. 1999;94(6):985-9. [pmid: 10576187].
165 Paterson C M, Saunders N J. Mode of delivery after one caesarean section: audit of current practice in a health region. BMJ. 1991;303(6806):818-21. [pmid: 1932972].
166 Kumar S, Maouris P. Induction of labour for trial of vaginal birth after caesarean section in a remote district hospital. Aust N Z J Obstet Gynaecol. 1996;36(4):417-20. [pmid: 9006824].
167 Curtin S C, Kozak L J. Cesarean delivery rates in 1995 continue to decline in the United States. Birth. 1997;24(3):194-6. [pmid: 9355279].
168 Sieck C C. Vaginal birth after cesarean section: a comparison of rural and metropolitan rates in Oklahoma. J Oklahoma State Med Assoc. 1997;90(8):444-9.
169 Placek P J, Taffel S M. Vaginal birth after cesarean (VBAC) in the 1980s. Am J Public Health. 1988;78(5):512-5. [pmid: 3354732].
170 Stafford R S. Cesarean section use and source of payment: an analysis of California hospital discharge abstracts. Am J Public Health. 1990;80(3):313-5. [pmid: 2305912].
171 Wagner C L, Metts A K. Rates of successful vaginal delivery after cesarean for patients with private versus public insurance. J Perinatol. 1999;19(1):14-8. [pmid: 10685196].
172 Oleske D M, Linn E S, Nachman K L, et al. Cesarean and VBAC delivery rates in Medicaid managed care, Medicaid fee-for-service, and private managed care. Birth. 1998;25(2):125-7. [pmid: 9668747].
173 Miller M, Leader L R. Vaginal delivery after caesarean section. Aust N Z J Obstet Gynaecol. 1992;32(3):213-6. [pmid: 1445129].
174 Chapman R H, Stone P W, Sandberg E A, et al. A comprehensive league table of cost-utility ratios and a sub-table of “panel-worthy” studies. Med Decis Making. 2000;20(4):451-67. [pmid: 11059478].
175 Xenakis E-J, Langer O, Piper J M, et al. Low-dose versus high-dose oxytocin augmentation of labor - A randomized trial. Am J Obstet Gynecol. 1995;173(6):1874-1878. [pmid: 8610779].
176 Wing D A, Paul R H. Induction of labor with misoprostol for premature rupture of membranes beyond thirty-six weeks' gestation. Am J Obstet Gynecol. 1998;179(1):94-9. [pmid: 9704771].
177 Stone C, Halliday J, Lumley J, et al. Vaginal births after Caesarean (VBAC): a population study. Paediatr Perinat Epidemiol. 2000;14(4):340-8. [pmid: 11101021].
178 Stalnaker BL, Maher JE, Kleinman GE, et al. Characteristics of successful claims for payment by the Florida Neurologic Injury Compensation Association Fund. Am J Obstet Gynecol 1997;177(2):268–71; discussion 271–3.
179 Arulkumaran S, Ingemarsson I, Ratnam S S. Oxytocingmentation in dysfunctional labour after previous caesarean section. Br J Obstet Gynaecol. 1989;96(8):939-941. [pmid: 2775691].
180 Bais J M, van der Borden D M, Pel M, et al. Vaginal birth after caesarean section in a population with a low overall caesarean section rate. Eur J Obstet Gynecol Reprod Biol. 2001;96(2):158-62. [pmid: 11384799].
181 Gherman R B, Heath T. Trial of labor after cesarean delivery: a Pilot study of oral misoprostol for preinduction cervical ripening. Obstet Gynecol. 2001;97(4 Suppl. 1):S68.
182 Goldberger S B, Rosen D J, Michaeli G, et al. The use of PGE2 for induction of labor in parturients with a previous cesarean section scar. Acta Obstet Gynecol Scand. 1989;68(6):523-6. [pmid: 2520807].
183 Goldman G A, Kaplan B, Rabinerson D, et al. Vaginal delivery following caesarean section - the use of oxytocin and prostaglandins. J Obstet Gynaecol. 1998;18(4):328-330. [pmid: 15512101].
184 Norman M, Ekman G. Preinductive cervical ripening with prostaglandin E2 in women with one previous cesarean section. Acta Obstet Gynecol Scand. 1992;71(5):351-355. [pmid: 1326210].
185 Silver R K, Gibbs R S. Predictors of vaginal delivery in patients with a previous cesarean section, who require oxytocin. Am J Obstet Gynecol. 1987;156(1):57-60. [pmid: 3799769].
186 Sims E J, Newman R B, Hulsey T C. Vaginalrth after cesarean: to induce or not to induce. Am J Obstet Gynecol. 2001;184(6):1122-4. [pmid: 11349175].
187 Videla F L, Satin A J, Barth W H, et al. Trial of labor: a disciplined approach to labor management resulting in a high rate of vaginal delivery. Am J Perinatol. 1995;12(3):181-4. [pmid: 7612091].
188 Sakala E P, Kaye S, Murray R D, et al. Epidural analgesia. Effect on the likelihood of a successful trial of labor after cesarean section. J Reprod Med. 1990;35(9):886-90. [pmid: 2231564].
189 Asaad K, Alaily B. Oxytocin use and delivery outcome in women with one previous caesarean section and pre-labour rupture of the membranes at term. J Obstet Gynaecol. 1994;14(6):420-422.
190 Taylor A V G, Sellers S, Ah-Moye M, et al. A prospective random allocation trial to compare vaginal prostaglandin E2 with intravenous oxytocin for labour induction in women previously delivered by caesarean section. J Obstet Gynaecol. 1993;13(5):333-336.
191 Beall M, Eglinton G S, Clark S L, et al. Vaginal delivery after cesarean section in women with unknown types of uterine scar. J Reprod Med. 1984;29(1):31-5. [pmid: 6708018].
192 Holt V L, Mueller B A. Attempt and success rates for vaginal birth after caesarean section in relation to complications of the previous pregnancy. Paediatr Perinat Epidemiol. 1997;11(Suppl 1):63-72. [pmid: 9018716].
193 Zelop C M, Shipp T D, Repke J T, et al. Effect of previous vaginal delivery on the risk of uterine rupture during a subsequent trial of labor. Am J Obstet Gynecol. 2000;183(5):1184-6. [pmid: 11084564].
194 Zelop C M, Shipp T D, Repke J T, et al. Uterine rupture during induced or augmented labor in gravid women with one prior cesarean delivery. Am J Obstet Gynecol. 1999;181(4):882-6. [pmid: 10521747].
195 Choy-Hee L, Raynor B D. Misoprostol induction of labor among women with a history of cesarean delivery. Am J Obstet Gynecol. 2001;184(6):1115-7. [pmid: 11349173].
196 Chua S, Arulkumaran S, Singh P, et al. Trial of labour after previous caesarean section: Obstetric outcome. Aust N Z J Obstet Gynaecol. 1989;29(1):12-7. [pmid: 2562593].
197 Chuck F J, Huffaker B J. Labor induction with intravaginal misoprostol versus intracervical prostaglandin E2 gel (Prepidil gel): Randomized comparison. Am J Obstet Gynecol. 1995;173(4):1137-42. [pmid: 7485307].
198 Coltart T M, Davies J A, Katesmark M. Outcome a second pregnancy after a previous elective caesarean section. Br J Obstet Gynaecol. 1990;97(12):1140-3. [pmid: 2279020].
199 Del Valle G O, Adair C D, Sanchez-Ramos L, et al. Cervical ripening in women with previous cesarean deliveries. International Journal of Gynecology & Obstetrics. 1994;47(1):17-21. [pmid: 7813746].
200 MacKenzie I Z, Bradley S, Embrey M P. Vaginalostaglandins and labour induction for patients previously delivered by caesarean section. Br J Obstet Gynaecol. 1984;91(1):7-10. [pmid: 6581835].
201 Norman P, Kostovcik S, Lanning A. Electivepeat cesarean sections: how many could be vaginal births?. Can Med Assoc J. 1993;149(4):431-5. [pmid: 8348425].
202 Plaut M M, Schwartz M L, Lubarsky S L, et al. Uterine rupture associated with the use of misoprostol in the gravid patient with a previous cesarean section. Am J Obstet Gynecol. 1999;180(6 Pt I):1535-1542. [pmid: 10368501].
203 Miles A M, Monga M, Waller K, et al. Risk factors for symptomatic uterine rupture during a trial of labor: The 1990s. Am J Perinatol. 2000;17(7):385-389. [pmid: 12141526].
204 Stone J L, Lockwood C J, Berkowitz G, et al. Use of cervical prostaglandin E2 gel in patients with previous cesarean section. Am J Perinatol. 1994;11(4):309-12. [pmid: 7945629].
205 Abitbol M M, Taylor U B, Castillo I, et al. The cephalopelvic disproportion index. Combined fetal sonography and x-ray pelvimetry for early detection of cephalopelvic disproportion. J Reprod Med. 1991;36(5):369-73. [pmid: 2061886].
206 Morgan M A, Thurnau G R. Efficacy of the fetal-pelvic index for delivery of neonates weighing 4000 grams or greater: a preliminary report. Am J Obstet Gynecol. 1988;158(5):1133-7. [pmid: 3285685].
207 Hook B, Kiwi R, Amini S B, et al. Neonatal morbidity after elective repeat cesarean section and trial of labor. Pediatrics. 1997;100(3 Pt 1):348-53. [pmid: 9282704].
208 Hanley M L, Smulian J C, Lake M F, et al. Analysis of repeat cesarean delivery indications: implications of heterogeneity. Am J Obstet Gynecol. 1996;175(4 Pt 1):883-8. [pmid: 8885741].
209 Taffel S M, Placek P J, Moien M, et al. 1989 U.S. cesarean section rate steadies--VBAC rate rises to nearly one in five. Birth. 1991;18(2):73-7. [pmid: 1930436].
210 Eriksen N L, Buttino L. Vaginal birth after cesarean: a Comparison of maternal and neonatal morbidity to elective repeat cesarean section. Am J Perinatol. 1989;6(4):375-9. [pmid: 2789534].
211 Placek P J, Taffel S M. Vaginal birth after cesarean (VBAC) in the 1980s. Am J Public Health. 1988;78(5):512-5. [pmid: 3354732].
212 Hadley C B, Mennuti M T, Gabbe S G. Analuation of the relative risks of a trial of labor versus elective repeat cesarean section. Am J Perinatol. 1986;3(2):107-14. [pmid: 3964379].
213 Boucher M, Tahilramaney M P, Eglinton G S, et al. Maternal morbidity as related to trial of labor after previous cesarean delivery. A quantitative analysis. J Reprod Med. 1984;29(1):12-6. [pmid: 6708013].
214 Ravasia D J, Wood S L, Pollard J K. Uterinepture during induced trial of labor among women with previous cesarean delivery. Am J Obstet Gynecol. 2000;183(5):1176-9. [pmid: 11084562].