# Acknowledgments

The research team would like to express our regard and appreciation for the efforts of Patty Davies, MS, for database searching; Benjamin K.S. Chan, MS, for statistical support; A.J. Mayhew for editing; Susan Wingenfeld, Lynne Schwabe, Nina Mahmud, and James Wallace for program support; Linda Slattery for administrative support; and everyone else who shared support and ideas throughout the development of this report. We would also like to thank Rosaly Correa-de-Araujo, MD, MSc, PhD, of the Agency for Healthcare Research and Quality for her help as our Task Order Officer.

We also thank the representatives from the American College of Obstetricians and Gynecologists and the American Academy of Family Physicians, our technical expert panel, our peer reviewers, and those on the uterine rupture terminology conference call for their invaluable contributions.