# Appendix G. Uterine Rupture Terminology Conference: September 5, 2002

Call Participants:

Stanley Zinberg, MD, MS, FACOG

Vice President for Practice Activities

American College of Obstetricians and Gynecologists

Washington, DC

Watson Bowes, MD

Professor Emeritus of Obstetrics and Gynecology

University of North Carolina at Chapel Hill

Chapel Hill, North Carolina

Benjamin Sachs, MB, BS, DPH, FACOG

Obstetrician-Gynecologist-in-Chief

Beth Israel Deaconess Medical Center

Boston, Massachusetts

Evan Myers, MD, MPH

Assistant Professor of Obstetrics and Gynecology

Duke University Medical Center

Durham, North Carolina

Eric Wall, MD, MPH

Clinical Associate Professor of Family Medicine

Oregon Health & Science University

Vice President and Regional Director, Lifewise and Blue Cross/Blue Shield of Alaska Medical Director

Portland, Oregon

Fay Menacker, DrPH, RN, CPNP

Division of Vital Statistics

National Center for Health Statistics

Hyattsville, Maryland

Jun “Jim” Zhang, PhD, MD

Division of Epidemiology, Statistics and Prevention Research

National Institute of Child Health and Human Development

National Institutes of Health

Bethesda, Maryland

David Atkins, MD, MPH

Chief Medical Officer

Center for Practice and Technology Assessment

Agency for Healthcare Research and Quality

Bethesda, Maryland

Mark Helfand, MD, MPH

Director, Oregon Evidence-based Practice Center

Associate Professor of Medicine and Medical Informatics & Outcomes Research,

Oregon Health & Science University

Jeanne-Marie Guise MD, MPH

Assistant Professor of Obstetrics and Gynecology and of Medical Informatics and Outcomes Research

Oregon Health & Science University

Portland, Oregon

## Purpose of the Uterine Rupture Terminology Conference Call

A conference call was held on September 5, 2002 to discuss terminology for uterine rupture. Specifically, some peer reviewers of the VBAC evidence report were concerned with terminology used in the draft report. If the members of the call could reach consensus on appropriate terminology, the final evidence report would be revised to reflect this consensus, as possible.

### Defining Uterine Rupture

The draft evidence report found inconsistencies and ambiguities in terminology used for uterine rupture. Call participants were directed to a table of terminologies used for uterine rupture among several studies in the evidence report. We discussed the challenges in studying the epidemiology of the condition due to these inconsistencies. We also discussed the inability to identify predictors for morbidity due to uterine rupture when they were embedded in the definition of uterine rupture. Motivated by these issues, we presented the terminology used in the draft report to start discussion about more precise terminology.

One alternative terminology proposed was complete rupture, incomplete rupture, or window. Members of the call were pleased with the fact that incomplete and complete would provide a clear anatomic description. The majority felt that there was not a need to distinguish between incomplete rupture and window. There was some concern that these terms did not provide a description for the severity of the condition. Although the severity of the condition is important, indicating the origin or cause of uterine rupture is needed to establish contributing factors. One suggestion was to use the following terms:

Symptomatic Uterine Rupture Not Related to a Cesarean Scar

Symptomatic Uterine Rupture Related to a Cesarean Scar

Asymptomatic Uterine Rupture Not Related to a Cesarean Scar

Through discussion it was suggested that the descriptors, clinically significant or consequential, would be more appropriate than a/symptomatic since they are easier to define. However, questions as to what “clinically significant” meant were raised. Some members of the call considered any uterine rupture as “clinically significant” since the patient would need an unexpected surgical procedure and may have delivered her baby via an unintended route. Also, some mentioned that any uterine rupture could also lead to significant morbidity if left untreated.

It was then suggested that outcomes should not be used to diagnosis/describe a uterine rupture. In order to accurately determine and record the frequency of uterine rupture, it must be kept in simple terms. Several members of the call agreed with this suggestion. There was some agreement on using the following terms:

Incomplete uterine rupture of a cesarean scar - separation that was not completely through all layers of the uterine wall (e.g., serosa intact)

Complete uterine rupture of a cesarean scar - entire thickness of the uterine wall including visceral serosa (with or without expulsion of part or complete extrusion of fetal-placental unit)

### Next Steps

The evidence report is constrained by the data provided within the studies. The text was revised to replace cesarean disruption with uterine rupture of a cesarean scar. Because few studies presented data exclusively for complete or incomplete rupture, the authors were not able to present these data specifically in the report. The text has included the table of terminology used among studies (referred to in the call) and a discussion of the difficulties raised by inconsistent terminology to pave the way for future research with explicit outcomes.

Although full consensus was not reached on terminology, the call was the first step in bringing together experts in the field to discuss this issue. Future work can be done to arrive at a consensus and potentially shape the field by uniformity in reporting terminology.