# Appendix F. Criteria for Grading in the Internal Validity of Individual Studies

Our team used the criteria listed below to rate studies.^*^ Details on use of these criteria follow. See individual topic method and/or results sections for discussion on those components considered fatal flaws for particular topics.

* Harris, R.P.Helfand, M.Woolf, S.H.Lohr, K.N.Mulrow, C.D.Teutsch, S.M.Atkins, D. (2001). Current methods of the U.S. Preventive Services Task Force. Am J Prev Med, V20; 21–35.

Undertaking Systematic Reviews of Research Effectiveness: CRD's Guidance for those Carrying Out or Commissioning Reviews. CRD Report Number 4 (2^nd^ ed). NHS Centre for Reviews and Dissemination; York, England. March 2001.

## Randomized Controlled Trials

- Random assignment
- Allocation concealed
- Groups similar at baseline
- Eligibility criteria specified
- Outcome assessors blinded
- Care provider blinded
- Patient unaware of treatment
- Intention-to-treat analysis
- Maintenance of comparable groups
- Reporting of attrition, crossovers, adherence, and contamination
- Differential loss to followup or overall high loss to followup

## Cohort Studies

- Comparable groups assembled/ Database representative for study (e.g., comparing women who all would qualify for TOL rather than TOL versus medically indicated repeat cesarean)
- Maintenance of comparable groups
- Clear definition of comparison groups/sufficient description of distribution of prognostic factors
- Measures equal, reliable, valid/ explicit definition of outcomes (objective, consistently applied e.g., uterine rupture)
- Outcome assessment blind to exposure status
- Loss/dropout rate
- Follow-up long enough for outcomes to occur
- Consider/adjust for potential important confounders (obstetric/medical conditions)

## Case-control Studies

- Case definition explicit
- State of the cases reliably assessed and validated
- Accurate ascertainment of cases
- Nonbiased selection of cases/controls (controls randomly selected)
- Cases and controls comparable with respect to potential confounding factors
- Procedures applied equally
- Appropriate attention to confounders
- Appropriate statistical analysis used (matched, unmatched, overmatching)

## Case Series Studies

- Representative sample selected from a relevant population
- Inclusion criteria explicit
- Individuals entered the survey at a similar point in their disease progression
- Followup long enough for important events to occur
- Outcomes assessed using objective criteria/ blinding used
- If comparison of sub-series, sufficient description of the series and distribution of prognostic factors

The Methods Work Group for the US Preventive Services Task Force (USPSTF) developed a set of criteria by which the quality of individual studies could be evaluated in terms of both internal validity and external validity. The USPSTF accepted the criteria, and the associated definitions of quality categories, that relate to internal validity at its September 1999 quarterly meeting. Details on this criteria and grading study quality has also been documented.^*^

This document describes the criteria relating to internal validity and the procedures followed to make these judgments.

All topic teams will use initial “filters” to select studies for review that deal most directly with the question at issue and that are applicable to the population at issue. Thus, studies of any design that use outdated technology or that use technology that is not feasible for primary care practice may be filtered out before the abstraction stage, depending on the topic and the decisions of the topic team. The teams will justify such exclusion decisions if there could be reasonable disagreement about this step. The criteria below are meant for those studies that pass this initial filter.

## Design-Specific Criteria and Quality Category Definitions

Presented below are a set of minimal criteria for each study design and then a general definition of three categories—good, fair, and poor—based on those criteria. These specifications are not meant to be rigid rules but rather are intended to be general guidelines, and individual exceptions, when explicitly explained and justified, can be made. In general, a good study is one that meets all criteria well. A fair study is one that does not meet (or it is not clear that it meets) at least one criterion but has no known “fatal flaw.” Poor studies have at least one fatal flaw.

## Randomized Controlled Trials and Cohort Studies

Criteria:

- Initial assembly of comparable groups
  -for RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  -for cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to follow-up or overall high loss to follow-up
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intention to treat analysis for RCTs.

## Definition of ratings based on above criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention to treat analysis is used.

Fair: Studies will be graded fair if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention to treat analysis is done for RCTS.

Poor: Studies will be graded poor if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention to treat analysis is lacking.

## Case-control Studies

Criteria:

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variable

## Definition of ratings based on criteria above

Good:Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.

Fair: Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rate less than 80 percent or attention to some but not all important confounding variables.

Poor: Major selection or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.

## Systematic Reviews

Criteria:

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Regency and relevance are especially important for systematic reviews

## Definition of ratings from above criteria

Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions.

Fair: Recent, relevant review that is not clearly biased but lacks comprehensive and search strategies.

Poor: Outdates, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies.

## Quality Analysis Details: Uterine Rupture

Three studies (Lydon-Rochelle, 2001; Rageth, 1999; Stone, 2000), used ICD-9 codes to measure uterine rupture rates, a method that has been shown to be inaccurate (Anonymous, 2000). Hospital discharge data has important limitations. For example, one state-wide study of ICD-9 codes from hospital discharge data compared the codes for uterine rupture to detailed medical records including surgical reports and discharge summaries in Massachusetts (Anonymous, 2000). In a seven-year period 1,244 suspected uterine ruptures were identified from ICD-9 codes. After detailed record review 480 (39.8 percent) of these were confirmed as true uterine ruptures rather than incidental extension of uterine incision at surgery or uterine windows without disruption. The positive predictive value was 50.7percent for the ICD-9 codes 665.0 (rupture of uterus before the onset of labor) and 665.1 (rupture of uterus during labor or not otherwise specified) and 28.6 percent for code 674.1 (disruption of cesarean wound including dehiscence or disruption of uterine wound). If they had restricted cases of uterine rupture to those identified by codes 665.0 and 665.1, as was done in the two retrospective studies above (Lydon-Rochelle, 2001; Stone, 2000), they would have missed one third of cases classified as having uterine rupture by chart review. Thus, ICD-9 codes are not an accurate means to identify cesarean disruption. Seven of 15 prospective cohort studies were rated poor.

References

Anonymous. Use of hospital discharge data to monitor uterine rupture--Massachusetts, 1990-1997; US Department of Health & Human Services. MMWR - Morbidity & Mortality Weekly Report 2000;49(12):245–8.

Lydon-Rochelle M, Holt VL, Easterling TR, et al. Risk of uterine rupture during labor among women with a prior cesarean delivery. New England Journal of Medicine 2001;345(1):3–8.

Rageth JC, Juzi C, Grossenbacher H. Delivery after previous cesarean: a risk evaluation. Swiss Working Group of Obstetric and Gynecologic Institutions. Obstetrics & Gynecology 1999;93(3):332–7.

Stone C, Halliday J, Lumley J, et al. Vaginal births after Caesarean (VBAC): a population study. Paediatric & Perinatal Epidemiology 2000;14(4):340–8.

Quality Ratings - Vaginal Delivery, Maternal and Infant Outcomes (see Bibliography for full citations)

Author/Year/Quality | Random assignment | Allocation concealed | Groups similar at baseline/Maintenance of comparable groups | Eligibility criteria specified | Blinded: Outcome Assessors/Care Provider/Patient | Cointerventions/Intention-to-treat analysis | Report of attrition, crossovers, adherence, & contamination | Differential loss to followup or overall high loss to followup | Quality Score
Random Control Trials
Lelaidier 1994 | Yes - randomized in pharmacy, “balanced rand list” | Yes - tablets all the same disp out of pharm | Yes, although diff in rates of postdates, IUGR between Mef and pl unsure if SS | Yes | Yes/Yes/Yes | Yes, f/u with oxytocin, specific details not available although authors looked at dose requirements/ | ? | NR | FAIR
Rayburn 1999 | Yes pharmaceutical company computer generated | Yes | Yes except never looked at parity/NR | Yes | ?/No/No | Yes oxytocin - similar between groups/No - non-compliance excluded prior to analysis | Yes oxytocin - similar between groups | No | FAIR
Xenakis 1995 | inadequate (days of the week) | no | yes/NR | yes | No/No/No | None/NR | NR | none | POOR
Wing 1998 | NR | NR | NR/NR | yes | No/No/No | None/NR | NR | none | POOR
Population-Based Database
Author, Year | Comparable groups assembled/Database representative for study | Maintenance of comparable groups | Clear definition of comparison groups/sufficient description of distribution of prognostic factors | Measures equal, reliable, valid/eplicit definition of outcomes | Outcome assessment blind to exposure status | Loss/Drop-out rate | Follow-up long enough for outcomes to occur | Consider/Ad just for potential important confounders | Quality Score
McMahon 1996 | Yes | NA | Yes | Yes | No | NA | Yes | Yes | GOOD
Smith 2002 | Uncertain | NA | Uncertain | Yes | No | NA | Yes | Yes | FAIR
Bais 2001 | Uncertain | NA | No | Most | No | NA | Yes | No | POOR
Lyndon-Rochelle 2001 | Yes | NA | Yes | No | No | NA | Yes | Yes | POOR
Stone 2000 | Uncertain | NA | No | No for uterine rupture | No | NA | Yes | No | POOR
Gregory 1999 | Uncertain | NA | No | Yes | No | NA | Yes | No | POOR
Rageth 1999 | No | NA | No | No | No | NA | Yes | No | POOR
Holt 1997 | Uncertain | NA | No | Yes | No | NA | Yes | No | POOR
Beall 1984 | Yes | NA | Yes | No | No | NA | Yes | Not adjusted for age, parity, obsteric or medical complications | POOR
Prospective Cohort
Duff 1988 | Yes | NA | Yes | Yes | No | NA | Yes | Y/N | GOOD
Flamm 1994 | Yes | NA | Yes, age, prior #CD, birth weight | Yes | No | NA | Yes | Yes | GOOD
Flamm 1988 | Yes | NA | NA | Yes | No | NA | Yes | looked at group specific rates for parity, prior CD reason | GOOD
Flamm 1987 | yes | NA | partial, reasons for induction not given | yes | No | NA | Yes | Yes | FAIR
Blanchette 2001 | nr | NA | No | yes | No | NA | yes | yes | FAIR
Cowan 1994 | NA, no comparison | NA | NA, no comparison | Yes | No | NA | Yes | Y/N | FAIR
Flamm 1990 | Yes/No | NA | NA | Yes, defined rupture | No | NA | Yes | uncertain | FAIR
Phelan 1987 | Yes | NA | No info for parity, age | Yes | No | NA | Yes | Yes/No | FAIR
Paul 1985 | Yes | NA | No | Yes | No | NA | Yes | No, scar type, age, parity | FAIR
Martin 1983 | Yes | NA | No | Yes except fever | No | NA | Yes | No | FAIR

Quality Ratings: Predictive Tools and Individual Factors

RCT | Quality Components
Study, Year | Random assignment | Allocation concealed | Groups similar at baseline/Maintenance of comparable groups | Eligibility criteria specified | Blinded: Outcome Assessors/Care Provider/Patient | Intention-to-treat analysis | Report of attrition, crossovers, adherence, & contamination | Differential loss to followup or overall high loss to followup | Quality Score
Thubisi, 1993 | Y | NA | Y/N | Y | N/N/N | Y | NA | NA | GOOD
Fraser, 1997 | Y | NA | Y/Y & N | Y | N/N/N | N | Y | Y/N | FAIR
COHORT | Quality Components
Study, Year | Comparable Groups. Clear inclusion criteria. | Maint. of comparable groups | Clear definition of comparison groups | Measures reliable, valid | Unbiased assessment of data and analysis of results | Loss/Drop - out rate | Follow-up long enough for outcomes to occur | Adjust for potential confounders (obstetric conditions) | Quality Score
Flamm, 97 | Y | Y | Y/N | Y | N | NA | Y | Y | GOOD
Jakobi, 93 | Y | Y | N | Y | N | NA | Y | Y | FAIR
McNally, 99 | Y | Y | N | Y/N | N | NA | Y | Y | FAIR
Stronge, 1996 | Y | Y | N | Y/N | N | NA | Y | Y/N | FAIR
Troyer, 92 | Y | Y | N | Y/N | N | NA | Y | N | FAIR
Vinueza, 2000 | Y | Y | Y | Y/N | N | NA | Y | N | FAIR
Weinstein, 96 | Y | Y | N | Y/N | N | NA | Y | Y | FAIR
Zelop, 2001 (A) | Y | Y | Y/N | Y | N | NA | Y | Y | FAIR
Zelop, 2001 (B) | Y | Y | Y/N | Y | N | NA | Y | Y | FAIR
Abitbol, 91 | N | NA | N | Y | N | NA | Y | N | POOR
Lao, 87 | Y | Y | N | Y/N | N | NA | Y | N | POOR
Morgan, 88 | Y | Y | N | Y | N | NA | Y | N | POOR
Thurnau, 91 | Y | Y | N | Y | N | NA | Y | N | POOR
Wright, 85 | Y | Y | N | Y/N | N | NA | Y | N | POOR
Case-Control | Quality Components
Author, Year | Case definition explicit | State of the cases reliably assessed and validated | Accurate ascertainment of cases | Cases/controls: Nonbiased selection & comparable confounding factors | Procedures applied equally | Measurement of exposure accurate and applied equally | Appropriate attention to confounders | Appropriate statistical analysis used (matched, unmatched, overmatching) | Quality Score- Review 1
Macones, 2001 | Y | Y/N | Y | N/N | Y | Y/N | Y | Y | FAIR
Pickhardt, 92 | Y | Y/N | Y/N | N/N | Y | Y/N | Y | Y | FAIR
Case-Series | Quality Components
Author, Year | Representative sample selected from a relevant population | Inclusion criteria explicit | Individuals entered the survey at a similar point in their disease progression | Follow-up long enough for important events to occur | Outcomes assessed using objective criteria/blinding used | If sub-series, sufficient description & distribution of prognostic factors | | | Quality Score
Flamm, 91 | Y | Y | Y/N | Y | Y | N | | | FAIR
de Meeus, 98 | Y | Y | Y/N | Y | Y | N | | | FAIR
Schatcher, 94 | Y | Y/N | Y/N | Y | Y | Y | | | GOOD

Quality Ratings: Decision Making/Patient Preference

RCT | Quality Components
Study, Year | Random assignment | Allocation concealed | Groups similar at baseline/Maintenance of comparable groups | Eligibility criteria specified | Blinded: Outcome Assessors/Care Provider/Patient | Intention-to-treat analysis | Report of attrition, crossovers, adherence, & contamination | Differential loss to followup or overall high loss to followup | Quality Score
Fraser, 1997 | Yes | Yes | No differences in baseline demographic. Similar proportions of women had previous labors and were requesting tubal ligation. | Used validated Birth Experience Rating Scale. | Blocked by hospital and by the women's motivation (either low or high) | Yes, used intent-to-treat | Yes | Lost 140/1275 (11.0%). | Good
COHORT | Quality Components
Study, Year/Quality/Design | Comparable Groups. Clear inclusion criteria. | Maintenance of comparable groups | Clear definition of comparison groups | Measures reliable, valid | Unbiased assessment of data and analysis of results | Loss/Drop - out rate | Follow-up long enough for outcomes to occur | Adjust for potential confounders (obstetric conditions) | Quality Score
Kirk, 1990 | Incl/excl criteria NR. At Hospital B: 73% of patients who planned a TOL returned surveys compared with 47% of ERCD. | | | NR | Yes | Lost 97/257 (38%) | Yes | NA | Fair: Fair follow-up, validity of measures not described.
Kline, 1993 | Clear exclusion criteria. No differences in demographic | Yes | Women requesting elective CD. Women attempting TOL. | Validation unlikely but not reported. | Unclear who asked patients about delivery reasons but biased if patient's clinician did. | NR | Yes | No confounders or adjustments are presented. | Fair. Unclear who interviewed patients. Potentially biased results.
McClain, 1985; McClain, 1987; McClain, 1990 | Yes | Yes | Women who chose TOL and those who chose elective repeat CD. | Unclear if reasons validated. | Yes | NR | Follow-up not reported. | Yes. Adjusted for education when examining ethnicity. | Fair. Measures validation not reported.
Martin, 1983 | Yes | | | NR | Unclear who interview the women regarding their birth choice and reasons. | Accounted for all patients. | Follow-up NR | Accounted conditions (# of prior CDs, epidural use ) in outcomes. | Fair. Measures validation NR.
Meier, 1982 | Clear inclusion criteria. | Reported no demographics for groups. | | NR | Yes | Lost 14/53 (26.4%) of TOL. | Yes | NA | Fair. Follow-up rate is for subgroup. Measures validation NR.
Melnikow, 2001 | Yes, groups determined by underlying CD rates at hospitals. | | | Yes, used ICD-9CM coding. | Yes. Independent chart abstraction. | Lost 73/1662 (4.3%) | NA | NR | Fair. No mention of adjustments.
Quinlivan, 1996 | Not clear of some patients eligible for TOL. | No baseline demographics or risks presented. | Women with emergency and elective CD. | Probably clinically valid. | No, the clinician who performed the CD provided the data. | NR | NA | NA | Poor.
Cross-sectional | Quality Components
Study, Year/Quality/Design | Comparable Groups. Clear inclusion criteria. | Maintenance of comparable groups | Clear definition of comparison groups | Measures reliable, valid | Unbiased assessment of data and analysis of results | Loss/Drop - out rate | Follow-up long enough for outcomes to occur | Adjust for potential confounders (obstetric conditions) | Quality Score
Lau, 1996 | Clear inclusion criteria. | | | Not clear | Yes | NA | Yes | NA | Good
Murphy, 1989 | Yes | | | Content validity. Pretesting. | Yes | Lost 3/53 (5.7%) | Y | NA. Discussed possible confounders | Good
Joseph, 1991 | Clear exclusion criteria. | Unclear. | Presented may groups of patients with crossovers. | Yes/No | No. | Accounted for all patients | Yes | Presented only descriptive statistics. | Fair.
Gamble, 2001 | NR by group. Inclusion/exclusion criteria NR. | | | Yes. Content validity. | Yes | Lost 3% at recruitment | NA | NA | Fair. No demographics by group.
Fawcett, 1994 | NA. Only one group. | Unclear | Unclear | Interrater reliability was 92%. | Yes. | NR | 12–48 hours after delivery. | NA | Fair. Follow-up rate NR.
Mould, 1996 | Clear inclusion criteria. No baseline demographic or risks presented. | Cross-sectional study | Women having an ERCD. Women having an emergency CD. | Validation unlikely but not reported. Yes/No | No, patient's clinician interviewed for preference. | Lost 15/102 (14.7%) | Yes | No | Poor
Abitbol, 1993 | Clear inclusion criteria. No baseline demographics. | Unclear. | Women requesting elective CD. Women attempting TOL. | Validation unlikely but not reported. | No | 0%? | Yes | No | Poor. Potentially biased results.
Dilks, 1997 | Yes | | | Yes | Unclear | Recruited 74/225. Lost (67.2%) | Yes | NA | Poor. Recruitment rate poor.

Quality Ratings- Economic Studies

Author/year | Perspective Stated | Prog Benef. Described | Intervention Cost incl | Morbidity/SE Costs include | Averted Costs include | Induced Costs include | Costs/Ben Discounted | Sensitivity Analyses | C/E Ratio Stated | Quality Score
Chung (2001) | Good | Good | Good | Good | Good | Good | Good | Good | Good | GOOD
Grobman (2000) | Good | Good | Good | Good | Good | Good | Good | Good | Fair | FAIR
Finkler (1997) | Good | Poor | Good | Good | Good | Fair | NA | Poor | NA | POOR
Keeler (1996) | Good | Poor | Fair | Poor | Poor | Poor | NA | Poor | NA | POOR
Spellacy (1991) | Poor | Fair | Fair | Poor | Fair | Poor | NA | Poor | NA | POOR
Shy (1981) | Poor | Poor | Fair | Poor | Poor | Poor | NA | Poor | NA | POOR
Chuang (1999) | None | Fair | Fair | Fair | Poor | Poor | NA | Good | Poor | POOR
Clark (2000) | Poor | Poor | Fair | Poor | Fair | Fair | Poor | Poor | NA | POOR
Traynor (1998) | Good | Fair | Good | Fair | Poor | Fair | NA | None | NA | POOR
Shorten (1998) | Good | Fair | Good | Fair | Fair | Fair | NA | Good | NA | POOR
Hadley (1986) | Fair | Good | Fair | Fair | Poor | Fair | NA | Poor | Poor | POOR
Flamm (1985) | Poor | Fair | Fair | Poor | Poor | Poor | NA | Poor | Poor | POOR
DiMaio (2002) | Poor | Fair | Fair | Fair | Fair | Fair | NA | Poor | Poor | POOR

Quality Ratings - Provider Characteristics

RCT
Study, Year | Random assignment | Allocation concealed | Groups similar at baseline/Maintenance of com-parable groups | Eligibility criteria specified | Blinded: Outcome Assessors/Care Provider/Patient | Intention-to-treat analysis | Report of attrition, cross-overs, etc | Loss to follow-up | Quality Score
Guidelines
Bickell (1996) | Good | NA | Good/NA | Good | NA | Fair | NA | NA | FAIR
Lomas (1991) | Good | NA | Good/NA | Good | NA | Good | NA | NA | GOOD
CASE CONTROL
Author, Year | Case definition explicit | State of the cases reliably assessed and validated | Accurate ascertainment of cases | Non-biased selection of cases/controls | Cases and controls comparable with respect to potential confounding factors | Measurement of exposure accurate and applied equally/Procedures applied equally | App attention to confounders | App. Stat Analy | Quality Score
Physician Characteristics
Goldman (1993) | Good | Fair | Fair | Good | Poor | Fair/NA | Good | Poor | POOR
Goldman (1990) | Good | Good | NA | NA | Good | Fair | Poor | Good | POOR
Hospital Characteristics
Goldman (1993) | Good | Fair | Fair | Good | Poor | Fair/NA | Good | Poor | Poor
Goldman (1990) | Good | Good | NA | NA | Good | Fair | Poor | Good | POOR
Case-Series
Author, Year | Representative sample selected from a relevant population | Inclusion criteria explicit | Individuals entered the survey at a similar point in their disease progression | Follow-up long enough for important events to occur | Outcomes assessed using objective criteria/blinding used | Sufficient description of the series (subseries) and distribution of prognostic factors | Other important issues | | Quality Score
Health Care Resources
Iglesias (1991) | Good | Good | NA | NA | Good | NA | Poor (small n) | | POOR
Hospital Characteristics
Iglesias (1991) | Good | Good | NA | NA | Good | NA | Poor (small n) | | POOR
Kumar (1996) | Good | Good | NA | NA | Good | NA | Poor (small n) | | POOR
Raynor (1993) | Good | Good | NA | NA | Good | NA | Fair (smaller n) | | FAIR
Schlimmel (1992) | Good | Good | NA | NA | Good | NA | Fair (smaller n) | | FAIR
Walton (1993) | Good | Good | NA | NA | Good | Good | Fair (smaller n) | | FAIR
Hangsleben (1989) | Fair | Fair | NA | NA | Good | Fair | Poor (did not report ERCD in sample) | | POOR
Cross-Sectional Studies
Guidelines
Coulter (1995) | NA | Good | NA | NA | Fair (self report) | Poor | Poor (small n) | Poor | POOR

Author, Year | Comparable Groups/Clear inclusion criteria | Maintenance of comparable groups | Clear definition of comparison groups | Measures reliable, valid | Un-biased assessment of data | Loss/Drop-out rate | Follow-up long enough for outcomes to occur | Adjust for confounders | Quality Score
Resources
Flamm (1994) | Good | NA | Fair | Fair | NA | NA | NA | Poor | POOR
Mor-Yosef (1990) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Phelan (1987) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Placek (1988A) | Poor | NA | Good | Fair | NA | NA | NA | Poor | POOR
Placek (1988B) | Poor | NA | Good | Fair | NA | NA | NA | Poor | POOR
Roberts (1997) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Stovall (1987) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Taffel (1991) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Boucher (1984) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Cowan (1994) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Data Strat & Bench Marks (1998) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Eriksen (1989) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Flamm (1988) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Hadley (1986) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Hanley (1996) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Curtin (1997) | Poor | NA | Fair | Fair | Good | NA | NA | Poor | POOR
Hook (1997) | Fair | NA | Fair | Good | Good | NA | NA | Poor | POOR
anonymous (1998) Data Strategies & Benchmarks, Oct. 154 | Poor | NA | Poor | Good | Good | NA | NA | Poor | POOR
Author, Year | Comparable Groups/Clear inclusion criteria | Maintenance of comparable groups | Clear definition of comparison groups | Measures reliable, valid | Unbiased assessment of data | Loss/Drop - out rate | Follow-up long enough for outcomes to occur | Adjust for potential confounders (obstetric conditions) | Quality Score
Insurance Type
Stafford (1990) | Good | NA | Good | Good | NA | NA | NA | Good | GOOD
Stafford (1991) | Good | NA | NA | Good | NA | NA | NA | Good | GOOD
King (1994) | Good | NA | Good | Good | NA | NA | NA | Good | GOOD
Gregory (1999) | Good | NA | Good | Good | NA | NA | NA | Fair | FAIR
Santerre (1996) | Fair | NA | Good | Good | NA | NA | NA | Good | FAIR
Oleske (1998) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Rageth (1999) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Wagner (1999) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Placek (1988A) | Poor | NA | Good | Fair | NA | NA | NA | Poor | POOR
Skelton (1997) | Good | NA | Good | Good | NA | NA | NA | Poor | POOR
Curtin (1997) | Poor | NA | Fair | Fair | Good | NA | NA | Poor | POOR
Miller (1992) | Fair | NA | Fair | Good | Good | NA | NA | Poor | POOR
Physician Charactreristics
Davis (1994) | Poor | NA | Fair | Good | NA | NA | NA | Poor | POOR
Barnsley (1990) | Poor | NA | Poor | Fair | NA | NA | NA | Poor | POOR
Coco (2000) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Deutchman (1995) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Hueston (1995) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Miller (1995) | NA | NA | NA | Good | NA | NA | NA | Poor | POOR
Sinusas (2000) | Poor | NA | NA | Good | NA | NA | NA | Poor | POOR
Stone (1996) | NA | NA | NA | Fair | NA | NA | NA | Poor | POOR
Berkowitz (1989) | Poor | NA | Adequate | Good | NA | NA | NA | Poor | POOR
Harrington (1997) | Fair | NA | Good | Good | NA | NA | NA | Poor | POOR
Hueston (1994) | NA | NA | NA | Fair | Good | NA | NA | Poor | POOR
Hospital Characteristics
Gregory (1999) | Good | NA | Good | Good | NA | NA | NA | Good | GOOD
Santerre (1996) | Fair | NA | Good | Good | NA | NA | NA | Good | FAIR
McMahon (1996) | Good | NA | Good | Good | NA | NA | NA | Good | GOOD
King (1994) | Good | NA | Good | Good | NA | NA | NA | Good | GOOD
Stafford (1991) | Good | NA | NA | Good | NA | NA | NA | Good | GOOD
Barnsley (1990) | Poor | NA | Poor | Fair | NA | NA | NA | Poor | POOR
Shiono (1987) | Fair | NA | NA | Good | NA | NA | NA | Fair | FAIR
Whitsel (2000) | Good | NA | NA | Good | NA | NA | NA | Poor | POOR
Gregory (1999) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Mor-Yosef (1990) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Skelton (1997) | Good | NA | Good | Good | NA | NA | NA | Poor | POOR
Paterson (1991) | Good | NA | Good | Good | Good | NA | NA | Poor | POOR
Curtin (1997) | Poor | NA | Fair | Fair | Good | NA | NA | Poor | POOR
Sieck (1997) | Poor | NA | Good | Fair | Good | Poor | NA | Poor | POOR
Placek (1988A) | Poor | NA | Good | Fair | NA | NA | NA | Poor | POOR
Legal Factors
King (1994) | Good | NA | Good | Good | NA | NA | NA | Good | GOOD
Studnicki (1997) | Good | NA | Good | Good | NA | NA | NA | Good | GOOD
Guidelines
Santerre (1996) | Fair | NA | Good | Good | NA | NA | NA | Good | FAIR
Lomas (1989) | Fair | NA | Good | Good | NA | NA | NA | Fair | FAIR
Myers (1993) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Sanchez-Ramos (1990) | Poor | NA | Good | Good | NA | NA | NA | Poor | POOR
Myers (1988) | Poor | NA | Adequate | Good | NA | NA | Adequate | Poor | Poor
Porreco (1985) | Poor | NA | Adequate | Good | NA | NA | Adequate | Poor | POOR