# Appendix D. Search Strategies: All Topics

## VBAC Success/Maternal and Infant Outcomes

### Spontaneous Labor

Databases: MEDLINE (1980-April 2002), HealthSTAR (1980-April 2002)

1. Vaginal birth after cesarean/ or “vaginal birth after cesarean”.mp.
2. (trial of labor or trial of labour or trial of scar$).mp.
3. Delivery/ or Episiotomy/ or Extraction, obstetrical/ or Home childbirth/ or Labor, induced/ or Natural childbirth/ or Version, fetal/
4. (vaginal birth or vaginal delivery or uterine rupture).mp.[mp=title, abstract, registry number word, mesh subject heading]
5. exp Labor/
6. 2 or 3 or 4 or 5
7. exp cesarean section/ or “cesarean”.mp.
8. 6 and 7
9. 1 or 8
10. limit 9 to human
11. limit 10 to english
12. 10 not 11
13. limit 12 to abstracts
14. 11 or 13

### Elective Repeat Cesarean Section

Databases: MEDLINE (1980-April 2002), HealthSTAR (1980-April 2002)

1. Vaginal birth after cesarean/ or “vaginal birth after cesarean”.mp.
2. (trial of labor or trial of labour or trial of scar$).mp.
3. Delivery/ or Episiotomy/ or Extraction, obstetrical/ or Home childbirth/ or Labor, induced/ or Natural childbirth/ or Version, fetal/
4. (vaginal birth or vaginal delivery or uterine rupture).mp. [mp=title, abstract, registry number word, mesh subject heading]
5. exp Labor/
6. 2 or 3 or 4 or 5
7. exp cesarean section/ or “cesarean”.mp.
8. 6 and 7
9. 1 or 8
10. limit 9 to human
11. limit 10 to english language
12. 10 not 11
13. limit 12 to abstracts
14. 11 or 13
15. Risk factors/ or “risk factors”.mp.
16. exp ethnic groups/ or “ethnic groups”.mp.
17. exp demography/ or “demographics”.mp.
18. Midwifery/ or “midwife”.mp.
19. “NATUROPATH”.mp.
20. Family practice/ or “family practice”.mp.
21. Health maintenance organizations/ or “hmo”.mp.
22. exp prepaid health plans/ or “prepaid health plans”.mp.
23. Pregnancy outcome/
24. exp “Outcome assessment (health care)”/
25. Physicians, family/ or “family physician”.mp.
26. exp insurance/ or exp insurance, health/
27. Hospitals, rural/ or Rural health/ or Rural health services/ or Rural population/ or “rural”.mp.
28. Medical indigency/ or “medical indigency ”.mp.
29. Urban health/ or Urban population/ or “metropolitan”.mp.
30. exp hospitals, teaching/ or “teaching hospital”.mp.
31. Hospitals, community/ or “community hospital”.mp.
32. exp hospitals, public/ or “public hospital”.mp.
33. exp hospitals, private/ or “private hospital”.mp.
34. obstetric factor$.ti.
35. exp infant, low birth weight/ or “low birth weight”.mp.
36. Fetal weight/ or “fetal weight”.mp.
37. exp pregnancy, multiple/ or “multiple gestation”.mp.
38. exp labor presentation/ or “labor presentation”.mp.
39. Parity/ or “parity”.mp
40. 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25
41. 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39
42. 40 or 41
43. 14 and 42

### Induction and Augmentation

Databases: MEDLINE (1980-April 2002), EMBASE (1980-April 2002),

HealthSTAR (1980-April 2002)

1. exp labor, induced/ or “labor induction”.mp.
2. (labor and augment$).tw
3. 1 or 2
4. limit 3 to human
5. limit 4 to english language
6. 4 not 5
7. limit 6 to abstracts
8. 5 or 7

### Predictors

Databases: MEDLINE (1980-April 2002), HealthSTAR (1980-April 2002)

1. Vaginal birth after cesarean/ or “vaginal birth after cesarean”.mp.
2. (trial of labor or trial of labour or trial of scar$).mp.
3. Delivery/ or Episiotomy/ or Extraction, obstetrical/ or Home childbirth/ or Labor, induced/ or Natural childbirth/ or Version, fetal/
4. (vaginal birth or vaginal delivery or uterine rupture).mp. [mp=title, abstract, registry number word, mesh subject heading]
5. exp Labor/
6. 2 or 3 or 4 or 5
7. exp cesarean section/ or “cesarean”.mp.
8. 6 and 7
9. 1 or 8
10. limit 9 to human
11. limit 10 to english language
12. 10 not 11
13. limit 12 to abstracts
14. 11 or 13
15. exp risk assessment/ or “risk assessment”.mp.
16. exp probability/ or “probability”.mp.
17. Predictive value of tests/
18. previous vaginal delivery.mp.
19. Gestational age/ or “gestational age”.mp.
20. “SPONTANEOUS LABOR”.mp.
21. Birth weight/ or “birth weight”.mp.
22. Fetal weight/ or “fetal weight”.mp.
23. exp labor presentation/ or Oxytocin/ or “cervical dilation”.mp.
24. exp treatment outcome/ or Pregnancy outcome/ or “outcome”.mp.
25. Cesarean section, repeat/ or “repeat cesarean”.mp.
26. 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25
27. 14 and 26

### Patient Satisfaction, Health Status, and Patient Preference

Databases: MEDLINE (1980-April 2002), HealthSTAR (1980-April 2002)

1. Vaginal birth after cesarean/ or “vaginal birth after cesarean”.mp.
2. (trial of labor or trial of labour or trial of scar$).mp.
3. Delivery/ or Episiotomy/ or Extraction, obstetrical/ or Home childbirth/ or Labor, induced/ or Natural childbirth/ or Version, fetal/
4. (vaginal birth or vaginal delivery or uterine rupture).mp. [mp=title, abstract, registry number word, mesh subject heading]
5. exp Labor/
6. exp cesarean section/ or “cesarean”.mp.
7. 1 or 2 or 3 or 4 or 5 or 6
8. exp health status/ or “health status”.mp.
9. exp health status indicators/ or “health status indicators”.mp.
10. exp quality of life/ or “quality of life”.mp.
11. Patient satisfaction/ or “patient satisfaction”.mp.
12. 8 or 9 or 10 or 11
13. 7 and 12
14. limit 13 to human
15. limit 14 to english language
16. 14 not 15
17. limit 16 to abstracts
18. 15 or 17
19. exp MALPRACTICE/ or malpractice.mp.
20. exp Jurisprudence/ or litigation.mp.
21. lj.fs.
22. 19 or 20 or 21
23. 7 and 22
24. limit 23 to (human and english language)
25. 18 or 24
26. exp Depression, Postpartum/ or postpartum depression.mp.
27. 7 and 26
28. 27 not 25
29. limit 28 to (human and english language)
30. 25 or 29

### Economics/Cost

Databases: MEDLINE (1980-April 2002), HealthSTAR (1980-April 2002)

1. Vaginal birth after cesarean/ or “vaginal birth after cesarean”.mp.
2. VBAC.mp.
3. 1 or 2
4. ec.fs.
5. exp “costs and cost analysis"/
6. exp economics/
7. exp Insurance/
8. 4 or 5 or 6 or 7
9. 3 and 8
10. Vaginal birth after cesarean/ or “vaginal birth after cesarean”.mp.
11. (trial of labor or trial of labour or trial of scar$).mp.
12. Delivery/ or Episiotomy/ or Extraction, obstetrical/ or Home childbirth/ or Labor, induced/ or Natural childbirth/ or Version, fetal/
13. (vaginal birth or vaginal delivery or uterine rupture).mp. [mp=title, abstract, registry number word, mesh subject heading]
14. exp Labor/
15. 11 or 12 or 13 or 14
16. exp cesarean section/ or “cesarean”.mp.
17. 15 and 16
18. 10 or 17
19. limit 18 to human
20. limit 19 to english language
21. 19 not 20
22. limit 21 to abstracts
23. 20 or 22
24. 8 and 23

### Access

Databases: MEDLINE (1980-April 2002), HealthSTAR (1980-April 2002)

1. Vaginal birth after cesarean/ or “vaginal birth after cesarean”.mp.
2. VBAC.mp.
3. (trial of labor or trial of labour or trial of scar$).mp.
4. Delivery/ or Episiotomy/ or Extraction, obstetrical/ or Home childbirth/ or Labor, induced/ or Natural childbirth/ or Version, fetal/
5. (vaginal birth or vaginal delivery or uterine rupture).mp. [mp=title, abstract, cas registry/ec number word, mesh subject heading]
6. exp Labor/
7. 3 or 4 or 5 or 6
8. exp cesarean section/ or “cesarean”.mp.
9. 7 and 8
10. 1 or 2 or 9
11. exp Health Services Accessibility/
12. (access to healthcare or access to health care).mp.
13. exp HOSPITALS, RURAL/ or exp RURAL HEALTH SERVICES/
14. exp HOSPITALS, URBAN/ or exp URBAN HEALTH SERVICES/
15. Physicians, Family/ or family physicians.mp.
16. general practitioners.mp.
17. Midwifery/ or midwives.mp.
18. Length of Stay/
19. exp Clinical Competence/ or clinical competence.mp.
20. exp Utilization Review/
21. 19 and 20
22. exp *clinical competence/
23. 21 or 22
24. exp Physician's Practice Patterns/ or physician's practice patterns.mp.
25. 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24
26. 11 or 12 or 25
27. 10 and 26
28. limit 27 to (human and english language)

### Medicaid

Databases: MEDLINE (1980-April 2002), HealthSTAR (1980-April 2002)

1. Vaginal birth after cesarean/ or “vaginal birth after cesarean”.mp.
2. VBAC.mp.
3. (trial of labor or trial of labour or trial of scar$).mp.
4. Delivery/ or Episiotomy/ or Extraction, obstetrical/ or Home childbirth/ or Labor, induced/ or Natural childbirth/ or Version, fetal/
5. (vaginal birth or vaginal delivery or uterine rupture).mp. [mp=title, abstract, registry number word, mesh subject heading]
6. exp Labor/
7. 3 or 4 or 5 or 6
8. exp cesarean section/ or “cesarean”.mp.
9. 7 and 8
10. 1 or 2 or 9
11. exp MEDICAID/ or medicaid.mp.
12. 10 and 11
13. limit 12 to (human and english language)

### Laws

Databases: MEDLINE (1980-April 2002), HealthSTAR (1980-April 2002)

1. Vaginal birth after cesarean/ or “vaginal birth after cesarean”.mp.
2. VBAC.mp.
3. (trial of labor or trial of labour or trial of scar$).mp.
4. Delivery/ or Episiotomy/ or Extraction, obstetrical/ or Home childbirth/ or Labor, induced/ or Natural childbirth/ or Version, fetal/
5. (vaginal birth or vaginal delivery or uterine rupture).mp. [mp=title, abstract, registry number word, mesh subject heading]
6. exp Labor/
7. 3 or 4 or 5 or 6
8. exp cesarean section/ or “cesarean”.mp.
9. 7 and 8
10. 1 or 2 or 9
11. exp LEGISLATION/ or legislation.mp.
12. lj.fs. or law$1.mp.
13. 11 or 12
14. 10 and 13

### Guidelines

Databases: MEDLINE (1980-April 2002), HealthSTAR (1980-April 2002)

1. Vaginal birth after cesarean/ or “vaginal birth after cesarean”.mp.
2. VBAC.mp.
3. (trial of labor or trial of labour or trial of scar$).mp.
4. Delivery/ or Episiotomy/ or Extraction, obstetrical/ or Home childbirth/ or Labor, induced/ or Natural childbirth/ or Version, fetal/
5. (vaginal birth or vaginal delivery or uterine rupture).mp. [mp=title, abstract, registry number word, mesh subject heading]
6. exp Labor/
7. 3 or 4 or 5 or 6
8. exp cesarean section/ or “cesarean”.mp.
9. 7 and 8
10. 1 or 2 or 9
11. exp Practice Guidelines/ or practice guidelines.mp.
12. 10 and 11
13. limit 12 to english language