# Appendix C. Identifying Developed Countries

Our research team decided to include only studies that were conducted in developed countries. We used the definition of “developed country” taken from the CIA World Factbook 2001, Appendix B (Washington, DC: Central Intelligence Agency). According to this source, 35 countries are considered developed countries:

- Andorra
- Australia
- Austria
- Belgium
- Bermuda
- Canada
- Denmark
- Faroe Islands
- Finland
- France
- Germany
- Greece
- Holy See
- Iceland
- Ireland
- Israel
- Italy
- Japan
- Liechtenstein
- Luxembourg
- Malta
- Mexico
- Monaco
- Netherlands
- New Zealand
- Norway
- Portugal
- San Marino
- South Africa
- Spain
- Sweden
- Switzerland
- Turkey
- United Kingdom
- United States