# Appendix B. Procedures for Suspect or Missing Data

If there was a discrepancy between data in text and tables of the studies we reviewed, we followed the following protocol:

- If the correct data could be derived from other data within the study, we used these data.
- If the data could not be determined from within the study, a search of an ‘erratum’ in the literature was done to see if updated data were published. If this was determined, the investigator used the updated information and included the study. The investigator noted this in the evidence table of the specific topic.
- If the study data could not be determined using other study data or no ‘erratum’ information was available, the study was excluded. In summary of subtopics, investigators noted how many and which studies were excluded for this reason.

(In some cases, where no data was available for an entire subtopic, investigators contacted authors to determine correct study data. See individual subtopic methods for details on this procedure.)