# Appendix A. Project Personnel, Technical Panel, and Peer Reviewers

## OHSU Evidence Report Team, Portland Oregon

Principal Investigator

Jeanne-Marie Guise, MD, MPH

Assistant Professor of Obstetrics and Gynecology and of Medical Informatics and Outcomes Research

Oregon Health & Science University

EPC Director

Mark Helfand, MD, MPH

Associate Professor of Medicine and Medical Informatics & Outcomes Research

Oregon Health & Science University

Co-investigator

Michelle Berlin, MD, MPH

Associate Professor of Obstetrics and Gynecology and Medical Informatics and Outcomes Research

Oregon Health & Science University

Co-investigator

Karen Eden, PhD

Assistant Professor of Medical Informatics & Outcomes Research

Oregon Health & Science University

Co-investigator

Dale Kraemer, PhD

Assistant Professor of Medical Informatics & Outcomes Research

Oregon Health and Science University

Co-investigator

Marian McDonagh, PharmD

Clinical Research Pharmacist

Center for Health Research

Kaiser Permanente

Co-Investigator

Jason Hashima, BS

Division of Medical Informatics & Outcomes Research

Oregon Health & Science University

EPC Administrator

Kathryn Pyle Krages, AMLS, MA

Division of Medical Informatics & Outcomes Research

Oregon Health & Science University

Research Coordinator

Peggy Nygren, MA

Division of Medical Informatics & Outcomes Research

Oregon Health & Science University

Co-Coordinator

Patricia Osterweil, BS

Division of Medical Informatics & Outcomes Research

Oregon Health & Science University

Librarian

Patty Davies, MS

OHSU Library

Oregon Health & Science University

AHRQ Task Order Officer

Rosaly Correa-de-Araujo, MD, MSc, PhD

Center for Practice and Technology Assessment

Agency for Healthcare Research and Quality

Rockville, Maryland

## Partner Contacts

American Academy of Family Physicians (AAFP)

Eric Wall, MD, MPH

Clinical Associate Professor of Family Medicine, OHSU

Vice President and Regional Director, Lifewise and Blue Cross/Blue Shield of Alaska Medical Director

Portland, Oregon

American College of Obstetricians and Gynecologists (ACOG)

Jone Sampson, MD

Assistant Professor of Obstetrics and Gynecology/Genetics

Oregon Health & Science University

Portland, Oregon

## Technical Expert Panel

Resident Training Perspective

Paul Kirk, MD

Professor of Obstetrics and Gynecology

Oregon Health & Science University

Portland, Oregon

Insurance Perspective

David Labby, MD

Associate Medical Director for CareOregon and Assistant Professor of Medicine and Family Medicine

Oregon Health & Science University

Portland, Oregon

Midwifery Perspective

Polly Malby, NP, CNM

Assistant Professor of Family Nursing

Department of Family Nursing

Oregon Health & Science University

Portland, Oregon

Rural Medicine Perspective

Michelle Petrofes, MD

Physician and Partner

Dunes Family Health Care

Reedsport, Oregon

Patient Perspective

Diana Blaser

Vancouver, Washington

Patient Perspective

Alison Wetchler

Vancouver, Washington

## Peer Reviewers

### Content Experts

William Phillips, MD

Clinical Professor of Family Medicine

University of Washington

Seattle, Washington

Deborah Wing, MD

Women's and Children's Hospital

University of Southern California

Los Angeles, California

Nancy Sullivan, CNM

Assistant Professor

Oregon Health & Science University

Portland, Oregon

Martin T. November, MD, MBA

Instructor of Obstetrics, Gynecology and Reproductive Biology

Harvard Medical School

Boston, Massachusetts

William A. Grobman, MD

Assistant Professor of Maternal-Fetal Medicine

Northwestern University

Chicago, Illinois

Sally Morton, PhD

RAND Chair in Statistics

RAND

Santa Monica, California

Evan Myers, MD

Assistant Professor of Obstetrics and Gynecology

Duke University Medical Center

Durham, North Carolina

### Professional Societies

Joint Commission on Accreditation of Healthcare Organizations (JCAHO) Representative:

Jerod M. Loeb, PhD

Vice President for Research & Performance Measurement

Oakbrook Terrace, Illinois

American College of Obstetricians and Gynecologists (ACOG) Representatives:

Benjamin Sachs, MD

Professor of Obstetrics, Gynecology and Reproductive Biology

Harvard Medical School

Department of Maternal and Child Health

Beth Israel Hospital

Boston, Massachusetts

Stanley Zinberg, MD

Vice President of Clinical Practice

ACOG

Washington, DC

American College of Nurse-Midwives Representative:

Ann Trudell, CNM

Lecturer-Nurse-Midwife

University of California, Los Angeles

Los Angeles, California

American Academy of Family Physicians (AAFP) Representative:

Richard Roberts, MD, JD

Belleville Family Medical Clinic

Belleville, Wisconsin

Society for Healthcare Consumer Advocacy Representatives:

Laura McHenry

Director, Patient Relations

Potomac Hospital

Woodbridge, Virginia

Jerri Scarzella

Director, Customer Relations

Holy Cross Hospital

Silver Spring, Maryland

American Academy of Pediatrics (AAP) Representatives:

William Kanto, MD

Augusta, Georgia

Anne Stark, MD

Up-To-Date

Wellesley, Massachusetts

### Federal Reviewer

David Atkins, MD, MPH

Chief Medical Officer

Center for Practice and Technology Assessment

Agency for Healthcare Research and Quality

Rockville, Maryland