# Appendixes

Appendix A. Project Personnel, Technical Panel, and Peer Reviewers

Appendix B. Procedures for Suspect or Missing Data

Appendix C. Identifying Developed Countries

Appendix D. Search Strategies: All Topics

Appendix E. Studies Excluded at the Data Abstraction Phase by Topic and Reason

Appendix F. Criteria for Grading in the Internal Validity of Individual Studies

Appendix G. Uterine Rupture Terminology Conference: September 5, 2002