# Evidence Tables

Evidence Table 1. Studies Evaluating Association of LBW and Multiple Outcomes: CNS, Lung, Griwth, etc. Part I

Author, Year UI# | Demographics | Inclusion Criteria | Exclusion Criteria | Disease/Condition Type (N) | Study Design (Duration)
Akermann 1992 93255928 | Location: Sweden | ND | ND | Low born twins (68, or 34 pairs) | Prospective longitudinal cohort (at 9, 18 months, and 4 years)
| Years of Birth: ND | (35 parents who were expecting twins) | (One child in a twin pair was stillborn)
| Median GA (range), wk: 7 pairs < 37 wks
| Median BW (range), g: 37 < 2500 g (23 of these > 37 wks)
| Male: 46%
| Race: ND
| Enrolled: 35 parents who were expecting twins
| Evaluated: 68 (34 twin pairs)
| Number of sites: 1
Thompson 1993 93234177 | Location: South African | BW <1250 g ventilated infants | Infants <900g and <28week are not routinely ventilated | VLBW ventilated infants (143) | Prospective cohort (2 years)
| Years of Birth: 1988 to 1989 | Survived to hospital discharge
| Mean GA (range), wk: 32±2.5 (26.8–40)
| Mean BW (range), g: 1044±149 (600–1250)
| Male: 50%
| Race: ND
| Enrolled: 143
| Evaluated: 143
| Number of sites: 1
Rademaker 1994 95003452 | Location: Netherlands | GA = 32 weeks | ND | Preterm infants (GA 32 weeks or less) with diagnosis of unilateral parenchymal involvement (20) | Prospective cohort
| Years of Birth: 9/1989–9/1992 | Unilateral parenchymal involvement on cranial ultrasound associated with GLH Germinal layer hemorrhage or IVH
| Mean GA (range), wk: 25–32
| Mean BW (range), g: 820–2200
| Male: 70%
| Race: ND
| Enrolled: 20
| Evaluated: 20
| Number of sites: 1
Vonderveid 1994 94297368 | Location: Italy | All newborns with BW: 500–1500 g BW | ND | Sample 1: | Prospective cohort study (24 mo CA)
| Years of Birth: 1987-1988 | Admitted in one of the 8 participating NICUs | | VLBW (500–1000 g): (191)
| Mean GA: ND | Born between 1/1987–12/1988 | | Sample 2:
| Mean BW : ND (only range: 500–1499 g) | | | LBW (1000–1499f): (443)
| Male: ND
| Race: ND
| Enrolled: 634
| Evaluated: 390 (alive at 2 yrs)
| Number of sites: 8
Kraybill 1995 95264242 | Location: USA | Premature VLBW: 700–1350 g (Detailed description available in another article) | ND | At 1 yr f/up | Randomized placebo-controlled double blind trial (at 1 year and at 2 years CA)
| Years of Birth: 1986-1989 | | | Sample 1:
| Sample with F/up at 1 year | | | Synthetic Surfactant at Birth via ET tube: 5 ml/kg (136)
| Mean GA: | | | Sample 2:
| Sample 1: 28.2±1.9 | | | Air placebo via ET tube at birth (122)
| Sample 2: 28.1±2.0 | | | At 2 yr F/up
| Mean BW: | | | Sample 1:
| Sample 1: 1022±177 | | | Synthetic surfactant at birth (57)
| Sample 2: 1028 ±184 | | | Sample 2:
| Male: | | | Air placebo (61)
| Sample 1: 51% Sample 2: 52%
| Race:
| Sample 1: White: 21%, Black: 53%, Hispanic: 23%, Other; 4%
| Sample 2: White: 34%, Black: 42%, Hispanic: 22%, Other: 2%
| Enrolled: 323 (survivors at 1 yr)
| Evaluated: 258 (at 1 yr f/up)
| Sample with F/up at 2 years
| Mean GA:Sample 1: 28.3±1.8
| Sample 2: 28.1±1.8
| Mean BW: Sample 1: 1043 ±165
| Sample 2: 1005 ±184
| Male:
| Sample 1: 49% Sample 2: 43%
| Race:
| Sample 1: White: 35%, Black: 60%, Other:5%
| Sample 2: White: 43%, Black: 54%, Other: 3%
| Enrolled: 136 (survivors at 2 yrs)
| Evaluated: 118
| Number of sites: 2
Speechley 1995 96356544 | Location: Canada | All infants born at a tertiary care hospital in Ontario | Family residence more than 120 Km from hospital | Sample 1: | Prospective, longitudinal, comparative, observational study (12 yrs)
| Years of Birth: 1978-1980 | Born between 1978-1980 | Newborn's survival was in question | Former NICU graduates: [116]
| Mean GA: | Transferred to NICU or Normal Neonatal Nursery (NNN) | Language barrier | Sample 2:
| Sample 1: 37 (28–43) | | Refused to participate to the original RCT. | Former NNN graduates [137]
| Sample 2: 40 (37–44)
| Mean BW:
| Sample 1: 2790 (850–4550)
| Sample 2: 3503 (2660–5170)
| Male:
| Sample 1: 56%
| Sample 2: 50%
| Race:
| Sample 1: whites : 90%
| Sample 2: whites: 90%
| (Original study: was a randomized interventional study of having a family volunteer visit the home on a regular base for 6 months)
| Eligible (for the original study): 828
| Enrolled (for the original RCT): 312
| Evaluated (at 12 yrs): 253
| Number of sites: 1
Hack 1996 97060805 | Location: US | VLBW infants, BW <1500gm, survived to 2 years of age | ND | VLBW infants (249) | Prospective cohort (8 years)
| Years of Birth: 1/1977 to 12/1979 | NBW: randomly selected NBW children (the selection method was described in the prior papers) | | Sample 1: AGA (199)
| Mean GA (range), wk: 30±2 | | | Sample 2: SGA (50)
| Mean BW (range), g: 1177±218 | | | NBW infants: (363)
| Male: ND
| Race: Mother black race 56%
| Enrolled: 249
| Evaluated: 249 (363 controls)
| Number of sites: 1
Hack 1996 97066007 | Location: US | BW 500–759 g | ND | Sample 1: VLBW survived infants born in 1990-1992 (surfactant/dex era) (114) | Prospective cohort (followed to 20 months corrected age)
| Years of Birth: 7/1982–6/1988, 1/1990–12/1992 | Survived to 20 months corrected | | Sample 2: VLBW survived infants born in 1982-1988 (surfactant and less dex. era) (166)
| Mean GA (range), wk: | Age
| Sample 1: 25.9±2 (22–31)
| Sample 1: 25.7±2 (22–31)
| Mean BW (range), g:
| Sample 1: 688.6±73 (560–740)
| Sample 2: 670.6±56 (502–742)
| Male:
| Sample 1: 28%
| Sample 2: 29%
| Race: White
| Sample 1: 31%
| Sample 2: 37%
| Enrolled: 280
| Evaluated: 280
| Number of sites: 1
Northern Neonatal Nursing Initiative Trial Group 1996 96304894 | Location: UK | GA <32 weeks; resident in northern UK | ND | Experiment 1: fresh frozen plasma treatment (257) | Randomized controlled trial (2 years)
| Years of Birth: 1990-1992 | | | Experiment 2: gelatin plasma substitute (261)
| Mean GA (range), wk: 29 (27–31) | | | Glucose controls (258)
| Mean BW (range), g: 1253 (965–1543)
| Male: 39%
| Race: ND
| Enrolled: 776
| Evaluated: 776
| Number of sites: 16
Sethi 1996 96334245 | Location: UK | Liveborn infants BW <1501 g | ND | VLBW infants 92 | Prospective cohort (2 years)
| Years of Birth: 1989-1992 | Survived until discharged
| Mean GA (range), wk: ND
| Mean BW (range), g: ND
| Male: ND
| Race: ND
| SES: ND
| Enrolled: 93
| Evaluated: 92
| Number of sites: 1
Wilkinson 1996 97087405 | Location: Australia | All NICU admissions <35 weeks GA or BW<1500g who had cranial US with cystic PVL | ND | VLBW preterm infants (10) | Retrospective cohort
| Years of Birth: 1/1989–12/1991
| Mean GA (range), wk: 27.7 (23–34)
| Mean BW (range), g: 1144 (700–1725)
| Male: 50%
| Race: ND
| Enrolled: 12
| Evaluated: 10
| Number of sites: 1
DeReginer 1997 98041177 | Location: US | BW = 1500 g survived until Discharged | Presence of LBW independent of chronic lung disease known to adversely affect neurodevelopment, sensory, or growth, i.e. severe intracranial abnormalities, congenital anomalies or viral infections, etc. | Sample 1: | Retrospective chart review with marched subject group (1 year of adjusted age)
| Years of Birth: 1987-1991 | Able to match to a patient in other two respiratory groups | Unable to match to a patient in other groups | No chronic lung disease (58)
| Mean GA (range), wk: | | Died after discharged (6) | Sample 2:
| Sample 1: 28.0±1.5 | | Lost to follow-up (4) | Mild chronic lung disease (58)
| Sample 2: 27.1±1.2 | | | Sample 3:
| Sample 3: 27.5±1.7 | | | Severe chronic lung disease (58)
| Mean BW (range), g:
| Sample 1: 1030±140
| Sample 2: 1007±122
| Sample 3: 1007±140
| Male: ND
| Race: ND
| Enrolled: 174
| Evaluated: 164
| Number of sites: 2
Dezoete 1997 97359687 | Location: New Zealand | BW<1000g and survived to hospital discharge. | Died after discharge | VLBW infants (105) | Prospective cohort (18 months)
| Years of Birth: 1990-1992 | | Congenital malformations
| Mean GA (range), wk: 26.7±1.9 | | Lost to follow-up
| Mean BW (range), g: 834.6±120.0
| Male: 51%
| Race: European 63%, Maori 20%,
| Other 22%
| SGA: 32%
| Enrolled: 110
| Evaluated: 105
| Number of sites: 1
O'Shea 1997 98049056 | Location: US | BW 501–800g | ND | Sample 1: VLBW infants born between 7/1/1979 and 6/30/1984 (120 ? 24) | Retrospective cohort (1 year corrected age)
*overlapped sample with 98190123 | Years of Birth: 1979-1994 | Born to mother's residing in 17 countries in NW N.Carolina | | Sample 2: VLBW infants born between 7/1/1984 and 6/30/1989 (175 ? 63)
| Mean GA (range), wk: | Survived to 1 year of age | | Sample 3: VLBW infants born between 7/1/1984 and 6/30/1994 (218 ? 129)
| Sample 1: 25 (22–31)
| Sample 2: 25 (22–30)
| Sample 3: 25 (22–29)
| Mean BW (range), g:
| Sample 1: 673 (522–790)
| Sample 2: 670 (527–800)
| Sample 3: 688 (520–793)
| Male:
| Sample 1: 49%
| Sample 2: 51%
| Sample 3: 48%
| Race: White
| Sample 1: 61%
| Sample 2: 60%
| Sample 3: 56%
| Enrolled: 513
| Evaluated: 513 ? 216 (1 year of age)
| Number of sites: 2
Piecuch 1997 97456215 | Location: US | BW<1000g | Genetic diagnosis | Sample 1: BW 500–599 (15) | Prospective cohort (1 year)
| Years of Birth: 1979-1991 | Discharged from Mt. Zion Hospital + M.C. & UCSF | {Died after discharge (14) Lost to follow-up (58) Late genetic diagnosis (1)} | Sample 2: BW 600–699 (38)
| Median GA (range), wk: | | | Sample 3: BW 700–799 (92)
| Sample 1: 25.9±1.5 (24–29) | | | Sample 4: BW 800–899 (135)
| Sample 2: 25.8±1.6 (24–32) | | | Sample 5: BW 900–999 (165)
| Sample 3: 26.3±1.5 (24–32)
| Sample 4: 27.1±1.4 (24–34)
| Sample 5: 27.8±1.7 (25–35)
| Mean BW (range), g:
| Sample 1: 560±28
| Sample 2: 653±28
| Sample 3: 747±29
| Sample 4: 850±29
| Sample 5: 942±30
| Male:
| Sample 1: 25%
| Sample 2: 24%
| Sample 3: 48%
| Sample 4: 47%
| Sample 5: 48%
| Race: ND
| Enrolled: 518
| Evaluated: 445
| Number of sites: 2
Piecuch 1997 98012134 | Location: US | 24, 25 or 26 week GA | ND | Sample 1: GA 24 weeks (18) | Prospective cohort (at 12months, 18 months, 2 ½ years, 4 ½ years. 7–8 years)
| Years of Birth: 1990-1994 | Non-anomalous | (Died after discharge (2) Accidental severe central nervous system insult after discharge (1) Lost to follow-up (5)} | Sample 2: GA 25 weeks (30)
| Mean GA (range), wk: | Born at University of California, San Francisco | | Sample 3: GA 26 weeks (38)
| Sample 1: 24
| Sample 2: 25
| Sample 3: 26
| Mean BW (range), g:
| Sample 1: 668±91 (450–850)
| Sample 2: 790±115 (550–1000)
| Sample 3: 842pulsmn;158 (505–1260)
| Male:
| Sample 1: 50%
| Sample 2: 73%
| Sample 3: 50%
| Race: ND
| SES: high social risk
| Sample 1: 89%
| Sample 2: 43%
| Sample 3: 68%
| Enrolled: 94
| Evaluated: 86
| Number of sites: 1
Singer 1997 98049057 | Location: US | Cases (sample 1&2): premature infants, BW < 1500g | Major congenital abnormality | Sample 1: VLBW infants with BPD infants (122) | Prospective cohort (followed to 3 years corrected age)
Singer 2001 21163669 | Years of Birth: 1989-1991 | Controls: term infants with no diagnosed medical illness or abnormalities at birth, >36 weeks, GW>2500g | Drug exposure | Sample 2: VLBW without BPD (84)
| Mean GA (range), wk: | | Maternal illness | Sample 3: Full term infants (123)
| Sample 1: 27±2 | | HIV
| Sample 2: 30±2 | | Maternal mental retardation >2 hours driving time from hospital
| Controls: 40±2
| Mean BW (range), g:
| Sample 1: 956±248
| Sample 2: 1252±178
| Controls: 3451±526
| Male:
| Sample 1: 52%
| Sample 2: 43%
| Controls: 50%
| Race: White
| Sample 1: 55%
| Sample 2: 48%
| Controls: 51%
| SES: Hollingshed classification:
| Sample 1: 3.5±1
| Sample 2: 3.6±1
| Controls: 3.6±1
| Enrolled: 464
| Evaluated: 206 (123 controls)
| Number of sites: 3
Victorian Infant Collaborative study Group, 1997 98026322 | Location: Australia | ELBW infant (Sample 1–3ts, BW | Excluded infants born in 1979-1980 for current review | ELBW infants (448): | Retrospective cohort (2 years)
*This study is also in CNS table | Years of Birth:1979-80, 1985-87, 1991-92 | 500–999 g born in Victoria, Australia survived to age of 2 years | | Sample 1: born in 1985-1987 (212)
| Mean GA (range), wk: ND | Controls: | | Sample 2: born in 1991-1992 (241)
| Mean BW (range), g: ND | Normal birth weight (>2499 g) infants born in 1991-1992 | | Controls: Normal BW (>2499 g) infants (242)
| Male: ND
| Race: ND
| Enrolled: 453 (242 controls)
| Evaluated: 448 (242)
| Number of sites: 3
Victorian Infant Collaborative study Group, 1997 97466059 | Location: Australia | ELBW infants, BW 500–999 g born outside the level III perinatal centers in Victoria, Australia survived to age of 2 years | Excluded infants born in 1979-1980 for current review | ELBW infants (36): | Retrospective cohort (2 years)
| Years of Birth: 1979-80, 1985-87, 1991-92 | | | Sample 1: born in 1985-1987 (19)
| Mean GA (range), wk: ND | | | Sample 2: born in 1991-1992 (16)
| Mean BW (range), g: ND
| Male: ND
| Race: ND
| Enrolled: 36
| Evaluated: 35
| Number of sites: 3
Cheung 1998 99059896 | Location: Canada | VLBW survivors, BW < 1500 g, Requiring inhaled nitrous oxide (INO) (continues to be hypoxenic) at >90% O_2_ and MAP 15 ± 2) | Mosaic trisomy 18 | VLBW infants treated with INO (10) | Prospective cohort
| Years of Birth: 12/93–10/97 | | Potter's syndrome
| Mean GA (range), wk: 25 (24–30) | | Survived to 1 year of chronological age
| Median BW (range), g: 860 (340–1460)
| Male: 67%
| Race: ND
| Enrolled: 24
| Evaluated: 10
| Number of sites: 1
Finnström 1998 99041345 | Location: Sweden | BW = 1000 g and GA = 23 weeks | ND | Preterm infants (362) | Prospective cohort of a previously published study (followed to the median corrected age of 36 months)
| Years of Birth: 1990-1992 | Survived to the age of 1 year
| Mean GA (range), wk: ND
| Mean BW (range), g: 798±144
| Male: ND
| Race: ND
| Enrolled: 370
| Evaluated: 362
| Number of sites: ND
Gregoire 1998 98232532 | Location: Canada | Inborn infants GA 24–28 weeks, Admitted to NICU | ND | Sample 1: BPD-1 group - preterm infants who received O_2_ at 28 days but not at 396 weeks' GA (48) | Prospective cohort (18.5±1.1 months )
| Years of Birth: 1987-1992 | | | Sample 2: BPD-2 group - preterm infants with oxygen dependency at 36 weeks' GA (93)
| Mean GA (range), wk: | Survival to 18months CA | | Comparison: preterm infants who were not oxygen-dependent at 28 days of age (76)
| Sample 1: 27.3±1.1
| Sample 2: 26.8±1.3
| Comparison: 27.9±0.8
| Mean BW (range), g:
| Sample 1: 997±195
| Sample 2: 930±178
| Comparison: 1129±181
| Male:
| Sample 1: 45%
| Sample 2: 56%
| Comparison: 45%
| Race: ND
| Enrolled: 217
| Evaluated: 217
| Number of sites: 1
Kurkinen-Raty 1998 98387235 | Location: Finland | Preterm PROM between 17–30 weeks gestation; singleton; delivered > 2 hr after rupture | Rupture unconfirmed or transient | Sample 2: Preterm rupture (78) | Retrospective cohort
(All+Lung) | Years of Birth: 1990-1996 | Controls: preterm no PROM; spontaneous preterm delivery matched for GA and year of delivery. | | Sample 2: Preterm delivery no rupture (78)
*sample from the same big population as 20284814 | Mean GA (range), wk:
| Cases: 28.2 (23.8– 37.2)
| Controls: 28.4 (22.9–36.9)
| Mean BW (range), g:
| Cases: 1138.3±434
| Controls: 1272.4±547.2
| Male: ND
| Race: ND
| Enrolled: 78 (78 controls)
| Evaluated: 78 (78)
| Number of sites: 1
Lee 1998 98442293 | Location: Canada | For cases: | Neonates with major congenital anomalies | Sample 1: | Retrospective longitudinal comparative study with case control design and cases defined based on exposure to candidemia
| Years of Birth: 1990-1995 | Prematures with BW<1250 g | | Premature infants <1250 with candidemia and/ or candida meningitis (25) | and matched controls (f/up between 37 and 70 mo CA)
| Mean GA: ND | Admitted in the NICU s of UAH and RAH from 1990-1995 | | Sample 2: | Average age at assessment: for cases :31 ±19 mo, and for controls: 28 ±20 mo
| Mean BW: | Diagnosis of candidemia: by at least one positive blood culture | | Premature neonates with BW <1250 matched with cases for BW, GA, sex and admission dates, without candidal infection (25)
| Sample 1: 763 ±157 | Diagnosis of candidal meningitis:
| Sample 2: 807±176 | By isolation of candida in the CSF or >45×10^6^ WBCs in the CSF and candidemia.
| Male: ND | For controls:
| Race: ND | Prematures with BW <1250 g
| Enrolled: ND (total N not given, data only for enrolled cases with candidemia: N= 29) | Admitted to the same NICUs during the same period without candidal infection
| Evaluated: 50
| Assessed for outcome: 35 (14 cases and 21 controls)
| Number of sites: 2
Lefebvre 1998 98387703 | Location: Canada | GA<28 weeks | ND | Preterm infants (121): | Prospective cohort (CA 18.6±1.2 [17–19] months)
| Years of Birth: 1987-1992 | 3 or more cranial ultrasounds | | Low risk (50)
| Mean GA (range), wk: 27.0±1.2 | Survival to discharge | | Moderate risk (37)
| Mean BW (range), g: 961±179 (585–1450) | | | High risk (34)
| Male: 52%
| Race: ND
| Enrolled: 139
| Evaluated: 121
| Number of sites: 1
Millet 1998 98212544 | Location: France | Neonates considered at risk of neurologic impairment | Severe neurologic abnormalities (HIE, PVL, brain malformations and congruental infections) | Premature infants (40) | Prospective cohort (3–6 months correlated age)
| Years of Birth: ND | | | Term infants (20)
| Mean GA (range), wk: 31±3 (25–36)
| Mean BW (range), g: 1243±400
| Male: 75%
| Race: ND
| Enrolled: 60
| Evaluated: 40 (20 controls)
| Number of sites: 1
Piecuch 1998 98446413 | Location: USA | Prematurity | Congenital anomalies | Comparison of the outcome of infants 1000–1499 g born in three time periods: | (Not clearly stated)
| Years of Birth: | BW: 1000–1499 g | | Most recently born | Retrospective longitudinal comparative cohort study
| Sample 1: 1989-1991 | Discharged from NICUs of 5 Hospitals | | Born at a middle period | Age for outcome assessment was not specified. It could be done up to 7.5–8 yrs of age
| Sample 2: 1984-1986 | Born in one of the three time periods: | | Born at an early period | (Mean ages of f/up were: 24, 54, 75 mo for the 3 periods)
| Sample 3: 1979-1981 | 1989-1991 (Recent) | | Sample 1:
| Mean GA: | 1984-1986 (Middle) | | Born most recently, between 1989-1991 (186)
| Sample 1: 29 ±2 | 1979-1981 (Early) | | Sample 2:
| Sample 2: 30 ±2 | | | Born in a middle period, between: 1984-1986 (155)
| Sample 3: 30 ±2 | | | Sample 3:
| Mean BW: | | | Born in an early period, between 1979-1981 (109)
| Sample 1: 1221 ±142
| Sample 2: 1235 ±140
| Sample 3: 1246 ±146
| Male:
| Sample 1: 56%
| Sample 2: 50%
| Sample 3: 46%
| Race: ND
| Enrolled: 563
| Evaluated: 450
| Number of sites: 4
Sajaniemi 1998 99041674 | Location: Finland | For Preterm Group (sample 1): | For Preterm group | Sample 1: | Retrospective comparative study (24 mo CA)
| Years of Birth: 1989-1991 | GA: 23–34 wks | If mothers had chorioamnionitis | Preterm infants (80)
| Mean GA: | Mother being referred to University Central Hospital of Helsinki for threatened preterm delivery | If mother had insulin dependent diabetes | Sample 2
| Sample 1: 28.9 (23–35) | Born between 1989-1991 | Children with congenital anomalies, by U/S | Full term enrolled at: 20–28 mo of age (80)
| Sample 2: 39.4 (36–43) | For Full term group (Sample 2): | For Full term group
| Mean BW: | Born in Metropolitan Helsinki Visiting pediatric services in Helsinki for acute infectious diseases | Chronic diseases
| Sample 1: 1205 (560–2360) | | Developmental delay
| Sample 2: 3461 (2510–5360)
| Male: ND
| Race: ND
| Enrolled: ND
| Evaluated : 160
| Number of sites: 1
Scherjon 1998 98429216 | Location: Netherlands | Pregnant mother admitted to Obstetric Department of Amsterdam university with threatened preterm delivery GA < 33 wks. | Pregnancies with known congenital or chromosomal anomalies | Infants born prematurely between 26–33 wks (96) | Prospective observational cohort study (3 yrs CA)
| Years of Birth: 1989 | Admitted during a 10 month period in 1989
| Mean GA: ND [median and range given: 30.4 (26.1–32.8)]
| Mean BW: ND [median and range given: 1295 (605–2295)]
| Male: ND
| Race: ND
| Enrolled: 106
| Evaluated: 96 (at 3 yrs)
| Number of sites: 1
Cheung 1999 99146391 | Location: Canada | BW<1250 gm | Major congenital abnormalities, syndromes | Sample 1: | Prospective cohort (followed to 24 months adjusted age)
| Years of Birth: 1990-1993 | GA < 32 weeks | Infants with neurologic insult after discharge from NICU. | BW 500–749 g (26)
| Mean GA (range), wk: | Mild or no significant respiratory disease (O_2_ < 30%, RR < 70) | | Sample 2:
| Sample 1: 25 (22–29) | | | BW 750–999 g (63)
| Sample 2: 26 (24–30) | | | Sample 3:
| Sample 3: 28 (23–32) | | | BW 1000–1249 g (75)
| Mean BW (range), g:
| Sample 1: 660±56
| Sample 2: 873±73
| Sample 3: 1127±71
| Male: total 57%
| Race: ND
| Enrolled: 187
| Evaluated: 164
| Number of sites: 2
Duvanel 1999 99207097 | Location: Switzerland | Prematurity (< 34 weeks GA) | Major malformations | Sample 1 | Retrospective longitudinal cohort study with case control design. Cases defined based on exposure.
| Years of Birth: 1982-1990 | SGA (BW < 10% percentile) | Metabolic diseases | Hypoglycemic (62) | Control group matched with cases (not specified for which parameters)
| Mean GA: | Cases: hypoglycemia: glucose level < 47 mg/dl | Periventricular leukomalacia | Sample 2:
| Sample 1: 31.9 ±2.1 | Controls-matched: (not specified for which parameters): blood glucose > 47 mg/dl | Grade IV cerebral hemorrhage | Euglycemic (23)
| Sample 2: 31.9 ±1.7 | | Psychiatric illness detected in follow up study
| Mean BW (range) | | Very low socioeconomic status
| Sample 1:1142 ±285
| Sample 2: 1186 ±229
| Male:
| Sample 1: 47%
| Sample 2: 57%
| Race: ND
| Enrolled: : ND
| Evaluated: 85
| Number of sites: 1
Pennefather, 1999 20002011 | Location: UK | All surviving children <32wk GA born in geographically deprived region in Northern UK | No examined at age 2 years old | Preterm infants (558) | Prospective cohort and retrospective review of patient records (2–3 years)
Pennefather, 2000 20217908 | Years of Birth: 1/1/90–12/31/91 | Survived to 2 years old
* This study is also in eye table | Mean GA (range), wk: ND
| Mean BW (range), g: ND
| Male: ND
| Race: ND
| Enrolled: 566
| Evaluated: 558
| Number of sites: ND
Ambalavanan 2000 21031370 | Location: US | ELBW infants, BW <1000 g | ND | ELBW infants (218) | Retrospective cohort (followed to 18 months of age)
| Years of Birth: 1/1990 to 12/1994
| Mean GA (range), wk: 26±2
| Mean BW (range), g: 829±123
| Male: 45%
| Race: African-American 66%
| Enrolled: 218
| Evaluated: 218
| Number of sites: 1
Cioni 2000 20150341 | Location: Italy | All premature newborns with brain lesions on HUS who have abnormal neurological exam at term who are enrolled in neonatal follow-up study | Severe ROP (≥ stage 3), major refraction problems, and optic nerve atrophy, and infants with “congenital diseases” | All premature newborns with brain lesions who have abnormal neuro-logical exam at term (29) | Prospective cohort (1 yr [8–16 months] and 3 years [30–47 months])
| Years of Birth: 1/1989 to 2/1994
| Mean GA (range), wk: 31±2.8 (24–36)
| Median BW (range), g: ND
| Male: ND
| Race: ND
| Enrolled: 29
| Evaluated: 29
| Number of sites: 1
Hack 2000 20358826 | Location: US | BW<1000g | Major congenital malformations | VLBW infants (221) | Prospective cohort
| Years of Birth: : 1/1/1992–2/31/1995
| Mean GA (range), wk: 26.4±1.8
| Mean BW (range), g: 813±125
| Male: 43%
| Race: ND
| Enrolled: 333
| Evaluated: 221
| Number of sites: 1
Jankov 2000 20188680 | Location: Canada | Infants = 750 g and GA = 20 weeks who received CPR in the delivery room | Charts were not available for review (5) | Sample 1: Resuscitated (198) | Retrospective cohort
| Years of Birth: 1990-1996 | | Major congenital abnormalities (4) | Sample 2: Non-resuscitated (71)
| Mean GA (range), wk: | | Those infants not intubated in the delivery room (3)
| Sample 1: 23 (20–28)
| Sample 2: 25 (23–33)
| Mean BW (range), g:
| Sample 1: 669 (400–750)
| Sample 2: 515 (255–745)
| Male:
| Sample 1: 51%
| Sample 2: 46%
| Race: ND
| Enrolled: 281
| Evaluated: 269
| Number of sites: 1
Kurkinen-Raty, 2000 20284814 | Location: Finland | Cesarean delivered singleton, GA 24–33 weeks | ND | Sample 1: Indicated preterm (i.e., preterm birth ‘indicated’ for maternal/fetal reasons)(103) | Retrospective cohort
*sample from the same big population as 98197235 | Years of Birth: 1990-1997 | Controls: spontaneous delivered singleton after regular contractions and/or preterm rupture of the membranes no more than 24 hrs before. The mothers were matched one-to-one by gestational age at delivery plu7s or mines 1 week. | | Sample 2: Spontaneous preterm delivery due to preterm labor (103)
| Mean GA (range), wk:
| Cases: 30.5±2.1
| Controls: 30.4±2.1
| Mean BW (range), g:
| Cases: 1294±469
| Controls: 1605±427
| Male: ND
| Race: ND
| Enrolled: 103 (103 controls)
| Evaluated: 103 (103)
| Number of sites: 1
Marlow 2000 20150342 | Location: UK | For sensorineural hearing loss (SNHL) group | ND | Sample 1: SNHL group [15] | Retrospective case control study with a longitudinal component (unclear if retrospective or prospective) (12 mo CA)
| Years of Birth: 1990-1994 | GA: <33 wks | | Sample 2: Control group [30]
| Mean GA: ND | Family resident of Greater Bristol area | | Matched with cases for sex, GA, admission dates in NICU
| (Median and Range) | Records at Hearing
| Sample 1: 28 (26–31) | Assessment Center of Royal Hospital for Sick children.
| Sample 2: 28 (26–31) | Born during 1990-1994
| Mean BW: ND | Diagnosis of SNHL of 50 dB
| (Median and range) | For control group:
| Sample 1: 960 (600–2914) | Matched controls 2:1 to cases
| Sample 2: 1026 (410–2814) | Admitted to the same NICUs as cases
| Male: ND | Matched for sex and GA and next and preceding matching children in the admission books of St Michael's and Sothmead hospitals
| Race: ND
| Enrolled : 27
| Evaluated: 15
| Number of sites: 1
Victorian Infant Collaborative study Group, 2000 20307288 | Location: Australia | BW<1000 or GA<28 consecutive births, survived to 5 years of age | ND | Preterm infants (120): | Non-randomized comparison trial (5 years)
*some subjects overlapped with Doyle, 2001 | Years of Birth: 1991-92 | | | Sample 1: infants treated with corticosteroids
| Mean GA (range), wk: | | | Sample 2: infants not treated with corticosteroids (226)
| Sample 1: 25.5±1.3
| Sample 2: 27.3±1.9
| Mean BW (range), g:
| Sample 1: 797±147
| Sample 2: 932±149
| Male:
| Sample 1: 61.2%
| Sample 2: 39.5%
| Race: ND
| Enrolled: 346
| Evaluated: 346
| Number of sites: 4
Wood 2000 20373840 | Location: UK and Ireland | GA 20–25 weeks survivors | ND | Preterm infants (283) | Prospective cohort (30 [28–40] months)
| Years of Birth: 1995-1996
| Mean GA (range), wk: 22–25
| Mean BW (range), g: ND
| Male: ND
| Race: ND
| Enrolled: 314
| Evaluated: 283
| Number of sites: 276
Doyle 2001 21326609 | Location: Australia | Cases: GA 23–27 weeks, survived to 2 and 5 years of age | ND | Sample 1: Preterm survivors (N= 401) | Prospective cohort (Doyle - 5 years; Victorian - 2 years)
Victorian Infant Collaborative study Group, 1997 97290716 | Years of Birth: 1991-92 | Controls: randomly selected contemporaneous normal birth weight controls (BW > 2499 g) | | Controls: Randomly selected contemporaneous normal birth weight controls (BW>2499 grams) (N=265)
J Paediatr Child Health | Mean GA (range), wk: 23–27
*some subjects were overlapped with 20307288 (stated in text) | Mean BW (range), g: ND
*possibly overlapped with 98026322 | Male: ND
| Race: ND
| Enrolled: 225
| Evaluated: 225 (265 controls)
| Number of sites: 1
Gaillard 2001 21221175 | Location: UK | Retrospective cohort : | If transferred from another hospital after first postnatal week (mostly surgical referrals) | Sample 1: Ventilated beyond 27 (but not 50) postnatal ds (56) | First component: Retrospective longitudinal cohort with case-control design and cases defined based on exposure (length of ventilation). Unmatched.(3 years)
| Years of Birth:1994-1996 | All infants born from 1/1/1994 to 12/31/1996 | If ventilated after 27 postnatal days after a surgical procedure requiring anesthesia | Sample 2: Ventilated beyond 49ds (28) | Second component: Retrospective longitudinal cohort study With two historical control groups (3 years)
| Mean GA: ND | Born at Liverpool Women's Hospital
| (only median and range given) | Ventilated beyond 27 postnatal days
| Sample 1: 26 (23–34)
| Sample 2: 26 (23–33)
| Mean BW: ND
| (only median and range given)
| Sample 1: 852 (520–2710)
| Sample 2: 745 (580–1620)
| Male:
| Sample 1: 57%
| Sample 2: 50%
| Race: ND
| Enrolled: 100
| Evaluated: 84
| Number of sites: 1
Roth 2001 21262686 | Location: UK | GA < 33 weeks | ND | Sample 1: children had been studied by linear array US scanning (205) | Retrospective cohort (followed to age of 7 years and 2 months, and 10 years and 6 months)
| Years of Birth: 1979-1988 | During 1980, for logistic reasons, only infants who were either less than 1250 g or mechanically ventilated were enrolled | | Sample 2: children had been studied by mechanical sector scanning (577)
| Mean GA (range), wk:
| Sample 1: 29 (24–32)
| Sample 2: 29 (24–32
| Mean BW (range), g:
| Sample 1: 1350 (600–2500)
| Sample 2: 1324 (535–2390)
| Male:
| Sample 1: 49%
| Sample 2: 53%
| Race: ND
| Enrolled: 854
| Evaluated: 782
| Number of sites: 1
Saigal 2001 21376729 | Location: Canada | ELBW survivors, BW= 501–1000g | ND | Cases: ELBW infants (154) | Prospective cohort (followed to 12–16 years age)
* Important paper | Years of Birth: 1977-1982 | Controls: term infants recruited at 8 years of age from a random list obtained through the directors of 2 school boards and matched for gender, age, and SES to each case | (Died after discharge (10) Lost to follow-up (8) Refusal (5) Unable to be reached (2) Controls: Lost to follow-up (10) Refusal (8) Unable to be reached (2)) | Controls: Term infants (125)
| Mean GA (range), wk:
| Cases: 27±2
| Controls: “Term”
| Mean BW (range), g:
| Cases: 835±124
| Controls: 3401±481
| Male:
| Cases: 31%
| Controls: 36%
| Race: ND
| SES: middle class
| Cases: 30%
| Controls: 30%
| Enrolled: 179 (145 controls)
| Evaluated: 154 (125)
| Number of sites: 1
Schmidt 2001 1298249 | Location: Canada, USA, Australia, New Zealand, Hong Kong | BW: 500–999g | Excluded total 981 (not eligible) | Sample 1: Indomethacin group [574] | Randomized, multicenter, placebo/controlled, double-blind trial (18 mo CA)
| Years of Birth: 1996-1998 | 2 hrs old | Unable to administer study drug within 6 hrs of birth, n=469 | Sample 2: Placebo group [569]
| Mean GA: | Born in 1 of the 32 participating centers in Canada, USA or Australia. | Structural heart disease Renal disease or both, or strongly Suspected (n=24)
| Sample 1: 25.9±1.8 | Born during 1/1996–3/1998 | Dysmorphic feature or congenital abnormalities likely to affect life expectancy or neurologic development or to be associated with structural heart disease or renal disease (n=49)
| Sample 2: 26±1.9 | | Maternal tocolytic therapy with indomethacin or another prostaglandin inhibitor within 72hr before delivery (n=245)
| Mean BW: | | Overt clinical bleeding at more than one site (n=8)
| Sample 1: 782±131 | | Platelet count <50.000 (n=25)
| Sample 2: 783± 130 | | Hydrops (n=9)
| Male: 51% | | Not considered viable (n=171)
| Race: | | Unlikely to be available for f/up (n=31)
| Sample 1:White: 69%, black: 13%, Asian: 5%, other: 12%
| Sample 2: White: 67%, black: 14%, asian: 7%, other: 12%
| Enrolled: 2756
| Evaluated: 1202
| Number of sites: 32

Evidence Table 1. Studies Evaluating Association of LBW and Multiple Outcomes: CNS, Eye, Lung, Growth, etc. Part II

Author, Year | Predictors | Predictor Measures | Outcomes | Outcome Measures
Akerman 1992 93255928 | General: BW, GA, Twinning | Interviews with mother prior to delivery | CNS: | Griffith's Mental Development Scales: including locomotor, personal-social, hearing and speech, hand and eye coordination, performance, and practical reasoning scores
| Other: Mother's negative or ambivalent expectations concerning the twin pregnancy | | Motor delay
| | | Cognitive delay
| | | Behavioral disorders
| | | Ophthalmology: Visual Impairment
| | | Audiology:
| | | Deafness
| | | Speech
Thompson 1993 93234177 | Birth weight | ND | CNS: | Griffith's scale
| GA | | Motor delay
| | | CP
| | | Cognitive delay
| | | Mental retardation
| | | Ophthalmology: Visual impairment
| | | Audiology: Hearing disorders
Rademaker 1994 95003452 | CNS: | US grading | CNS: | Griffith's mental development scale
| 1) Intracranial/Intraventricular hemorrhage | GLH-IVH | Cognitive delay | Amiel-Tison, Greniers and Touwen scores
| 2) White Matter Disorder | | Mental retardation | IQ
| 3) Periventricular leukomalacia | | Post Hemorrhagic Hydrocephalus (PHH)
| | | Ophthalmology: Visual impairment
| | | Audiology: Hearing disorders
Vonderveid 1994 94297368 | General: | ND | CNS-Audiology-Ophthalmology: | 1) Each limb was evaluated separately:
| 1) BW (in 100 g intervals) | | 1) Neuromotor disorders: | • 0= nl function
| 2) GA (in wks) | | • impairment | • 1= impairment with no loss of function
| 3) Gender | | • disability | • 2= mild motor disability
| 4) SGA(<10% vs > 10%) | | • handicap | • 3= severe motor disability
| 5) Type of pregnancy | | • (including CP, Blindness, Deafness) | • 4= complete loss of function
| 6) Fetal presentation | | 2) Developmental quotients | 2) Cerebral palsy:
| 7) Antenatal steroid | | | Monoplegia, diplegia, paraplegia, hemiplegia, quadriplegia)
| 8) Place of birth | | | 3) Developmental quotients: Brunet-Lezine test
| 9) Apgar score 1 min | | | (24 mo CA)
| 10) Apgar score 5 min
| 11) Transport
| 12) On admission to NICU: Spontaneous respirations (present or absent); Body temperature (<35 vs >35); PH (<7.00 vs 7.00–7.09 vs > 7.09); PCO2: 80 vs 60–79 vs 40–59 vs <40
| Pulmonary:
| 1) RDS
| 2) Maximum FIO2 required
| CNS:
| 1) Peri-intra-ventricular hemorrhage
| 2) PVL
| Others:
| 1) Sepsis
| 2) Maximum bilirubin level
| 3) Hypoglycemia (< 25 mg/dl)
| 4) Hyperglycemia (>175 mg/dl)
| 5) Acidosis (pH<7.20)
Kraybill 1995 95264242 | General: | Infants were treated, as soon as after birth, either with 5 ml/kg of surfactant or air placebo, via ET tube. | 1 yr assessment (NCMH and HCHD cohort): | No further specifications given, except for the followings:
| 1) Surfactant (single dose 5 ml/kg given via ET tube at birth) | | General: | Oxygen via Nasal canula: providing alveolar O2 concentrations of: 26%–40%, based on NC flow and NC O2 concentration
| | | Overall survival | Bayley Scale of Infant Development:
| | | Pulmonary: | 1) MDI= Mental Development Index Score
| | | Need for O2 via Nasal canula | 2) PDI: Psychomotor Development Index Score
| | | Need for O2 via CPAP CLD | ROP: (no further definitions)
| | | 2 yr assessment (NCMH cohort only) | 1) No ROP,
| | | General: | 2) Mild/moderate
| | | Overall survival | 3) Severe
| | | Hospitalization for respiratory illness | CP (no further definitions)
| | | Pulmonary: | 1) Mild
| | | Bronchodilator regular use | 2) Moderate/Severe
| | | Tracheostomy | Severity of impairments:
| | | 1 and 2 yr assessment: | 1) Severe
| | | Growth: | 2) Mild/Moderate
| | | Height for age | Types of impairments:
| | | Weight for age | 1) MDI<69
| | | HC for age | 2) MDI: 69–84
| | | Mean MDI score | 3) Moderate/severe CP
| | | MDI scores <2 SDs | 4) Mild CP
| | | Mean PSI score | 5) Bilateral sensorineural deafness
| | | PDI scores <2 SDs | 6) Deafness not requiring amplification
| | | Severity of impairments | 7) Bilateral blindness
| | | Types of Impairments | 8) Visual defect
| | | Any surgery | (1 yr and 2 yr CA)
| | | Assessment between 28 ds–12mo:
| | | Ophthalmology:
| | | ROP
| | | Tx for ROP
| | | ROP presence at latest exam
| | | Severe ROP
Speechley 1995 96356544 | General: | Not further specified | Physical health outcome at 12 yrs | Based on responses on an interviewer administered and self-report questionnaire.
| 1) Former NICU graduate (of any BW) | | 1) Chronic physical health (mother's report) | Physical health outcome at 12 yrs
| 2) Gender | | 2) Lifetime hospitalizations (mother's report) | 1) Chronic physical health (mother's report): Precoded 25 chronic illnesses
| | | 3) Physical impairments (mother's report) | 2) Lifetime hospitalizations (mother's report)
| | | 4) Perception of child's heath (child's report) | 3) Physical impairments (mother's report):response to a question asking whether their child had any physical impairments
| | | 5) Perception of child's health (mother's report) | 4) Perception of child's heath (child's report): 4-item scale
| | | Emotional and social wellbeing at 12 yrs: | 5) Perception of child's health (mother's report): 4-item scale
| | | 1) Internalizing problems (child's report) | Emotional and social well being at 12 yrs:
| | | 2) Externalizing problems (child's report) | 1) Internalizing problems (child's report) 3-item scale
| | | 3) Social competence (child's report) | 2) Externalizing problems (child's report) 3-item scale
| | | 4) Social support (child's report) | 3) Social competence (child's report) 36-item scale
| | | 5) Self esteem (child's report) | 4) Social support (child's report) 24-item scale
| | | 6) School performance (mother's report) | 5) Self-esteem (child's report) 10-item scale
| | | | 6) School performance (mother's report) 5-item scale
Hack 1996 97060805 | General : | VLBW<1500gm (AGA+SGA) to compare growth with FT NBW infants | CNS:Major neurosensory abnormal. | ND
| 1) VLBW vs. NBW | | Growth:
| 2) GA | | Weight
| 3) SGA/IUGR | | Height
| 4) Sex | | Head Circumference
| CNS: Neurosensory Development IA+II, I
| Other: Maternal Factors, race, education, height, martial
Hack 1996 97066007 | General: Birth Weight | 500–750 gm | CNS: | Neurosensory status
| | | Cerebral palsy | BSID: MDI, PDI
| | | Motor and cognitive delay
| | | Ophthalmology:Blindness
| | | Audiology:Deafness
Northern Neonatal Nursing Initiative Trial Group 1996 96304894 | Cardiovascular or Pulmonary | ND | CNS Outcomes: | Motor delay: Griffith's gross motor quotient >350 below mean
| Predictors: use of FFP or plasma substitute to expand vascular volume prophylactically | | Motor delay
| | | Cerebral palsy
| | | Seizure disorder
| | | Post hemorrhagic hydrocephalus
| | | Ophthalmology: | Griffith's quotient for speech + hearing >350 below mean
| | | Visual impairment
| | | Blindness
| | | Audiology Outcomes:
| | | Hearing disorders
| | | Speech
| | | Other outcomes:
| | | a. blind, deaf, or unable to walk - combined outcome
| | | b. no severe disability - combined outcome
| | | c. overall developmental quotient - Griffith's
Sethi 1996 96334245 | General Predictors: | 1) | CNS Outcomes: | “abnormal neurodevelopmental outcome” - not defined
| 1) Birth weight | 2) <1000g | Cerebral palsy | “major impairment” - any CP blindness, deafness, “significant” developmental delay or hydrocephalus requiring a shunt
| | 3) 1000g – 1500 g | Cognitive delay | deafness OAE testing before discharge and at 7 months
| | | Seizure disorder | “minor impairment” - squint, refractive error, mild auditory impairment (< 50 dB loss), stable epilepsy, or needing speech therapy assessment
| | | Ophthalmology outcomes:
| | | Blindness
| | | ROP - eye exam
| | | Audiology outcomes:
| | | Deafness
| | | Other outcomes:
| | | Survival
Wilkinson 1996 97087405 | CNS predictors: | Changes not seen on first scan | CNS outcomes: | Not specifically defined. Spastic quadriparesis, cortical blindness, seizures presumably self-evident.
| Periventricular leukomalacia (severe cystic PVL) | Multiple cysts must be present (excludes cases with flare only) | Motor delay
| | The cysts are bilateral | Cerebral palsy
| | The cysts are distributed in the periventricular area involving the region of the trigones and variable involvement anterior to the trigones | Cognitive delay
| | | Mental retardation
| | | Ophthalmology outcomes:
| | | Visual impairment
| | | Blindness
| | | Audiology outcomes:
| | | Hearing disorders
DeReginer 1997 98041177 | Cardiovascular/ Pulmonary: | Classification based on the duration of supplemental oxygen requirements. | General: | Bayley PDI & MDI
| Chronic lung disease | “No CLD” - breathing room air at 28 days | Motor and cognitive delay
| | “Mild CLD” - requiring supplemental oxygen at 28 days but not at 36 weeks PMA | Cerebral palsy
| | Sever CLD" - requiring oxygen at 28 days and 36 weeks PMA | Opthalmology:
| | | Visual impairment
| | | Blindness
| | | Audiology:
| | | Hearing loss
| | | Deafness
| | | Growth:
| | | Weight Z score
| | | Length Z score
| | | Head circumference Z score
| | | Other: any adverse outcome
Dezoete 1997 97359687 | General: | Clinical measures | CNS: | Stratify outcome into 4 categories base on severity of disability:
| 1) Birth weight | | Motor delay | “Severe disability” / Category I - =1 of the following: (1) Sensorineural deafness (requiring hearing aids). (2) Bilateral blindness. (3) Severe cerebral palsy. (4) Developmental delay (adjusted Bayley mental scores 2 or more SD below mean).
| 2) GA | | Cerebral palsy | Category II - =1 of the following: (1) Adjusted Bayley mental scores between 1 and 2 SD below mean. (2) Mild-moderate CP w/o developmental cognitive delay. (3) Impaired vision requiring spectacles.
| 3) SGA/IUGR | | Cognitive delay | Category III - Presence of tone disorder or motor delay (adjusted Bayley motor score more than one SD below mean but adjusted mental score within average rage.)
| CNS: Intracranial/Intraventricular | | Ophthalmology: | Category IV / “apparently normal” - (1) No apparent tone disorder, and (2) No apparent developmental delay when mental and motor scores adjusted for GA.
| Hemorrhage | | Visual impairment
| Cardiovascular/ Pulmonary: Chronic Lung disease | | Blindness
| | | Audiology:
| | | Deafness
O'Shea 1997 98049056 | General: BW, GA, Yr of birth | Hemorrhage disease diagnosed by cranial US finding, classified by Stewart's method | CNS: | CP - presence of definitely abnormal position and posture attributable to impaired neuromotor function
*overlapped sample with 98190123 | CNS: | | Cerebral palsy | Bayley scales - MDI, PDI
| 1) Intracranial/ Intraventricular hemorrhage | | Cognitive delay
| 2) White matter disorder | | Major neurosensory impairments
| 3) Periventricular leuko-malacia | | Ophthalmology:Blindness
| | | Growth:
| | | Head Circumference<10^th^ percentile at 1 yr
| | | Weight<10%
| | | Length<10%
| | | Other: Rehospitalization
Piecuch 1997 97456215 | General: | Well defined in text | CNS: | Neuromotor problems, OP
| 1) Birth weight | | Motor delay | Neurosensory-blindness/hearing loss
| 2) GA | | Cerebral palsy | Cognitive outcome-abnormal if <2 SD below mean testing
| 3) SGA/IUGR | | Cognitive delay
| 4) Social Risk | | Ophthalmology: Visual Impairment
| CNS: Intracranial/Intraventricular | | Audiology: Hearing Disorder
| Hemorrhage, Periventricular leukomalacia
| Cardiovascular/Pulmonary:
| Chronic lung disease
| Other:
| 1) Inborn-Outborn
| 2) Year of birth
| 3) Sex
Piecuch 1997 98012134 | General predictors: | CLD - at 36 weeks PCA, requirement for supplemental O_2_ | CNS outcomes: | Visual - Near point tests or Snellen eye charts
| 1) GA | IVH grade 3 or 4 & PVL, according to sonogram | cerebral palsy | Audiologic - behavioral testing followed by BAER or pure tone audiometry.
| CNS predictors: | | cognitive delay | Cognitive outcome - Bayley scales at 12 and 18 months; Stanford-Binet at 2.5–4 years; McCarthy scales at 4–6 years.
| 1) intracranial/ intraventricular hemorrhage | | Ophthalmology outcomes: | Abnormal neurological outcome - CP, quadriplegia, dysplegia, hemiplegia
| 2) periventricular leukomalacia | | visual impairment | Suspicious neurological outcome - clumsiness, tremors
| Cardiovascular or pulmonary predictors: | | Audiology outcomes: | Severe neurosensory abnormalities - Bilateral hearing loss, blindness
| 1) chronic lung disease | | hearing disorders | Mild neurosensory abnormalities - high frequency hearing loss without hearing aids, visual deficit without glasses
| Other predictors:
| 1) social risk: economic | Social risk economic - maternal education <12 grade; complete unemployment in household; or government assistance for health insurance
| 2) social risk: substance abuse | Social risk substance abuse - positive toxicology screens or confirmed history of drug or alcohol abuse
Singer 1997 98049057 | Cardiovascular or pulmonary predictors: | BPD: preterm,<1500g BW, oxygen for >28 days with radiographic evidence of CLD | CNS outcomes: | Bayley Scales of Infant Development
Singer 2001 21163669 | 1) Bronchopulmonary dysplasia | | Cerebral palsy
| | | Cognitive delay
| | | Mental retardation
| General : BW, Neurologic risk | | Ophthalmology outcomes: | Language (speech/communication) measured by Battelle Developmental Communication Subscale Domain→ receptive, expressive and total communication scores converted to DQ mean 100 and SD 15.
| Other: Race, Socioeconomic status | | Visual impairment
| | | Audiology outcomes:
| | | Hearing disorders
| | | Speech
| | | Language
| | | Communication disorder
Victorian Infant Collaborative study Group, 1997 98026322 | General: BW | Each sample were subdivided into BW=500–749 g and BW=750–999 g 1985-1987 vs. 1991-1992 | CNS: | CP was not defined
*This study is also in CNS table | Other: period of time when born | | Cerebral palsy | Bayley Scales of Infant Development DQ, using the published mean and SD Disability: “Severe”—bilateral blindness, cerebral palsy with the child unlikely ever to walk, or a DQ score <-3SD; “Moderate”—bilateral sensorineural deafness requiring hearing aids, cerebral palsy in children not walking at 2 but expected to walk, or a DQ score from -3SD to <-2 SD; “Mild”—cerebral palsy but walking at 2 , or a DQ score form -2 SD to <-1 SD.
| | | Neurodevelopmental: Cognitive and motor delay
| | | Disability
| | | Ophthalmology: Blindness
| | | Audiology: Deafness or hearing aid
Victorian Infant Collaborative study Group, 1997 97466059 | Other: time period of birth | ND | CNS: | CP neurologic exam Bayley MDI, PDI scores
| | | Cerebral Palsy | Blindness-not stated
| | | Cognitive delay | Deafness-not stated
| | | Post Hemorrhagic Hydrocephalus (PHH) | Degrees of sensorineural delay are defined as an aggregate measure and are approximated.
| | | Ophthalmology: Blindness
| | | Audiology: Deafness
| | | Other:
| | | Sensorineural disability: severe, mental, moderate, none.
Cheung 1998 99059896 | Cardiovascular or Pulmonary Predictors: | ND | CNS Outcomes: | PDI + MDI of Bayley Scales of Infant Developmental Index were used.
| Inhaled nitric oxide (INO) | | Post Hemorrhagic Hydrocephalus (PHH) | “Neurodevelopmental” outcomes:
| | | “Neurodevelopmental outcomes” | Disability: one of more of:
| | | Intraventricular hemorrhage | 1. CP (all types or severity)
| | | Audiology Outcomes: Deafness | 2. Legal blindness (corrected visual acuity of the better eye <20/200
| | | Pulmonary Outcomes: BPD or CLD (with or without meds) | 3. Hearing loss (sensorineural hearing loss of >30 dB in the better ear)
| | | Aspiration pneumonia | 4. Severe mental retardation (MDI >3 SD below the mean)
| | | Growth Outcomes: Wt, HC, length (height) | Delay: does not have disability and either MDI or PDI was >2 SD below the mean.
| | | | Normal: free of disability or delay and MDI and PDI were within 2 SD of the mean.
Finnström 1998 99041345 | General Predicators | Self-explanatory | CNS Outcome: Cerebral palsy | CP: spastic diplegia, spastic hemiplegia, spastic hemiplegia
| 1) GA | | Ophthalmology: Visual impairment | Scheffzek's categories of functional disabilities are not defined in this article. They refer to a previous article which is written in German. “Major Handicaps” (category 3–4) CP, severe visual impairment, CP+ severe visual impairment, mental retardation and cardiomyopathy, hearing less
| 2) SGA/IUGR | | Audiology: Deafness
| 3) Apgar score | | Growth:
| 4) Other: gender | | Height
| CNS Predicators | | Weight
| 1) Intracranial/Intraventricular hemorrhage | | Head circumference
| 2) Periventricular leukomalacia
| Ophthalmology Predicators
| 1) Retinopathy of Prematurity (ROP)
| Cardiovascular or Pulmonary Predictors
| 1) Chronic Lung Disease
| 2) Other: Mechanical ventilation
| Other Predicators
| 1) Other: PDA
Gregoire 1998 98232532 | Cardiovascular/Pulmonary: | ND | CNS: | Giffith's Mental Development Scales Neurologic examinations
| 1) Chronic Lung Disease | | Cerebral palsy
| 2) Bronchopulmonary dysplasia | | Motor and cognitive delay
| Compared O_2_ dependence at 28 days with O_2_ dependence at 36 wk | | Audiology:
| | | Hearing Disorders→ Free field audiograms
| | | Pulmonary:
| | | Respiratory readmissions
| | | PICU admissions
| | | Growth: Weight, height, head circumference
| | | Other: Health Outcomes
Kurkinen-Raty 1998 98387235 | General : PROM | Diagnose was through clinical assessment or with the use of a PROM-test, which detects insulin growth factor binding protein-1 in the cervico-vaginal secretions, or with the use of a nitrazine test. | CNS: | Neurologic exams
(All+Lung) | | | Motor delay | Diagnosis of CLD was made if infants required oxygen, continuous bronchodilator, or steroid tx because of respiratory signs and symptoms.
*sample from the same big population as 20284814 | | | Cerebral delay | Diagnoses of RDS were made based on need for respiratory support, radiologic findings, and clinical assessments
| | | Ophthalmology: Visual Blindness
| | | Audiology: Hearing disorders
| | | Pulmonary: Chronic lung disease
| | | Growth: weight percent
| | | Other:
| | | Days of re-hospitalization Steroid therapy at followed up
Lee 1998 98442293 | General: | Diagnosis of Candidemia: by at least one positive Blood Culture | CNS: | 1) Bayley Scales of Infant development; MDI, PDI for ages < 24 mo.
| 1) Candidemia and/or Candidal meningitis | Diagnosis of Candidal meningitis: by isolation of Candida in the CSF or >45x10^6^ WBCs in the CSF and candidemia. | Neurodevelopmental disabilities (NDDs) | 2) Stanford-Binet Intelligence Scale and Peabody Development Motor Scales for ages > 24 mo
| | | Cognitive delay | 3) Scores obtained by psychologists, psychometricians, pediatricians specialized.
| | | Cerebral palsy | Neurodevelopmental Disabilities:
| | | Ophthalmology: Legal blindness | 1) Cerebral palsy (all types and severity)
| | | Audiology: Hearing loss | 2) Legal blindness (corrected VA of the better eye<20/200)
| | | Growth: Growth retardation | 3) Hearing loss (neurosensory hearing loss in the better ear > 30 dB) (done by certified audiologist
| | | | 4) And/or cognitive delay (MDI>3 SDs below the mean)
| | | | Growth retardation: Weight, Height, HC > 2 SDs below the mean
| | | | (Between 3–6 yrs CA)
Lefebvre 1998 98387703 | Other: Neurobiologic risk score (NBRS) | Items in NBRS: ventilation, PH, surgeries, IVH< PVL, infection, hypoglycemia-items scored zero or greater in progression | CNS: | Neurologic exam
| | | Cerebral palsy | Griffith's mental development scale
| | | Cognitive delay | Mental retardation-Griffith's mental development scale
| | | Other neurodevelopmental impairment | 1) Global developmental quotient (DA)
| | | Ophthalmology: Blindness | 2) Mild/moderate: DA 80–89 or CP
| | | Audiology: hearing disorders-free fetal audiogram | 3) Severe: DA<80, severe CP unilateral blindness or severe hearing defect
| | | | 4) Normal: more of the above
| | | | Areas of Griffith's Developmental Scales:
| | | | - Locomotor
| | | | - Personal-social
| | | | - Hearing and speech
| | | | - Eye and hand coordination
| | | | - Performance
| | | | Control mean DA=110+or- in literature
Millet 1998 98212544 | CNS: | ND | CNS: | Neurodevelopmental outcome poorly defined
| MRI findings at 3–6 months | | Motor delay
| | | Cerebral palsy
| | | Cognitive delay
| | | Behavioral disorders
| | | Ophthalmology: Visual impairment
| | | Audiology: Hearing loss
| | | GI: Dysphagia
Piecuch 1998 98446413 | General: | Birth in a recent period: 1989-1991 | CNS: | Neurologic:
| 1) Birth in a recent period vs early period vs midpoint period | Birth in an early period : 1979-1981 | 1) Neurologic: normal, suspect, abnormal | 1) Normal
| (the authors wanted to assess whether changes in neonatology for the care of VLBW infants have changed the outcome of LBW infants: 1000–1500g) | Birth in a midpoint period:1984-1986 | 2) Cognitive: Average or above, Mild delays, Moderate/severe delays | 2) Suspect: (clumsiness, tremors, mild tone and reflexes changes, but without fixed impairment)
| 2) Birth weight | | Ophthalmology-Audiology: Significant visual and/ or auditory deficits (B/L blindness or need for hearing aids) | 3) Abnormal: moderate/ severe: fixed impairments such as CP, diplegias, hemiplegias
| 3) GA | | | Sensory
| 4) Gender | | | 1) Visual acuity screening
| 5) Place of birth (inborn vs outborn) | | | 2) Behavioral screening assessment
| 6) Weight for age (AGA vs SGA) | | | Cognitive:
| CNS: | | | < 24 mo: Bayley Scale
| 1) Intracranial hemorrhage (ICH) | | | >24 mo: Stanford-Binet scale
| Pulmonary: | | | Carthy Scale
| 1) Duration of mechanical ventilation | | | 7–8 yrs: Wechsler Intelligence Scale for Children Revised
| 2) Duration of O2 requirements (CLD) | | | 1) Average or above
| | | | 2) Mild delays: 1–2 SDs below mean
| | | | 3) Moderate/severe delays: > 2 SDs below mean
| | | | Time of outcome assessment not specified:
| | | | It could be done up to age 7.5–8 yrs
| | | | (Mean age at assessment in the cohort was: 24 mo)
Sajaniemi 1998 99041674 | General: | Not further specified | CNS: | Neurologic outcome:
| 1) Prematurity per se | | Neurologic outcome | 1) Cerebral palsy
| 2) Premature with BW< 1000 g vs premature with BW > 1000 g | | Developmental outcome | 2) Free of major disabilities
| 3) Pre-eclampsia | | Temperament profile | Developmental outcome:
| 4) SGA | | Behavioral profile | 1) Bayley Scales of Infant Development
| 5) Duration of NICU stay | | | 2) Mental Development Index (MDI)
| CNS: | | | Temperament: Toddler Temperament questionnaire (TTQ) (contains 97 statements) 9 temperament dimensions:
| 1) PVL | | | 1) Activity
| 2) IVH | | | 2) Rhythmicity
| Pulmonary: | | | 3) Approach
| 1) Duration of ventilation | | | 4) Adaptability
| | | | 5) Intensity
| | | | 6) Mood Persistence
| | | | 7) Distractability
| | | | 8) Threshold
| | | | Behavior: Infant Behavior Record:
| | | | 1) Social responsiveness
| | | | 2) Attention
| | | | 3) Affect
| | | | 4) Energy level
| | | | 5) Goal directedness during the test
| | | | (24 mo CA)
Scherjon 1998 98429216 | CNS: | 1) U/C ratio: | Growth: | Hempel outcome:
| 1) U/C ratio: Doppler finding of umbilical/cerebral artery pulsatility index (U/C ratio: raised vs normal) | The ratio between umbilical artery and cerebral artery pulsatility index (used as a marker of fetal blood redistribution to the brain, and indirect marker of placental insufficiency) | Growth (Weight, Height, HC) | 1) Specific for toddlers
| 2) Neonatal Cranial Ultrasound findings | 2) Neonatal cranial Ultrasound: | CNS: | 2) Observed children while playing in a standardized situation
| General: | Normal: | Neurodevelopmental outcome Behavioral outcome | 3) 89 items
| 1) Fetal growth ratio | No intracranial or subependymal bleeding, Echodensities less bright than choroid plexus | | Motor aspects of Hempel examination:
| 2) GA | Moderate: | | Classification of infants:
| | IVH (< 50% of lumen filled) some echodensity brighter than choroid plexus, lasting less than 3 days. | | 1) Normal
| | Abnormal: | | 2) Mildly abnormal (e.g., slight asymmetry, or mild hypo-, hypertonia which does not lead to handicapping condition)
| | IVH (>50% of lumen filled) | | 3) Abnormal (e.g., CP, which leads to handicap in daily life)
| | Intraparenchymal bleeding Some echodensities brighter than choroid plexus and lasting longer than 3 days | | Behavioral aspects of Hempel examination:
| | 3) Fetal growth ratio (observed birth weight divided by expected mean BW for GA) | | 1) Information based on parental questionnaire on child's cognitive function and
| | | | 2) language skills
| | | | (level of activity, nocturnal enuresis, eating, sleeping disturbances, language development, comprehensibility, passive understanding, number of words used in sentences)
| | | | Hempel outcome assessment was done by a person blind to prior medical history of child.
| | | | ( 3 yrs CA)
Cheung 1999 99146391 | General predictors: | ND | CNS outcomes: | Bayley scores
| 1) BW | | Motor delay | Stanford-Binet Intelligence Scale
| 2) GA | | Cerebral palsy | Peabody Developmental Motor Scale
| 3) Apgar score | | Cognitive delay | Neurodevelopmental disability: "children with 1 or more of a) cerebral palsy b) legal blindness c) hearing loss d) convulsive disorder e) cognitive delay
| CNS predictors: | | Mental retardation
| 1) intracranial/ intraventricular hemorrhage | | Seizure disorder
| Cardiovascular or pulmonary predictors: | | Neurodevelopmental disability
| 1) days of ventilation | | Ophthalmology outcomes
| 2) days of O_2_ use | | Blindness
| Other predictors: | | Audiology outcomes:
| 1) frequency of apnea | | Hearing disorders
| 2) mean desaturation of apnea | | Growth outcomes:
| 3) mean frequency of apnea | | Weight > 2 SD below the mean
| 4) Blisten index (socioeconomic status) | | Height > 2 SD below the mean
| | | HC > 2 SD below the mean
Duvanel 1999 99207097 | General: | Blood glucose level in the first 24 hours of less than 47 mg/dl by reagents sticks, or confirmed by glucose analyzer for stick measurements less than 36mg/dl. | CNS: | Griffith's test (6 items): at 6, 12, 18 mo
| 1) Hypoglycemia: | About the frequency of episodes: no Precise information on the frequency | Scores in psychometric tests done for neurodevelopmental assessment at: | McCarthy test (6 items) : 3.5 yrs, 5 yrs
| 2) Severity of hypoglycemia (0–11 mg/dl, 11–29 mg/dl, 29–47 mg/dl), and | Of performance of glucose measurements. | • 6 moths
| 3) Frequencies of hypoglycemic episodes | | • 12 moths
| | | • 18 months
| | | • 3.5 yrs
| | | • 5 yrs.
| | | Growth:
| | | Head circumference at
| | | • 6, 12, 18 months, 3.5 yrs, 5 yrs
| | | • Growth rates for weight, length, and HC for time intervals:
| | | • 6–18 months
| | | • 6–3.5 yrs
| | | • 6–5 yrs
Pennefather, 1999 20002011 | Genera Predictor: GA | ND | CNS: | Retrospective review of patient records
Pennefather, 2000 2017908 | CNS: | | Cerebral palsy | Visual acutity, Visual fields
*This study is also in eye table | 1) IVH | | Ophthalmology:
| 2) Periventicular leukomalacia | | Visual impairment (cortical)(CVI)
| 3) Ventriculomegaly/Ventricular Dilation | | Cicatricial ROP
| Ophthalmology: | | Strabismus
| 1) ROP
| 2) Refractive error
| Other: Family Hxg strabismus, Developmental disability, CP
Ambalavanan 2000 21031370 | General: BW, GA, Antenatal steroids, Apgar score | Extensive list of the 21 predictor variables | CNS: | Bayley Scales of Infant Development
| Other: Race, Gender Multiple gestation, Maternal education, Maternal age | | Motor delay | Major handicap-presence of one or any poor outcome (i.e. CP, deadness, blindness). Mental retardation (MDI or PDI <70), PHH requiring sheet
| CNS: | | Cerebral palsy
| Intracranial hemorrhage | | Cognitive delay
| Periventricular/Ventricular | | Mental retardation
| Dilation | | PHH
| Bronchopulmonary dysplasia | | Neurologic exam
| GI: Necrotizing “entrocolitis” Interinal perforation, Chorioamnionitis | | Major handicap
| Multiple gestation | | Ophthalmology:
| Maternal education | | Visual impairment
| Maternal age | | Blindness
| | | Audiology:
| | | Hearing disorders
| | | Deafness
Cioni 2000 20150341 | CNS | MRI findings Total MRI score (the higher the worse, range 7–21) made by summation of subscores of following categories: Size of Lateral ventricles, white matter abnormal signal intensity, white matter reduction, cysts, size of subarachnoid space, corpus callosum, cortical gray matter; MRI score of visual cortex and optic radiations | CNS: | Neurological examination:
| intracranial hemorrhages, white matter disorder, Ventriculomegaly | | CP | Normal
| | | Ophthalmology: Visual assessment | Mildly abnormal (mild retardation and/or mild abnormal neurological signs, but not CP.
| | | Developmental | CP with relatively normal head and trunk control.
| | | | CP without head and trunk control.
| | | | [underlined: Visual assessment:]
| | | | Grating acuity: assessed with binocular Teller acuity card procedure (cycles per second)
| | | | Visual Field (kinetic perimetry)
| | | | Horizontal optokinetic nystagmus (OKN)
| | | | Oculomotor behaviour (following and fixation) and strabismus.
| | | | [underlined: Developmental Assessment:]
| | | | Griffith's developmental scales (global and each subscale: locomotor, personal-social, hearing-speech, hand-eye co-ordination, and performance)
| | | | Scores ≥85 = normal
| | | | Borderline 84–71
| | | | Abnormal ≤70
Hack 2000 20358826 | General: | ND | CNS: | Neurologic abnormality- includes: CP, hypotonia, hypertonia Shunt-dependent hydrocephalus
| 1) Birth weight | | Cerebral palsy
| 2) GA | | Motor delay
| 3) SGA/IUGR | | Cognitive delay MDI score<70
| 4) Antenatal steroids | | Post hemorrhagic Hydrocephalus
| 5) Jaundice
| CNS | | Ophthalmology:
| 1) Intracranial/Intraventricular Hemorrhage | | Blindness
| 2) Periventricular leukomalacia | | Audiology:
| 3) Ventriculomegaly/ ventricular dilation | | Deafness
| Cardiovascular/Pulmonary: Chronic lung disease
| Gastrointestinal: Necrotizing “entroclitis”
| Other:
| 1) Infectious Disease
| 2) Dexamethasone
| 3) Perinatal factors (chorioamnionotis)
| 4) Multiple birth
| 5) C-section
| 6) Social risk
| 7) Male sex
Jankov 2000 20188680 | Cardiovascular predictors: | 1) | CNS outcomes: | Adverse outcome defined as:
| 1) CPR | 2) Use of CPR in delivery room | Cerebral palsy | 1) CP causing non-ambulation beyond 2 years or spastic quadriparesis
| Other predictors: | 3) Assignment of Apgar scores in the delivery room | Cognitive delay | 2) Intellectual delay = below 2 SD
| 1) Apgar scores | | Mental retardation | 3) Hearing loss requiring aids
| | | Adverse outcome | 4) Legal blindness (<20/200)
| | | Ophthalmology outcome:
| | | Blindness
| | | Audiology outcome:
| | | Hearing disorders
Kurkinen-Raty, 2000 20284814 | General predictors: | BPD diagnoses were based on radiologic finding | CNS: | Motor delay = abnormalities of tone or reflexes but functionally normal or borderline
*sample from the same big population as 98197235 | Birth weight | | Motor delay | CP = spastic diplegia or hemiplegia or spastictetraplegia
| GA | | Cerebral palsy | Diagnosis of CLD was made if infants required oxygen, continuous bronchodilator, or steroid tx because of respiratory signs and symptoms.
| Antenatal steroids | | Ophthalmology
| Cord pH | | Visual impairment
| Bronchopulmonary dysphasia (BPD) | | Audiology
| Other predictors: | | Hearing disorder
| Indicated preterm delivery | | Pulmonary
| Spontaneous preterm delivery | | Chronic lung disease (CLD) at 1 year
| | | Growth:
| | | Wt, Ht, HC
Marlow 2000 20150342 | General:1) Birth weight | Not further specified | In case control component: | Cases of SNHL were identified if the hearing loss had been identified within 3 months of discharge home, (within 9 mo from birth); after excluding cases with conductive hearing loss, possible congenital cause, or had neonatal bacterial meningitis
| 2) Apgar score | | Audiology:
| 3) CRIB scores | | Sensorineural hearing loss (SNHL) of 50 dB within 9 months from birth
| CNS: | | In Longitudinal component:
| 1) Maximum bilirubin level// | | CNS:
| 2) Abnormal cenrebral US scan | | Cerebral palsy at 12 months of age in the 2 groups (SNHL and control group)
| Audiology:
| 1) Sensorineural hearing loss
| Cardiovascular/Pulomonary:
| 1) Duration of intubation, respiratory support, oxygen, pH<7.2, base excess
| 2) Dopamine excess
| 3) Furosemide
| 4) Indomethacin use
| Other:
| 3) Netilmicin
| 6) Vancomycin
| 7) Positive blood cultures
| 8) Bilirubin >200 mmol/l
| 9) Bilirubin>GA × 10
| 10) Creatinine >60 mmol/l
| 11) Netilmicin
| 12) Vancomycin
| Combination of the above:
| 1) Bili.200 + acidosis
| 2) Bili> 200 + sepsis
| 3) Bili >200+ netilmicin
| 4) Bili> 200+ vancomycin
| 5) Bili>200+ furosemide
| 6) Peak bil+ acidosis
| 7) Peak bili+ sepsis
| 8) Peak bili+ netilmicin
| 9) Peak bili+ furosemide
| 10) Creatinine>60+ netilmicin or vancomycin or furosemide
| 11) Netilmicin+furosemide
| 12) Vancomycin+ furosemide
Victorian Infant Collaborative study Group, 2000 20307288 | Other: Dexamethasone-Postnatal | ND | CNS: | Wechsler PPSI-R
*some subjects were overlapped with Doyle, 2001 | | | Cerebral palsy
| | | Cognitive delay
| | | Ophthalmology: Blindness
| | | Audiology: Deafness
Wood 2000 20373840 | General: | ND | CNS: | Bayley scales
| 1) GA | | Motor delay | Severe disability = need of physical assistance to perform daily activities.
| 2) Gender | | Cognitive delay | If disability did not fit into this category = “other disability”
| Other: Perinatal Factors → Multiple gestation | | Seizure disorder
| | | Overall development
| | | Ophthalmology:
| | | Visual impairment
| | | Blindness
| | | Audiology:
| | | Hearing disorders
| | | Deafness
| | | Speech
| | | Communication disorder
| | | Other:
| | | Severely disabled
| | | Other disability
| | | No disability
| | | Disability of hearing, vision, or communication
Doyle 2001 21326609 | General predictors: | 1) SGA/IUGR - BW ratio <0.8 | CNS: | 1) motor delay, cognitive delay - WPPSI-R and alternative IQ tests
Victorian Infant Collaborative study Group, 1997 97290716 | 1) GA | 2) intracranial/ intraventricular hemorrhage - Papille system | Motor delay | 2) cerebral palsy - not walking or walking with difficulty
*some subjects were overlapped with 20307288 (stated in text) | 2) SGA/IUGR | 3) periventricular leukomalacia - cystic lesions in PVWM dx < discharge | Cerebral palsy | 3) mental retardation - IQ < 2 SD below mean for NBW group
*possibly overlapped with 98026322 | 3) antenatal steroids | 4) bronchopulmonary dysplasia - ROS + O_2_ Rx after 28 days age | Cognitive delay
| 4) gender (female) | 5) dexamethasone - postnatal steroid use | Mental retardation
| 5) postnatal age | | Ophthalmology outcomes
| CNS predictors: | | Blindness
| 1) intracranial/ intraventricular hemorrhage | | Audiology outcomes:
| 2) periventricular leukomalacia | | Hearing disorders
| Cardiovascular or pulmonary predictors: | | Deafness
| 1) bronchopulmonary dysplasia | | Other outcomes:
| Other predictors: | | Survival without major disability at 5 years age
| 1) dexamethasone | | Survival with major neurosensory disability at 5 years age
| 2) perinatal factors
| a) multiple birth
| b) cesarian section
| 3) socioeconomic variables
| i) Asian mother
| ii) higher SEC
| iii) no English-speaking at home
| 4) surgery in primary hospital
| 5) patient with no adverse events
Gaillard 2001 21221175 | In retrospective case-control component: | Not further specified | CNS: | Normal neurodevelopmentally: no clinically apparent neurodevelopmental abnormality causing functional disability
| General: | | Neurodevelopmental outcome: | Mild disability: e.g. myopia, language delay, mild hearing loss, hyperactivity or motor clumsiness.
| 1) shorter length of ventilation beyond 27 (but not 50) postnatal ds vs more prolonged ventilation beyond 49 ds | | 1) Normal | Moderate disability: for example: spastic diplegia, hemiplegia or moderate learning disability (Developmental Quotient: 50–69)
| 2) Number of days “off”" ventilator in the groups of 27–49 postnatal ds ventilation and the group of >49ds ventilation | | 2) Mild disability | Severe disability: e.g. spastic quadriplegia, blindness, deafness (loss of 70 decibel or more), uncontrolled epilepsy, or severe learning disability (developmental quotient <50). Infants with multiple disabilities.
| In retrospective cohort with historical control group component: | | 3) Moderate disability | (3 yrs CA)
| General: | | 4) Severe disability
| 1) Birth in a period where Antenatal steroids and Surfactant were more routinely used vs birth in pre-surfactant pre-antenatal steroid period
Roth 2001 21262686 | CNS: | ND | CNS: | Outcome categories:
| 1) intracranial/Intraventricular hemorrhage | | Motor delay | 1) No neurodevelopmental impairment
| 2) white matter disorder | | Cerebral palsy | 2) Detectable impairment with disability (included neuromotor impairment with functional conse-quences, high tore hearing loss with need for aid, IQ 70–79, informal “help” in mainstream school)
| 3) Periventricular leukomalacia | | Cognitive delay | 3) Impairment leading to disability (included neuromotor impairment leading to disability sensory neural hearing loss, requiring aids, blindness or registered partial sight, IQ<70 or requirement for formal extra educational provision
| 4) Ventriculomegaly/ventricular dilation | | Mental retardation
| 5) Ultrasound methodology: linear array vs mechanical sector | | School problems
| | | Learning disabilities
| | | Ophthalmology:
| | | Visual impairment
| | | Blindness
| | | Audiology:
| | | Hearing disorder
| | | Deafness
Saigal 2001 21376729 | Birth weight | ELBW=500–1000 g | CNS: | Reported previously in the authors' other paper
* Important paper | GA | | Motor delay | Growth reference population was using the age- and gender- specific reference data provided by the NCHS growth chart
| | | Cognitive delay
| | | Other: neurosensory impairment
| | | Ophthalmology:
| | | Visual impairment
| | | Growth:
| | | 1) height
| | | 2) weight
| | | 3) head circumferences
| | | 4) BMI (wt/ht2)
| | | Other:
| | | 1) Health status and problems ; current and past
| | | 2) Extra health care expenses
| | | 3) Utilization and health care resources
Schmidt 2001 21298249 | 1) Prophylactic indomethacin administration : 0.1 mg/kg Q24 hrs × 3 days (vs NS placebo) in VLBW infants, during first 6 hrs of life | Nor further specified | Primary outcomes at 18 months of age: | 1) Death before a corrected age of 18 months or documentation in survivors of one of the following: CP, Cognitive delay, Hearing loss requiring amplification, B/L blindness
| | | 1) Composite outcome: death or impairment | 2) Cerebral palsy diagnosed if had nonprogressive motor impairment with abnormal muscle tone and decreased range or control of movements.
| | | 2) Death before 18 mo corrected age | 3) Cognitive delay: as MDI less than 70 (2SD below the mean of 100) on the Bayley scale between 85–114: classified as normal, Scores below 70: marked cognitive delay.
| | | 3) Cerebral palsy | 4) Documentation of composite primary outcome: required documentation that the infant had died or had survived with one of the 4 types of impairment. A single missing component of the f/up assessment would result in designation of missing for primary outcome. A priori criteria for definitions of presence or absence of component of the primary outcome.
| | | 4) Cognitive delay (MDI<70) | 5) In cases it was difficult to obtain Audiologic test results, deafness requiring amplification was assumed to be absent if no such indication was present during the Bayley test. (n=27 )
| | | 5) Hearing loss requiring amplification | 6) Blindness: a corrected visual Acuity of less than 20/200. F/up evaluation around 18 mo: allowed range 18–21 mo. (Home visits were permitted when necessary)
| | | 6) Bilateral blindness
| | | Secondary long term outcomes outcomes:
| | | 1) Hydrocephalus, necessitating the placement of shunt
| | | 2) Seizure disorders
| | | 3) Microcephaly (HC<3 d %)

Evidence Table 1. Studies Evaluating Association of LBW and Multiple Outcomes: CNS, Eye, Lung, Growth, etc. Part III

Author, Year | Associations found | | | | | | | | Potential Biases | Comments
Akerman 1992 93255928 | Physical and Emotional Problems at 4yrs: | | | | | | | | No infant weighed less than 1250 g | No data on funding source
| Psychomotor retardation-------- 11.8% | | | | | | | | Population homogeneous middle class with access to medical care
| Impaired hearing------------------2.9%
| Impaired vision--------------------2.9%
| Delay in speech/language--------11.8%
| Emotional Problems---------------2.9%
| No physical or psychological problems--------------------------67.7%
| All except 3 infants with physical and emotional problems were either premature or weighed less than 2500 gms at birth.
| Of the 22 infants with physical or psychomotor impairment, 17 were males
Thompson 1993 93234177 | Two years CA neurodevelopmental outcome and Griffith's scores for a cohort of South African infants with BW < 1250 g, n = 96. Mechanical ventilation not routinely used when BW < 900g. | | | | | | | | (None) | Study was private funded
| Normal | | | | Percent with outcome
| CP | | | | 75%
| DQ < 70 and CP | | | | 6%
| DQ < 70, no CP | | | | 3%
| DQ 70–79 and CP | | | | 1%
| DQ 70–79, no CP | | | | 0
| Hyperactive | | | | 15%
| “Squint” | | | | 3%
| Developmental delay | | | | 0
| Scores on Griffith's scales for most items fell significantly (P < 0.001) between one and two years of CA.
| Overall major handicap rate rose between years 1 and 2 CA from 14% to 22%
Rademaker 1994 95003452 | 3.6% of the Preemie population (=32 weeks) have unilateral intracranial parenchymal lesion. | | | | | | | | Small sample size | No data on funding source
| Not all unilateral parenchymal lesions are the same. Size of the lesion, location of the lesion, and whether the lesion communicates with the ventricle at any time all have important role in prediction of neurodevelopmental outcome. For example, if the initial lesion is triangular/fan-shaped and does not communicate with the ventricle at any time and is located in the fronto-parietal area, overall prognosis is favorable. But if the lesion is globular-shaped, continuous with the ventricle and extends beyond the trigone into the occipital periventricular white matter, risk for death and developing moderate to severe hemiplegia is significantly increased. | | | | | | | | | Cases series
Vonderveid 1994 94297368 | Of all these 22 predictors/variables evaluated for CNSoutcomes : | | | | | | | | •Cannot exclude Diagnosis bias as no information is given on blinding of personnel doing the outcome assessment on PMHx of the child.
| •PVL was associated with more than 5-fold increase in the risk of CP(OR: 5.8; 95% CI: 3.8–8.8) | | | | | | | | •Cannot exclude false Association found due to high number of predictors analyzed for the number of CP events (22 predictors for 46 CP cases)
| •Acidosis during hospitalization was associated with more than 1.5-fold increase in the risk of CP (OR: 1.6; 95% CI: 1.1–2.4)
| Overall in this NICU cohort: there were: 443/634 (70%) LBW and 191/634 (30%) were VLBW
| Overall CNS outcomesat 2 yrs:
| 1) Functionally normal were:
| •52% of all prematures
| •25% of VLBWs
| •63% of LBWs
| 2) 62/634 (10%) children had one or more disabilities
| •46/62 (74%) had CP of severity score 2–4
| •2 had peripheral motor disability
| •9 had DQ< 80 (without motor or sensory disability)
| Ophthalmology outcome:
| 1) 8 were blind due to ROP (3 also had CP)
| Audiology outcome:
| 1) 1 was deaf (was also blind and had CP)
| A definite handicap was considered for:
| •21/62 (34%) disabled children
| •(21/634=3%) (according to WHO definitions)
Kraybill 1995 95264242 | Predictor evaluation for Pulmonary, Growth and Neurodevelopmental outcomes at 1 yr.
| Single dose Surfactant tx at birth was not associated with the pulmonary, growth, neurodevelopmental and neurosensory status of VLBW premature infants at 1 yr of corrected age Placebo group vs Surfactant group, at 1 yr of age:
| 1) Overall survival at 1 yr: 160/193 (83%) vs 163/192 (85%)
| Pulmonary:
| 1) Oxygen via NC: 4/122 (3%) vs 2/136 (1.5%)
| 2) Oxygen via CPAP: 0/122 vs 1/136
| 3) CLD: 8/122 (6.5%) vs 10/136 (7%)
| Growth:
| 1) Distribution of pts in both groups across different percentiles:
| Ht/age, Weight/age and HC/age: were not s/s different across the two groups.
| CNS:
| 1) Mean MDI score: 85 ± 20 vs 88 ±22 (not ss))
| 2) MDI scores< 2SDs : 11/118 vs 23/133
| 3) Mean PDI score: 89±22 vs 91 ±23 (not ss)
| 4) PDI scores < 2 SDs: 11/118 vs 8/133
| 5) No impairment: 69/119 (58%) vs 78/134 (58%)
| 6) Impairment present (total ): 50/119 (42%) vs 56/134 (42%)
| 7) Severe impairment: 29/119 (24%) vs 37/ 134 (28%)
| 8) Mild/Moderate impairment: 21/119 (18%) vs 19/134 (14%
| 9) Types of impairment:
| MDI<69: 21/119 (18%) vs 27/134 (20%)
| MDI: 69–84: 19/119 (16%) vs 20/134 (15%)
| Moderate/severe CP: 10/119 (8%) vs 9/134 (7%)
| Mild CP: 10/119 (8%) vs 12/ 134 (9%)
| Audiology:
| 1) Bilateral sensorineural deafness: 0% vs 0%
| 2) Deafness not requiring amplification 1/119 (1%) vs 2/134 (1%)
| Ophthalmology:
| 1) Bilateral blindness: 4/119 (3%) vs 2/134 (1%)
| 2) Visual defect: 9/119 (8%) vs 9/134 (7%)
| Assessment from 28ds-12 mo:
| • No ROP: | | | | 50/132 (38%) vs 57/143 (40%)
| •Present ROP overall: | | | | 82/132 (62%) vs 86/143 (60%)
| •Mild/Moderate ROP: | | | | 79/132 (60%) vs 84/143 (59%)
| •Severe ROP: | | | | 3/132 (5%) vs 2/143 (2%)
| •Treatment for ROP overall: | | | | 7/132 (5%) vs 10/ 143 (7%)
| Surgery: | | | | 4/132 (3%) vs 3/143 (2%)
| Cryotherapy: | | | | 4/132 (3%) vs 8/143 (6%
| In the NCMH cohort there was no difference in impairments (present or absent), the severity of impairments and the types of impairments at the 1yr of age assessment of this cohort)
| Predictor evaluation for Pulmonary, Growth and Neurodevelopmental outcomes at 2 yr.
| Single dose of Surfactant tx at birth was not associated with the pulmonary, growth, neurodevelopmental and neurosensory status of VLBW premature infants at 2 yrs of corrected age24/52 (46%)
| Placebo group vs Surfactant group, at 2 yr of age:
| •Overall survival at NCMH only at 2 yrs: 68/60 (13%) vs 67/83 (81%)
| Pulmonary:
| 1) Hospitalized for respiratory illness: | | | | 9/84 (82%) vs 9/52 (17%)
| 2) Bronchodilator regular use: | | | | 10/61 (16%) vs 6/57 (11%)
| 3) Tracheostomy: | | | | 2/61 (3%) vs 0/57
| Growth:
| 1) Distribution of pts in both groups across different percentiles: Ht/age, Weight/age and HC/age were: not s/s different across the two groups
| CNS:
| 1) Mean MDI score: | | | | 89 ±21 vs 90 ±19
| 2) MDI scores< 2SDs: | | | | 5/58 (9%) vs 2/48 (4%) (NS)
| 3) Mean PDI score: | | | | 89 ±18 vs 88 ±16
| 4) PDI scores < 2 SDs: | | | | 4/58 (8%) vs 3/48 (7%)
| 5) No impairment: | | | | 32/60 (53%) vs 24/52 (46%)
| 6) Impairment present (total): | | | | 28/60 (47%) vs 28/52 (54%) (NS)
| 7) Severe impairment: | | | | 11/60 (18%) vs 7/52 (13%)
| 8) Mild/Moderate impairment: | | | | 17/60 (28%) vs 21/52 (40%)
| 9) Types of impairment:
| | MDI<69: | | | 8/60 (13%) vs 2/52 (4%)
| | MDI: 69–84 | | | 14/60 (23%) vs 18/52 (35%) (NS)
| | Moderate/severe CP: | | | 6/60 (10%) vs 5/52 (10%) (NS)
| | Mild CP: | | | 2/60 (3%) vs 3/52 (6%) (NS)
| Audiology:
| 1) Bilateral sensorineural deafness: 0 vs 0
| 2) Deafness not requiring amplification: 0 vs 0
| Ophthalmology:
| 1) Bilateral blindness: 0 vs 3/52 (6%)
| 2) Visual defect: 8/60 (13%) vs 2/52 (4%) (not ss)
| Others:
| 1) Any surgery (between 1–2 yrs): 10% vs 9 %
| Administration of single dose surfactant at birth in premature VLBW infants, with BW: 700–1350 g, results in improved survival rates up to 28 ds, without BPD and is not associated with adverse physical or neurodevelopmental outcomes at 1 yr or 2 yr corrected age.
Speechley 1995 96356544 | General Health outcome: | | | | | | | | 1) There is an inconsistency in mother's appreciation of their child's physical health: mothers of NICU graduate boys reported that their children had more physical impairments than NNN boy graduates; however, their overall perception of their child's health status was not any different from NNN boys graduates. | 1) In this NICU cohort, only 36% of infants had BW<2500 g and only 5% had BW < 1500 gs, reflecting more NICU populations in the 1970s and early 1980s than the current ones.
| Among boys around 12 yrs of age: NICU graduates as opposed to normal boys: | | | | | | | | 2) Some of the outcomes collected are prone to recollection bias (e.g., frequency of lifetime hospitalizations). | 2) It is unclear whether statistically significant differences in psychometric scales, with 10–36 items each, reflect clinically significant differences in the emotional and social well wellbeing of these children.
| 1) Are living with more chronic health problems | | | | | | | | | 3) Conversely, given the fact of many negative findings, post hoc power analyses demonstrated that the study had an 80% power to detect a 40% difference between the 2 groups. (considering 20% as small effect and 50% as medium effect)
| 2) Are more likely to have a physical impairment | | | | | | | | | 4) The fact that girl NICU graduates had a more substantial psychological effect than boys may reflect that girls are further into adolescence than the boys, experiencing the sequelae earlier. Thus in order to determine whether the differences observed are a temporary effect/related to adolescence, this cohort had to be followed further into their teenage years
| 3) And have been hospitalized more often.
| Among girls around 12 yrs of age: NICU graduates as compared to normal girls: No statistically significant differences in their physical health outcome. Among NICU graduates, boys were not different from girls in their long-term physical health outcomes.
| Emotional and Social well being outcomes:
| Among girls around 12 yrs of age: NICU graduates as opposed to normal girls:
| 1) Had significantly lower social competence
| 2) Lower social support
| 3) And Lower self-esteem.
| Among boys around 12 yrs of age: NICU graduates as compared to normal boys:
| 1) They had no difference in their emotional or social well being. There was no interaction between family's socioeconomic status and long term outcomes among NICU graduates.
| Analytically:
| The physical health outcomes at 12 yrs were
| (Boys NICU grads vs Boys NNN grads/ Girls NICU grads vs Girls NNN grads)
| • Chronic physical health (mother's report): 2.8 vs 1.8 (p<0.005)/ 2.4 vs 1.3
| • Lifetime hospitalizations (mother's report): 2.5 vs 1.6 (p<0.005)/ 1.7 vs 0.4
| • Physical impairments (mother's report): 0.29 vs 0.10 (p<0.005)/ 0.22 vs 0.06
| • Perception of child's heath (child's report): 21.6 vs 22.2/ 21.1 vs 21.9
| • Perception of child's health (mother's report): 16.9 vs 17.7/ 16.8vs 18.0
| Emotional and social well being at 12 yrs:
| (Boys NICU grads vs Boys NNN grads, Girls NICU grads vs Girls NNN grads)
| • Internalizing problems (child's report): 15.3 vs 15.5/ 18.2 vs 14.8
| • Externalizing problems (child's report): 15.9 vs 16.0 / 14.3 vs 13.5
| • Social competence (child's report): 109.1 vs 113.9 / 101.7 vs 115.7 (p<0.005
| • Social support (child's report): 81.6 vs 83.2/ 79.9 vs 86.1 (p<0.005)
| • Self esteem (child's report): 31.9 vs 32.4/ 29.8 vs 32.5 (p<0.005)
| • School performance (mother's report): 4.5 vs 4.6/ 4.8 vs 5.3
Hack 1996 97060805 | At 8 year age, 10% of VLBW (24/249) had major neurosensory abnormality vs. | | | | | | | | (None) | No data on funding source
| 0% of Normal Birth Weight. | | | | | | | | | ELBW: Lost to follow-up (22), families refused (17), families moved out of state (20)
| At 8 years age, VLBW vs. Normal Birth weight were significantly less for each of the growth outcomes: weight, height, and head circumference (p<0.001)
| Significantly greater % of former VLBW infants with (22%) vs. without (7%) major neurosensory abnormal had significantly greater subnormal growth at 8 yr (OR 3.91, 95% CI 1.18–12.88). VLBW with major neurosensory abnormal had no catch-up growth after 20 months age. VLBW +SGA had increased odds of subnormal growth at 8 years (OR 3.89, 95%CI 1.35–11.23)
Hack 1996 97066007 | | MR (MDI<84) | CP | Blind | Deaf | Major Neurosensory abnormal +MDI<80 | | | (None) | No data on funding source
| 1982-1988 | 52% | 10% | 10% | - | 49%
| 1990-1992 | 34% | 10% | 2% | 6% | 35%
| 20-month Neurodevelopmental outcomes did not change appreciably between the 2 eras.
| 20% of infants had subnormal cognitive function (MDI<70) and 10% had CP during 1990-1992 period. One third of infants with BW 500–750 gram had major neurosensory abnormalities and / or MDI<80.
Northern Neonatal Nursing Initative Trial Group 1996 96304894 | No significant differences by Griffith's Developmental quotients, incidence of CP, seizures, hearing disorders. Initial demographics available in an earlier study. | | | | | | | | (None) | Study was government and privately funded
Sethi 1996 96334245 | Single evaluation at 2 years age. Follow-up information available for 99% of cohort. | | | | | | | | Results are from a single district general hospital | No data on funding source 93 infants; follow-up available for 92; 20 infants had follow-up data from local medical care center rather than clinic visits
| Normal | 70% | | | | | | | No accounting for confounders: IVH, antenatal steroids, etc.
| Major impairment | 11% | | | | | | | Very little information provided to characterize groups BW distribution, degree of illness, IVH, BPD, etc.
| Minor impairment | 19% | | | | | | | Inadequate information about population and about determination of cognitive function
| Cerebral palsy | 8.7%
| Blindness | 2%
Wilkinson 1996 97087405 | Among 10 surviving infants GA<35 wk/ BW<1500 gm who had severe cystic PVL, all (100%) had severe neurodevelopmental outcome (CNS [spastic quadriplegia, abnl neuro exam, seizures], impaired vision and hearing) at mean 27.3 mo age. | | | | | | | | 10/12 examined (8 by single neurologist/ 2 by pediatrician and neurologist) | No data on funding source
| | | | | | | | | 9/10 eye examined in NICU ? 7/10 followed as outpatients
| | | | | | | | | Not a complete population sample of all GA<35 weeks or BW<1500 g with complete scanning data
| | | | | | | | | Small sample size
DeReginer 1997 98041177 | Chronic lung disease | | | | | | | | Matching scheme used is likely to be ineffective | No data on funding source
| Any adverse outcome: | | | | | | | | Large proportion of study population excluded by their matching strategy: subjects excluded were: 329/387=85% with no chronic lung disease; 53/111=47.7% with mild chronic lung disease; 122/180=68% with severe chronic lung disease
| 2/54
| 12/54 | P<0.001
| 18/56
| Sensorineural hearing loss:
| 0/54
| 0/54 | P<0.05
| 3/56
| Low MDI<2 SD from mean:
| 0/54
| 4/54 | P<0.05
| 5/56
| Low PDI<2 SD from mean:
| 1/54
| 4/54 | P<0.05
| 7/56
| Weight Z-score:
| No numbers given | <0.05
| Chronic lung disease and cerebral palsy, unilateral blindness, length Z-score, head circumference Z-score are not significant.
Dezoete 1997 97359687 | Outcome of category I & II: | | | | | | | | Entry criteria of infants that admitted to NICU; don't know standards of resuscitation in all 276 centers and it expertise of resuscitators creates a different kind of population. | No data on funding source
| SGA: No difference between SGA and AGA infants
| IVA gr. III, IV: signify more cat I & II outcome with gr III–IV IVA vs I+II P=0.01 | P=0.0.1
| Category IV:
| CLD: Children with CLD more likely to be normal (category IV) | P<0.01
O'Shea 1997 98049056 | Major neurosensory impairment: | | | | | | | | (None) | Study was government funded
*overlapped sample with 98190123 | Grade 3 LVH or PVE: 6.21(2.56, 15.101)
| CP:
| Total: (N=216) 14% (17/129 survivors)
| Blindness:
| Total: (N=126) 4% (5/129 survivors)
| MDI<68
| Total: (N=216) 14% (17/129 survivors)
Piecuch 1997 97456215 | Neurologic abnormal, neurosensory abnormal, cognitive abnormal | | | | | | | | (None) | No data on funding source
| BW | No association
| Neurologic:
| GA | Negative association
| Neurologic/neurosensory:
| ICH/PVL | Significant association with abnormal outcome
| Cognitive:
| CLD | Significant association with poor outcome
| Social risk | Strong association
| No association was found between outcome and birth weight.
Piecuch 1997 98012134 | Mean age at follow-up was 32 months. Bayley exams were done at 18 months. | | | | | | | | All inborn infants | No data on funding source
| Neurologic abnormalities and CP did not differ significantly across the gestational ages of 24 to 26 weeks. Between 67% and 89% were normal in each gestational age group.
| Significant differences (P = 0.036) related to gestational age were found in 18 month Bayley exam scores when group as normal borderline or deficient
| | Normal | Deficient
| 24 wk | 28% | 39%
| 25 wk | 47% | 30%
| 26 wk | 71% | 11%
| Significant differences (P = 0.008) related to gestational age were found in the combined end point of CP or an abnormal Bayley exam score:
| | Neither | One | Both
| 24 wk | 28% | 39% | 33%
| 25 wk | 47% | 23% | 30%
| 26 wk | 63% | 34% | 3%
Singer 1997 98049057 | Evaluation at 36 months corrected age. VLBW, VLBW with BPD, full term (FT). | | | | | | | | Single region, but at least it is a region | Study was government funded
Singer 2001 21163669 | | Bayley MDI | | | % with MDI below 70 | | | | | | | | | Unclear if examiners were blinded to group status
| VLBW | 90± 16 (38–126) | | | 11%
| VLBW w/ BPD | 84±24 (10–116) | | | 21%
| FT | 96±12 (57–127) | | | 4%
| P = 0.001 for VLBW vs. VLBW w/ BPD
| | Bayley PDI | | | % with PDI below 70
| VLBW | 98±20 (33–122) | | | 9%
| VLBW w/ BPD | 84±29 (8–127) | | | 9%
| FT | 103±15 (58–128) | | | 1%
| P = 0.001 for VLBW vs. VLBW w/ BPD
| At 3 years BPD predicted poorer motor outcome but not poorer mental outcome.
| Receptive DQ: BPD < VLBW < Term, p < 05
| Receptive DQ < 85: BPD 49%, VLBW 34%, Term 30%,
| BPD < VLBW + Term p < .05
| Expressive DQ: BPD < VLBW + Term, p < .05
| Expressive DQ<85: BPD 44%, VLBW 25%, Term 25%
| BPD < VLBW + Term p < .05
| Communication DQ: BPD < VLBW + Term, p < .05
| Communication DQ < 85: BPD 43%, VLBW 31%, Term 28%, NS
| Rank order listing of risk factors in order of magnitude of effect and the number of communication DQ lowered by the risk factor: PDA lowered DQ by 13 points, Minority race by 6 points, lower socioeconomic status by 5 points, and higher neurologic risk by 5 points. p .001
| Bayley Scales MDI:
| BPD 83.7 ± 24, VLBW 90 ±16, Term 96.4 ± 12, BPD < VLBW < Term, p< 0.05
| Bayley Scales PDI:
| BPD 84.1 28, VLBW 97.4 19, Term 102.8 14
| BPD < VLBW + Term, p< .05
| ROP: BPD 43%, VLBW 4%, p= .001
| Seizures: BPD 7%,
| Neurologic score: BPD 1.3 ± 2, VLBW 58 ± 1, p < .001
Victorian Infant Collaborative study Group, 1997 98026322 | Birth weight < 1000g; assessed at 2 years corrected age. | | | | | | | | Incomplete reporting of demographic data, methods and results. | Study was government funded
*This study is also in CNS table | Cohort | n | DQ < -3 SD | DQ -3 to -2 SD | DQ -2 to -1 SD | | DQ> -1 SD
| '91-'92 | 237 | 5.9% | 6.3% | 13.9% | | 73.4%
| '85-'87 | 211 | 6.2% | 4.3% | 14.2% | | 75.4%
| Cohort | n | Mild CP | Mod. CP | Severe CP | Any CP | Blindness | Deaf
| '91-'92 | 237 | 3.8% | 1.7% | 3.8% | 9.3% | 2.1% | 0.8%
| '85-'87 | 211 | NS | NS | NS | 6.6% | 4.3% | 0.5%
| Cohort | No disability | Mild Disability | | Moderate disability | | Severe disability
| '91-'92 | 71.3% | 14.8% | | 7.2% | | 6.8%
| n = 237
| '85-'87 | 71.6% | 15.6% | | 6.2% | | 6.6%
| n = 211
Victorian Infant Collaborative study Group, 1997 97466059 | All children born outside the level III perinatal centers. Assessment at 2 years corrected age. | | | | | | | | Incomplete reporting of demographic data, methods and results. | Study was government funded
Arch Dis Child | | | 1985-1987 | | | 1991-1992
| n | | 19 | | | 16
| Cerebral Palsy | | 19.1% | | | 12.5%
| Cognitive delay | | 19.1% | | | 18.8%
| Blind | | 5.6% | | | 6.2%
| Deaf | | 0 | | | 0
| Sensorineural disability
| Mild | | 15.8% | | | 6.2%
| Moderate | | 0 | | | 0
| Severe | | 5.3% | | | 12.5%
Cheung 1998 99059896 | Mean MDI 81 ± 21, PDI 64 ± 22 | | | | | | | | Very small sample size | No data on funding source
| Normal development 31% | | | | | | | | Descriptive study with no control group for comparison
| Neurodevelopmental delay 20%
| Disabled 50%
| Severe mental retardation 10%
| Spastic diplegic CP 30%
| Hemiplegic CP 10%
| <3^rd^ %ile for weight 20%
| <3^rd^%ile for height 40%
| <3^rd^%ile HC 30%
| BPD 80%
| Need bronchodilators for CLD 10%
| Recurrent wheezing but did not need meds 40%
| Grade 4 IVH 20%
| Grade 3 IVH 20%
| VP shunt 30%
| PVL 10%
| Sensorineural hearing loss 10%
Finnström 1998 99041345 | CP in 23–24 wks: 14%, in 25–26 wks 10%, =27 wks 3%, p<0.02 | | | | | | | | Exams done by infants' own pediatrician who is not blinded. Also they were not specifically trained in the evaluation so that results may be inconsistent. No control group. | No data on funding source
| CP 25–26 wks AGA: 8%, SGA 24% | | | | | | | | Scheffzek's categories not well defined. | Possible that because of national recommendation that mothers should not be treated actively on fetal indications before completion of 25 weeks that only the fittest survive and this may underestimate Incidence of CP in this study. {Died by the follow-up exam (1) Left the country (6) Incomplete identification Number (1)}
| Major handicap by GA: | | | | | | | | Infants were in the era of limited use of antenatal steroids and surfactant so that they may have been much sicker.
| 23–24 wks: 14% | | | | | | | | How GA was determined not reported.
| 25–26 wks: 9%
| =27 wks: 3%
| Major handicap by predictors:
| Grade = 3 IVH and/or PVL: 29%, OR 5.6 (95%CI 2.4–12.9)
| Stage = 3 ROP 19%, OR 2.8 (1.1–7.6)
| Oxygen-dependent at 36 wks: 11%, OR 2 (0.9–4.1)
| PDA requiring treatment: 10%, OR 1.2 (0.5–2.8)
| Apgar score 0–3 at 1 min: 15%, OR 1.7 (0.7–4.0)
| Mechanical ventilation: 7%, OR 1.3 (0.4–4.5)
| After adjusting for GA, significant increased risk of handicap in infants with Grade = 3 IVH/PVL and Stage = 3 ROP
| The mean height, weight and head circumferences were significantly lower than reference values.
Gregoire 1998 98232532 | Neurodevelopmental Outcome at 18 Months | | | | | | | | Exam of SGA infants in BPD-2 group | Study was private and hospital funded
| | Control | BPD-1 | BPD-2 | | | | | Higher receipts of postnatal steroids in BPD-2 groups
| N | 76 | 48 | 93 | | | | | Higher rate of severe IVH in BPD-2 groups
| Developmental quotient (DQ) | 97.4 (15.6) | 97.9 (11.6) | 90.7 *(19.3)
| DQ when no grade 4
| IVH or PVL | 97.4 (15.6) | 99.9 (9.1) | 93.0 *(19.3)
| Percent w/
| DQ ≤ 93 | 25% | 29% | 46%*
| Percent w/
| DQ ≤ 82 | 13% | 13% | 24%
| Total CP | 14% | 17% | 17%
| Severe CP | 13% | 13% | 17%
| Total disabilities 29% | | 31% | 50%**
| BPD-1: supplemental O2 at 28 days but not at 36 weeks PCA.
| BPD-2: supplemental O2 at 36 weeks PCA.
| *P < 0.05 for comparison between BPD-1 vs. BPD-2.
| ** P < 0.05 for control group vs. BPD-2 and for BPD-1 vs. BPD-2.
Kurkinen-Raty 1998 98387235 | Retrospective controlled cohort study of early PROM between 17 and 30 weeks of gestation. Assessments at one year corrected age. N = 55 for early PROM and 56 for control. | | | | | | | | (None) | No data on funding source
(All+Lung) | Outcome | Early PROM | Control | OR (CI)
*sample from the same big population as 20284814 | Cerebral palsy | 18% | 16% | 1.2 (0.4, 3.1)
| Delayed motor
| Development | 9% | 16% | 0.5 (0.2, 1.7)
| Visual disability | 4% | 4% | 1.0 (0.1, 7.5)
| Hearing loss | 7% | 9% | 0.8 (0.2, 3.2)
| Good nuerosensory development | 67% | 61% | 1.2 (0.6, 2.2)
| Early PROM seems to be a major obstetric and neonatal problem with pulmonary ramifications extending beyond the neonatal period. However, most of these infants can be saved.
Lee 1998 98442293 | Growth, CNS and Audiology, and ophthalmology outcomes for prematures<1250 g with candidemia/candida meningitis | | | Cases | | | Controls | | 1) Cannot exclude missed association due to the small number of patients analyzed n both groups
| Growth:
| 1) No difference in Growth retardation: | | | 7/14 survivors(50%) | | | 11/21 survivors (50%)
| CNS:
| 1) No difference in MDIs of survivors | | | 83 ±20 | | | 90 ±20 (p>0.05)
| 2) Lower PDIs in survivors | | | 71 ±21 | | | 87±18 (p<0.05)
| 3) No difference in overall Neurodevelopmental disabilities (NDDs) | | | 4/14 (29%) | | | 3/21 (14%) (p>0.05)
| 4) Cerebral palsy | | | 4/14 (29%) | | | 3/21 (14%)
| Ophthalmology:
| 1) Vision loss | | | 2/14 (14%) | | | 1/21 (5%)
| Audiology:
| 1) Hearing loss (All the children with NDDs had Cerebral palsy with or without visual or hearing deficit) | | | 2/14 (14%) | | | 1/21 (5%)
| Prematures<1250 g with candidemia/candida meningitis had: Higher Combined mortality and NDDs | | | 60% (OR=3.9; 1.2–12.6) | | | 28% (p< 0.05)
Lefebvre 1998 98387703 | Assessed at 18 months corrected age. Divided into low, moderate and high-risk group based on Neurobiologic risk score (NBRS). Tested with Griffith's Developmental Scales. | | | | | | | | (None) | Study was privately funded
| Griffith's Developmental Score Category
| Risk Group | | n | Severe impairment, <80 | | | All < 80
| Low | | 50 | 0% | | | 12%
| Moderate | | 37 | 22% | | | 24%
| High | | 34 | 50% | | | 71%
| Significance: for severe or any delay the NBRS was predictive, P < 0.0001
| Risk Group | | n | Severe CP (+) | | | Any CP
| Low | | 50 | 0% | | | 4%
| Moderate | | 37 | 13% | | | 19%
| High | | 34 | 26% | | | 41%
| Significance: NBRS predictive of CP, severe CP, P < 0.0009, any CP P < 0.0001
Millet 1998 98212544 | Motor deficits: | | | | | | | | This paper has serious flaws | No data on funding source
| Diffuse brain damage (N=26); 14
| Moderate CP: | | | | | | | | There is little demographic information and sparse reporting of CNS outcome. No statistical testing is report
| Diffuse brain damage (N=26); 6
| Visual impairment:
| Diffuse brain damage (N=26); 12
| Sensorineural hearing loss:
| Diffuse brain damage (N=26); 2
| Cognitive impairment:
| Diffuse brain damage (N=26); 16
| Epilepsy(in..? spasm):
| Diffuse brain damage (N=26); 2
Piecuch 1998 98446413 | Neural/Neurosensory outcome | | | | | | | | Concern about generalizability of findings in other populations with higher socieconomic status and higher maternal education. (For 50% of infants families were on public assistance and had maternal education of <12 yrs) | Severe cognitive delay may be apparent at 26 mo CA (the mean age of assessment of the youngest group in the study). However, subtle or late appearing cognitive problems may not have yet been diagnosed. Thus, the study had a limitation in detecting borderline cognitive or academic problems.
| 1) Neurologic and cognitive outcomes were relatively stable over the 3 time periods (1989-1991, 1984-1986, 1979-1981) for infants of 1000–1499 g BW. | | | | | | | | Predictors were assessed for their association with the outcomes; but the outcomes were measured with different scales for the different age groups (Bayley, Stanford-Binet, McCarthy, Wechler Intelligence scale) and the mean age at assessment were different in the 3 periods
| 2) > 90% of the infants born in each time period were neurologically normal.
| 3) There was a non-statistically significant trend towards an increased number of infants with neurologic abnormalities in the more recent period.
| 4) The incidence of CP was stable over the 3 time periods.
| Born in a recent period vs Born in a midpoint period vs Born in an Early period
| • Normal: 168/186 (90%) vs 143/155 (92%) vs 102/109 (94%)
| • Suspect: 10/186 (5%) vs 3/155 (2%) vs 1/109 (1%)
| • Abnormal: 8/186 (4%) vs 9/155 (6%) vs 6/109 (5%)
| More than 80% of infants in each group had normal cognitive outcome.
| Cognitive outcome:
| • Average/Above average: 152/182 (83%) vs 122/150 (81%) vs 86/102 (84%)
| • 1–2 SD< mean: 23/182 (13%) vs 19/150 (13%) vs 12/102 (12%)
| • > 2 SDs< mean: 7/182 (4%) vs 9/150 (6%) vs 4/102 (4%)
| 5) MDI scores declined slightly over time. But, mean PDI scores and MDI scores were not “clinically” significant across the 3 periods. More recent periods the infants born were smaller, younger, and had longer CLD
| Mean PDI: 96.6 vs 98.5 vs 96.9; Mean MDI: 101.0 vs 103.4 vs 106.9
| In all the infants from the 3 time periods: General Predictors evaluation:
| Univariate analyses of predictors showed different relationships between outcome depending on inborn or outborn, with inborn having better neurologic and cognitive outcome. Predictors associated with with poor neurologic/neurosensory (suspect and abnormal) or poor cognitive outcome (p< 0.02) were: Place of birth (outborns vs inborns); GA; male gender; ICH; CLD. When infants of suspect or abnormal neurologic outcome and infants of abnormal neurosensory outcome were grouped together and compared with infants of normal neurologic/neurosensory outcome (multivariate): For inborns: ICH, GA were predictors of poor outcome; For outborns:ICH, CLD were predictors of poor outcome. When infants of mild and moderate to severe cognitive deficits were grouped together and compared with infants of normal cognitive outcome (multivariate): For inborns: males had poorer outcome; For outborns: CLD was associated with poorer outcome
Sajaniemi 1998 99041674 | The neurological outcome of preterm infants was: | | | | | | | | • Post hoc multiple comparisons were done between preterms and full terms for the multiple individual items of the tests used.
| For Cerebral palsy: | | | Free from major disabilities | | | MDI | | • Cannot exclude selection bias
| 1) All prematures: 17.5% | | | 82.5% | | | 103 | | • No matching between groups cannot exclude the presence of confounders.
| 2) Prematures < 1000 gs: 23.5% | | | 23.5% | | | 98 | | • Interactions between predictors may have masked some real associations; possible interactions were not formally tested
| 3) Prematures > 1000 gs: 13.5% | | | 85.6% | | | 107 | | • Cannot exclude diagnosis bias, as no information is given on the blinding of the personnel doing the outcome evaluation of the child's PMHx.
| The developmental outcome: Preterm infants had significantly lower MDI scores when compared to full terms (Full terms 124 )
| When temperament was considered: the premature children were significantly less active; more adaptive; less intensive; more positive in mood and had lower sensory threshold than the healthy control term children. When behavior was assessed (Infant's Behavior Records): the preterms were significantly less goal directed; less attentive and; had lower in endurance than the controls.
| When Bayley neurodevelomental was assessed:
| 1) The preterms performed significantly less well than the controls.
| 2) Low Bayley scores correlated with temperament scores of high rythmicity, positive mood, low persistence and high threshold
| 3) Low Bayley scores correlated with IBR scores
| 4) No strong relationship between temperament characteristics and cognitive performance. Preterm infants had significantly lower MDI compared to full terms:
| • Preterm infants were different in 5/9 items of temperament profile compared to full terms: less active (p<0.008), more adaptive (p<0.02), less intense (p<0.01), more positive in mood (p<0.0004), lower in threshold to respond (p<0.0003)
| • Preterm infants were different in 3/5 items in IBR profile, when compared to full terms: less goal directed, less attentive, lower in endurance
| Predictors evaluation:
| • From the perinatal risk factors: pre-eclampsia, SGA, PVL and IVH were not associated with developmental outcome or temperament profiles.
| • PVL, IVH were associated with shorter attention span (1/5 items in IBR profile); when preterms compared to full terms.
| • Duration of NICU stay was not associated with Bayley score
| • Duration of ventilation was not associated with Bayley score
| • Duration of ventilation and days in NICU were associated with the 5 items of IBR profile; Duration of ventilation was associated with 1/9 items of temperament profile
Scherjon 1998 98429216 | Predictors for Neurodevelopmental outcomes (Univariate analysis) | | | | | | | | Cannot exclude possible confounders between compared groups. | The methods used for evaluation of qualitative behavioral and language differences at the age of 3 years between infants with and without placental insufficiency, possibly was not sensitive enough.
| Adverse neurodevelopmental outcome at 3 years, measured with the Hempel test, was related to: | | | | | | | | | There was blinding for the Hempel outcome assessment on the patients PMH or cranial U/S findings.
| 1) neonatal cranial ultrasound abnormalities of neonatal periventricular echodensities- as a sign of cerebral ischemia or intracranial haemorrhages (p< 0.0001) | | | | | | | | | The focus of this study was on motor development and quality of motor function. However, as there is weak association between neurodevelopmental outcome at 3 yrs and at school age yrs, it remains to reevaluate these children for their cognitive function at school age.
| 2) low head circumference at 3 years. (when compared to normal and moderate abnormal findings) (p< 0.0001)
| Hempel test was not related to the umbilical/cerebral artery pulsatility index (raised vs normal) (p=0.23)
| Fetal growth retardation (IUGR) or gestational age was not related to behavioral aspects, language and speech skills using a parental questionnaire.
| Abnormal neurosonographic findings had an influence on Hempel outcome, only if these findings occurred in combination with a normal U/C ratio.
| However, abnormal neurosonographic findings with raised U/C ratio were not associated with a poor Hempel outcome. (Raised U/C ratio reflects a more favorable adaptation to prematurity related risks, preventing the infant from having severe intracranial pathology)
| Predictors for Growth outcomes at 3 yrs (Univariate model)
| In preterm infants born 26–33 wks, lower median HC at 3 yrs was associated with
| 1) fetal Doppler findings of raised Umbilical/cerebral artery pulsatility index (U./C ratio) (vs Normal U/C ratio) (p=0.01)
| Weight or height at 3 yrs was not associated with this predictor.
| Predictors for Growth and Neurodevelopmental outcome (multivariate)
| 1) Cranial U/S findings of IVH and ED were associated
| a) with Hempel outcome (p<0.001), and
| b) with HC at 3 yrs. (p=0.01)
| (it is not clear if it refers to moderate or abnormal U/S classification, or both)
| 2) U/C ratio, fetal growth ratio and GA were not associated with Hempel outcome
Cheung 1999 99146391 | Mental Score: | | | | | | | | (None) | No data on funding source
| Days of ventilation: (N=64) <0.0001
| Motor Score:
| Days of ventilation: (N=164) <0.004
| Mental Score:
| Grade of IVH: (N=164) 0.003
| Motor Score:
| Grade of IVH: (N=164) <0.0001
| Motor Score:
| Infants <1250g with gr. 3 or 4 IVH: (N=50) <0.001
| Motor Score:
| Infants <1250g with gr. 3 or 4 IVH: (N=50) <0.001
Duvanel 1999 99207097 | There was no association of hypoglycemia with scores in Griffith's test at 6, 12, 18 months and in the McCarthy's test at 5 years. | | | | | | | | 1) Selection bias | Selected Population/Potential
| There was association of hypoglycemia with significantly lower scores in 2 items of the McCarthy's test (the perceptive index and the motricity index score) at 3.5 years | | | | | | | | 2) Information bias (in the measurement of the independent variable/glucose levels) | Selection bias: Apparently a high-risk population was studied as the frequency of hypoglycemia identified was much higher than usually anticipated.
| Repeated episodes of hypoglycemia were associated with significantly decreased scores for 2/ 6 items in the McCarthy's test (perceptive performance and motricity scale index) only at 3.5 years. (p< 0.05) | | | | | | | | 3) Confounders between the 2 groups | Methods: Not clear for which parameters the matching between the 2 groups was done. Did not describe the flow of patients (Enrolled, excluded, lost to follow up, eligible for the analysis)
| | | | | Hypoglycemic | | Euglycemic group | | 4) Multiple subgroup comparisons. Hypothesis generating analyses. | Statistical analysis: No predefined in the Method section of primary and secondary outcomes to be studied. Many exploratory, hypothesis generating, subgroup analyses, which were not predefined in the Method sections.
| One episode of hypoglycemia: | | | | | | | | | Information bias: Not consistent measurement of the predictor (glucose level) across different categories of hypoglycemia. Dextrosticks if glucose> 36mg/dl vs glucose analyzer if glucose<36 mg/dl)
| Mean MDI perception score at 3.5 yrs: | | | | 44.00 | | 50.33 (p<0.01)
| >6 episodes of hypoglycemia
| • MDI perception score at 3.5 yrs | | | | 44.89 | | 50.33 (p<0.05)
| >7 episodes of hypoglycemia:
| • MDI perception score at 3.5 yrs (P<0.01) | | | | 42.64 | | 50.33
| • Motricity index score at 3.5 yrs (p<0.05) | | | | 43.00 | | 52.33
| Moderate hypoglycemia (11–29 mg/dl) was associated with significantly lower score in 2/6 items (perceptive performance and motricity scale index) in the McCarthy's test only at 3.5 years. (p< 0.005)
| No data on the association between the severity of hypoglycemia and the outcomes at 6, 12, 18 months and 5 years. (No complete data reporting)
| Infants with recurrent mild hypoglycemia had lower neurodevelopmental scores than the group with 1 unique severe episode of hypoglycemia. (Multiple subgroup comparisons, between subgroups of the independent variable and subgroups of the dependent variable)
| Hypoglycemia was not associated with growth rates for Weight, length, and HC at intervals 6–18 months, 6 mo–3.5 yrs, or 6mo –5 yrs.
| Hypoglycemia was associated with significantly reduced HC at 12, 18 mo and 5 yrs. (p<0.05)
Pennefather, 1999 20002011 | Strabismus in 70/558 (12.5%) infants GA<32 week | | | | | | | | Prospective evaluation but retrospective collection of neonatal data; therefore, probable incomplete collection of variable reason for present and absent data | No data on funding source
Pennefather, 2000 20217908 | The incidence of strabismus increased with decreasing GA (p=0.0004), increasing severity of ROP (p=0.0001), and decreasing general developmental quotient (GMDS) (p<0.0001). | | | | | | | | No demographic data was report (the cohort was described elsewhere)
* This study is also in eye table | Stabismus present in 28 (52%) of patients with CP (P< 0.001)
| OR (95% CI) of Strabismus if following predictor was present:
| Cicatricial ROP: 4.94 (1.1–22.12), p0.037
| Fam Hx of Strabismus: 4.15 (2.19–7.88), p<0.00005
| Refractive Error: 2.71 (1.3–5.66), p=0.008
| GMDS 78–100: 3.34 (1.46–7.64), p =0.004
| GMDS <77: 46.2 (17.1–125), p<0.00005
| This study confirms findings of other studies that strabismus is increased in premature infants with decreasing GA and is increased with increasing severity of ROP and CP. Independent factors related to strabismus are cicatricial ROP, refractive error, family hx of strabismus, and developmental delay (especially delayed hand-eye coordination)
Ambalavanan 2000 21031370 | ELBW: | | | | | | | | Retrospective, relatively small samples size (218). | No data on funding source
| MDI<68 : 12%
| PDI<68: 20%
| Major handicap: 28%
| CP:28%
| MR 16%
| Post-hemorrhagic hydrocephalus: 5%
| Deaf 1.4%
| Blindness 1%
| Predictors of major handicap (Low MDI and/or PDI): Grade of IVH, PVL, absence of chorio (in this population, not in most others), NEC≥II; race; multiple gestation, BPD, maternal education
| For ELBW infants without IVH, the prevalence of major handicap, low MDI, and Low PDI was 25%, 17%, 16%, respectively.
| For ELBW infants with grade III IVH, the prevalence of major handicap, low MDI, and Low PDI was 33%, 29%, 24% respectively.
| For ELBW infants with grade IV IVH, the prevalence of major handicap, low MDI, and Low PDI was 69%, 44%, 63% respectively.
| This study identifies major determinants of adverse neurodevelopmental outcome (i.e. major handicaps, low MDI, low PDI) of ELBW (<1 kg) infants born 1990-1994. Grade of IVH is strong predictor of adverse outcome. But note large % of ELBW without IVH who had major handicap, low MDI, and Low PDI. BPD was a significant determinant of low MDI and PDI. Mat education level was significant determinant of neurodevelopmental outcome. NEC, race, multiple gestation, PVL independently contributed to poor outcome in ELBW infant. Lower BW predicted low PDI.
Cioni 2000 20150341 | Multivariate analysis found that periventricular leukomalacia in premature infants is highly, significantly correlated with visual impairment and abnormal neurodevelopment at 1 and 3 years age. The degree of visual impairment correlated well with degree of neurodevelopmental abnormality at 1 and 3 years age. Strong association between visual impairment and involvement of optic radiation on MRI. | | | | | | | | (None) | Study was government funded
| 28 of 29 infants had abnormal neurological examination at follow-up (6 mild abnormal; 22 had CP). | | | | | | | | | Visual function plays a strong role in early global development. But the presence of exceptions to these results also illustrate the complex, multifactorial nature of neurodevelopmental outcome. This study also illustrates the importance of a comprehensive assessment that includes various aspects of visual function. No single visual assessment will detect all visual abnormalities.
| 23/29 premature infants with PVL abnormality on MRI had at least one abnormality of visual function, and 50% had multiple visual function abnormalities.
| 8/29 severe ‘fixation and following’ disorders
| 19/29 had strabismus
| abnormal grating visual acuity 13/29
| reduced visual field 9/29
| OKN abnormalities 17/29
Hack 2000 20358826 | MDI Score< 70: | | | | | | | | | The authors concluded that there is an urgent need for research into the etiology and prevention of neonatal morbidity.
| CLD: 55% (49/89); | 2.18 (1.20–3.94)
| MDI Score<70 (multi stepwise logistic regression)
| Male sex: | 2.73 (1.52–4.92)
| Social risk: | 1.48 (1.09–2.00)
| CLD: | 2.18 (1.20–3.94)
| OR adjusted for sex, social risk & BW:
| Gr III–IV IVH:
| 50% (16/32); | 8.55 (3.52–20.76)
| 50% (8/16); | 4.45 (1.54–12.84)
| 50% (17/34); | 5.48 (2.41–12.47)
| CLD: 30% (27/89); | 3.09 (1.51–6.35)
| Sepsis: 14% (13/93); | 3.47 (1.16–10.36)
| Jaundice: 26% (6/23); | 5.15 (1.63–16.22)
| Mult. Stepwise Logistic regression:
| Male sex: | 2.79 (1.02–7.62)
| Sepsis: | 3.15 (1.05–9.48)
| Jaundice: | 4.80 (1.46–15.73)
| Predictors of neurologic abnormality were a severely abnormal finding on cerebral ultrasound (OR, 8,09; 95% CI 3.69–17.71) and chronic lung disease (OR 2.46; 95% CI 1.12–5.40); predictors of deafness were male sex (OR 2.79 95% CI 1.02–7.62), sepsis (OR 3.15 95 % CI 1.05–9.48), and jaundice (maximal bilirubin level >171)
Jankov 2000 20188680 | Infants CPR in delivery room | | | | | | | | Incomplete disclosure of data as it relates to the subgroups | No data on funding source
| -9 survived to discharge | | | | | | | | Small sample size
| 8/9 were free of severe neurologic disability | | | | | | | | Opposite results to other studies might be explained by decisions in many cases not to resuscitate infants that are extremely high risk which would be resuscitated in other centers
| 1/9 was legally blind
| DR resuscitation beyond PPVin <750 gms was associated with high mortalilty but without unnecessary prolongation of life
| Persistent Apgar score <5 and delayed onset of respirations beyond 5 mins in CPR recipients were associated with death or severe disability.
| Did not find a high rate of severe neurodevelopmental disability in CPR recipients
Kurkinen-Raty, 2000 20284814 | CLD at 1 year age: | | | | | | | | Outcome not well defined | No data on funding source
*sample from the same big population as 98197235 | Indicated PT delivery: (81) | 12/81 (15%) | | | | | | | Difficult to know if lack of difference between groups is due to sample size or event rate.
| Spontaneous PT delivery: (94) | 3/94 (3%)
| RR 4.6 (1.4, 1.6)
| Growth:
| Indicated PT delivery: (81)
| Spontaneous PT delivery: (94)
| Weight | RR = 0.03 (-5.3, 0.3)
| L | RR = 0.002
| HC | RR = 0.03
| CP:
| Indicated PT delivery: (81) | 5/81 (6%)
| Spontaneous PT delivery: (94) | 10/94 (11%)
| RR=0.6 | (0.25–1.6)
| Delayed motor:
| Indicated PT delivery: (81) | 8/81 (6%)
| Spontaneous PT delivery: (94) | 8/94 (9%)
| RR 1.2 (0.5–3.0)
| Visual disability:
| Indicated PT delivery: (81)
| Spontaneous PT delivery: (94)
| RR = 1.9 (0.5, 7.8)
| Hearing loss:
| Indicated PT delivery: (81)
| Spontaneous PT delivery: (94)
| RR = 1.9 (0.5, 7.8)
| This study demonstrated that premature infants who were born due to ‘indicated maternal/fetal reasons’ vs. spontaneous preterm delivered infants had worse pulmonary outcome a 1 yr age. More infants in ‘indicated’ group were SGA and were significantly smaller than control group at 1 yr in Wt, HT, and HC. There was no difference between groups in neurosensory outcomes.
Marlow 2000 20150342 | Pulmonary and Other predictors evaluation for Audiology outcome. | | | | | | | | 1) Very small sample size (cases with SNHL only 15) | Not reported source of funding
| Children with sensorineural hearing loss [15] as compared to control group[30] had longer periods of: | | | | | | | | 2) Analyzed too many predictors and combination thereof, for very few outcomes. Very wide confidence intervals; and even those predictors found to be associated with the SNHL this may have been due to chance.
| 1) Intubation, (14 ds vs 2 ds) | | | | | | | | 3) The association found between SNHL and cerebral palsy was [underlined: not] based on an adjusted analyses for possible confounders;
| 2) Ventilation (34 ds vs 6 ds) | | | | | | | | 4) The 2 groups were different in many factors that were associated with both SNHL and CP
| 3) Oxygen therapy (57 ds vs 10 ds)
| 4) Acidosis (12 ds vs 0.5 ds), and
| 5) More treatments with dopamine (33% vs 7%)or
| 6) Furosemide (87% vs 53%)
| 7) Neither P/T of aminoglycosides
| 8) nor duration of jaundice
| 9) or level of bilirubin varied between the 2 groups.
| SNHL was more likely when :
| 1) netilmicin use coexisted with the peak of bilirubin (87% vs 14%)_
| 2) when acidosis occurred when bilirubin was over 200 mmol/l, (31% vs 4%)
| 3) when furosemide was used in the face of high creatinine levels (64% vs 27%)
| 4) when furosemide was used with netilmicin (67% vs 37%)
| CNS outcome at 12 mo:
| At 12 months of age evidence of cerebral palsy was present in 7/15 (47%) of children with SNHL vs 2/30 (7%) of children without SNHL.(p=0.022)
Victorian Infant Collaborative study Group, 2000 20307288 | | | Cortocosteroids | | No Cortocosteroids | | P-value | | (None) | No data on funding source
*some subjects were overlapped with Doyle, 2001 | n | | 98 | | 195 | | Cerebral
| Palsy | | 22.7% | | 3.6% | | <0.0001
| Blindness | | 5.2% | | 0.5% | | <0.02
| Deafness | | 1% | | 1.5% | | ns.
| IQ scores | | | | | | <0.0001
| =-1SD | | 46.4% | | 68.2%
| -2 SD to <-1 SD | | 27.8% | | 24.1%
| -3 SD to <-2 SD | | 13.4% | | 4.6%
| < -3 SD | | 12.4 | | 3.1
| Sensorineural disability | | | | | | <0.0001
| Mild | | 26.8% | | 23.6%
| Moderate | | 18.6% | | 6.7%
| Severe | | 13.4% | | 3.6%
| Subgroup case-control study: cases (subjects with cortocosteroids treatment) and controls (subjects w/o with cortocosteroids treatment) were well matched in most perinatal variable
| | | Cortocosteroids | | No Cortocosteroids | | P-value
| n | | 60 | | 60 | | Cerebral
| Palsy | | 21.7% | | 5.0% | | <0.002
| Blindness | | 1.7% | | 1.7% | | ns
| Deafness | | 1.7% | | 3.3% | | ns
| IQ scores, SDS | | -1.26 | | -0.86 | | <0.05
| Sensorineural disability
| Mild | | 26.7% | | 26.7%
| Moderate | | 21.7% | | 6.7%
| Severe | | 10% | | 8.3%
Wood 2000 20373840 | Infants 22–25 weeks GA developmentally assessed at median 30 months | | | | | | | | (None) | Severe disability common children born extremely premature
| • 138/283 had disability 49% (64 met criteria for severe disability)
| • 49% no disability
| • 53/283 severely delayed 19% (Bayley below 3 SD)
| • 32/283 2–3 below SD 11%
| • 28 severe neuromotor disability 10%
| • 7 blind or perceived light only 2%
| • 8 hearing loss that was uncorrectable or required hearing aids 3%
| Survived without overall disability
| 22 wks--------------0.7 %
| 23 wks--------------5%
| 24 wks--------------12%
| 25 wks--------------23%
| Severe disability at 30 months
| 22 -------------------0.7%
| 23 --------------------3%
| 24---------------------6%
| 25---------------------9%
| • no relation between morbidity pattern and either gestational age &multiple birth
| • boys were likely to be disabled than girls
Doyle 2001 21326609 | Evaluation at 5 years corrected age: | | | | | | | | Perinatal data lacking on some infants, | Study was government funded
Victorian Infant Collaborative study Group, 1997 97290716 J Paediatr Child Health | CP : 23–27 wk survivors (11.3%) 25/221 | | | | Blindness : 23–27 wk (1.8%) 4/221 | | | | Especially outborn (in level II or I)
*some subjects were overlapped with 20307288 (stated in text) *possibly overlapped with 98026322 | FT controls (0%) | | | | FT control 0% | | | | Different methods of testing IQ
| IQ <-2 SD: 23–27 wk (15.4%) 34/221 | | | | | | | | Different times of assessing
| Major neurosensory disability | | | | | | | | Neurodevelopmental outcome
| 23 –27 wk (19.6%) 44/225 | | | | FT control (4.1%) 10/245 | | | | Some children not evaluated at 5 years (evaluated at 2 years)
| Major disability among survivors | | | | | | | | 210/401 preterm infants were assessed at both 2 and 5 years
| 23 wk GA: 2/5 (40%) | | | | 24 wk GA: 7/21 (33%) | | | | The classification of disability or no disability was the same at both 2 and 5 years (90.5% agreement; k=0.691)
| 25 wk GA: 13/51 (25%) | | | | 26 wk GA: 17/71 (24%) | | | | Inadequate discussion of study population,
| 27 wk GA: 5/79 (6%) | | | | Overall 23–27 wk: 19% | | | | Demographic
| OR for survival with major disability at 5 years: | | | | | | | | Also various surrogate data
| OR each 1 wk increase in GA = 0.59 (95% CI 0.43, 0.8)
| Prognostic factors with major disability at 5 years: IVH, cystic PVL, surgery during primary hospitalization, postnatal steroid treatment.
| Rates of survival free of major disability for surviving PT infants:
| None 96/103 =93% | | | | One 59/71 =83 %
| Two 23/43 =53 % | | | | Three 3/9 =33%
| Four 0/1 = 0
| Evaluation at 2 years corrected age. Data shown are for births in 1991-1992.
| Gestational age | | Sensorineural disability (% of survivors)
| | n | Severe | Moderate | | Mild | None
| 23 weeks | 5 | 29% | 20% | | 40% | 20%
| 24 weeks | 21 | 14.3% | 19% | | 33.3% | 33.3%
| 25 weeks | 51 | 5.9% | 21.6% | | 25% | 47%
| 26 weeks | 68 | 8.8% | 11.8% | | 20.6% | 58.8%
| 27 weeks | 74 | 1.4% | 10.8% | | 23% | 64.9%
| Overall | 219 | 6.4% | 14.6% | | 24.2% | 54.8%
| Decrease in disability with increase in gestational age was significant, p = 0.014.
| Also showed significant fall in severe disability with increase in gestational age, Odds ratio = 0.58 (0.36–0.94)
| Comparison of cohorts born in 1985-1987 vs. 1991: 1992 did not demonstrate any difference between cohorts.
Gaillard 2001 21221175 | Predictors for Neurodevelopmental outcome: | | | | | | | | In First component: | ND
| 1) Shorter length of ventilation (beyond 27(but not 50) postnatal days) was associated with better neurodevelopmental outcome : | | | | | | | | Retrospective cases control design:
| 59% (33/56) neurodevelopmentally normal or only mildly disabled survivors vs 25% (7/28) with more prolonged ventilation( > 49 ds ) | | | | | | | | 1) the 2 groups were unmatched for possible confounders, thus cannot exclude false associations
| Ventilated beyond 27 (but not 50)ds vs Ventilated beyond 49 ds | | | | | | | | 2) Cannot exclude selection Bias as only 62 survivors were analyzed from the 84 initially included in the 2 groups
| Total: 56 vs 28 | | | | | | | | In the Second component:
| Survived: 48/56 (86%) vs 14/28 (50% | | | | | | | | 3) Problems of confounders due to historical control group could be even greater
| Normal neurodevelopmentally: 26/48 (54%) vs 5/14 (36%)
| Mild disability: 7/48 (15%) vs 2/14 (14%)
| Moderate disability: 11/48 (23%) vs 4/14 (29%)
| Severe disability: 4/48 (8%) 3/14 (21%)
| 2) Number of days “off”" ventilator was not associated with the neurodevelopmental outcome at 3 yrs neither in the groups of 27–49 postnatal ds ventilation nor in the group of >49ds ventilation ( but had only 1,4 and 9 survivors in the 3 subgroups respectively)
| Ventilated beyond 27 (but not 50)ds and O ds “off” ventilator vs 1–7 ds “off” ventilator vs > 7 ds off ventilator
| Total: 18 vs 17 vs 21
| Survived: 13 (72%) vs 15 (88%) vs 20 (95%)
| Neurodevelopmentally normal: 8 (44%) vs 7 (41%) vs 11 (52%)
| Mild disability: 2 (11%) vs 2 (12%) vs 3 (14%)
| Moderate disability: 3 (17%) vs 4 (24%) vs 4 (19%)
| Severe disability: 0 vs 2 (12%) vs 2 (10%)
| (In the second component: comparison of the retrospective cohort with the historical control)
| 3) Birth in a period where antenatal steroids and exogenous surfactant was more routinely used was associated with better neurodevelopmental outcome (69% vs 40% and 45% respectively in the 2 historical control cohorts)
Roth 2001 21262686 | Neurodevelopment Impairment: | | | | | | | | Groups outcome into large categories of Disability unable to specify motor vs cognitive Vs hearing vs vision
| Liner array- all impairments 58 (28%)
| Disabling impairment 24 (12%)
| Mech sector all impairments 207 (36%)
| Disabling impairment 80 (14%)
Saigal 2001 21376729 | Neurosensory Impairment:: ELBW 28%, FT Controls 2%, p= 0.001 | | | | | | | | Didn't specify exclusion criteria but these are implied based on clear industry criteria | Study was private funded
* Important paper | Growth: Weight: diff. between ELBW and FT (mean z scores ) -5.78 (p<0.0001) | | | | | | | | Limits to generalizability:
| Visual Problems: ELBW 57%, FT Controls 21%, p=<0.001 (OR 5.1, CI 2.89–9.05) | | | | | | | | 1) different era of natural care
| Current Health Problems (multiple/patient): ≥3 Health Problems: ELBW 35%, FT Controls 7%, p<0.0001 | | | | | | | | 2) white race
| Past Health Problems: | | | | | | | | 3) access to universal health care in Canada
| Seizures: ELBW 11%, FT Controls 2%, p<0.005
| Asthma: ELBW 25%, FT Controls 14%, p=0.05
| Recurrent bronchiolitis/pneumonia: ELBW 14%, FT Controls 3%, p=0.005
| Current (at 12–16 yr age) Functional Limitation (Table 4 page 411) (multiple/patient)
| Visual difficulty: ELBW 57%, FT Controls 21%, p<0.001
| Hearing Difficulty: ELBW 7%, FT Controls 5%, ns.
| Emotional problems: ELBW 4%, FT Controls 1%, ns
| Mental problems: ELBW 4%, FT Controls 1%, ns.
| Clumsiness: ELBW 25%, FT Controls 1%, p<0.001
| Developmental Delay: ELBW 26%, FT Controls 1%, p<0.001
| Learning Disability: ELBW 34%, FT Controls 10%, p<0.001
| Hyperactivity: ELBW 9%, FT Controls 2%, p=0.04
| Reduced self-abilities: ELBW 5%, FT Controls 0%, p=0.02
| Limitation in school or in normal activity: ELBW 31%, FT Controls 9%, p<0.002
| Any functional limitation: ELBW 81%, FT Controls 42%, p<0.001
| Functional limitation/child [Mean (SD)]: ELBW 2.0 (1.8), FT Controls 0.6 (0.8), p<0.001
| Utilization of Health Care Resources:
| Pediatrician: ELBW 34%, FT Controls 14%, p<0.0002
| Ophthalmologist: ELBW 62%, FT Controls 34%, p<0.0001
| Ear/nose/throat: ELBW 14%, FT Controls 6%, p<0.05
| Occupational therapist: ELBW 7%, FT Controls 1%, p=0.002
| Speech therapist: ELBW 8%, FT Controls 0%, p<0.002
| Special Education: ELBW 48%, FT Controls 10%, p<0.0001
| Prescription Glasses: ELBW 36%, FT Controls 10%, p<0.001
Schmidt 2001 21298249 | 1) There was no difference in primary outcomes between the 2 groups at 18 months of age. | | | | | | | | | 1) By using the Bayley test at 18 mo the authors found that more than one quarter of all surviving infants had moderate to severe cognitive delays, defined by MDIs< 70. The validity of the MDI score at this age as a predictor of later intellectual functioning remains to be determined.
| 2) Among the 574 infants who were assigned to prophylaxis with indomethacin, 271 (47%) died or survived with impairment as compared with 261 of 569 infants (46%) assigned to placebo (OR: 1.1; 95% Confidence intervals; 0.8–1.4) | | | | | | | | | 2) At a post hoc calculation the study had a 90% power to detect a 20% reduction in risk, had it existed
| 3) In VLBW infants, prophylaxis with indomethacine does not improve the rate of survival without neurosensory impairments at 18 months of age | | | | | | | | | 3) Authors report that the outcome assessments were done blindly by investigators unaware of treatment groups assignments.
| 4) There was no difference in any of the secondary outcomes between the 2 groups , at 18 months of age. | | | | | | | | | 4) Authors report that they had almost complete ascertainment for the primary outcome at 2 yrs of age.
| Primary: Composite / CNS Outcomes: | | | | Indomethacin vs. Placebo
| • Death or impairment | | | | 271/574(47%) vs. 261/569 (46%)
| • Death before 18 mo | | | | 121/595 (21%) vs 111/594 (19%)
| • Cerbral palsy | | | | 58/467 (12%) vs 55/477 (12%)
| • Cognitive delay (MDI<70 by Bayley scale | | | | 118 /444 (27%) vs 117/457 (26%)
| Audiology outcome:
| • Hearing loss requiring amplification | | | | 10/456 (2%) vs 10/466 (2%)
| Ophthalmology outcome:
| • Bilateral blindness | | | | 9/456 (2%) vs 7/472 (1%)
| (Odds ratios adjusted for BW stratum and Center)
| Secondary CNS outcomes were not affected by indomethacin administration:
| • Hydrocephalus requiring shunt | | | | 15/470 (3%) vs 9/480 (2%)
| • Seizure disorder | | | | 8/470 (2%) vs 7/483 (1%)
| • Microcephaly | | | | 49/461 (11%) vs 54/475 (11%)
| Kaplan Meier estimates of survival in the 2 groups:
| • 0 months | | | | n=601 vs 601
| • 6 months | | | | n=479 (80%) vs 490 (82%)
| • 12 months | | | | n=473 (79%) vs 487 (81%)
| • 18 months | | | | n=470 (78%) vs 483 (80%)

Evidence Table 2. Randomized Controlled Trials for LBW Infants and Multiple Outcomes: CNS, Eye, Lung, Growth, etc. Part I

Author, Year UI# | Demographics | Inclusion Criteria | Exclusion Criteria | Disease/Condition Type (N) | Study Design (Duration)
Casiro 1995 95264245 | Location: Canada | BW 500–749 g | “Exclusion criteria for this study were the same as those used in an earlier trial of synthetic surfactant” (Long W, Thompson T, et al., 1991) | Experiment: | Randomized Controlled
| Years of Birth: 1988- 1990 | Informed consent | Died by age of 1 year | Exosurf (47) | Trial
| Mean GA (range), wk: | Mechanical ventilation required within 24 hr. b/o RDS | | Control: Placebo (42)
| Experiment: 25.8±1.6 | A/A PO2 ratio< 0.22
| Control: 24.8±1.1
| Mean BW (range), g:
| Experiment: 652±64
| Control: : 661±52
| Male:
| Experiment: 40%
| Control: 40%
| Race: White
| Experiment: 6%
| Control: 14%
| Enrolled: 113 (111 controls)
| Evaluated: 47 (42 controls)
| Number of sites: 13
Gerdes 1995 95264241 | Location: US | Mothers who were expected to deliver premature infants with BW 700–1100 g | All exclusion prenatal. | Experiment 1: One doses surfactant (244) | Randomized comparison trial (1 year)
| Years of Birth: 3/1989–4/1990 | | 1) Proven fetal lung maturity | Experiment 2: Three doses surfactant (264)
| Mean GA (range), wk: | | 2) Known malformation or chromosome anomaly
| Experiment 1: 27.2±1.7 | | 3) Fetal growth retardation
| Experiment 2: 27.2±1.8 | | 4) Hydrops
| Mean BW (range), g: | | 5) Purulent amnionitis
| Experiment 1: 907±121 | | 6) Maternal heroin addiction
| Experiment 2: : 911±125 | | 7) Obstetric decision not to support fetus
| Male: | | Postnatal exclusions:
| Experiment 1: 55% | | 1) Major malformation
| Experiment 2: 56% | | 2) ≥3 minor anomalies
| Race: | | 3) Hydrops
| Experiment 1: White 55%, Black 37%, Hispanic 4%, Other 5%
| Experiment 2: White 60%, Black 30%, Hispanic 5%, Other 5%
| Enrolled: 826
| Evaluated: 508
| Number of sites: 33
O'Shea 1998 98167528 98190123 | Location: US | BW 500–1500g, admitted to the 2 intensive care nurseries that served the 17 countries in NW N. Carolina. Birth at only tertiary OB center in region | Major congenital anomaly | [underlined: Born in 1978-1989]: | Case-control study (1 year corrected age)
*also in CNS table | Years of Birth: 1978-89; 1990-94 | Survived to age 1 year corrected age | | Cases: CP (80)
*overlapped sample as 98049056 | Mean GA (range), wk: | Cases: diagnosis of any subtypes of cerebra palsy | | Unmatched controls (160)
| [underlined: Born in 1978-1989]: | Controls: VLBW infants born closest in time to the respective case, who after exomination at 1 year of age were felt to be free of any signs of cerebra palsy | | Matched controls (80)
| Cases: 28(24–33) | | | [underlined: Born in 1990-1994:]
| Unmatched controls: 29 (23–39) | | | VLBW infants: 723
| Matched controls: 28 (24–34)
| [underlined: Born in 1990-1994]: 28.0±2.9
| Mean BW (range), g:
| [underlined: Born in 1978-1989]:
| Cases: 1021 (520–1500)
| Unmatched controls: 1150 (580–1490)
| Matched controls: 1095 (580–1490)
| [underlined: Born in 1990-1994]: 1039±291
| Male:
| [underlined: Born in 1978-1989]:
| Cases: 54%
| Unmatched controls: 50%
| Matched controls: 51%
| [underlined: Born in 1990-1994]: 51%
| Race:
| [underlined: Born in 1978-1989]:
| Cases: 45% African-American
| Unmatched controls: 35% African-American
| Matched controls: 32% African-American
| [underlined: Born in 1990-1994]: 56% White
| Enrolled: 1978-1989 (1559); 1990-1994 (1264)
| Evaluated: 1978-1989 (80 cases, 240 controls); 1990-1994 (723)
| Number of sites: 2
O'Connor 2001 21376723 | Location: US | GA < 33 weeks and BW 750–1805 g | Serious congenital abnormalities, major surgery prior to enrollment/ randomization. PVL/IVH > grade II | Sample 1: EHM-T fed infants (43), reference group only, not included in analyses | Randomized controlled trial (12 months)
| Years of Birth: 1996-1998 | Completed the study to 12 months' CA | Maternal Incapacity | At 12 months:
| Mean GA (range), wk: 29 (27–31) | | Liquid ventilation | Sample 2: AA+OHA (fish/fungal) (120)
| Mean BW (range), g: 1253 (965–1543) | | Severe asphyxia | Sample 3: AA+DHA (egg-TG/fish) (126)
| Male: 39% | | Uncontrolled systemic infection at enrollment | Control: formula-fed infants (126)
| Race: ND
| Enrolled: 376
| Evaluated: 246 (126 controls)
| Number of sites: 8

Evidence Table 2. Randomized Controlled Trials for LBW Infants and Multiple Outcomes: CNS, Eye, Lung, Growth, etc. Part II

Author, Year | Predictors | Predictor Measures | Outcomes | Outcome Measures
Casiro 1995 95264245 | Cardiovascular/Pulmonary: Exosurf vs. placebo | ND | CNS: | Bayley Scales of Infant Development: MDI and PDI
| | | Motor delay | The details of ophthalmologic examination, 1-year follow-up, health status evaluation were described in elsewhere (Courtney SE, Long W, et al.,1995)
| | | Cerebral palsy
| | | Cognitive delay
| | | Severity impairment
| | | Ophthalmology: ROP
| | | Growth: Height, weight, head circumference
| | | Other: Re-hospitalization in 1^st^ year of life
Gerdes 1995 95264241 | Cardiovascular or Pulmonary: Surfactant use | ND | CNS: | Mental retardation Bayley Scales
| | | Cerebral palsy | MDI<69
| | | Cognitive delay
| | | Mental retardation
| | | Ophthalmology: Visual impairment, Blindness
| | | Audiology: Hearing Disorder, Deafness
| | | Pulmonary:
| | | Asthma
| | | e/o CLD
| | | Respiratory support @ 1yr
| | | Growth: Height, Weight, HC
| | | Other: hospital re-admissions, h/o surgery
O'Shea 1998 98167528 98190123 | General predictors: | Hemorrhage disease diagnosed by Cranial US finding | CNS: | CP including spastic hemiplegia (involvement of an arm and leg on the same side of the body), spastic diplegia (involvement of the both legs with minimal to no involvement of the arms); and, spastic quadriplegia (involvement of all four extremities)
*also in CNS table | Birth weight | | CP
*overlapped sample as 98049056 | GA
| CNS predictors:
| IVH
| White matter disorder
| Periventricular leukomalacia
| Ventriculomegaly/Ventricular dilation
| Other:
| Infectious disease
| Perinatal factors
O'Connor 2001 21376723 | Other: Nutrition/growth | ND | CNS: | Bayley scales - PDI; MDI
| | | Motor delay | Teller visual acuity cards
| | | Cognitive delay
| | | Other: information processing languages
| | | Ophthalmology:
| | | Visual Acuity
| | | Growth:
| | | Weight
| | | Length
| | | Head circumferences

Evidence Table 2. Randomized Controlled Trials for LBW Infants and Multiple Outcomes: CNS, Eye, Lung, Growth, etc. Part III

Author, Year | Associations found | | | | Potential Biases | Comments
Casiro 1995 95264245 | Assessed at one year corrected age. | | | | All patients had RDS requiring mechanical ventilation | No data on funding source
| No significant differences between placebo group and Exosurf group for:
| Bayley MDI (Placebo 79 ± 22 vs. Exosurf 87 ± 20)
| Bayley PDI ( Placebo 73 ± 18 vs. Exosurf 81 ± 19)
| Percent of patients with Bayley MDI < 69 (22% vs. 21%)
| Percent of patients with Bayley PDI < 69 (29% vs. 19%)
| No significant differences between placebo and Exosurf groups for:
| No impairment (38% vs. 55%, Placebo vs. Exosurf)
| Any impairment (62% vs. 45%, Placebo vs. Exosurf)
| Serious impairment (41% vs. 32%, Placebo vs. Exosurf)
| No significant differences between placebo and Exosurf groups for:
| Bilateral sensorineural deafness: 7% vs. 9%, Placebo vs. Exosurf)
| Blindness: (7% vs. 2%, Placebo vs. Exosurf)
| No significant difference in height, weight or head circumference.
Gerdes 1995 95264241 | Severe ROP: | | | | 25% loss to follow up, equal in both groups 1 year follow up does not predict long term outcome from all infants | No data on funding source
| 1 dose: 47(16) | 3 dose: 35(11) | | | | “Prenatal and postantal this identical to those used in an earlier prophylactic trial of synthetic surfactant”
| Physical evidence of CLD: | | | | | Died by 1-year adjusted age
| 1 dose: 43(18) | 3 dose: 40(15) | | | | Lost to follow-up
| Medication for CLD:
| 1 dose: 35(14) | 3 dose: 30(11)
| Medication for chronic neurologic disease:
| 1 dose: 12(5) | 3 dose: 3(1)
| Index<2 SD (%)
| 1 dose: 29(15) | 3 dose: 30(13)
| Impairment present:
| 1 dose: 106(44) | 3 dose: 92(35)
| No impairment:
| 1 dose: 123(51) | 3 dose: 155(59)
| Severity of impairment:
| Mild/moderate:
| 1 dose: 40(17) | 3 dose: 39(15)
| Serious:
| 1 dose: 66(27) | 3 dose: 53(20)
| Types of impairments:
| MDI<69:
| 1 dose: 40(16) | 3 dose: 38(14)
| Moderate/severe CP:
| 1 dose: 22(9) | 3 dose: 16(6)
| Bilateral sensorineural deafness:
| 1 dose: 5(2) | 3 dose: 10(2)
| Deafness not requiring amplification:
| 1 dose: 5(2) | 3 dose: 2(1)
| Bilateral blindness:
| 1 dose: 10(4) | 3 dose: 4(2)
| Visual defect:
| 1 dose: 24(10) | 3 dose: 22(8)
O'Shea 1998 98167528 98190123 | | Dexamethasone | Placebo | P | (None) | Study was government funded
*also in CNS table | Definite Cerebral Palsy: | 12 | 3
*overlapped sample as 98049056 | Possible CP: | 5 | 2
| Overall CP: | 17 | 5 | 0.006
| Neuro exam severe
| Abnormal: | 4 | 2
| Mild abnormal: | 16 | 6
| Overall abnormal
| Neuro exam: | 20 | 8 | 0.03
| Authors analyze associations between prenatal factors and cerebral palsy in 80 infants with weights 500–1500g who were born in 1978-1989 to a resident of northwest region of Carolina. Factors that were strongly associated with increased risk of CP were: multiple gestation, chorioamnionitis, maternal antibiotics, antepartum vaginal bleeding, and labor lasting less than 4 hours. Pre-eclampsia and delivery without labor were associated with decreased risk of CP.
O'Connor 2001 21376723 | Growth (Wt, Ht, HC) no difference among the 4 pretem groups in terms of gm/kg/day for weight ; mm/wk for Ht and HC. | | | | (None) | No data on funding source
| Bayley at 12 months
| MDI range 92.2–93.4 (no difference among 4 groups)
| PDI range 85.9–87.2 (no difference among 4 groups)
| For infants with BW<1250 gm
| Control group: PDI 81.8 which was sig less than PDI in AA-DHA (fish/fungal) (90.6)or AA-DHA (egg) (84.7) groups
| Language vocabulary comprehension at 14 mo.
| Comprehension: 97–101.6 (no difference among 4 groups)
| Production: 96.6–98.3 (no difference among 4 groups)
| Results support benefit in PDI of supplementing formulas for premature infants with AA+DHA from either fish/fungal or egg/fish source from first enteral feeding through 12 months in infants BW<1250 g

Evidence Table 3. Studies Evaluating Association of LBW and Cerebral Palsy and Neurological Outcomes Part I

Author, Year UI# | Demographics | Inclusion Criteria | Exclusion Criteria | Disease/Condition Type (N) | Study Design (Duration)
Leonard 1990 90204169 | Location: US | BW<1250 g | Died after discharge | VLBW infants (129): | Prospective cohort (4.5 to 5 years)
| Years of Birth: 9/1/77– 9/1/82 | Head CT between 5–6 days of life or head ultrasound days 3 and 10 after delivery | Lost to follow-up before reaching school age | Without ICH (84), including 72 no parenting risk factor and 12 having parenting risk factor
| Median GA (range), wk: 28.54±1.97 | | | With ICH (45), including 38 no parenting risk factor and 7 having parenting risk factor
| Mean BW (range), g: 1003±155
| Male: 43%
| Race: ND
| Enrolled: 193
| Evaluated: 129
| Number of sites: 1
Lucas 1992 92122860 | Location: UK | Premature | ND | Sample 1: | Prospective comparative longitudinal study (7.5–8 yrs)
| Years of Birth: 1982-1985 | BW< 1850 g | | Preterms- no mother's milk (mother's choice to provide breast milk to her infant within 72 hrs from delivery) [90]
| Mean GA: | | | Sample 2:
| Sample 1: 31.4 ± 0.3 | | | Preterms- no mother's milk (mother's choice to provide breast milk to her infant within 72 hrs from deliver) matched with sample 1 for:BW, GA, need for ventilation, ds of NICU stay, other diets [210]
| Sample 2: 31.4 ± 0.2
| Mean BW:
| Sample 1: 1420 ± 30
| Sample 2: 1440 ± 20
| Males:
| Sample 1: 42%
| Sample 2: 55%
| Race: ND
| Enrolled: 313
| Evaluated: 300
| Number of sites: 5
Robertson 1994 94181384 | Location: Canada | BW 500–1249 g, lived born in Alberta to Alberta parents | Corrected rates exclude infants with syndromes and / or CNS malformations | VLBW infants survived to 1 year corrected age (163) | Retrospective cohort (at 1 year and 2 year corrceted age)
| Years of Birth: 1990 | | Survived to 1- and 2- years of corrected age | ? survived to 2 year corrected age (157)
| Median GA (range), wk: ND
| Mean BW (range), g: 500–1500
| Male: ND
| Race: ND
| Enrolled: 241
| Evaluated: 163 ? 157
| Number of sites: 2
Spinillo 1994 94257064 | Location: Italy | Cases: LBW infants with diagnosis of abnormal antepartum bleeding in mother's pregnancy | ND | [underlined: Cases]: | Prospective cohort (2 year)
*sample overlaps with Spinillo, 1997 | Years of Birth: 1983-1989 | Controls: two liveborn LBW infants of similar GA and free of malformations born immediately after each case | | Sample 1: Abruptio Placentae (40)
| Median GA (range), wk: | | | Sample 2: Placenta Previa (22)
| Sample 1: 33.4±3.4 | | | Sample 3: Unclassified reason for antepartum bleeding (vaginal and cervical polyps, excessive blood show, and cervical lacerations)
| Sample 2: 31.6±4.3 | | | [underlined: Controls](154)
| Sample 3: 32.7±5.1
| Controls 32.7±4.0
| Mean BW (range), g:
| Sample 1: 1800±458
| Sample 2: 1641±570
| Sample 3: 1768±633
| Controls 1748±569
| Male: ND
| Race: ND
| Enrolled: 87
| Evaluated: 77 (154 controls)
| Number of sites: 1
Chen 1995 96009403 | Location: Taiwan | VLBW preterm infants | ND | VLBW pretern infants (17): | Prospective cohort (18–42 months)
| Years of Birth: 2/1990– 12/1991 | | | Group 1 - normal brain US (12) | Left the hospital soon after birth at the request of their families (28)
| Mean GA (range), wk: 30 (27–36) | | | Group 2 - abnormal brain US (5, including 1 IVH grade I, 1 IVH grade III, and 3 PVL) | Families' refusal for further imaging studies (26 normal infants and 3 PVL infants)
| Mean BW (range), g: 1197 (625–1500)
| Male: ND
| Race: ND
| Enrolled: 74
| Evaluated: 17
| Number of sites: 1
Goetz 1995 96119489 | Location: US | LBW < 1500 g | Death | LBW infants with PVL (14) | Unclear (Retrospective or Prospective cohort, 11 months to 3 2/1 years)
| Years of Birth: 1/1/1989 to 12/31/1992 | Diagnosis of PVL | Transferred prior to being studied
| Median GA (range), wk: ND | | Not being followed-up
| Mean BW (range), g: 550–1100
| Male: ND
| Race: ND
| Enrolled: 115
| Evaluated: 14
| Number of sites: 1
Speechley 1995 96356544 | Location: Canada | All infants born at a tertiary care hospital in Ontario | Family residence more than 120 Km from hospital | Sample 1: | Prospective, longitudinal, comparative,
| Years of Birth: 1978-1980 | Born between 1978-1980 | Newborn's survival was in question | Former NICU | observational study (12 yrs)
| Mean GA: | Transferred to NICU or Normal Neonatal Nursery (NNN) | Language barrier | graduates: [116]
| Sample 1: 37 (28–43) | | Refused to participate to the original RCT. | Sample 2:
| Sample 2: 40 (37–44) | | | Former NNN graduates [137]
| Mean BW:
| Sample 1: 2790 (850–4550)
| Sample 2: 3503 (2660–5170)
| Male:
| Sample 1: 56%
| Sample 2: 50%
| Race:
| Sample 1: whites : 90%
| Sample 2: whites: 90%
| (Original study: was a randomized interventional study of having a family volunteer visit the home on a regular base for 6 months)
| Eligible (for the original study): 828
| Enrolled (for the original RCT): 312
| Evaluated (at 12 yrs): 253
| Number of sites: 1
Wildin 1995 95385294 | Location: US | (Sapme 1&2:) | “Significant” sensory impairment, meningitis, encephalitis, symptomatic congenital syphilis, congenital abnormality of brain, short bowel, HIV positive mother | Cases: preterm LBW infants (184): | Prospective cohort (at 6, and 12 months of age)
Wildin 1997 97422739 | Years of Birth: 1991-1992 | BW< 1600g | Primary care giver< 16y/o, drug abuser or did not speak English | Sample 1: High risk (HR) (69)
*Data from same longitudinal study as Anderson, 1996 96314587 & Smith, 1996 97081985; overlapped sample | Median GA (range), wk: | GA< 36wk | | Sample 2: Low risk (LR) (115)
| Sample 1: 28.2±2.3 | Complete neurologic and developmental exams at 6 and 12 month corrected age. | | Controls: Full Term (114)
| Sample 2: 30.8±2.2 | Controls:
| Controls 39.6±3.7 | GA 37–42wks
| Median BW (range), g: | Apgar scores greater than 8 at 1 and 5 min
| Sample 1: 922±226 | Normal physical exam
| Sample 2: 1245±209
| Controls 3177±809
| Male:
| Sample 1: 46%
| Sample 2: 42%
| Controls 51%
| Race: African American
| Sample 1: 56%
| Sample 2: 56%
| Control 3: 62%
| Enrolled: 370
| Evaluated: 184 (114)
| Number of Setting: 2
Anderson 1996 96314587 | Location: US | [underlined: (Sample 1&2)]: | Infants with maternal substance abuse, major dysmorphisms, chromosomal anomalies, sensory impairment, meningitis, encephalitis, congenital syphilis, congenital abnormality of brain, cardiac abnormalities, NEC or HIV antibody positive | Sample 1: High risk VLBW (89) | Prospective cohort (6 and 12 months)
Smith 1996 97081985 | Years of Birth:1990-1992 | VLBW (<1600g) and GA<36 wk | Primary caregiver age < 16, drug abuser or not English-speaking (only in Smith, 1996) | Sample 2: Low risk VLBW (123)
(CNS+All) | Median GA (range), wk: | Female primary care giver completed both a 6 and 12 month home visit | | Controls: Full term (128)
*Data from same longitudinal study (U. of Texas Health Sciences Center in Houston and the U. of Texas Medical Branch in Galveston) as Wildin, 1995 & 1997; overlapped sample | Sample 1: 28.2±2.3 | [underlined: Controls]:
| Sample 2: 30.8±2.2 | FT infants examined at 6 and 12 month corrected age
| Controls: 39.6±3.7
| Mean BW (range), g:
| Sample 1: 922±226
| Sample 2: 1245±209
| Controls: 3177±809
| Male: 50%
| Race:
| African American:
| Sample 1: 57%
| Sample 2: 62%
| Controls: 62%
| Caucasian:
| Sample 1: 25%
| Sample 2: 20%
| Controls: 25%
| Hispanic:
| Sample 1: 13%
| Sample 2: 15%
| Controls: 13%
| Other:
| Sample 1: 5%
| Sample 2: 3%
| Controls: 0%
| Enrolled: 368
| Evaluated: 212 (128 controls)
| Number of sites: 2
Kato 1996 97182916 | Location: Japan | VLBW singletons | Major anomaly | VLBW infants (228) | Retrospective cohort (> 12 months)
| Years of Birth: 1984-1993 | | Multiple gestation
| Median GA (range), wk: 28±2.8
| Mean BW (range), g: 1031.3±271.7
| Male: 48%
| Race: ND
| Enrolled: 305
| Evaluated: 228
| Number of sites: 2
Katz 1996 97145056 | Location: UK | ≤34 weeks, no major congenital anomaly, 3 cranial u/s in first week of life | Lost to follow-up | Cases: Preterm infants (64) | Prospective cohort (6–8 years)
| Years of Birth: 5/83– 4/85 | | Too impair due to multiple cognitive, sensory, or motor disabilities, to complete testing | Controls: Full-term comparison sample (40)
| Median GA (range), wk: 29.2±2.5 (26–34)
| Mean BW (range), g: 1227.5±341.4 (740–2240)
| Male:
| Cases: 52%
| Controls: 55%
| Race:
| Cases: 75% White, 19% Black, 6% Asian
| Controls: 75% White, 12.5% Black, 12.5% Asian
| Enrolled: 212
| Evaluated: 64 (40 controls)
| Number of sites: 2
Korkman 1996 96374730 | Location: Finland | Born at OB/GYN dept of Univ Helsinki | Children with : | Sample 1: | Prospective comparative longitudinal study (5–9 yrs )
Psy1996 | Years of Birth: ND | F/up at Children's Hospital and Children's Castle Hospital | Cerebral Palsy | VLBW and SGA [34] | (mean age: sample 1: 7.1 yrs, sample 2: 7.3 yrs, sample 3: 6.9 yrs, sample 4: 6.11 yrs)
| Mean GA: | Had neuropsychological assessment between 5yrs–9 yrs. | Mental retardation | Sample 2:
| Sample 1: 30.8±2.25 | And specifically for each sample: | Visual impairment | VLBW and AGA [43]
| Sample 2: 28.8±1.41 | Sample 1: VLBW: less than 1500 g
| Sample 3: 39.7±1.98 | And SGA (at least 2 SD below mean for their GA) | | Sample 3:
| Sample 4: 40.0±0.77 | Sample 2: VLBW and AGA | | Birth asphyxia group of term infants [36]
| Mean BW: | Sample 3: Asphyxiated Term infants, | | Sample 4:
| Sample 1: 1068.5±151.2 | GA> 34 weeks with: Umbilical arterial ph<7.05 Or Apgar scores at 5 min less than 6 (From a Birth Cohort of 982 deliveries that included all the term asphyxiated infants) | | Control Group [45]
| Sample 2: 1212.2±189.3 | Sample 4: Healthy term with normal
| Sample 3: 3596.7±705.0 | delivery, AGA (within 1.5 SD),
| Sample 4: 3469.9±275.9 | Umbilical artery pH: 7.18 or more
| Males: | Apgar score 1 min: 8 or more
| Sample 1: 44% | Neonatal period: uneventful
| Sample 2: 49% | Born in the same hospital from healthy mothers by a singleton uncomplicated pregnancy
| Sample 3: 42%
| Sample 4: 55%
| Race: ND
| Enrolled: ND
| Evaluated: 158
| Number of sites: 2
Lucas 1996 96302121 | Location: US | Breast feeding BW<1850; GA< 37, Survived to randomization at 48–72 hr; Received any breast milk | Not resident in UK and the present major congenital abnormalities (e.g. trisomy) known to influence neurodevelopment | Sample 1: Fortified breast milk (137) | RCT (9 and 18 months)
| Years of Birth: 1988-1991 | | | Sample 2: Minimally supplemented breast milk (138)
| Median GA (range), wk:
| Sample 1: 29.8±0.2
| Sample 2: 29.8±0.2
| Mean BW (range), g:
| Sample 1: 1306±28
| Sample 2: 1263±26
| Male:
| Sample 1: 47%
| Sample 2: 47%
| Race: ND
| Enrolled: 275
| Evaluated: 275
| Number of sites: 2
Rieck 1996 Psy 1996 06905005 | Location: Israel | Sample 1: | ND | Prospective longitudinal component: | Longitudinal f/up study of children participating in a previous prospective longitudinal study (3–7 yrs)
| Years of Birth: ND | Premature | | Sample 1: | Cross sectional comparative component (3 arms: 2 control arms) (3– 7 yrs)
| Mean GA: ND | VLBW < 1500 g
| Mean BW: ND | Sample 2:: | | Sample 1:
| Males: ND | Children from middle socioeconomic class (MC) families | | Premature VLBW <1500) [83]
| Race: | Sample 3: | | (mean age at assessment: 4.5 yrs)
| Sample 1: whites 90%, asian-african10% | Children from low socioeconomic class (LC) families | | Cross-sectional comparative component:
| Sample 2: whites: 94%, Asian-African: 5%
| Enrolled: | | | Sample 1
| Sample 1,2,3 : ND | | | Premature VLBW < 1500 [83]
| Evaluated: | | | Sample 2:
| Sample 1: 103 | | | Term children of middle class families [71]
| Sample 2,3: ND | | | Matched with sample 1 only for mean age at assessment : 5.1 yrs
| Number of sites: ND | | | Sample 3:
| | | | Term children from low
| | | | Class families [322]
| | | | Matched with sample 1 only for mean age at assessment: 5.0 yrs
Whitaker 1996 97040639 | Location: US | BW 501–2000 g | Families refusal (45) | Central New Jersey | Prospective cohort (6 years)
| Years of Birth: 9/1/84–6/30/87 | Survived to 6 years of age and participated in the study | Unable to be located (143) | Neonatal Brain
| Median GA (range), wk: 31.5 | Home visit interview subjects | Had been adopted (25) | Hemorrhage study cohort LBW infants (597):
| Median BW (range), g: 1480.7 | | | Normal US finding (468)
| Male: 51% | | | GM/IVH (83)
| Race: White 74%, African-American 22%, Other 5% | | | PL/VE (46)
| SES: middle class (19% of the families receiving public assistance)
| Enrolled: 685
| Evaluated: 597
| Number of sites: ND
Blitz 1997 97154301 | Location: US | Preemies, BW < 1001 g | Survived to hospital discharge | ELBW preemies (100): | Prospective cohort
| Years of Birth: 1/90– 8/90 | Maryland residents | Declined participation | Meningitis 6%
| Mean GA (range), wk: 26.5±2.4 | | Serious congenital malformations, genetic disorder, diagnosed congenital syndromes with brain abnormality of known correlation with developmental disability, disorders secondary to prenatal toxic exposure with microcephaly, severe head injury after discharge | PVL 10%
| Mean BW (range), g: 775.9±138.4 | | Developed meningitis after discharge | Hydrocephalus 18%
| Male: 36% | | | Seizures 7%
| Race: 40% White | | | IVH = grade III 26%
| Enrolled: 248 | | | BPD 63%
| Evaluated: 100 | | | ROP 49%
| Number of sites: 1 | | | Retinopathy of prematurity 49%
Cheung 1997 97310950 | Location: Canada | Preterm neonates (GA < 30 weeks, BW < 1200 g) with severe respiratory failure treated with high frequency ventilation (HFO) | ND | Preterms with IVH (21) | Retrospective cohort
| Years of Birth: 1988-1993
| Median GA (range), wk: 26 (24–30)
| Mean BW (range), g: 891 (530–1180)
| Male: 67%
| Race: ND
| Enrolled: 52
| Evaluated: 21
| Number of sites: 1
Ekert 1997 97251211 | Location: Canada | GA<32 wks informed parental consent | Congenital anomalies, meningitis, congenital infections, GBS disease, lack of consent | Patients entering study (123)→ 104 left in analysis for outcome studies | Prospective cohort (seen at corrected age 4,8,12,18,24 months)
| Years of Birth: 1988-1994
| Median GA (range), wk: 27.6±2.1
| Mean BW (range), g: 962±262g
| Male: 50%
| Race: ND
| Enrolled: 123
| Evaluated: 123
| Number of sites: 2
Gerner 1997 97329414 | Location: Sweden | Sample 1 and 2: | ND | Sample 1: | First component:
| Years of birth: 1988-1993 | Premature,VLBW infants<15000g | | Preterm VLBW infants “healthy” without any risk factors [50] | Prospective observational
| Mean BW: 1047 ±258 g | From NICU of Karolinska Hospital and St Goran's Hospital in Stockholm | | Sample 2: | cohort with 171 preterm VLBW infants (sample 1 and 2)
| Mean GA: 28.2 ±2.7 wks | Born between 9/1988 and 2/1993. | | Preterm VLBW infants With one or more risk factors [Brain hemorrhage, white matter lesion, surgical closure of PDA, ventilator treatment or septicemia (except Staph epi) [121] | Second component:
| Males: ND | Inborns and outborns included | | (Risk factors and group definition were based on the risk factors that were statistically significantly correlated with outcome in the cohort of the 171 preterm VLBW infants) | Prospective comparative component:
| Race: ND | Had neurodevelopmental assessment at 10 months corrected age | | Sample 3: | sample 1 vs sample 3
| Enrolled: | Sample 3: | | Full term “ healthy” infants, born at Karolinska hospital, during the same period, and matched with the combined preterm VLBW cohort [35]
| Sample 1 and 2: 211 | Full term infants | | | Third component:
| Sample 3: ND | Uneventful pregnancy and delivery | | | Prospective Comparative
| Evaluated: | Apgar score at 5 min: 10 | | | component:
| Sample 1: 50 | No neonatal complications | | | Sample 2 vs sample 1
| Sample 2: 121 | Born at Karolinska hospital | | | [10 months]
| Sample 3: 35 | During the same period
| Number of sites: 2 | Matched with cases for:
| | sex, maternal age, maternal education and parity
| | Had neurodevelopmental assessment at 10 months corrected age
Koller 1997 97193708 | Location: US | GA <1500, data obtained at 4 follow-up data points | ND | VLBW infants (203) | Retrospective cohort
| Years of Birth: 1975-1989
| Median GA (range), wk: 30.9 (25–37)
| Mean BW (range), g: 117±227
| Male: 45%
| Race: 51% Black
| Enrolled: 203
| Evaluated: 203
| Number of sites: 3
Murphy 1997 97192793 | Location: Korea | GA<32 weeks Singleton | Multiple birth | Cases: CP cases (59) | Case-control study
| Years of Birth: 1984-1990 | Oxfordshire and West Berkshire resident | Died before discharged | Controls (234)
| Median GA (range), wk: | Neonatal notes were available
| Cases: 28.6±2.3 (24–32)
| Control: 29.9±1.9 (23–32)
| Median BW (range), g: ND
| Male:
| Cases: 63%
| Control: 57%
| Race: ND
| Enrolled: 638
| Evaluated: 59 (234 controls)
| Number of sites: 1
Schendel 1997 98033417 | Location: US | Singleton livebirths in MMIHS study population, survived to 1 year of age | ND | Sample 1: VLBW infants (367) | Case-control study
| Years of Birth: 12/1/89 to 3/31/91 | Cases: MLBW infants, BW 1500–2499g; VLBW infants, BW<1500g | | Sample 2: MLBW infants (553)
| Mean GA (range), wk: | Controls: NBW infants randomly selected from the birth certificate files on the basis of frequency matching with cases by maternal race, age, and residence | | Controls: NBW infants (555)
| Sample 1: 28.4±3.0
| Sample 2: 35.6±2.8
| Controls: 39.4±1.5
| Mean BW (range), g:
| Sample 1: 1088±268
| Sample 2: 2184±267
| Controls: 3417±432
| Male:
| Sample 1: 49%
| Sample 2: 46%
| Controls: 52%
| Race: Black
| Sample 1: 37%
| Sample 2: 37%
| Controls: 41%
| Enrolled: 920 (555 controls)
| Evaluated: 920 (555)
| Number of sites: 5
Thompson 1997 97268338 | Location: US | Born at Duke | ND | VLBW infants (55) | Prospective cohort (4 years)
| Years of Birth: 1986-1991 | BW<1500g | | | Death (12), lost to follow-up (34), incomplete data (4), invalid score (5)
| Median GA (range), wk: 28.36±2.11(24–33) | Survived to discharge or to 6 mo. corrected age
| Mean BW (range), g: 1100±2.11 (700–1500)
| Male: 46%
| Race: ND
| Enrolled: 111
| Evaluated: 55
| Number of sites: 1
Victorian Infant Collaborative study Group 1997 98026322 | Location: Australia | (Sample 1–3): | Excluded infants born in 1979-1980 for current review | Cases: ELBW infants (448): | Retrospective cohort
*There are a series of Victorian articles in LBW-ALL. | Years of Birth: 1979-80, 1985-87, 1991-92 | ELBW infants, BW 500–999 g born in Victoria, Australia | | Sample 1: born in 1985-1987 (212)
*This study will be combined in LBW-ALL table | Median GA (range), wk: ND | Survived to age of 2 years | | Sample 2: born in 1991-1992 (241)
| Mean BW (range), g: ND | [underlined: Controls]: | | Controls: Normal BW (>2499 g) infants (242)
| Male: ND | Normal birth weight (>2499 g) infants born in 1991-1992
| Race: ND
| Enrolled: 453 (242 controls)
| Evaluated: 448 (242)
| Number of sites: 3
Battin 1998 99002694 | Location: British Columbia, Canada | Prospective cohort: | Cases of therapeutic termination of pregnancies for lethal congenital anomalies Outborns | Prospective cohort of ELGA born during a period when antenatal steroids, surfactant and dexamethasone for BPD had become an accepted treatment [44] | Prospective observational cohort study and a comparative study with an historical control group (18 months)
| Enrollment period: 1991-1993 | Birth at British Children's Hospital and British Womens' Hospital
| Mean GA: ND (range: 23–25 wks) | Born during 1991-1993
| Mean BW: ND | Extremely low gestational age (ELGA): 23–25 wks
| (Mean BW for the 333 live births during the study period : for GA of 23 wks: 581, for GA of 24 wks: 648, for GA of 25 wks: 764) | Had follow up at 18 mo of age
| Male: ND | Historical control group:
| Race: ND | Born at the same institution
| Enrolled: 333 | Born between 1983-1989
| (total live births GA: 23–28 wks) | GA: 23–25 wks
| Evaluated : 44
| (out of 49 of GA 23–25 surviving to NICU discharge)
| Number of sites: 2
Bos 1998 98218970 | Location: Netherlands | AGA | Major congenital anomalies | Preterm infants with echodensities (27) | Prospective cohort
| Years of Birth: 1992-1994 | GA <35 wks | Developed cystic PVL, or grade 3 or 4 IVH
| Mean GA (range), wk: 26–34 | Lived within 60km of hospital
| Mean BW (range), g: 835–1780 | Normal US findings
| Male: ND
| Race: ND
| Enrolled: 27
| Evaluated: 27
| Number of sites: ND
Cherkes-Julkowski 1998 98262696 | Location: ND | Preterm: | ND | Preterms (28) | Retrospective cohort
| Years of Birth: ND | <38 wks, BW<5 lbs, no congenital disorders, no retrolenteal fibroplasia, discharge from hospital prior to 42 wks conceptional age, mother willing to participate | | Controls: full term infants (20)
| Mean GA (range), wk: ND | Controls: participants were enrolled in a longitudinal study before their second month of age
| Mean BW (range):
| Cases: 4.14±1.87 lbs
| Controls: 7.30±1.87 lbs
| Male:
| Cases: 61%
| Controls: 50%
| Race: ND
| SES: “middle class”
| Enrolled: 48
| Evaluated: 28 (20 controls)
| Number of sites: 1
Emsley 1998 98238139 | Location: US | GA 23–25 weeks | Survived until discharge | Sample 1: Cohort 1 Born 1984-1989 (24) | Prospective cohort (3.3 –10.6 years)
(CNS+ All) | Years of Birth: 1984 to 1994 | | | Sample 2: Cohort 2 born 1990-1994 (40)
| Median GA (range), wk:
| Sample 1: 24.5
| Sample 2: 24.2
| Mean BW (range), g:
| Sample 1: 751.7
| Sample 2: 697.1
| Male:
| Sample 1: 67%
| Sample 2: 55%
| Race: ND
| Enrolled: 192
| Evaluated: 64
| Number of sites: 2
Pasman 1998 98196839 | Location: Netherlands | GA=25–34 weeks, admitted to university hospital | Dysgenetic brain lesions | Sample 1: Early preterms, low risk (15) | Prospective cohort (followed to 5–7 years age)
| Years of Birth: ND | | Major congenital anomalies | Sample 2: Late preterms, low risk (21)
| Median GA (range), wk: | | Clinical syndromes | Sample 3: Early high risk preterms (8)
| Sample 1: 28.9±1.5 (25–30) | | Lost to follow-up | Sample 4: Late high risk preterms (9)
| Sample 2: 32.5±1.1 (31–34) | | | Controls: Full term (18)
| Sample 3:
| Sample 4: 30.1±1.6 (25–34)
| Controls: 39.4±1.5 (38–42)
| Mean BW (range), g:
| Sample 1: 1071±269
| Sample 2: 1568±351
| Sample 3:
| Sample 4: 1317±299
| Controls: 3144±516
| Male: ND
| Race: ND
| Enrolled: 81 (25 controls)
| Evaluated: 45 (18 controls)
| Number of sites: 2
Redline 1998 99086405 | Location: US | [underlined: Cases] (Sample 1&2): Infants with major neurologic impairment at 20 months (strictly defined CP, loosely defined CP, hypertonia, Hypotonia) and those with NL neurologic exam at 20 months. | No placental reports and slides available | Cases: VLBW infants with major neurologic impairment at 20 months (60) | Case-control (at 20 months corrected age)
| Years of Birth: 1983-1991 | [underlined: Controls]: infants born in the same year and matched for weight (±250 g), GA (±2 weeks), race, and sex who had a normal neurologic examination at 20 months. | | Sample 1: Strict CP (42)
| Median GA (range), wk: | | | Sample 2: Neurologic abnormalities (18)
| Sample 1: 27.3 ± 2.3 | | | Controls (59)
| Sample 2: 27.5 ± 2.2
| Mean BW (range), g:
| Sample 1: 978±228
| Sample 2: 1012±226
| Male: ND
| Race: African-American
| Sample 1: 57%
| Sample 2: 59%
| Enrolled: 72
| Evaluated: 60 (59 controls)
| Number of sites: 2
Rogers 1998 98438124 | Location: US | GA < 33 weeks live birth with unspecified IVH | ND | Sample 1: No growth failure (23) | Retrospective cohort
| Years of Birth: 1988 to 1993 | | | Sample 2: Growth failure (18)
| Median GA (range), wk:
| Sample 1: 27.9±2.0
| Sample 2: 27.6±1.8
| Mean BW (range), g:
| Sample 1: 1158±330
| Sample 2: 1082± 290
| Male: ND
| Race: ND
| Enrolled: 41
| Evaluated: 41
| Number of sites: 1
Spinillo 1998 98237382 | Location: Italy | GA 24–33 completed weeks | Severe malformations or chromosome abnormalities | Sample 1: Preterm infants with CP (40) | Prospective cohort (3, 6, 12, and 24 months)
Spinillo, 1997 98021316 & 97277958 | Years of Birth: 1987 to 1993 | Had a US scan done before 20 weeks' gestation | | Sample 2: Preterm infants without CP (305)
*have some overlapped sample with spinillo, 1994 | Median GA (range), wk:
| Cases: 29.6
| Controls: 30.5
| Mean BW (range), g:
| Cases: 1317
| Controls: 1451
| Male: 52%
| Race: ND
| Enrolled: 461
| Evaluated: 345
| Number of sites: 2
Tin 1998 99046171 | Location: North of England | GA 23–l31 weeks | ND | 1983 cohort (230): | Prospective cohort
| Years of Birth: 1983, 1990-1991 | | | Child reviewed without difficulty (204) | *2 Cohorts of different time periods
| Median GA (range), wk: ND | | | Child traced with difficulty (14)
| Mean BW (range), g: ND | | | Child seen with difficulty after child was traced (12)
| Male: ND | | | 1990 to 1991 (566):
| Race: ND | | | Child reviewed without difficulty (505)
| Enrolled: 1983 (230); 1990-1 (566) | | | Child traced with difficulty (26)
| Evaluated: 1983 (230); 1990-1 (566) | | | Child seen with difficulty after child was traced (35)
| Number of sites: 5
Burguet 1999 99126269 | Location: France | All liveborn premature in 20 maternity hospitals in Franche-Comte region | Chromosomal or neurological congenital anomaly diagnosed in the neonatal period, discordance of 2 wks or more between pediatric and obstetrical or echographic determination of gestational age, triplets and more | Preemies (167): | Prospective (93%) and retrospective (7%) cohort (followed until 2 years of age)
| Years of Birth: : 10/1/90– 9/10/92 | | | RDS 40%
| Mean GA (range), wk: 25–32 | | | No RDS 60%
| Mean BW (range), g: 8% BW>2000g
| Male: 51%
| Race: 86% Caucasian
| SES: 5% Family precariousness
| Enrolled: 203
| Evaluated: 167
| Number of sites: 20
Cooke 1999 99257637 | Location: UK | VLBW (not specifically defined) | ND | VLBW infants (1187): | Retrospective cohort (followed until 3 years corrected age)
| Years of Birth: 1982-1993 | Have data at 3 years old | | 1982-19855 (411)
| Median GA (range), wk: ND | | | 1986-1989 (387)
| Mean BW (range), g: ND | | | 1990-1993 (398)
| Male: ND
| Race: ND
| Enrolled: 1722
| Evaluated: 1187
| Number of sites: 1
Cooke 1999 99380719 | Location: UK | VLBW infants prospectively followed birth to age 13 with MRIs between age 15–17 yrs | ND | VLBW infants (87), with white matter disorder, PVL, Ventriculomegaly, MRI abnormality | Prospectively cohort (15–17 years)
| Years of Birth: 1982-1993 | Controls: FT infants | | Controls: FT infants (8)
| Median GA (range), wk: 28.6±1.7 (24–35)
| Mean BW (range), g: 1103±203 (630–1500)
| Male: ND
| Race: ND
| Enrolled: 137
| Evaluated: 87 (8 controls)
| Number of sites: 1
Finer 1999 99436635 | Location: UK | Cases: | Lethal congenital malformations | Cases: ELBW survived infants received DR-CPR (10) | Retrospective cohort (median 28 months)
| Years of Birth: 1/1/94 to 12/31/96 | Inborn infants BW < 1000g | | Controls (10)
| Median GA (range), wk: 25 (24–28) | Received DR-CPR
| Mean BW (range), g: 663 (440–968) | Survived until discharge
| Male: 50% | Controls:
| Race: ND | Matched controls with similar mean BW and length of follow-up
| Enrolled: 177
| Evaluated: 10 (10 controls)
| Number of sites: 1
Futagi 1999 99450356 | Location: Japan | Presurfactant era cohort: | Hereditary disorders | Sample 1 | Retrospective comparative longitudinal study.
| Years of Birth: 1981-1986 and 1989 | BW less than 1000 gms | Chromosomal abnormalities | Presurfactant cohort: | Comparison done between 2 retrospective cohorts (pre-surfactant era cohort vs surfactant era cohort)
| 1993 | Admitted to NICU | Follow up less than 3 years | Born during presurfactant era, between 1981-86 [107] | [ 3–8.8 years, mean f/up: 6.0 ±1.3 yrs (not given per group)]
| Mean GA: | Born during presurfactant era 1981-1986 | Absence of documentation of neurodevelopmental or mental outcome in medical records | Sample 2:
| Sample 1: 27.2±2.2 | Follow up for at least 3 years. | | Surfactant era cohort:
| Sample 2: 26.8±2.4 | Neurodevelopmental and Mental outcome documented in medical records | | Born during surfactant era, between 1989-1993 [169]
| Mean BW: | Surfactant era cohort: same as above except
| Sample 1: 834.1±133.4 | Born during surfactant era, 1989-1993
| Sample 2: 786.0±133.2
| Males:
| Sample 1: 38%
| Sample 2: 53%
| Race: ND
| Enrolled: 305
| Evaluated: 276
| Number of sites: 1
Kim 1999 99416608 | Location: UK | Preterm (GA<37 wks) infants and term infants with an Apgar score of less than 6 at 5 minutes, neonatal hyperbilirubinemia (total bilirubin concentration of 20 mg/dl or more) and bacterial meningitis | Chromosomal abnormalities and congenital malformation | Cases: VLBW infants with CP or Developmental D (17) | Prospective cohort (at 2, 6, 12 months corrected age)
| Years of Birth: July 1996 to November 1997 | BW<2000 g | | VLBW Controls (62)
| Median GA (range), wk:
| Cases: 30.8±3.5
| Control: 31.4± 2.2
| Mean BW (range), g:
| Cases: 1557±252
| Control: 1418±376
| Male:
| Cases: 47%
| Control: 52%
| Race: ND
| Enrolled: 184
| Evaluated: 17 (62 controls)
| Number of sites: ND
Krageloh-Mann 1999 99431017 | Location: Denmark | Preterm infants | Death (1), lost to follow-up (7), parental refusal (4), difficulties with sedation for MRI (1) | Cases: preterm infants (29) | Prospective cohort
| Years of Birth: 1986-1989 | | | Controls: term-born pre-school children (57)
| Median GA (range), wk: 30.2 (27–34)
| Mean BW (range), g: 1461 (690–2655)
| Male: 66%
| Race: ND
| Enrolled: 40
| Evaluated: 29 (57 controls)
| Number of sites:1
Salokorpi 1999 99353226 | Location: Finland | Premature infants, BW < 1000 g, admitted to NICU | ND | Sample 1: CP present (27) | Prospective cohort
| Years of Birth: 1991 to 1994 | | | Sample 2: CP absence (116) | Lost to follow-up (13) due to parent refusal or because had moved to remote areas
| Median GA (range), wk: | | | | Died by the age of 2 year (72)
| Sample 1: 26.7±2.0
| Sample 2: 26.7±2.4
| Mean BW (range), g:
| Sample 1: 833±130
| Sample 2: 817± 130
| Male:
| Sample 1: 33%
| Sample 2: 46%
| Race: ND
| Enrolled: 228
| Evaluated: 143
| Number of sites: 1
Shepherd 1999 99165413 | Location: Scotland | Preterm infants admitted to the special-care unit | Genetic or prenatal anomalies | Cases: preterms (81) | Prospective cohort
| Years of Birth: 2/95 to 2/97 | | | Controls: term infants (68)
| Median GA (range), wk: 25.7–35
| Mean BW (range), g: 570–3200
| Male: ND
| Race: ND
| Enrolled: 81 (68 controls)
| Evaluated: 81 (68)
| Number of sites: 1
Stathis 1999 99325758 | Location: Australia | BW 500–999g survived to discharge | ND | ELBW survived infants (87) | Prospective cohort (followed at 4, 8, 12, months)
| Years of Birth: :1977-1986 | Cared for in study NICU
| Median GA (range), wk: 27.7(27.3–28.1) | Enrolled in follow-up programs
| Mean BW (range), g: 860 (837–833)
| Male: 36%
| Race: ND
| Enrolled: 124
| Evaluated: 87
| Number of sites: 1
Vohr 1999 99332101 | Location: US | BW 600–1250g | Non-English speaking home | Sample 1: Early IVH positive (29) | Unclear (Retrospective or prospective cohort, followed to 36 months corrected age)
| Years of Birth: 1989-1992 | Survived the first 3 years of life, and were seen for neurodevelopmental follow-up at 36 months CA | | Sample 2: Early IVH negative (249)
| Median GA (range), wk:
| Sample 1: 27.9±2
| Sample 2: 28±2
| Mean BW (range), g:
| Sample 1: 960±178
| Sample 2: 965±179
| Male:
| Sample 1: 59%
| Sample 2: 56%
| Race:
| Sample 1: Black 21%, Hispanic 3%, White 76%
| Sample 2: Black 20%, White 78%, Other 2%
| Enrolled: 392
| Evaluated: 278
| Number of sites: 3
Agustines 2000 20279724 | Location: US | BW: 500–750 g | ND | VLBW infants (36) | Retrospective cohort (followed to 30 months CA)
| Years of Birth: 1990-1995 | Born in Long Beach Hospital, between 1990 and 1995 (post corticosteroid, postsurfactant era) | | | Lost to follow-up (27)
| Median GA (range), wk: 25 (24–29) | Survived to discharge
| Median BW (range), g: 674 | Had follow up at 30 months
| Male: ND
| Race: ND
| Enrolled: 63
| Evaluated: 36
| Number of sites: 1
Breslau 2000 20298367 | Location: US | LBW cohort: <2500 g | From the target sample: were excluded children with severe neurologic impairment: CP, MR, blindness | At 11 yrs (717): | Prospective cohort (11 years)
| Years of Birth: 1983-1985 | NBW cohort: | From the analysis of incidence of severe attention problems were excluded children that already had severe attention problems at the assessment at 6 yrs | Sample 1:
| Mean GA (range), wk: ND | Born between 1983-85, that were 6 yrs old during 1990-92; when the fieldwork took place | | LBW (411)-
| Mean BW (range), g: ND Male: ND | From 2 major hospitals of South Michigan: one urban and one suburban (In each hospital, random samples of LBW and NBW children were drawn). | | Urban LBW (217)
| Male: ND | | | Suburban LBW (194 )
| Race: | | | Sample 2:
| Sample 1 (urban) Blacks: 80% | | | NBW (306) -
| Sample 1 (suburban) Blacks:11% | | | Urban NBW)164)
| Sample 2 (urban) Blacks:74% | | | Suburban NBW (142)
| Sample 2 (suburban) Blacks: 3%
| Enrolled: 1095
| Evaluated: 823→717
| Number of sites: ND
Buhrer 2000 20280896 | Location: Germany | VLBW, BW < 1500 g | ND | VLBW infants (352) | Prospective cohort (followed until 1 year CA)
| Years of Birth: 1/192– 12/31/97
| Mean GA (range), wk: 28.7 (23.2–37.2)
| Mean BW (range), g: 1149 (430–1495)
| Male: ND
| Race: ND
| Enrolled: 455
| Evaluated: 352
| Number of sites: 1
Grether 2000 20448692 | Location: US | BW < 1500g or BW 1500–1999g and <33 GA | Postural cause of CP identified. | Cases: Cerebral palsy (170) | Retrospective case-control study (2 years)
| Years of Birth: 1988-1994 | | Congenital infection identified | Controls (288)
| Median GA (range), wk:
| Cases: : 27.1±2.4
| Controls: 37.6±2.6
| Mean BW (range), g:
| Cases: 1085±350
| Controls: 1112±349
| Male:
| Cases: 56%
| Controls: 47%
| Race:
| Cases: 47% White
| Controls: 33% White
| Enrolled: 170 (280 controls)
| Evaluated: 170 (280)
| Number of sites: 22
Katz-Salamon 2000 20332284 | Location: Sweden | Cases: | Cases: | Cases: VLBW infants with CLD (43) | Prospective cohort
| Years of Birth: 1988-1993 | VLBW | Unable to be examined because of other medical problems, including congenital cardiac malformation, hepatitis C, immobilization of the legs, severe visual defect, and severe cerebra infarction | VLBW Controls (43)
| Median GA (range), wk: | Survival with CLD
| Cases: : 26.1±2.0 | Controls:
| Controls: 26.7±1.3 | No IVH>2
| Mean BW (range), g: | No CLD
| Cases: 874±183 | No PVL
| Controls: 940±179 | VLBW
| Male: ND
| Race: ND
| Enrolled: 70
| Evaluated: 43 (43 controls)
| Number of sites: 1
Marlow 2000 20150342 | Location: UK | For sensorineural hearing loss (SNHL) group | ND | Sample 1: | Retrospective case control study with a longitudinal component (unclear if retrospective or prospective)
| Years of Birth: 1990-1994 | GA: <33 wks | | SNHL group [15] | (12 mo CA)
| Mean GA: ND | Family resident of Greater Bristol area | | Sample 2:
| (Median and Range) | Records at Hearing Assessment Center of Royal Hospital for Sick children. | | Control group [30]
| Sample 1: 28 (26–31) | Born during 1990-1994 | | Matched with cases for sex, GA, admission dates in NICU
| Sample 2: 28 (26–31) | Diagnosis of SNHL of 50 dB
| Mean BW: ND | For control group:
| (Median and range) | Matched controls 2:1 to cases
| Sample 1: 960 (600–2914) | Admitted to the same NICUs as cases
| Sample 2: 1026 (410–2814) | Matched for sex and GA and next and preceding matching children in the admission books of St Michael's and Sothmead hospitals
| Male: ND
| Race: ND
| Enrolled : 27
| Evaluated: 15
| Number of sites: 1
Palta 2000 20096107 | Location: US | Birth weight =1500 g | Refusing participation at follow-up | VLBW infants (425) | Prospective cohort (followed to an average age of 5 years)
(CNS+Eye) | Years of Birth: August 1988–June 1999 | Survived to 5 years of age
| Median GA (range), wk: 28.54±1.97 | Parental agreement to potential follow-up and provided recontact information before discharge.
| Mean BW (range), g: 1003±155
| Male: 43%
| Race: ND
| Enrolled: 626
| Evaluated: 425
| Number of sites: 6
Torrioli 2000 20275419 | Location: Italy | BW < 1500 gm | Frankly disabling conditions (CP, MR, blindness, CNS infections, genetic syndromes, etc.); abnormal head ultrasound findings | VLBW preterm infants (36) | Prospective cohort
(CNS+Eye) | Years of Birth: 1991-1993 | Controls: born at term and without any perinatal or neonatal complication, matched for age, gender and socioeconomic condition including occupational status of the family and parents' educational status was performed by the same observers that examined the study group | Refused to participate in the study
| Median GA (range), wk: 32 (21–34)
| Median BW (range), g: 1120(560–1500)
| Male: 42%
| Race: ND
| SES: “medium and there was the same ethnic background”
| Enrolled: 86
| Evaluated: 36 (ND on number of controls)
| Number of sites: 1
Valkama 2000 20233239 | Location: Finland | VLBW <1500g and <34 weeks | Congenital anomalies | VLBW preterm infants (51) | Prospective cohort (18 months)
| Years of Birth: 11/1/1993–10/31/1995 | | Died during neonatal period
| Median GA (range), wk: 29.3±2.2 (24.9–33.7) | | Parental refusal
| Median BW (range), g: 1153±289
| Male: 53%
| Race: ND
| Enrolled: 62
| Evaluated: 51
| Number of sites: 1
Vohr 2000 20295211 | Location: US | Live born BW 401–1000 g | ND | 1151 extremely low birth weight survivors cared for in the 12 participating centers of the National Institute of Child Health and Human Development Neonatal Research Network | Prospective cohort (18–22 months corrected age)
| Years of Birth: 1/93–12/94
| Median GA (range), wk:
| Mean BW (range), g:
| Male:
| Race:
| Enrolled:
| Evaluated:
| Number of sites: 12
Dammann 2001 21334215 | Location: Germany | BW ≤1500g | ND | LBW infants (324): | Prospective cohort (6 years)
| Years of Birth: July 1983–June 1986 | | | SGA (92) | 7 non-BSCP cerebral palsy (no further explanation)
| Median GA (range), wk: ND | | | AGA (232)
| Mean BW (range), g: ND
| Male: ND
| Race: ND
| Enrolled: 591
| Evaluated: 324
| Number of sites: 1
Gaillard 2001 21221175 | Location: UK | Retrospective cohort : | If transferred from another hospital after first postnatal week (mostly surgical referrals) | Sample 1 : | First component:
| Years of Birth: 1994-1996 | All infants born from 1/1/1994 to 12/31/1996 | If ventilated after 27 postnatal days after a surgical procedure requiring anesthesia | Ventilated beyond 27 (but not 50) postnatal ds (56) | Retrospective longitudinal cohort with case-control design and cases defined based on exposure (length of ventilation). Unmatched. (3 years)
| Mean GA: ND (only median and range given) | Born at Liverpool Women's Hospital | | Sample 2: | Second component:
| Sample 1: 26 (23–34) | Ventilated beyond 27 postnatal days | | Ventilated beyond 49ds ( 28) | Retrospective longitudinal cohort study With two historical control groups (3 years)
| Sample 2: 26 (23–33)
| Mean BW: ND (only median and range given)
| Sample 1: 852 (520–2710)
| Sample 2: 745 (580–1620)
| Male:
| Sample 1: 57%
| Sample 2: 50%
| Race: ND
| Enrolled: 100
| Evaluated: 84
| Number of sites: 1
Horwood 2001 20574647 | Location: US | VLBW infants admitted to neonatal unit still living in New Zealand at time of assessment, 7–8 years of age | Death | VLBW infants (298) | Prospective cohort
| Years of Birth: 1/93 to 12/96 | | 17 children could not complete IQ testing because of substantial disability
| Median GA (range), wk: ND
| Mean BW (range), g: ND
| Male: ND
| Race: ND
| Enrolled: 413
| Evaluated: 298
| Number of sites: 1
Nadeau 2001 21163667 | Location: Canada | Cases: GA<29 weeks, BW<1500 g | Cases: | Cases: EP/VLBW infants (86? 61) | Prospective cohort (at 18 months, 5 years 9 months, and age 7)
| Years of Birth: 1987-1990 | Controls: Normal BW children , born at the same hospital during the same time period | Lost to follow-up at 5 years 9 months: families had moved away (33), parents' refusal (10)
| Median GA (range), wk: | | Lost to follow-up at age 7: families had moved away (10), parents' or school's refusal (13)
| Cases: 27.4±1.1
| Control: 39.8±1.6
| Median BW (range), g:
| Cases: 1024.3±204.2
| Control: 3453.4±497.8
| Male:
| Cases: 51%
| Control: 50%
| Race: ND
| Enrolled: 129
| Evaluated: 86 ? 61 (50 controls)
| Number of sites: 1
Pierrat 2001 27221167 | Location: France, Netherlands | GA < 32 weeks, admitted to Lille and Utrecht | ND | Preterm infants with PVL (78): | Prospective cohort (1 year)
| Years of Birth: 1990-1998 | Diagnosis of grade II or III PVL | | Grade II (39) | Cysts on the first scan and therefore were considered to be of antenatal onset (7), admitted after the first month of life with evidence of cysts on the first scan (9); no definite classification could be achieved (2)
| Median GA (range), wk: 28.54±1.97 | | | Grade III (39)
| Mean BW (range), g: 1003±155
| Male: 43%
| Race: ND
| Enrolled: 72
| Evaluated: 60 (59 controls)
| Number of sites: 2

Evidence Table 3. Studies Evaluating Association of LBW and Cerebral Palsy and Neurological Outcomes Part II

Author, Year | Predictors | Predictor Measures | Outcomes | Outcome Measures
Leonard 1990 90204169 | CNS Predictors: | Intracranial/ Intraventricular hemorrhage - Grades 0–IV by Papille; head CT if born before 1981, head U/S is born after 1981 | CNS: | Cognitive delay: measured by McCarthy Scales of Chilren's Abilities, Wechsler Intelligence Scale for Children (Revised), Wechsler Preschool and Primary Scale of Intelligence, and Stanford-Binet
| Intracranial/ Intraventricular hemorrhage | Parenting risk factor - defined as referral by a physician, nurse, or health professional to child protective services for neglect or mild abuse (none were for severe abuse) | Neurodevelopmental: | “mild” - score between 1–2 SD below the mean (69–83)
| Cardiovascular or Pulmonary Predictors: | Low socioeconomic status - one or both parents unemployed, mother not complete high school or health insurance through public assistance | 1) Cognitive delay | “moderate to severe” - score >2 SD below the mean
| Number of days on supplemental oxygen to help pO_2_ > 50 | | 2) Neurologic abnormalities | Neurologic abnormalities: abnormalities in muscle strength, tone, reflexes or movement that cause functional impairment, i.e. hemiplegia, ataxia, quadriplegia. Clumsiness or mild tremors [underlined: not] included.
| Other predictors:
| Parenting risk factor
| Low socioeconomic status
Lucas 1992 92122860 | Primary predictor: General: | Social class: 4 categories: | IQ score in Weschler Intelligence Scale for Children-Revised-Shortened version (WISC-R)-Anglicised. | Not further specified
| 1) Maternal choice to breast feed | •Social class I or II | 1) Verbal scale
| Secondary predictors: | •Non manual Social class III | 2) Performance scale
| Others: | •Manual social class III | 3) Overall IQ
| 1) Received mother's milk | •Social class IV or V | (Assessment at 9 mo, 18 mo, 7.5–8 yrs)
| 2) Social class | Mother's education: 5 point scale
| 3) Maternal education | From 1: no educational qualifications
| 4) Gender | To 5: degree or higher performance qualifications
| 5) Days of ventilation
Robertson 1994 94181384 | Birth weight | ND | CNS: | CP definition was that of Bax, “A disorder of movement and posture due to a defect or lesion of the immature brain”, along with more recent guidelines by Levine using at least four of six clinical motor abnormalities leading to a constellation of findings of the cerebra palsy syndrome
| | | CP | Mental retardation = scores Bayley mental scales.
| | | Neurodevelopmental: | Initially by newborm screening; with subsequently tested repeatedly in a sound booth and/or by bristem audiological evoked response.
| | | Motor delay | Visual loss: acuity in the best seeing eye after correction, <20/60) including legal blindness (corrected acuity, <20/200)
| | | Seizure disorder | Hearing loss (loss of >= 30 dB binaurally)
| | | Multiple disabled
| | | Ophthalmology: Visual
| | | Audiology: Hearing
Spinillo 1994 94257064 | Cause of antepartum bleeding | Histological examination of detached placeta were used for confirmation of clinical classification | CNS: | Amiel-Tison and Grenier Neonatal neurological Examination
*have some overlapped sample with spinillo, 1997 | CNS: | Diagnosis of IVH and PVL according to US finding | CP | Major neonatal handicaps included definite CP such as spastic diplegia, hemiplegia or tetraplegia causing definite physical disability with moderate to severe interference with functioning, or mental retardation (Bayley Scale)
| Intracranial hemorrhage | | Neurodevelopmental:
| Periventricular leukolacia | | Motor and cognitive delay
| | | Mental retardation
| | | Presence of grade 3–4 IVH or PVL
Chen 1995 96009403 | CNS: | ND | CNS: | Development Screening test, modified for Chinese children
| 1) Intracranial hemorrhage | | Motor delay | Diagnosed by “complete neurological exams”, including transient spasticity and spastic di-/ quardriplegia
| 2) Periventricular leukomalacia | | CP
Goetz 1995 96119489 | PVL | ND | CNS: | ND
| | | CP
| | | Neurodevelopmental:
| | | Motor and cognitive delay
| | | Seizure disorder
| | | Ophthalmology:
| | | Visual impairment
Speechley 1995 96356544 | General: | Not further specified | Physical health outcome at 12 yrs | Based on responses on an interviewer administered and self-report questionnaire.
| 1) Former NICU graduate (of any BW) | | 1) Chronic physical health (mother's report) | Physical health outcome at 12 yrs
| 2) Gender | | 2) Lifetime hospitalizations (mother's report) | 1) Chronic physical health (mother's report): Precoded 25 chronic illnesses
| | | 3) Physical impairments (mother's report) | 2) Lifetime hospitalizations (mother's report)
| | | 4) Perception of child's heath (child's report) | 3) Physical impairments (mother's report):response to a question asking whether their child had any physical impairments
| | | 5) Perception of child's health (mother's report) | 4) Perception of child's heath (child's report): 4-item scale
| | | Emotional and social well being at 12 yrs: | 5) Perception of child's health (mother's report): 4-item scale
| | | 1) Internalizing problems (child's report) | Emotional and social well being at 12 yrs:
| | | 2) Externalizing problems (child's report) | 1) Internalizing problems (child's report) 3-item scale
| | | 3) Social competence (child's report) | 2) Externalizing problems (child's report) 3-item scale
| | | 4) Social support (child's report) | 3) Social competence (child's report) 36-item scale
| | | 5) Self esteem (child's report) | 4) Social support (child's report) 24-item scale
| | | 6) School performance (mother's report) | 5) Self esteem (child's report) 10-item scale
| | | | 6) School performance (mother's report) 5-item scale
Wildin 1995 95385294 | CNS: | | CNS:
Wildin 1997 97422739 | 1) Neurological exam- 6 months – 12 months | Based on Amiel-Tison examination done at 6 months corrected age | Neurodevelopmental: | Stanford-Binet developmental test
*Data from same longitudinal study as Anderson, 1996 96314587 & Smith, 1996 97081985; overtapped sample | 2) Quantitative neurologic score | | Motor delay | McCarthy Gross Motor subtests
| Other: | | Cognitive delay | Bayley scale
| 1) Socioeconomic status | | Rate of development
| 2) Medical risk category: High Risk (HR); Low Risk (LR) | High medical risk = severe medical complications of prematurity
Anderson 1996 96314587 | Other Predictors: | Based on the severity of neonatoal complications grouping into High- and Low- risk groups: | CNS: | Baley Mental and Psychomotor development indices (MDI, PDI)
Smith 1996 97081985 | Illness Acuity - grouped into low-risk and high-risk. | High risk: =1 severe neonatoal complications, including chronic lung disease (bronchopulmonary dysplasia), grade III or IV intraventricular hemorrhage, and periventicular leukomalacia | Neurodevelopmental: Cognitive delay | Neurologic scores based on scales developed by Amiel-Tison, Baird and Gordon, and Swaiman
(CNS+All) | Maternal Behaviors: | Low risk: : =1 less severe neonatal complications, including transient respiratory distress, respiratory distress syndrome, and grade I or II intraventricular hemorrhage, and periventicular leukomalacia | Audiology: Language | Sequenced mixture of communication development
*Data from same longitudinal study (U. of Texas Health Sciences Center in Houston and the U. of Texas Medical Branch in Galveston) as Wildin, 1995 & 1997; overlapped sample | 1) warm sensitivity | Maternal Behaviors - home observation with use of a rating scale. | Other: Living skills | Daily living skills subscale from Adaptive Behavior Scale
| 2) Maintaining of infant interests and directiveness
Kato 1996 97182916 | VLBW | VLBW= ND | CNS | ND
| GA | Small for Dates = ND | CP:
| Sex | PROM = ND | Neurodevelopmental:
| Perinatal factors (mat age, parity, preeclampsia, previa, PROM, fetal presentation, | | Mental retardation
| | | Seizure disorder
| | | Blindness
| | | Lump all together as major handicap
Katz 1996 97145056 | General: GA | IA IVH: no lesion= consistently NC scans. | CNS: | Measured by CPT test (continuous Performance Test) measuring errors of omission or commission.
| CNS: | Mild lesion = germinal hem or small IVH or PVD or mild vent dilation without hem. | Neurodevelopmental: Attention | Is also measured by CBCC (Child Behavior Check List): parents check off behavior related to n attention and hyperactivity.
| 1) Intracranial/ Intraventicular hemorrhage | Severe lesion: blood distends the vents or in parenchyma, or multicystic PVC. | IQ | Measured by British Abilities Scale
| 2) Periventricular leukomalcia (cystic PVD)
| 3) PVD (if unilateral or bilateral periventicular echogenic lesions present on at least 3 scans)
Korkman 1996 96374730 Psy1996 | Main predictors: | 1) | 1) | Psychometric Intelligence score: by Finnish standardized Revised version of the Wechsler Intelligence Scale for Children (WISC-R 1984)
| General: | 2) VLBW: less than 1500 g | 2) Psychometric Intelligence score. | 1) FSIQ: Full Scale IQ
| 1) VLBW and AGA (surrogate for perinatal asphyxia in preterm) | 3) SGA: 2 SD below normal for GA | 3) Detailed Neuropsychological assessment score. | 2) VIQ: Verbal IQ
| 2) VLBW and SGA (surrogate for ante-natal asphyxia in preterm) | 4) Birth asphyxia: Umbilical arterial ph<7.05 | 4) Neurological Disability status examination | 3) PIQ: performance IQ
| Secondary predictors | 5) Or Apgar scores at 5 min less than 6 | (Assessment between 5–9 yrs) | Detailed Neuropsychological assessment score:
| General: | | | 1) NEPSY test ( a new test consisting of testing of attention, language, motor, sensory, visuospatial and memory subsets)
| 1) Apgar scores | | | 2) The Token test shortened version
| 2) Arterial PH at 2 hrs of life | | | 3) The VMI test
| 3) Intrauterine growth retardation | | | Established Finnish norms.
| 4) BW | | | Scores reported as SD scores (z scores)
| Pulmonary: | | | Sum scores in all 3 tests also calculated
| 1) RDS | | | Neurological Disability status assessment: not specified
| 2) Duration of ventilatory tx
| CNS:
| 1) IVH
Lucas 1996 96302121 | General: | Full breast milk Fortification vs Minim supplementation with minerals only, both groups received vitamins | CNS: | At 9 month: Knobloch Developmental Inventory
| 1) Full fortification for breast milk | | 1) Neurodevelopmental: | At 18 month: Knobloch; Bayley scales; Vineland test of social maturity
| | | 2) Motor delay
| | | 3) Mental retardation
| | | Audiology:
| | | 1) Language
| | | Other:
| | | 2) Social development
Rieck 1996 Psy 1996 06905005 | In prospective longitudinal component: | Neurologic complications in NICU: | CNS: | MSCA:
| General: | 1) Severe asphyxia | Neurodevelopmental outcome: | Translated in Hebrew
| 1) Perinatal factors: | 2) Loss of consciousness | 1) Scores in McCarthy's 5 Scales of Children's Abilities test (MSCA) | Adapted to Israeli children
| 2) BW | 3) Convulsions | 2) General Cognitive Index (GCI) score | 5 scales:
| 3) GA | 4) IVH grade 3–4 | (Assessment between 3–7 yrs of age) | 1) Verbal
| 4) SGA | 5) CNS infections | | 2) Perceptual-Performance
| 5) Neurological complications in NICU | HC percentile: | | 3) Quantitative
| 6) Sex | 1) > 20% | | 4) Memory
| Growth: | 2) 3–20% | | 5) Motor
| 1) HC percentile | 3) < 3% | | (GCI) scores:
| CNS: | Country of origin: | | From subtests of the :
| 1) Developmental scores at 1–2 yrs of age | Israel | | 1) Verbal
| Others: | Euro-American | | 2) Perceptual-performance and
| 1) Age at assessment | Asian-African | | 3) Quantitative scales
| 2) Parental (mother's and father's) age
| 3) Parental education
| 4) Country of origin
| Prospective comparative component.
| • VLBW vs Middle class term child
| And vs Low class term child
Whitaker 1996 97040639 | General predictors: | Mat-Social Disadvantage: not high school gradated; nonwhite race; income from public assist; <19 yrs; not married. | CNS: | Test of language Development
| BW,GA, SGA/IUGR | According to US findings | Neurodevelopmental: | Stanford-Binet Intelligence Scale
| Chronic illness, Apgar score | | Cognitive delay
| Sex | | Mental retardation
| CNS Predictor: | | Memory
| IVH | | Ophthalmology : Visual perceptual
| PL/VE | | Audiology: Language
| Bronchopulmonary dysplasia
| Maternal-social disadvantage
Blitz 1997 97154301 | Neonatal complications of ELBW infants, including meningitis, PVL, hydrocephalus, seizures, IVH, BPD, ROP, and whether the infant was discharged on oxygen | Diagnosis based on hospital course. IVH = grade III | CNS: | BSID (Bayley Scale of Infant Development), MDI (Mental Developmental Index), PDI (Psychomotor developmental Index), CLAM (Clinical Linguisitc and Auditory Milestone Scale): Total (CLAM-T), Expressive (CLAM-E), and Receptive (CLAM-R) scores
| | | CP | Neurodevelopmental examination, modified after Amiel-Tison and the Primitive Reflex Profile
| | | Neurodevelopmental | ND
| | | Development outcome | Strabismus, hyperopia, myopia, or retinal detachment
| | | Neurologic Outcome
| | | Ophthalmology:
| | | Visual problems
| | | Audiology:
| | | Hearing loss
| | | Hearing loss
| | | Visual problem
Cheung 1997 97310950 | IVH grade III or IV | Diagnosed by US finding | CNS: | Cognitive delay - Belay Mental and Psychomotor development indices (MDI, PDI)
| | | Cognitive delay | Normal neurodeveloplement: free of neurodevelopmental disability, with Bayley scores higher than 2 SD below the mean
| | | | Neurodevelopmental disability: cerebral palsy or blindness or hearing loss
Ekert 1997 97251211 | General: | Diagnosis of IVE or PVE according to US findings | CNS: | Motor and cognitive delays: Bayley score of < 84 (i.e., = 1 SD below mean) or developmental quotient (developmental age divides by corrected age) of < 0.75
| 1) Birth weight | | Motor delay | Evidence of hypertonicity and hyperreflexive in association with at least gross motor developmental delay
| 2) GA | | Cerebral palsy
| 3) Apgar score | | Cognitive delay
| CNS:
| 1) Intracranial / Intraventricular hemorrhage
| 2) Periventricular leuko-malacia
| Cardiovascular/pulmonary:
| 1) Bronchopulmonary dysplasia other: a) ventilator days, b) 02 days
| Other:
| Hospital/health care resource (admission days) utilization.
Gerner 1997 97329414 | General: | Maternal education:3 levels | 1) Griffith's Developmental Scale for Psychomotor development | Griffith's developmental scale, standardized for Swedish infants: 5 subclasses
| 1) Prematurity (per se) | Parity: 0 or more | 2) Total Score (sum of subclasses scores) | Scale A: locomotor function,
| 2) General maternal, obstetric, and perinatal predictors: | Maternal toxemia, Maternal septicemia, Placental bleeding: presence or absence | 3) Individual subclasses Scores | Scale B: Personal-social competence,
| • Maternal education | Intrauterine growth: SGA or AGA | (Assessment at 10 months of age) | Scale C: hearing and speech
| • Maternal age | Cardiotocography: normal or abnormal | | Scale D: Hand and eye coordination: fine motor grasping
| • Parity | All cranial U/S findings classified according to the most advanced stage observed | | Scale E: Performance: Perception and intelligence scale
| • Maternal toxemia | Subependymal bleeding: 3 grades: | | Scale Specificity of subclasses: limited when infants tested are immature/ Specificity increases with age.
| • Maternal septicemia | B1: isolated germinal matrix/ subependymal haemorrhage
| • Placental bleeding | B2:IVH without ventricular dilatation
| • Sex, Gestational age, Birth weight, Intrauterine growth, Cardiotocography, Apgar score at 5 min | B3:IVH with ventricular dilatation
| 3) CNS: | Intraparenchymal lesions: 4 grades:
| (Ultrasound findings) | W1:Subtle or diffuse echodensity
| • Subependimal bleeding | W2: Definite, distinct echodensity
| • Intraparenchymal lesions | W3: perventricular cystic formation (PVL) Intraparenchymal
| 4) Cardiovascular or Pulmonary: | W4: echodensity of haemorrhagic type or other gross pathology
| • PDA, RDS, Surfactant therapy, Days of Ventilatory tx, Chronic Lung Disease (CLD), Pneumothorax, | W1 – W2: correspond to non-cystic PVL
| 5) Other : | B1–3 plus W1–4
| • Age at time of test, Infantile septicemia | PDA: none, spontaneous/ pharmacologic closure, Surgical ligation
| | RDS: presence or absence
| | CLD: according to Bacalari criteria
| | Infantile septicemia: verified by blood culture: staph epi, candida, naerobic bacteria, other.
| | (The other predictors were not specifically defined)
Koller 1997 97193708 | General: | Neurological status at 1 year corrected age: | CNS: | Bayley MDI, Stanford-Binet IQ, Wechsler scale
| 1) Birth weight | (1) abnormal, a severe abnormality, such as CP, global hypotonicity, chronic seizure, hydrocephaly, blindness, or severe sensorineural hearing loss, for which a diagnosis could be established | Neurodevelopmental:
| 2) GA | (2) suspicious, some atypical or questionable signs in tone, reflexes, gait, or movement, but for which there is no definitive diagnosis or syndrome | Cognitive delay
| 3) Illness severity-neonatal health index | (3) Normal, based on a completely normal neurologic examination
| 4) maternal education
| CNS:
| Neurological status at 1 year
Murphy 1997 97192793 | General: GA, Apgar score | Definitions not given for most predictors. | CNS: | Obtained diagnosis from regional registry of childhood impairments.
| CNS: | | Cerebral palsy
| Intracranial/Intraventricular hemorrhage
| White Matter Disorder
| Periventricular leukomalacia
| Ventriculomegaly/Ventricular diration.
| Seizures
| Cardiovascular:
| Bronchopulmonary dysplasia
| Preurmothora
| GI: Total Patenteral Nutrition
| Other:
| Infectious disease, Transfusion
| PDA, Prolonged ventilation.
Schendel 1997 98033417 | General Predictors | ND | CNS: | Developmental delay measured by Denver Developmental Screening Test II.
| 1) Birth Weight- 3 groups | | Other: Developmental Delay | “DELAY” defined by 9 measures of performance on Denver Developmental Screening Test II at age 15 months corrected.
| VLBM ( very low birth wt) | | Pulmonary Outcomes
| MLBW (moderately low birth wt.) | | Birth weight
| NBW (normal birth wt)
| Other Predictors
| 1) Other: married at birth
| 2) Other: Medicaid recipient
Thompson 1997 97268338 | Other predictors: | NBRS→weighted scored of medical events: ventilation, acidosis, seizures, IVH, PVL, sepsis and hypoglycemia | CNS: | McCarthy scales at age 4 years
| 1) Neurobiological Risk Score (NBRS) | | Neurodevelopmental: | Definition: not clear on how well validated either of the predictors are.
| 2) Hasseles Scale Score (HSS) → divided mothers into high and low risk; a “stress” score | | Cognitive delay | Definitions of NBRS and Hasseles scores are probably OK, but I am not familiar with these
| 3) Maternal variables
Victorian Infant Collaborative study Group 1997 98026322 | General: BW | Each sample were subdivided into BW=500–749 g and BW=750–999 g | CNS: | CP was not defined
*There are a series of Victorian articles in LBW-ALL. | Other: period of time when born | 1985-1987 vs. 1991-1992 | Cerebral palsy | Bayley Scales of Infant Development
*This study will be combined in LBW-ALL table | | | Neurodevelopmental: | DQ, using the published mean and SD
| | | Cognitive and motor delay | Disability: “Sever” — bilateral lindness, cerebral palsy with the child unlikely ever to walk, or a DQ score <-3SD; “Moderate” — bilateral sensorineural deafness requiring hearing aids, cerebral palsy in children not walking at 2 but expected to walk, or a DQ score from -3SD to <-2 SD; “Mild” — cerebral palsy but walking at 2 , or a DQ score form -2 SD to <-1 SD.
| | | Disability
| | | Ophthalmology: Blindness
| | | Audiology: Deafness or hearing aid
Battin 1998 99002694 | General: | ND | CNS: | Neurologic exam
| 1) GA (23–25 wks) | | 1) Neurodevelopmental outcome | Bayley scale: MDI, PDI
| In comparative component with Historical control group | | 2) CP | Formal hearing test
| General: | | 3) Low MDI (below 2 SDs) | Ophthalmologic examination
| 1) Birth during a period with routine use of: antenatal steroids, surfactant and dexamethasone for BPD ( vs birth in presurfactant, presteroid period) | | Ophthalmology- Audiology:
| | | 1) Blind, Deaf
Bos 1998 98218970 | General predictors | Diagnosed by US examination. The duration was determined for the frontal and the parieto-occipital region separately and classified according to four categories: (1) no echodensities, (2) echodensities between 1 and 6 d, (3) echodensities between 7 and 13 d, and (4) echodensities persisting for more than 14 d | CNS: | Developmental trajectory of general movement quality, analyzed according to Prechtl's method. Movements were judged globally based on visual Gestalt perception. Normal general movements are characterized by complexity, variability, and fluency.
| Quality of general movements | | Neurodevelopmental
| CNS | | CP
| Head ultrasound finding of transient periventricular | | Cognitive delay
| Echodensities
Cherkes-Julkowski 1998 98262696 | General: GA | ND | CNS: | Cognitive delay, measured by Stanford-Binet
| Other: Mother perception of childcompetence | | Cognitive delay | School programs (school concerns = SC)
| | | Neurodevelopmental | Learning disabilities (LD)
| | | School problem | Neurological Impairment (NI)
| | | Neurological Impairment (NI) | Attention deficit Disorder (ADD)
| | | Attention Deficit Disorder (ADD) | Language impairment = LI - dx made by speech and language clinician
| | | Audiology:
| | | Language
Emsley 1998 98238139 | General | | CNS : | ND
(CNS+ All) | 1) Birth weight | | CP | “Normal”- No clinically apparent developmental abnormality causing functional disability
| 2) GA | | Neurodevelopmental | “Mild Disability” - myopia, language delay, mild hearing loss, hyperactivity or clumsiness.
| CNS | | Disability : normal, mild, moderate severe | “Moderate Disability” - Spastic diplegia, hemiplegia, moderate learning disability (DQ 50–69)
| 1) Other: significant cranial U/S findings (see page 1 for definition) | | Behavioral disorders | “Severe Disability” - spastic quadriplegia, blindness, deafness (> 70 dB), uncontrolled epilepsy or severe learning disability (DQ < 50) and multiple disabilities.
| Other: | | Learning disabilities | Not defined or how it is measured
| 1) Illness acuity - CRIB score | CRIB score is determined by BW, GA< congenital malformations, max base excess in first 12 hours, minimum FIO_2_ in first 12 hours and max FIO_2_ in first 12 hours | Seizure disorder | ND
| 2) Other: male sex | | Developmental Delay | DQ < 70
| | | Ophthalmology : | > 70 dB, dot defined or how it is measured
| | | Blindness | ND
| | | Other
| | | Squint
| | | Audiology:
| | | Deafness
| | | Speech delay
Pasman 1998 98196839 | CNS | | CNS | Standardized testing:
| 1) Other: Neurobiologic risk score (NBRS) | 13 items of NBRS | Neurodevelopmental: | VMI
| 2) Neonatal Neurologic Inventory (NNI) table 1 | 4 items of NNI | Cognitive delay | Leiden diagnostic test
| | | Mental retardation | WISC-R
| | | | BWVR
| | | | ADIT
Rogers 1998 98438124 | Birth weight | IVH according to discharge clinical record diagnosis | CNS: | According to discharge clinical record diagnosis (quadriplegia, diplegia, or hemiplegia)
| GA | | CP | Weight-for-age z score was more than 2 SD below the mean and subsequently fell below -2 SDS
| Periventricular | | Neurodevelopmental:
| Bronchopulmonary dysplasia | | Growth failure
| Hospital/Health care resource utilization-length of stay
Spinillo 1998 98237382 | General predictors: | Preeclampsia defined as: | CNS | CP: Spastic diplegia, hemiplegia, tetraplegia , With moderate to severe interference with function, With or without mental retardation (MDI< 71)
Spinillo, 1997 98021316 & 97277958 | 1) Birth weight' | 1) Diastolic BP> 90 | CP | Bayley scales
*have some overlapped sample with spinillo, 1994 | 2) GA | 2) Systolic BP> 140 | Neurodevelopmental: Mental retardation
| 3) SGA/IUGR | 3) Proteinurea> 0.3 g
| 4) Maternal disease (diabetes, respiratory, cardiovascular, renal etc) | Severe preeclampsia defined as:
| 5) Antenatal steroids | 1) Diastolic BP> 110
| Other predictors: | 2) Systolic BP> 160
| 1) Infectious disease | 3) Proteinurea> 3 g
| 2) Dexamethasone | Intrapartum Fetal HR abnormalities:
| 3) Perinatal factors (Socioeconomic factors, pregnancy variables, Delivery variables) | • Late decelerations
| 4) Meconum-stained amniotic fluid | 1) Variable decelerations
| | 2) Bradycardia
| | Tachycardia
Tin 1998 99046171 | General: GA (23–31 wks) | ND | CNS: | Definition of “severe disability” and “severe sensorimotor disability” were not given in this article . They referred to the wrong reference for these definitions, therefore, I am unable to find the definitions.
| | | Neurodevelopmental: | Reference population for Griffith's scales were “preterm babies in the study S serious sensorimotor disability”
| | | 1) Mental retardation (IQ < 75)
| | | 2) Other; disability (severe, severe sensorimotor)
| | | 3) Other: development - assessed by Griffith's mental and developmental scales
Burguet 1999 99126269 | General Predictor: | RDS diagnosed by chest radiography examination | CNS: | One or more of the following signs was observed - hemiplegia, diplegia, tetraplegia, dystonia, athetosis, blindness, or neurosensory deafness
| 1) Male gender | PROM = premature rupture of membrane | CP
| Cardiovascular | | PVL
| 1) Bronchopulmonary dysplasia
| Other predictor:
| 1) Infectious disease neonatal sepsis
| 2) Maternal hypertension
| 3) RDS
| 4) Outborn birth
| 5) Race
| 6) Urban residence
| 7) Family precariousness = father absent or both parents unemployed
| 8) PROM > 48 hours (preterm)
| 9) Monochorionic placentation
| 10) Singleton placentation
| 11) Dichorionic placentation
Cooke 1999 99257637 | General predictors: | ND | CNS: | Data from Regional Cerebral Palsy Register
| Antenatal steroids | | CP
| Period of birth
| CNS:
| IVH
| Periventricular leukomalacia
| Other:
| Surfactant use
Cooke 1999 99380719 | Birth weight | ND | CNS: | IQ: WISC III
| CNS: white matter disorder, periventricular leukomalacia, ventriculomegaly, MRI abnormality, thinning of corpus callosum, povencephaly, Brain measurements (multiple) | | Motor delay | Motor delay (motor disability): Movement of ABC scores
| | | Cerebral palsy | Mental retardation
| | | Cognitive delay | Behavioral disorders
| | | Mental retardation | School problems
| | | Behavioral disorders | Learning disability: Suffolk Reading Scale. Basic Math and Spelling Test
| | | School problems
| | | Learning disabilities
Finer 1999 99436635 | CNS Predictors: | Defined as chest compressions and/or epinephrine used. | CNS: | In the first year, neurodevelopmental assessment by Amiel-Tison Neurologic Screen. Thereafter, used Knoblick-Gesell Developmental Inventory.
| Delivery room resuscitation (DR-CPR) | | Neurodevelopmental | “Neuromotor Outcome - questionable”: hypotonia, hypertonia, asymmetry
| | | 1) Motor delay | “Neuromotor Outcome - abnormal”: cerebral palsy
| | | 2) Post hemorrhagic hydrocephalus (PHH) | “Developmental Outcome - normal”: both mental and motor composite scores ?86
| | | 3) Apgar scores | “Developmental Outcome - questionable”: either score 76–85
| | | 4) IVH/echolucenies | “Developmental Outcome - abnormal”: either score <75
| | | 5) Developmental | “Neurodevelopmental Outcome - normal” if both neuromotor and developmental evaluations are normal. “Neurodevelopmental Outcome - questionable” if either neuromotor or developmental evaluations are questionable.
| | | 6) White matter injury | “Neurodevelopmental Outcome - abnormal” if either neuromotor or developmental evaluations are abnormal.
| | | | “White matter injury”: presence of grade 4 hemorrhage, echolucencies, or ventricular dilation unrelated to hemorrhage.
Futagi 1999 99450356 | General: | Not specified further | 1) Normal neurodevelopmental outcome | 1) Normal neurodevelopmental outcome: Absence of motor disturbances and developmental quotient and/or intelligence quotient more than 84.
| 1) Birth in surfactant era 1989-1993 vs Birth in pre-surfactant era 1981-1986 | | 2) Cerebral palsy | 2) Cerebral palsy: diagnosis based on Bax criteria (Outcome data also given for one child with spinal palsy: no definition given)
| | | 3) Mental retardation | 3) Mental retardation: DQ or IQ scores less than70
| | | 4) Borderline intelligence | 4) Borderline intelligence: DQ or IQ scores between 70–84, DQ and /or IQ scores: (of latest exam)according to Kyoto child guidance clinic development scale for children for subjects up to 7 yrs of age, Or according to the revised Wechsler Intelligence scale adapted for Japanese children for cases more than 7 yrs of age. (the results of gross motor skills in the former test were excluded for cerebral palsy children when computing DQs)
| | | (Assessment between 3–8 yrs, mean age of assessment was 6 yrs)
Kim 1999 99416608 | Other Predictor-Perinatal factors | ND | CNS: CP | Non-progressive, often changing motor impairment syndromes secondary to lesions or anomalies of the brain arising in the early stages of development
| | | Neurodevelopmental: Development delay | Delay in parameters for motor development of more than two months according to the stages of motor development by Vojta
Krageloh-Mann 1999 99431017 | CNS: | CBF measured with^133^Xe clearance at 12.9 hours of life (range 1–48hr) | CNS: Spastic CP | Stott-Moyes-Henderson test - Spasticity of extremities with flexor hypertonicity, increased tendon reflexes and characteristic posturing
| 1) Intracranial/ Intraventricular hemorrhage | Cerebral oxygen flow calculated as CBF × ART 02 content | Neurodevelopmental: | Motor disability was graded as severe if the child could not walk unaided at the age of 5 y, otherwise as mild WISC
| 2) PVL | | Motor delay
| 3) Cerebral blood flow | | Mental retardation
| 4) Cerebral oxygen delivery | | Anatomical abnormalities on MRI
| | | Ophthalmology: Visual blindness
Salokorpi 1999 99353226 | General: BW, GA, SGA/IUGR, Maternal disease | ND | CNS: CP | A diagnosis of CP was confirmed when abnormal muscular tone, persistent or exaggerated primitive reflexes and major delay in motor development were found.
| CNS: | | Mortality by 2 years | The classification of CP syndromes was based on the definition by Hagberg et al.
| IVH grade III or IV
| PVL
| Other: duration of ventilation, hypotension, hypocarbia, infectious disease
Shepherd 1999 99165413 | Ophthalmology : VEP (visual evoked potential ) | One flash per second 20 cm from eyes. Each trial included 30 responses. 2 trials averaged. In preterms, VEP measured at 3 day of life in groups < 34 weeks, 34–36 weeks and 40 weeks, when 3, 6–12 months. | CNS: Cerebral palsy | No definition of CP given
Stathis 1999 99325758 | CNS Predictors | Self-explanatory | CNS: | Academic problems--Answer questionnaires given to teacher
| 1) Other: head circumference category | | Neurodevelopmental: | ADHD--Dr. Paul rating scale
| 2) Head growth velocity | | Cognitive delay | McCarthy's scales
| | | Behavioral disorders-ADHD
| | | School problems
| | | Learning disabilities
Vohr 1999 99332101 | Intracranial/Intraventricular hemorrhage | Cranial ultrasound finding | CNS: CP | CP diagnosed by routine neurological exam. CP was based on the presence of hypertonicity, hyperreflexia, and dystonic or spastic movement quality in the affected limbs.
| | | Neurodevelopmental: Cognitive and Motor delay | Stanford-Binet Intelligence Scale
| | | | PPVT-R
Agustines 2000 20279724 | General predictors: | ND | Neurodevelopmental outcome: Bayley scale | 1) Normal development: Performance within 1 SD
| 1) BW (500–750) | | 1) MDI | 2) Mild delay: Performance below 1 SD
| 2) GA | | 2) PDI | 3) Severe delay: Performance below 2 SD
| | | 3) Overall neurodevelopmental outcome
| | | 4) Neurodevelopmental outcome stratified by GA (assessment at 30 months corrected age)
Breslau 2000 20298367 | General: | ND | CNS/Behavior | Mother's rating was done with: Child Behavior Checklist (CBCL)
| 1) LBW (vs Normal BW=NBW) | | 1) Behavioral problems in 3 domains: Attention , Externalization Internalization | Teacher's rating was done with Teacher Report Form (TRF) (teachers were blind to the BW information of the child)
| 2) Urban (vs suburban setting) | | 2) Severe attention problems (above a cutoff point of 67) | Assessments at 11 yrs were conducted blindly to the results of assessments at 6 yrs (reported in another publication)
| 3) Maternal smoking during pregnancy | | Assessment at 11 yrs of age (assessment at 6 yrs: reported in another publication) | Attention problem subscale; 20 items
| | | | Externalization problem subscale: 2 subclasses
| | | | Internalization problem subscale: 3 subclasses
Buhrer 2000 20280896 | CRIB score | Routinely measure on the first day of a baby's life. CRIB score determined from: BW, GA, congenital life-threatening malformations, worse base excess, min+max FIO2 in first 12 hrs of life | CNS: Neurodevelopmental | Griffith's test
Grether 2000 20448692 | Received Magnesium sulfate | Chart review | CNS: CP | Mild, moderate, or severe CP assessed from record of 2 state agencies.
Katz-Salamon 2000 20332284 | Cardiovascular or pulmonary predictors: chronic lung disease | 1^st^ week ? acute lung injury; clinical signs; supplemental O_2_ at 28 days; typical CXR | CNS: | Griffith's development scale
| | | Neurodevelopmental: | Movement assessment index (MAI): the original number of items was reduced to include only those reported to be the most valid as predictors of CP
| | | Cognitive delay
| | | CP
Marlow 2000 20150342 | General: | Not further specified | In case control component: | Cases of SNHL were identified if the hearing loss had been identified within 3 months of discharge home, (within 9 mo from birth); after excluding cases with conductive hearing loss, possible congenital cause, or had neonatal bacterial meningitis
| 1) Birth weight 2) Apgar score 3) Illness severity (CRIB) scores | | Audiology: Sensorineural hearing loss (SNHL) of 50 dB within 9 months from birth
| CNS: | | In Longitudinal component:
| 1) Maximum bilirubin level | | CNS: Cerebral palsy at 12 months of age in the 2 groups (SNHL and control group)
| 2) Abnormal cerebral US scan
| Audiology:
| 1) Sensorineural hearing loss
| Cardiovascular/Pulomonary:
| 1) Duration of intubation, respiratory support, oxygen, pH<7.2, base excess
| 2) Dopamine
| 3) Furosemide
| 4) Indomethacin use
| Other:
| 5) Netilmicin
| 6) Vancomycin
| 7) Positive blood cultures
| 8) Bilirubin >200 ?mol/l
| 9) Bilirubin>GA × 10
| 10) Creatinine >60 mmol/l
| 11) Netilmicin
| 12) Vancomycin
| Combination of the above:
| 1) Bili.200 + acidosis
| 2) Bili> 200 + sepsis
| 3) Bili >200+ netilmicin
| 4) Bili> 200+ vancomycin
| 5) Bili>200+ furosemide
| 6) Peak bil+ acidosis
| 7) Peak bili+ sepsis
| 8) Peak bili+ netilmicin
| 9) Peak bili+ furosemide
| 10) Creatinine>60+ netilmicin or vancomycin or furosemide
| 11) Netilmicin+furosemide
| • Vancomycin+ furosemide
Palta 2000 20096107 | General: 1) Birth weight | BW ≤1500 gms VLBW | CNS: | CP: physician dx at parent interview and confirmed by clinic record abstraction as well as blindness and use of corrective lenses.
(CNS+Eye) | 2) Antenatal steroids | -Baseline respiratory scores = disease 1^st^3 days of life | CP | Pediatric Evaluation of Disability Index (PEDI): standardized scores for self care, mobility and social function
| 3) Multiple birth | 0–100 based on increasing severity | Neurodevelopmental:
| CNS:Intracranial/ Intraventricular hemorrhage | BPD: O2 use at 36 wks post conceptional age postnatal used corticosteroid use mechanical ventilation or both = severe BPD at 30 days | Functional assessments
| Ophthalmology: Retinopathy of Prematurity (ROP) | | Ophthalmology:
| Cardiovascular/ Pulmonary: | | Visual impairment
| 1) Surfactant administration | | Blindness
| 2) Respiratory score | | Standardized scores for self care, mobility and social function
| Other:
| 1) Multiple birth
| 2) Socioeconomics
| 3) Number days in NICU
Torrioli 2000 20275419 | General: | ND | CNS: | For VMI &WISC measures, “abnormal” was defined as under the 5^th^%tile; “normal” was defined as over 15^th^ %tile of a control group
(CNS+Eye) | 1) Birth weight | | Neurodevelopmental: | VMI Movement
| 2) GA | | Motor delay | WISC
| 3) SGA/IUGR | | Cognitive delay | Conner's relent symptom questionnaire
| | | Behavioral disorder
| | | Ophthalmology:Visual impairment
Valkama 2000 20233239 | General predictors: | IVH grading according to Papile | CNS: | Infants whose motor development was delayed and who had abnormal muscle tone and motor function as an impairment or disability at a corrected age of 18 mo were defined as having CP in the sense of Hasberg et al.
| Birth weight | PVL grading according to DeVries | Cerebral palsy
| GA
| SGA/IUGR
| CNS predictors:
| IVH
| White matter disorder
| Periventricular leukomalacia
| MRI findings
Vohr 2000 20295211 | General: | GR 3 to 4 IVH. PVL undefined sepsis undefined | CNS : | “normal Neurologic exam”: no abnormalities on neurologic exams
| 1) Birth weight | | Cerebral palsy
| 2) Maternal disease (HTN) | | Neurodevelopmental:
| 3) Antenatal steroids | | 1) Motor delay (sitting, walking, pincer grasp, feeding)
| CNS: | | 2) Seizure disorder
| 1) Intracranial/Intraventricular hemorrhage ( GR 3 to $ IVH/PVL) | | 3) Post hemorrhagic Hydrocephalus (PHH) and shunt
| Cardiovascular or Pulmonary: | | 4) Other: Neurologic exam (normal; abnormal)
| 1) Chronic lung disease (oxygen requirement at 36 weeks) | | 5) Development (MDI and PDI by Bayley II Scale)
| 2) Other: postnatal steroids | | Ophthalmology :
| 3) Other: Surfactant | | 1) Visual impairment (any)
| Gastrointestinal: | | 2) Blindness (unilateral, bilateral)
| 1) Necrotizing “enterocolitis” | | Audiology:
| Other: | | 1) Hearing disorders
| 1) Other: male sex
| 2) Other: Race (white)
| 3) Other: sepsis (early and late onset)
| 4) Other: maternal education
Dammann 2001 21334215 | General Predictors: | ND | CNS: | ND
| Birth weight | | CP
| SGA/IUGR
| CNS Predictors:
| 1) Intracranial/ Intraventricular hemorrhage
| Other predictors:
| 1) Infectious disease
| 2) Perinatal factors - PTL, PROM, C-section
Gaillard 2001 21221175 | In retrospective case-control component: | Not further specified | CNS: | Normal neurodevelopmentally: no clinically apparent neurodevelopmental abnormality causing functional disability
| General: | | Neurodevelopmental outcome: | Mild disability: e.g. myopia, language delay, mild hearing loss, hyperactivity or motor clumsiness.
| 1) shorter length of ventilation beyond 27 (but not 50) postnatal ds vs more prolonged ventilation beyond 49 ds | | 1) Normal | Moderate disability: for example: spastic diplegia, hemiplegia or moderate learning disability (Developmental Quotient: 50–69)
| 2) Number of days “off” ventilator in the groups of 27–49 postnatal ds ventilation and the group of >49ds ventilation | | 2) Mild disability | Severe disability: e.g. spastic quadriplegia, blindness, deafness (loss of 70 decibel or more), uncontrolled epilepsy, or severe learning disability (developmental quotient <50). Infants with multiple disabilities.
| In retrospective cohort with historical control group component: | | 3) Moderate disability | (3 yrs CA)
| General: | | 4) Severe disability
| 1) Birth in a period where Antenatal steroids and Surfactant were more routinely used vs birth in pre-surfactant pre-antenatal steroid period
Horwood 2001 20574647 | Other: Breastfeeding duration | Retrospective questioning | CNS: | WISC-R verbal and performance IQ scores at age seven years.
| | | Neurodevelopmental:
| | | Cognitive delay
| | | Mental retardation
Nadeau 2001 21163667 | General: GA | Evaluated at 5 years 9 months, was developed using SES data such as the family status (two-parent, single-parent, blended), age of each parent, their respective levels of education, and professional occupations. 0=low ~ 7=high | CNS: | Neuromotor development index: Huttenlocher neurological task test
| Other: Family adversity Index | | Neurodevelopmental: | McCarthy Scales of Children's Abilities
| | | Motor function | Behaviors were assessed by peers, teachers, and parents: RCP, TRF, parent's CBCL
| | | Cognitive delay
| | | Behavioral disorders
| | | Behavior
Pierrat 2001 27221167 | CNS Predictors: | Grade II - Transient periventricular densities, evolving into small cysts. | CNS: | Motor delay - 12, 18, 24 month outcome as the protocol of Amiel-Tison and Stewart, and Touwen
| Periventricular leukomalacia (cystic) in≤32 wk GA infants | Grade III - Transient periventricular densities, evolving into large cysts. | Neurodevelopmental: | Criteria of Hagberg et al.
| | | Motor delay
| | | Cerebral palsy

Evidence Table 3. Studies Evaluating Association of LBW and Cerebral Palsy and Neurological Outcomes Part III

Author, Year | Associations found | | | | | | | | Potential Biases | Comments
Leonard 1990 90204169 | Neurologic abnormalities: | | | | | | | | Almost 30% dropout rate. | No data on funding source
| Oxygen group (no IVH and no parenting risk): 0–29 days 9%, = 50 days 0%, p=NS among oxygen groups, total 6% | | | | | | | | Incomplete description of study groups
| IVH (no parenting risk factor): none 6%, Gr 1-II 0%, Gr III–IV 21% | | | | | | | | No description of how neurodevelopmental assessment was done (who evaluated and were they blinded to the group).
| Parenting risk (no IVH): absent 6%, Present 17%, p=NS | | | | | | | | Conclusion that antenatal steroids and surfactant improves neurologic outcome is inappropriate since he had no control group that did not receive these treatments.
| Cognitive deficits:
| Oxygen (no IVH and no parenting risk): 0–29 days 18%, = 50days 7%, total 17%
| IVH (no parenting risk factor): none 17%, Gr I–II 29%, Gr III–IV 50%, p < .005 between none and Gr III–IV groups
| Parenting risk (no IVH): Absent 17%, Present 75%, p<.001
| NO cognitive risk factors:
| Low socioeconomic status with no parenting risk 74%
| Low socioeconomic status with parenting risk: 20% p<.02
| Abnormal cognitive outcome (logistic regression):
| Oxygen: NS
| IVH: Grades 0–IV p= .0042, Gr I–II p=.18, Grade III–IV p=.003
| Parenting risk with no IVH p= .0002
| Low socioeconomic status p= .0107
Lucas 1992 92122860 | Fortified breast-milk-fed vs. Minimally supplemented breast-milk-fed: | | | | | | | | Not exclusively breast fed: in both groups total maternal intake was < 50 % breast milk with the | No data on funding source
| Gross motor development/Knobloch scale: | | | | | | | | Differential loss to follow up not reported-cannot determine BWT/GA of groups at follow-up
| (Not significant) 102.7±1.8; 102.9±2
| Language development/Knobloch scale:
| (Not significant) 92.6±0.9; 92.1±1.1
| Social development:
| (Not significant) 104.6±1.1; 105.6±4
| Motor development/Bayley:
| (Not significant) 92.3±1.6; 89.9±1.5
| Mental development/Bayley:
| (Not significant) 106±2; 105.8±2
| Social development/Vineland
| (Not significant) 118.9±1.7; 115.8±1.7
Robertson 1994 94181384 | CP | | | | | | | | Does not give detailed characteristics of cohort | Study was private funded
| 500–749 g (20) | 1/20
| 750–999 g (54) | 6/59
| 1000–1249 g (84) | 4/84
| 500–1249 g (163) | 11/163 (6.7%)
| Vision loss
| 500–749 g (20) | 2/20
| 750–999 g (54) | 0/59
| 1000–1249 g (84) | 0/84
| 500–1249 g (163) | 2/163 (1.2%)
| Hearosensory
| 500–749 g (20) | 1/20
| 750–999 g (54) | 0/59
| 1000–1249 g (84) | 1/84
| 500–1249 g (163) | 2/163 (1.2%)
| Mental retardation
| 500–749 g (20) | 3/20
| 750–999 g (54) | 0/59
| 1000–1249 g (84) | 0/84
| 500–1249 g (163) | 3/163 (1.8%)
| Convulsive disorder
| 500–749 g (20) | 0/20
| 750–999 g (54) | 0/59
| 1000–1249 g (84) | 0/84
| 500–1249 g (163) | 0/163 (0%)
Spinillo 1994 94257064 | Studied outcome of LBW infants after 3rd trimester bleeding | | | | | | | | Not all severe VLBW | No data on funding source
*have some overlapped sample with spinillo, 1997 | Controls were LBW's without 3rd trimester bleeding. | | | | | | | | No information regarding frequenting of VLBW
| Abruption, n = 40; previa, n= 22; unclassified bleeding, n = 15; controls, n = 153. | | | | | | | | Bayley test score information no presented
| Group | Grade 3–4 IVH | Cystic PVL | Major handicap | Poor Outcome
| Abruption | 12.5%* | 5% | 11.1%+ | OR = 3.9 (1.2, 2.1)
| Previa | 13.6% | 0 | 0 | OR = 0.9 (0.2, 3.6)
| Unclassified | 6.7% | 0 | 0 | OR = 0.6 (0.1, 0.3)
| Control | 3.9% | 0.6% | 0.7% | Reference group
| *P = 0.02 vs. control
| +P = 0.007 vs. control
Chen 1995 96009403 | All of the LBW preterm infants with normal brain US finding (N=12) had “normal development”. Two (17%) of them developed spastic CP. | | | | | | | | No reference of DDST | No data on funding source
| All of the LBW preterm infants with abnormal brain US finding (N=5) showed signs of spastic CP. | | | | | | | | Cases report without statistical analyses
| | | | | | | | | Vague or no definition of outcomes
Goetz 1995 96119489 | Tone abnormalities : (PVL) 12/12 | | | | | | | | Missing information | No data on funding source
| Seizure disorder: (PVL) 1/12 | | | | | | | | Small sample
| Strabismus: (PVL) 3/12
| Cognitive delay: (PVL) 6/12 mild 2/12 severe 4/12
| They found cognitive delay in 6 of 12, seizures in 1 of 12 and strabismus in 3 of 12
Speechley 1995 96356544 | General Health outcome: | | | | | | | | 1) There is an Inconsistency in Mother's appreciation of their child's physical health: mothers of NICU graduate boys reported that their children had more physical impairments than NNN boy graduates; however, their overall perception of their child's health status was not any different from NNN boys graduates. | 1) In this NICU cohort, only 36% of infants had BW<2500 g and only 5% had BW < 1500 gs, reflecting more NICU populations in the 70s and early 80s, than the current ones.
| Among boys around 12 yrs of age: NICU graduates as opposed to normal boys: | | | | | | | | 2) Some of the outcomes | 2) It is unclear whether statistically significant differences in psychometric scales reflect clinically significant differences in the emotional and social wellbeing of these children.
| 1) Are living with more chronic health problems | | | | | | | | 3) Collected are prone to recollection bias (e.g., frequency of lifetime hospitalizations). | 3) Given the fact of many negative findings, post hoc power analyses demon-strated that the study had an 80% power to detect a 40% difference between the 2 groups.
| 2) Are more likely to have a physical impairment | | | | | | | | | 4) The fact that girls ex NICU graduates had a more substantial psychological effect than boys may reflect that girls are further into adolescence than the boys, experiencing the sequelae earlier. Thus in order to determine whether the differences observed are a temporary effect/related to adolescence, this cohort had to be followed further into their teenage years
| 3) And have been hospitalized more often.
| Among girls around 12 yrs of age: NICU graduates as compared to normal girls: No statistically significant differences in their physical health outcome. Among NICU graduates, boys were not different from girls in their long-term physical health outcomes.
| Emotional and Social well being outcomes:
| Among girls around 12 yrs of age: NICU graduates as opposed to normal girls:
| 1) Had significantly lower social competence
| 2) Lower social support
| 3) And Lower self-esteem.
| Among boys around 12 yrs of age: NICU graduates as compared to normal boys:
| 1) They had no difference in their emotional or social well being. There was no interaction between family's socioeconomic status and long term outcomes among NICU graduates.
| Analytically:
| The physical health outcomes at 12 yrs were
| (Boys NICU grads vs Boys NNN grads/Girls NICU grads vs Girls NNN grads)
| • Chronic physical health (mother's report): 2.8 vs 1.8 (p<0.005)/ 2.4 vs 1.3
| • Lifetime hospitalizations (mother's report): 2.5 vs 1.6 (p<0.005)/ 1.7 vs 0.4
| • Physical impairments (mother's report): 0.29 vs 0.10 (p<0.005)/ 0.22 vs 0.06
| • Perception of child's heath (child's report): 21.6 vs 22.2/ 21.1 vs 21.9
| • Perception of child's health (mother's report): 16.9 vs 17.7/ 16.8vs 18.0
| Emotional and social well being at 12 yrs:
| (Boys NICU grads vs Boys NNN grads, Girls NICU grads vs Girls NNN grads)
| • Internalizing problems (child's report):15.3 vs 15.5/ 18.2 vs 14.8
| • Externalizing problems (child's report): 15.9 vs 16.0 / 14.3 vs 13.5
| • Social competence (child's report): 109.1 vs 113.9 / 101.7 vs 115.7 (p<0.005
| • Social support (child's report): 81.6 vs 83.2/ 79.9 vs 86.1 (p<0.005)
| • Self esteem (child's report): 31.9 vs 32.4/ 29.8 vs 32.5 (p<0.005)
| • School performance (mother's report): 4.5 vs 4.6/ 4.8 vs 5.3
Wildin 1995 95385294 | High risk (HR) preterms, low risk (LR) preterms and full term controls. Most infants who were classified as high risk were classified as such due to BPD. Bayley MDI and PDI at 12 months corrected age: | | | | | | | | Preterm HR (high risk) | No data on funding source
Wildin 1997 97422739 | Group | n | Bayley MDI | | Bayley PDI | | | | Group:
*Data from same longitudinal study as Anderson, 1996 96314587 Smith, 1996 97081985; overlapped sample | HR | 49 | 92.8 (24.9) | | 89.8 (20.7) | | | | 84% were HR because of BPD only, so this groups is really a BPD group
| LR | 92 | 103.8 (16.3) | | 99.1 (19.5) | | | | Many exclusion criteria
| Control | 114 | 108.2 (11.3) | | 108.5 (12.3) | | | | Full developmental evaluation only done on a subgroup; others only partly examined
| In Hierarchical linear models analyses: | | | | | | | | Only analyzed infants retained through all 40 months
| Cognitive/Bayley, Stanford-Binet | | | | | | | | Do not account for infants lost to follow-up
| Medical risk category LR (N=115) | | | Hierarchical linear | | | | | Do not describe how group at 40 months differed in composition from group at enrollment.
| HR (N=69) | | | model P=0.02 | | | | | Use one-tailed test to achieve significance.
| Rate of mental development/Bayley, Stanford-Binet
| Medical risk category LR (N=115)
| HR (N=69) | | | P=0.0004
| Socioeconomic status and cognitive/ Bayley Stanford-Binet association not significant.
| Medical risk category SES and rate of mental development/Bayley, Stanford-Binet association not significant.
| SES and rate of mental development/Bayley, Stanford-Binet association not significant.
| Motor development not significant
Anderson 1996 96314587 | Cognitive Development (Bayley MDI) at 6 and 12 months, respectively: | | | | | | | | Some comparison scores not shown | Study was government funded
Smith 1996 97081985 | VLBW high risk (N=58): 100.7 (24.9), 92.8 (19.2) | | | | | | | | The overwhelming majority of HR VLBW's were HR because of BPD with or without IVH | Significantly more abnormal neurologic scores at 12 month of age in VLBW high-risk infants compared to FT controls. Higher abnormal scores suggest degree of abnormality at 12 months depending at 12 months depending on level of risk as neonate.
(CNS+All) | VLBW low risk (N=96): 106.8 (19.5), 103.8 (16.3) | | | | | | | | Low socioeconomic status, inner city population
*Data from same longitudinal study (U. of Texas Health Sciences Center in Houston and the U. of Texas Medical Branch in Galveston) as Wildin, 1995 & 1997; overlapped sample | FT (N=119): 113.6 (15.8), 108.2 (11.3)
| Motor Development (Bayley PDI) at 6 and 12 months, respectively:
| VLBW high risk (N=58): 100.7 (24.9), 92.8 (19.2)
| VLBW low risk (N=96): 106.8 (19.5), 103.8 (16.3) | | | | | | | | | risk infants compared to FT
| FT (N=119): 113.6 (15.8), 108.2 (11.3)
| All groups differed significantly on MDI and PDI at 6 months (p<.001). At 12 months, only the high-risk infants differed from the term infants (p<.001). The means for all three groups at 6 and 12 months were within the normal range. However, significantly more high-risk infants fell within the moderately and severely delayed ranged than low-risk and term infants did (data not given)
| Total neurologic score at 6 and 12 months, respectively:
| VLBW high risk (N=58): 0.30 (0.23), 0.16 (0.22)
| VLBW low risk (N=96): 0.16 (0.17), 0.08 (0.12)
| FT (N=119): 0.05 (0.07), 0.04 (0.05)
| All groups differed significantly on total neurologic score at both 6 and 12 months (p<.001). Total score significantly improved from 6 to 12 months of age in all groups (p<.001). Total score in high-risk group still remained abnormal after improvement, while the score in low-risk and term infants were normal at 12 months of age.
| Assessed risk status in relation to outcome in areas of development of cognitive skills, communication development and daily living skills. Mental Age and daily living skills data are in months and language data are in raw scores:
| | | | | Language
| Infant status | n | Mental Age | Daily living skills | Expressive | Receptive
| High risk | 88 | 11.6 (2.4)* | 11.9 (2.65) | 18.0 (5.4)# | 14.2 (2.6)
| Low risk | 123 | 12.8 (1.7)* | 12.97 (2.45) | 20.5 (5.9) | 15.3 (3.3)
| Full term | 128 | 12.9 (1.1)* | 13.29 (2.0) | 20.6 (4.7)# | 15.3 (2.4)
| *p < 0.01 for High risk v. low risk and full term
| # p < 0.01 for high risk v. full term
| Other differences are not significant.
Kato 1996 97182916 | Independent predictors of CP/MR | | | | | | | | Retrospective -completeness data (predictors/outcomes) not known. Predictors and outcomes poorly defined. | No data on funding source
| Fetal malpresentation vs. cephalic presentation (p<0.01) | | | | | | | | No FT comparison.
| Use of tocolytics vs. no tocolytics (p<0.005)
| Umb cord artery pH<7.2 (p<0.05)
| Major handicap (CP/MR/Blindess) increased in VLBW infants delivered by breech/vag (25%) v. ceph/vag (0%) vs. Breech/c-section (5%) vs. cephalic/c-section (8.5%) (p<0.05)
Katz 1996 97145056 | Attention deficit is measured by the CPT test (error of omission). Hyperactivity and impulsivity is measured by the CPT test (error of commission). | | | | | | | | Exactly how FT controls were selected in an unbiased way is not described. | No data on funding source
| There were no differences among the preterm infants with mild, moderate and severe intracranial lesions. However, there was a significant increase in both errors of commission and omission in preterm with mild lesions compared to full term infants as well as in preterm with severe lesions compared to full term infants. With increasing severity of lesions in preterm infants, increasing percentage in each group commit errors of commission. Even in the absence of detectable intracranial lesions, preterm infants are still at higher risk for developing attention deficits than full term infants. | | | | | | | | | This study does not explore relationship of attention deficits identified with the CPT test with actual school performance and achievement in this group of preterm infants.
| | | | | | | | | | This study includes older preterm 26–34 weeks and does not include the extremely preterm 24–25 wk infants.
Korkman 1996 96374730 | Overall: the VLBW/SGA group had the poorest test results. The VLBW/AGA group was somewhat less impaired, whereas the birth asphyxia group performed at the control group level | | | | | | | | 1) Cannot exclude potential selection bias (no description of patient flow in each group) | Supported by non-governmental foundations
Psy1996 | Impairment when present tended to be diffuse in all groups, affecting: psychometric intelligence, naming, visuo-motor performance, tactile finger discrimination, attention and phonological analysis. | | | | | | | | 2) Cannot exclude diagnosis bias/no information on blinding of personnel evaluating developmental outcome component on PMHx.
| Predictors evaluation for CNS outcome (Intelligence evaluation): | | | | | | | | 3) The authors investigated associations between 7 predictors and many outcomes (the different subcomponents of WISC-R test and the NEPSY test)/ thus cannot exclude “multiple comparison” effect
| 1) VLBW/AGA was associated with poorer WISC-R score, when compared to healthy full term (FT) (p<0.05)
| 2) VLBW/SGA was associated with poorer WISC-R score, when compared to healthy FT (p<0.05)
| 3) VLBW/SGA was associated with poorer WISC-R score when compared to asphyxiated term infants (There was no difference in the scores between asphyxiated terms and healthy terms)
| Predictors evaluation for CNS outcome (Neuropsychological evaluation):
| 1) VLBW/SGA was associated with poorer NEPSY score (p<0.05) when compared to healthy FT
| 2) In the VLBW cohort, impairment when present tended to be diffuse (in all items examined).
| 3) VLBW/SGA was associated with poorer NEPSY score when compared to asphyxiated terms.
| Overall In the VLBW group (AGA and SGA) (n=77):
| 1) Apgar scores were not correlated with outcome measures
| 2) Arteria PH was correlated with FSIQ score
| 3) Intrauterine growth retardation correlated with NEPSY score
| 4) BW correlated with NEPSY score
| 5) There was no correlation between RDS, IVH , duration of ventilatory tx and cognitive dysfunction
| Combined CNS / Ophthalmology outcome:
| 1) VLBW/AGA: 21% (both mild and severe)
| 2) VLBW/SGA : 6/34 (18%) (mostly lids)
| 3) Birth asphyxia/ Term: 7/32 (22%) (mostly severe)
Lucas 1996 96302121 | Predictor evaluation for :CNS outcomes | | | | | | | | Cannot exclude false association due to unrecognized confounders between the 2 groups as this study was non-randomized (despite matching for BW, GA, need for ventilation, NICU stay and other diets ; there are still exist important unconsidered confounders)
| (Unadjusted analysis)
| Mother's choice to breast feed was associated with higher IQ scores at 7 years:
| (No mother's milk group vs Mother's milk group)
| • WISC-R verbal scale (mean): 92.0 vs 102.1 (p<0.001)
| • WISC-R Performance scale : 93.2 vs 103.3 (p<0.001)
| • Overall IQ: 92.8 vs 103.0 (p<0.001)
| (Adjusted regression analysis for confounders)
| Mothers choice to Breast feed infant: N=210 babies
| • Higher Verbal scale scores: (p<0.001)
| • Higher Performance scale scores (p< 0.0001)
| • Higher Overall IQ: (p<0.0001)
| Successfully breast fed infants only:
| (Received breast milk) N=193 babies
| • Higher Verbal scale scores: (p<0.0001)
| • Higher Performance scale scores (<0.0001)
| • Higher Overall IQ: (p<0.0001)
| Overall (Regression analysis)
| • Whether Received breast milk: offered advantage of 8.3 points (p<0.001)
| • Social class: -3.5/class (p<0.004)
| • Mother's education: 2.0/ group (p=0.01)
| • Female sex (p=0.01)
| • Days of ventilation: -2.6/ week (p=0.02)
Rieck 1996 | In Prospective longitudinal component of the study: | | | | | | | | 1) There was no matching, except for the age between VLBW and MC, LC children. Thus, there was no control for possible confounders, | 1) No data on the absolute size of the association between predictors and outcomes were given.
Psy 1996 06905005 | Predictor evaluation for CNS outcome: | | | | | | | | 2) Selection bias might exists: As only those that had completed the test were analyzed. (Only 58% of VLBW children had completed the test) | 2) Statistically significant correlation does not always mean a clinically significant association.
| 1) Female Sex, HC percentile and Maternal education were independently associated with CGI score (r^2^= 0.41, p< 0.001) | | | | | | | | 3) Selection bias also might exist as no information is given in the selection process of the 103 VLBW infants that had participated in the original study
| 2) Age at assessment, GA and HC percentile were independently associated with Verbal scale score. (r^2^= 0.36, p< 0.001)
| 3) HC percentile was independently associated with Perception-performance score (r2= 0.12, p< 0.05)
| 4) Neurologic complication and HC percentile were independently associated with Quantitative scale score (r2= 0.30, p< 0.01)
| 5) Neurologic complications and HC percentile were independently associated with Memory scale score (r2= 0.36, p< 0.05)
| 6) HC's percentile were associated with higher scores in the 4 scales of McCarthy's test and in the GCI . (p<0.05)
| In Cross sectional component of the study:
| Predictor evaluation for CNS outcome:
| 1) VLBW children with normal IQ, score significantly lower than the Middle class group on many cognitive tasks, and may demonstrate more learning disabilities than Middle class children
| 2) VLBW and Low Class children had significantly lower score in all scales of McCarthy's test , as compared to Middle Class children. (p<0.01)
| 3) VLBW had no different scores from Low class children.
| 4) Evaluation of the change of scores with age revealed that from age 3–7 yrs, VLBW advanced significantly less than Middle class children in Word Knowledge, Conceptual grouping and Numerical Memory backwards.
| 5) The gap between the scores of the 2 groups increased with age.
Whitaker 1996 97040639 | MR higher in LBW<2kg (5%) than in general pop distribution (2.5%) | | | | | | | | (None) | Study was government and privately funded
| OR for MR vs Normal Intelligence:
| PVL/VE OR 65.83 (19.1–227.4)
| Isolated GMH/IVH OR 4.64(1.2–18.6)
| Verbal reasoning (Stanford-Binet area score) p<0.05
| PVL/VE: 98.9 (10.8)
| GMH/IVH 102.9 (10.5)
| No abnormality 104.3 (10.9)
| Visual perception organization
| All abstract visual reasoning, visual-motor integration, and visual-perceptual stills were significantly (p<0.01 or p<0.005) were significantly lower for children who had PVL/VE compared to those with isolated GMH/IVH or No abnormality.
| 50% of MR attributable to PVL/VE independent of other factors.
Blitz 1997 97154301 | Developmental outcome: | | | | | | | | 36% declined or did not appear (possible selection bias). | No data on funding source
| The mean MDI, PID, CLAMS Total, Expressive, and Receptive scores were 99.7 (19.8), 88.9 (19.8), 94.9 (23.0), 90.8 (26.2), and 99.7 (21.3), respectively. | | | | | | | | Language assessment at 2 years is too early to determine more subtle language delays.
| MDI < 70 9% | | | | | | | | No control group.
| PDI < 70 18%
| Language delay (>1 SD below the mean) 34%
| Significant language delay (>2 SD below the mean)12%
| Multiple regression analysis showed BW and surfactant did not relate to developmental outcome. BPD, PVL and IVH significantly increased the risk of impairment. PVL, BPD, seizures and hydrocephalus account for 29.7% of the variance on the MDI scores (F=10.05, p<. 001). PVL, IVH, and BPD accounted for 23 % of the variance on the PDI scores (F=9.6, p < .001). For the total CLAMS score, 11% of the variance was accounted for by PVL and BPD (F=7.1, p < .002)
| Neurologic outcome:
| Multiple regression analysis showed low BW was not associated with neurological impairment. On the contrary, BPD and PVL significantly increased the risk (14.8% if variance; F=8.4, p<. 001). No other individual variables reach the significance level.
| CP: present 24 %, suspect 27%, No CP 49%
| Audiology:
| Hearing loss 16%. None of the children were profoundly hearing-impaired.
| Visual problem 18%. None were clinically blind
Cheung 1997 97310950 | Of the 21 preterms with IVH treated with rescue HFO, 8 (38%) has neurodevelopmental disabilities. | | | | | | | | The title is “High Frequency Oscillatory Ventilation” but the authors state that a high frequency flow interrupt ventilator is used in their nursery. These distinct modes of ventilation should not be confused | No data on funding source
| Of the 8 preterms with grade III or IV IVH treated with rescue HFO, 6 (75%) has neurodevelopmental disabilities. | | | | | | | | 60% mortality among cohort meeting inclusion criteria
| | | | | | | | | Time of follow-up not well standardized
Ekert 1997 97251211 | Association between outcome (CP and/or developmental delay) and perinatal/neonatal variables: | | | | | | | | (None) | Study was government funded
| Multiple logistic regression analysis showed that only PVL was associated with abnormal outcome (PLV: p=0.0001)
Gerner 1997 97329414 | Predictors evaluation for CNS outcome: | | | | | | | | 1) In the comparative components (Group A vs C and Group B vs A), there was no control for possible confounders, as not appropriate matching was done between these compared groups | Supported by non-governmental Foundations.
| 1) Healthy preterms did not differ significantly in psychodevelopmental outcome | | | | | | | | 2) Cannot exclude diagnosis bias as no information is given about blinding of personnel performing the neurodevelopmental assessment on the infants' risk factors
| 2) Prematurity was not associated with the sum score in the Griffith's test | | | | | | | | 3) Two many predictors investigated (28) for the total number of patients in the VLBW group (cannot exclude false associations found in the regression analysis)
| 3) Prematurity was associated only with lower score Hand-Eye coordination scale | | | | | | | | 4) Cannot exclude false associations due to chance, as multiple subgroup analyses were done (subclasses of Griffith's test)
| 4) The predictors associated with poor psychodevelopmental outcome in preterms were (univariate analysis): | | | | | | | | 5) The subclasses of Griffith's test have limited specificity, thus limited differentiating capacity at 10 months of age and especially for infants with neonatal complications as performance in one scale requires skills assessed in another scale.
| General predictors: Low GA: Pearson correlation coefficient r=0.19 (171 pts) (p< 0.05); Low BW: Pearson correlation coefficient r=0.25 (171 pts) (p< 0.001); Intraventricular hemorrhage (IVH) + ventricular dilatation: Pearson correlation coefficient r=-0.27 (p< 0.001)
| CNS predictors: Periventricular Cystic leukomalacia, (PVL) r=-0.24 (p< 0.01); B1-3 + W1-4 U/S findings, r=-0.27 (p< 0.001)
| Cardiovascular predictors: PDA (n=72 pts), r=-0.32 (p< 0.001)
| Pulmonary predictors: Prolonged ventilatory therapy (n-94 pts), r=-0.39 (p< 0.001); CLD: (n=56 pts), r=-0.26 (p< 0.001)
| 5) Although the screening indicated that several risk factors were associated with adverse neurodevelopmental outcome- in the multiple regression model the contribution of individual variables was very low (less than 20%). 80% of the outcome variance still remained unexplained.
| 6) Only predictors independently associated with total sum score inGriffith's test were (multivariate analysis): combination contributed to outcome variance by 21%: Pulmonary predictors: Duration of ventilatory tx (r^2^=16%) and CNS: PVL (r^2^=5%)
| 7) Predictors independently associated with scores of individual subscales:
| Locomotor subscale : combination contributed to outcome variance by 14%
| • Duration of ventilatory tx (r^2^=9%), PVL (r^2^=5%)
| Personal-Social subscale: combination contributed to outcome variance by 17%
| • BW (r^2^=10%), PVL (r^2^=7%)
| Hearing and speech subscale:
| • Duration of ventilatory tx (r^2^=13%)
| Hand and eye coordination subscale: combination contributed to outcome variance by 15%
| • PDA requiring surgical ligation (r2=11%),
| • Hemorrhage plus White matter lesions (r^2^=4%)
| Performance subscale: combination contributed to outcome variance by 18%
| • Duration of Ventilatory tx (r^2^=12%) and White matter lesions (r^2^=6%)
Koller 1997 97193708 | Cognitive Development: | | | | | | | | Selection bias-does not include all VLBW infants-only those for whom all followup data are available--how are these different from the ones who did not show for follow-up? | Study was government funded
| Birth weight: | | | P <0.001
| Gestational age: | | | P<0.001
| Neonatal health index: | | | P<0.01
| Neurological status @ 1 yr: | | | P <0.001
| Male gender: | | | P <0.005
| Maternal education: | | | P<0.005
Murphy 1997 97192793 | Apgar score <3 at 5minutes - 5.3% cerebral palsy | | | | | | | | Ascertainment of CP was from registry--not examined as part of study | Study was privately funded
| Patent ductus arteriousus - 2.0% cerebral palsy | | | | | | | | Absence of CP was not obtained by exam as part of study
| Hypotension - 2.2% cerebral palsy | | | | | | | | Multiply definitions of predictor variables not reported
| Transfusion - 3.2% cerebral palsy | | | | | | | | Retrospective acquirement of risk factors-no standard definitions
| Prolonged ventilation - 2.7% cerebral palsy
| Pneumothorax - 3.4% cerebral palsy
| Sepsis - 2.8% cerebral palsy
| Total parenteral nutrition - 3.0% cerebral palsy
| Hyponatremia - 6.8% cerebral palsy
| Chorioamnionitis and neonatal sepsis - 7.1% cerebral palsy
| Any maternal infection and neonatal sepsis - 4.2% cerebral palsy
| Seizure - 10.0% cerebral palsy
| Parenchymal damage - 32.0% cerebral palsy
Schendel 1997 98033417 | Even apparently well VLBW with no overt physical impairment are consistently at higher risk for all measures of DELAY than MLBW or NBW infants. VLBW have DELAY in all areas of function with greatest risk for delay in gross motor domain. | | | | | | | | The people administering the Denver test were not blinded and were aware of degree of prematurity and this is a major source of bias. | Study was government funded
| “Abnormal” - VLBW 10.9%, NBW 2.9%, p = 0.001 | | | | | | | | The adjusted age at f/u had very wide range 9–34 months
| Personal-Social = 1 delays: VLBW 7.1%, NBW 2.2%, p = 0.001
| Language = 1delays: VLBW 8.8%, NBW 4%, p = 0.01
| Fine motor-adaptive = 1 delays: VLBW 7.9%, NBW 2.2%, p = 0.001
| Gross motor = 1 delays: VLBW 10.7%, NBW 1.8%, p = 0.001
Thompson 1997 97268338 | Neurobiologic risk score (NBRS) investigated to determine predictive value for performance on McCarthy Scales at 4 years age. N = 55. | | | | | | | | One institution | Study was government funded
| McCarthy Scale | | | Mean (SD) | | | Range | | No control group
| General cognitive index | | | 89 (20) | | | 49–126 | | Combined high NBRS and intermediate NRS patients into one group
| Verbal | | | 44 (10) | | | 21–65
| Perceptual-Performance | | | 44 (12) | | | 21–69
| Quantitative | | | 46 (12) | | | 22–67
| Memory | | | 46 (10) | | | 21–67
| Motor | | | 42 (12) | | | 20–70
| Also: The NBRS was not found to be predictive of the McCarthy General Cognitive Index; in multiple regression analysis only birth weight, gestational age and gender were significantly related to the McCarthy scores.
Victorian Infant Collaborative study Group 1997 98026322 | Birth weight < 1000g; assessed at 2 years corrected age. | | | | | | | | Incomplete reporting of demographic data, methods and results. | Study was government funded.
*There are a series of Victorian articles in LBW-ALL. | Cohort | n | DQ < -3 SD | DQ -3 to -2 SD | | DQ -2 to -1 SD | | DS>-1 SD
*This study will be combined in LBW-ALL table | '91-'92 | 237 | 5.9% | 6.3% | | 13.9% | | 73.4%
| '85-'87 | 211 | 6.2% | 4.3% | | 14.2% | | 75.4%
| Cohort | n | Mild CP | Mod. CP | Severe CP | Any CP | Blindness | Deaf
| '91-'92 | 237 | 3.8% | 1.7% | 3.8% | 9.3% | 2.1% | 0.8%
| '85-'87 | 211 | NS | NS | NS | 6.6% | 4.3% | 0.5%
| Cohort | No disability | Mild Disability | | Moderate disability | | Severe diability
| '91-'92 | 71.3% | 14.8% | | 7.2% | | 6.8%
| N=237
| '85-'87 | 71.6% | 15.6% | | 6.2% | | 6.6%
| n=211
Battin 1998 99002694 | CNS outcomes: | | | | | | | | 1) During 1991-93 period there is no concurrent control group for the comparative assessment of neurodevelopmental outcome | No report on source of funding
| Major impairment was present in 36% of infants born at 23–25 wks GA, during 1991-1993 (N=44) | | | | | | | | 2) Group of infants of 23–25 wks GA, born during 1991-1993, was not matched to the historical control group born during 1983-1989. Possibility of confounders cannot be excluded.
| 1) Cerebral palsy | | | 9/44 (20%) | | | | | 3) No data were given on the number of infants in the historical control group that had f/up at 18 mo of age.
| 2) Low MDI | | | 8/44 (18%)
| Ophthalmology outcome:
| 1) Blind | | | 4/44 (9%)
| Audiology outcome:
| 1) Deaf | | | 4/44 (9%)
| Combined outcome:
| 1) Overall impaired | | | 16/44 (36%)
| 2) Multiple handicaps | | | 6/16 (38%)
| Analysis of only 24–25 wks GA infants (N=43):
| Major handicaps: 15/44 (34%)
| The percentage of infants with major impairments and/ or multiple handicaps, for the 23–25 wks GA group, was the same in 1991-1993 and 1983-1989 periods
| (However, no data on the number of infants from this cohort that were actually followed up at 18 mo of age)
Bos 1998 98218970 | The developmental course of the quality of general movements significantly correlated only with the duration of parieto-occipital echodensities (r=0.482, p<.02), while the duration of PVE frontal was not associated with the developmental outcome (r=0.241, NS) | | | | | | | | No power estimates for defecting modest effects | No data on funding source
Cherkes-Julkowski 1998 98262696 | No disorder identified: PT 25%, FT 75 % | | | | | | | | Evaluators were people in the community and social system so that there may be significant variations in evaluations. | No data on funding source
| Attention deficit disorder: PT 17.8%, FT 7.1% | | | | | | | | Sample size too small for statistical analysis. | This study is more a study of predictability of the attention deployment test in identifying minimal brain dysfunction at 13 and 15 mos, rather than a study of predictors of long-term outcome.
| Learning disability: PT 17.8%, FT 14.2%
| Language impairment: PT 3.5%, FT 0%
| Neurological impairment: PT 7.1%, FT 0%
| School concerns: PT 28.5%, FT 21.4%
| This group of only mildly preterm, seemingly healthy PT infants have significantly more disability than expected χ2(5)=62.577, p= .0001
Emsley 1998 98238139 | Disability in 1^st^cohort 1984-1989 of 23–25 wks: | | | | | | | | Sample numbers small. | No data on funding source
(CNS+ All) | Any disability: 38% | | | | | | | | Does not state when the assessments were carried out and whether the evaluators were blinded to the GA and history of the infants.
| CP: 21%
| Data on 2^nd^cohort 1990-1994 of 23–25 wks:
| CP: 18%
| Blindness due to ROP: 18%, Myopia: 15%, Squint: 13%
| Developmental delay (DQ < 70): 15%
| Deafness: 3 %
| Epileptic seizures: 0
| Speech delay: 15%
| Clumsy, learning difficulties, behavioral disorder: 3%
| Disability: Mild 38%, Moderate 13%, Severe 18%
| Infants with disability have lower GA, worse CRIBscores and significant cranial ultrasound findings.
| In comparing the 2 cohorts, increased survival is associated with increased disability but mostly mild disability. No significant change in %CP. High CRIB score assoc. with disability.
Pasman 1998 98196839 | Assessment at 5 to 7 years of age. Full-term (FT) controls, neurologically normal low risk preterm (normal LR) infants, neurologically abnormal low risk preterm infants (abnormal LR), and high-risk preterm infants (HR). Risk classification was based on the neonatal neurologic inventory. | | | | | | | | Year of birth not given | Study was privately funded
| Group | n | Total IQ | Verbal IQ | Performance IQ | | | | | Small numbers in subgroups (e.g., 8,9)
| FT | 18 | 114 (17) | 113 (18) | 111 (14)
| Normal LR w/ GA 25–30 weeks: | 15 | 108 (15) | 107 (18) | 106 (11)
| Normal LR w/ GA 31–34 weeks | 21 | 113 (15) | 114 (18) | 107 (10)
| Abnormal LR w/GA 25–34 weeks | 8 | 99 (12) | 104 (12) | 93 (14)
| HR w/ GA 25–34 weeks: | 9 | 78 (20) | 79 (19) | 81 (19)
| HR infants excluded from statistical analysis. Term infants vs. all low risk infants: Total IQ, no significant difference. Verbal IQ, no significant difference. Performance IQ P = 0.02.
Rogers 1998 98438124 | There are no association between GA, BW, BPD Length of stay with growth failure P>0.05 | | | | | | | | (None) | Study was privately funded
| Growth failure with CPVL 16/41
| CP with CPVL 39/41
Spinillo 1998 98237382 | CP prevalence12.3% in 24–33 wk preemies | | | | | | | | 1) Major confounding postnatal factors such as BPD, IVH, and PVL, which may be associated with CP, were not controlled for. | No data on funding source
Spinillo, 1997 98021316 & 97277958 | Minor neurologic problems (abnormal tone or reflex but functionally normal) or borderline (71–84) Bayley MDI: 16.1% | | | | | | | | 2) We cannot exclude selection bias. The associations found were relevant to the group of surviving infants with cerebral palsy who alos had f/up at 2 yrs. A large number of infants were excluded from the analysis: 46 infants that were lost to f/up and 59 that had died.
*have some overlapped sample with spinillo, 1994 | Factors assoc with increased CP:
| PROM > 48 hrs OR 2.98 (1.12–7.96 CI 95^th^)
| Meconium-stained amniotic fluid OR 4.36 (1.69–11.2)
| Male sex OR 3.01 (1.32–6.71)
| Decreasing gestation: CP 22.2% in 24–25 wks, 23.1% in 26–27 wks, 14.5% in 287ndash;29 %, 8.3% in 30–31 wks, 9.3% in 32–33 wk infants.
| CP
| Meconium-stained fluid (N=17) | 41% (7/17%)
| Clear fluid (246) | 13.4% (33/246) P=0.06
| CNS outcome:
| The incidence of cerebral palsy in this cohort of preterm infants was : 40/345: (12%), but this refer only to those survived: 391/450 (87%) and to those that completed the 2 yr f/up: 345/450 (77%)
| Predictors evaluation for Survival at 2 yrs:
| 1) Survival at 2 yrs was associated with higher GA (p<0.0001), higher BW, (p<0.0001) And History of fewer previous abortions.
| Predictors evaluation of CNS outcomes:
| (In a univariate analysis) From the maternal and neonatal characteristics and the pregnancy complication/predictors, those found to be associated with CP were
| Odds Ratio (95% CI)
| 1) Higher Maternal age | | | | | 1.07 (1.0–1.15)
| 2) Lower GA | | | | | 0.87 (0.76–0.99)
| 3) Lower BW | | | | | 0.94 (0.87–1.00)
| 4) male gender | | | | | 2.65 (1.28–5.50)
| 5) More Previous voluntary abortion (25% vs 7%) | | | | | 4.51 (1.94–10.5)
| 6) Preeclampsia (5% vs 19%) | | | | | 0.22 (0.05–0.94)
| In a multivariate regression model (including maternal age, BW Standard deviation score, GA and preeclampsia) only preeclampsia was independently associated with the risk of cerebral palsy: OR: 0.16 (0.04–0.74) The authors conclude a protective effect of preeclampsia against CP, in the absence of Mg sulfate utilization
Tin 1998 99046171 | Result of 1983 cohort at 6 years: | | | | | | | | No definitions of outcome, incomplete methods description, wrong reference | Study was privately funded
| Severe disability:
| Sample 1: 4.4%, Sample 2 : 2.1%, Sample 3: 50%
| IQ < 75 without sensorimotor disability:
| Sample 1 : 4.9%, Sample 2 : 0, Sample 3 : 25%
| Severe sensorimotor disability:
| Sample 1 : 5.9%, Sample 2 : 21.4%, Sample 3 : 41.7%
| Severe sensorimotor or cognitive disability:
| Sample 1 : 8.4% (5 ‐ 13.1%, 95% CI)
| Sample 2 : 21.4% ( 4.7–50.8%)
| Sample 3: 41.7% (15.2–72.3%)
| Result of 1990 cohort at 2 years:
| Severe disability:
| Sample 1: 7.9%, Sample 2: 15.4%, Sample 3: 57.1%
| High f/u rate is critical because it may underestimate incidence of the outcome.
Burguet 1999 99126269 | In univariate analysis: | | | | | | | | 8% BW>2000g | No data on funding source
| The prevalence of CP in LBW preemies with RDS (66) was 20%, compared to 9% in preemies without RDS (101). The difference was significant (p=0.04) | | | | | | | | Nonstandard definition of CP | Severe disability is common among extremely preterm infants of GA 22–25 wk
| Incidence of CP 7% in no PROM, 20% in PROM < 48 hrs, 30% in PROM 48h to 7 days, 11% in PROM >7 days, χ^2^trend: p= .004 | | | | | | | | Suspected infant (mild hypotonia or delay to normal acquisition) were included in the normal group
| In multivariate analysis: | | | | | | | | Evaluations done by community physician of parents' choice so, no standardization, and unblinded
| Controlling for environmental and maternal factors, the risk of CP was about 3 times in preemies with RDS, than preemies without RDS (adjusted OR 2.8, 95% CI 1.1–7.1). “The introduction of surfactant in the second stage of our study was not shown to have any impact on the incidence of CP among the children of this cohort.” | | | | | | | | Used uncorrected age
| PROM =48 hours (OR 4.3, 95% CI 1.6–11.8), p= .005
| Monochorionic twin placentation (OR 6.0, 1.7=21.3), p = .007
| RDS (OR 2.8, 1.1=7.1)
| PROM +, PTL + (OR 7.5, 2.2=26.2), p= .001
Cooke 1999 99257637 | CP prevalences: | | | | | | | | ND | No data on funding source
| 1982-5 (411) | 45 | 10.9%
| 1986-9 (387) | 42 | 10.9%
| 1990-3 (398) 29 | 29 | 7.3% | P=0.046
Cooke 1999 99380719 | MRI abnormality: VLBW group : 37/87 (42.5%) | | | | | | | | No statistical/ data analysis section | Study was privately funded
| | FT Control group: 0/8 (0%) | | | | | | | Few controls (n=8) | Overall sample of LBW<2 kg had increased rate of MR compared to gen pop. PVL/VE was independently related to MR (OR 66) and to borderline IQ .
| Abnormal MRI not associated with ADHA, IQ, or motor coordination scores. | | | | | | | | Disagree and interpretation (i.e. conclusion) | Among children with nl IQ, those with PVL/VE vs. no PVL/VE performed more poorly on visual-perceptual organization.
| | | | | | | | | | White matter injury is associated with adverse cognitive and visual perceptual disability.
Finer 1999 99436635 | IVH: Sample 1: 70%, Sample 2 : 10%, p = .015. | | | | | | | | Very small sample size with 28% lost to f/u. | No data on funding source
| Normal neuromotor outcome: | | | | | | | | Results are from a single center, difficult to generalize the results. | Missing information
| Sample 1: 70 %, Sample 2: 70%. | | | | | | | | Exact criteria for chest compressions and epinephrine not specified | Retrospective collection of breast feeding data
| Abnormal neuromotor outcome: | | | | | | | | No information about the evaluators or whether they were blinded.
| Sample 1 : 20%, Sample 2: 0 | | | | | | | | Infants evaluated at wide range of ages where infants seen later may have done better or worse
| Normal developmental outcome:
| Sample 1: 80%, Sample 2: 60%
| Abnormal developmental outcome:
| Sample 1: 20%, Sample 2: 20%
| Normal neurodevelopmetal outcome:
| Sample 1: 70%, Sample 2 60%
| No difference in developmental scores of following domains: composite mental, composite motor, adaptive, language, personal/social, fine motor, gross motor.
| They conclude that intact survival is possible for infants weighting <750 g who received CPR in the DR.
Futagi 1999 99450356 | Predictor evaluation for CNS outcome: | | | | | | | | 1) Assessed the association between birth in the surfactant era and neurodevelopmental outcome and not of surfactant administration itself problems of ecological fallacy in that type of studies) | Source of funding not reported
| 1) Birth in surfactant era was not associated with neurodevelopmental outcome (good or poor prognosis) for infants of less than 1000 gms | | | | | | | | 2) It is unknown if the results of this study could be generalized in other NICU populations where more than 50% of infants receive surfactant
| (Pre-surfactant era[107] vs surfactant era [169] | | | | | | | | 3) The possibility of a masked association cannot be excluded due to existence of possible cofounders in the 2 groups.
| • Neurodevelopmental outcome: 71/107 (66%) vs 100/169 (59%) | | | | | | | | 4) Many subgroup exploratory analyses were performed that were not described in the Method section
| • Cerebral palsy: 13/107 (12%) vs 18/169 (11%)
| • Mental retardation: 11/107 (10%) vs 16/169 (9.5%)`
| • Borderline intelligence: 11/107 (10%) vs 35/169 (21%)
| 2) Birth in surfactant era was associated with higher incidence of borderline intelligence (20.6% in surfactant era vs 10.3% in pre-surfactant era)
| 3) Birth in surfactant era :was not associated with DQ or IQ scores in the individual neurodevelopmental categories (normal neurodevelopmentally, cerebral palsy, mental retardation, borderline intelligence)
| • Normal: 99.7 vs 100.1
| • Cerebral palsy: 57.5 vs 62.5
| • Mental retardation: 62.4 vs 55.1
| • Borderline intelligence: 77.1 vs 77.6
| 4) Birth in surfactant era: was not associated with the distribution of subtypes of cerebral palsy.(spastic diplegia, spastic hemiplegia, spastic quadriplegia)
| 5) Birth in surfactant era was not associated with severity of cerebral palsy.(minimal, mild, moderate, severe)
Kim 1999 99416608 | Infants with BW < 2000g. Assessed at 12 months age. | | | | | | | | Study group as a whole is not described-only those infants developing CP. | In this cohort of preterm infants (BW 600–1250 grams) <1%blind or deaf; 1%– 3% had seizure disorder; and 7% had CP.
| Risk Factor | CP | Devel. Delay | Both CP+DD | Neither | | | | CP infants are compared to “controls”, but no description of how the control group was recruited or in what ways they were similar to or different from the study group. Concurrent? Historical? Matched for gestational age or birth weight? We are not told. Leaves open the possibility of massive bias/confounding | Full scale IQ <80 occurred in 28% of total sample (BW 600–1250 grams) at 54 months follow-up
| Neonatal sepsis | 4/9* | 1/8 | 5/17* | 4/62
| BPD | 4/9* | 3/8* | 7/17* | 9/62
| IVH > grade 2 | 4/9* | 1/8 | 5/17* | 6/62
| Days on ventilator | 18.1 (25.1)* | 11.3 (8.7)* | 12.2 (19.6)* | 3.3 (3.3)
| Ventriculomegaly | 5/9* | 0 | 5/17 | 8/62
| P < 0.05 vs. neither CP/ DD
| Multivariate logistic regression, the following were not significant risk factors:
| Apgar score at 5 minutes, BPD, IVH, PDA, duration of mechanical ventilation, Sepsis
Krageloh-Mann 1999 99431017 | MRI normal (n=10)(%) | | MRI abnormal (n=19)(%) | | | p | | | 1) Selection of preterm subject bias | No data on funding source
| Preeclampsia | 50 | 11 | | | 0.03 | | | 2) No MRI of controls
| Placental abruption | 0 | 32 | | | 0.07 | | | 3) Controls, “From Copewnagen suburb”- well matched with regard to SES, health-care measures, etc.?
| Mechanical Ventilation>7d | 0 | 42 | | | 0.03 | | | 4) Design is bizarre, complicated, and difficult to interpret.
| ICH grades III + III | 0 | 16 | | | 0.53 | | | 5) Statistical analysis is not well described. It appears that they did not correct for multiple comparisons, which renders their positive findings suspect. They did not do a power analysis, which renders their negative findings suspect.
| DO2 <ml O2/100g/min | 12.5% | 63% | | | 0.03 | | | 6) Much of the paper analyzes association between outcomes evident at 5–7 yrs f/u, for ex., association between abnormal MRI at 5 yr. And IQ at 5 yr.; this does not examine association between neonatal MRI+ IQ at 5 yr.
Salokorpi 1999 99353226 | Assessed selected risk factor in relation to cerebral palsy (CP) diagnosed at two years age | | | | | | | | | Study was privately funded
| CP present, n = 27; CP absent, n = 116.
| Risk Factor | | | | | | Odds ratio (CI)
| Grade 3 or four IVH on head sonogram | | | | | | 7.94 (2.75, 22.95)
| Hypotension | | | | | | 1.26 (0.47, 3.35)
| Hypocarbia | | | | | | 2.20 (0.77, 6.31)
| Also found no association between average duration of ventilation and CP.
Shepherd 1999 99165413 | CP 9% in this group of preemies who were followed-up at least once after term age (N=53) | | | | | | | | CP not defined. | No data on funding source
| Of the 5 infants with CP, 3 had abnormal VEP. | | | | | | | | CP evaluated by generalists with no uniform definition.
| Of those without CP, 4 had abnormal VEP. | | | | | | | | Incomplete Methods and large number of missing information.
| Sensitivity of VEP before term for CP = 60%.
| Specificity is 92%.
| Positive predictive value of abnormal VEP for CP is 43%.
| Negative predictive value is 96%.
Stathis 1999 99325758 | Head circumference category at 8 months corrected age related to learning delay greater than one year when assessed at 6 years: | | | | | | | | One nursery | Study was privately funded
| HC Category | | | n | % with delay | | | | High rate of patients lost to follow-up (30%)
| < 3^rd^ percentile | | | 23 | 61% (39, 80) | | | | Small numbers: limited ability to detect small differences; high chances of type 2 error
| 3^rd^ to 10^th^ | | | 13 | 77% (46, 95) P = 0.004
| > 10^th^ | | | 40 | 30% (17, 47)
| Head circumference category at 12 months CA did predict McCarthy General Cognitive index at six years, but head circumference category at 24 months CA did not significantly predict McCarthy CGI at 6 years.
| Head circumference and head growth velocity was not shown to have a relationship with attention deficit hyperactivity disorder.
| Head circumference category < 10^th^ vs. greater than 10^th^ percentile at four and 8 months corrected age were significantly associated with McCarthy CGI at 6 years age
Vohr 1999 99332101 | Normal Neurologic Examination: 75% | | | | | | | | Poor f/u rate of 78% and this may significantly underestimate outcome.
| CP overall: 17% but 29% in 401–500 g babies
| CP (quadriplegia): 6.4%
| CP (left hemiplegia): 0.45%
| CP (right hemiplegia): 0.91%
| CP (diplegia): 8.2%
| Seizure disorder : 5%
| Hydrocephalus with shunt: 4%
| Visual impairment (any): 9%
| Unilateral blindness: 1% overall but 7 % in 401–500g and 801–900g babies
| Bilateral blindness : 2 % overall but 14 % in 401–500 g babies
| Legally blind in one or both eyes: 3%
| Hearing impairment: overall 11 %
| Wearing hearing aids: overall 3 %
| Sits unsupported: 93%
| Sits well alone: 86%
| Walks: 83%, Walks fluently: 70%
| Independently feeds self: 80%
| Bayley MDI < 85 : 66%, Bayley MDI <70: 37%
| Bayley PDI <85: 57%, Bayley PDI <70: 29%
| Chronic lung disease, grades 3–4 IVH/PVL, steroids for CLD, NEC, and male gender associated with increased risk for morbidity
Agustines 2000 20279724 | Predictors for CNS outcome: | | | | | | | | 1) Long term f/up for only 57% (36/63 infants that had survived) | Funding source not report
| Rates of developmental delay at 30 months of corrected age, were significant among extremely VLBW infants 500–750 g | | | | | | | | Those who had f/up had less morbidity than those lost to f/up (incidence of RDS was 47% vs 92% in lost to f/up group)
| Overall CNS outcomes in the 36 infants: | | | | | | | | 2) There was no control group to compare outcomes of extremely VLBW with VLBW infants.
| 1) Normal MDI: 32% | | | | | | | | 3) Stratified analysis for outcome in different GA subgroups had very few patients in each subgroup, thus the confidence intervals are very wide.
| 2) Mild delay in MDI: 40% | | | | | | | | 4) This study was not designed to compare outcomes of SGA vs AGA infants in the group of 500–750g: post hoc comparisons (most of the infants in the 26–29 GA group were SGA)
| 3) Severe Delay in MDI: 28%
| 4) Combined mild and severe delay in MDI: 58%
| 5) Normal PDI: 42%
| 6) Mild delay in PDI: 16%
| 7) Severe delay in PDI: 42%
| 8) Combined mild and severe delay in PDI: 58%
| | | | | | 24 wks | 25 wks | 26–29
| Stratified by GA: | | | | | (N=14) | (N=14) | (N=8)
| 1) Normal MDI: | | | | | 11% | 50% | 33%
| 2) Mild delay in MDI: | | | | | 55% | 25% | 50%
| 3) Severe Delay in MDI: | | | | | 33% | 25% | 17%
| 4) Combined mild and severe delay in MDI: | | | | | 88% | 50% | 67%
| 5) Normal PDI: | | | | | 34% | 50% | 0%
| 6) Mild delay in PDI: | | | | | 22% | 0% | 20%
| 7) Severe delay in PDI: | | | | | 44% | 50% | 80%
| 8) Combined mild and severe delay in PDI: | | | | | 68% | 50% | 100%
Breslau 2000 20298367 | 1) Information from mothers and teachers on children's behavior problems at age 11 revealed that the effect of LBW on attention problems differed between urban and suburban settings. | | | | | | | | 1) Recollection bias: The Hx of maternal smoking during pregnancy was elicited when the child was 6 yrs old. This bias would have resulted in underestimation of the confounding effect of smoking during pregnancy. | Supported by grant from National Institute of Mental Health and National Institute of Drug Abuse
| 2) LBW children had an excess of attention problems in the urban disadvantaged communities and not in the suburban middle class communities. | | | | | | | | 2) Diagnosis bias: Although there was a correspondence of the findings of teachers' reports (who were blind to the LBW status of children) and the mothers' reports, mothers' reports could have been biased (worse scores from mothers of LBW infants)
| 3) LBW infants in the urban setting had twice as high incidence of attention problems as more than twice as high in LBW than in NBW.
| 4) In Urban Setting LBW children had more than 2-fold severe attention problems than NBW children
| 5) In suburban setting there was no difference in severe attention problems between LBW and NBW children.
| 6) LBW children had externalizing problems both in the urban and suburban settings (this effect was mainly accounted for by maternal smoking in pregnancy)
| 7) No LBW effect was observed with respect to internalizing problems
| 8) Regardless of LBW status, maternal smoking during pregnancy was associated with an increase in externalizing problems
| 9) No association was found between maternal smoking during pregnancy and internalizing or attention problems.
| OVERALL SCORES | | | | | Attention scores | Internalizing | Externalizing
| MOTHER'S SCORES
| Urban | | | LBW (n=217) | | 58.8 | 52.7 | 52.2
| | | | NBW (n=164) | | 55.8 | 51.5 | 20.4
| Suburban | | | LBW (n=194) | | 55.1 | 50.4 | 48.4
| | | | NBW (n=142) | | 53.8 | 48.6 | 46.3
| TEACHER'S SCORES
| Urban | | | LBW (n=186) | | 56.9 | 50.3 | 53.9
| | | | NBW (n=151) | | 54.7 | 48.8 | 48.5
| Suburban | | | LBW (n=180) | | 53.7 | 49.0 | 48.5
| | | | NBW (n=135) | | 54.0 | 48.7 | 48.3
| 1) According to mother's ratings: [underlined: For attention, externalizing and internalizing problems:] LBW scored higher (had more problems) than NBW children.
| 2) According to teacher's rating:[underlined: Only for externalizing and internalizing problems:] LBW scored slightly higher than NBW.
| 3) Urban children received higher scores than suburban children on all 3 domains, according to both mother' and teacher's ratings
Buhrer 2000 20280896 | Major Neurodevelopmental impairment 22% | | | | | | | | No information as to whether evaluators were blinded | No data on funding source
| Independent predictors of neurodevelopmental impairment (logistic regression):
| CRIB score: R =0.216, β =0.2233, SE =0.051
| Maximum FIO2: R = 0.1201, β = 1.23, SE 0.4553
| Griffith's general quotient = 85 in this population: 21.6%…
| A CRIB score of 6 or more has a sensitivity and specificity 27.6% and 91.3% for predicting neurologic impairment.
Grether 2000 20448692 | Receipt of MgSO4 treatment: | | | CP | | Control | | | Retrospective case control | No data on funding source
| | | | (N=170) | | (N=288) | | | CP defined from chart review
| | | | 98 (58%) | | 178 (62%)
| | | | OR: 0.84 95% CI: 0.56–1.26
| Total duration (HR): (mean SD) | | | 51 ± 78 | | 53 ± 72 NS
Katz-Salamon 2000 20332284 | Infants were assessed at 10 months corrected age. Authors used Griffith's Development Scale and the Movement Assessment Index (MAI, a surrogate for evolving CP) to assess children without high-grade IVH or PVL to determine whether chronic lung disease (CLD) itself was a risk factor for adverse outcomes. | | | | | | | | One institution; small number of infants/group | Study was privately funded Incomplete result data.
| CLD was associated with significantly lower performance scores on each Griffith's subscale and with significantly higher MAI scores predicting a higher risk of CP. Even in the absence of high-grade IVH or PVL, CLD has a deleterious effect on early development. | | | | | | | | Oldest evaluation <10 months of age
| | | | | | | | | Used a surrogate measure, the MAI for CP
Marlow 2000 20150342 | Pulmonary and Other predictors evaluation forAudiology outcome. | | | | | | | | 1) Very small sample size (cases with SNHL only 15) | Did not report source of funding
| Children with sensorineural hearing loss [15] as compared to control group [30] had longer periods of: | | | | | | | | 2) Analyzed too many predictors and combination thereof, for very few outcomes. Very wide confidence intervals; and even those predictors found to be associated with the SNHL this may have been due to chance.
| 1) Intubation, (14 ds vs 2 ds) | | | | | | | | 3) The association found between SNHL and cerebral palsy was [underlined: not] based on an adjusted analyses for possible confounders;
| 2) Ventilation (34 ds vs 6 ds) | | | | | | | | 4) The 2 groups were different in many factors that were associated with both SNHL and CP
| 3) Oxygen therapy (57 ds vs 10 ds)
| 4) Acidosis (12 ds vs 0.5 ds), and
| 5) More treatments with dopamine (33% vs 7%)or
| 6) Furosemide (87% vs 53%)
| 7) Neither P/T of aminoglycosides
| 8) nor duration of jaundice
| 9) or level of bilirubin varied between the 2 groups.
| SNHL was more likely when :
| 1) netilmicin use coexisted with the peak of bilirubin (87% vs 14%)_
| 2) when acidosis occurred when bilirubin was over 200? mol/l, (31% vs 4%)
| 3) when furosemide was used in the face of high creatinine levels (64% vs 27%)
| 4) when furosemide was used with netilmicin (67% vs 37%)
| CNS outcome at 12 mo:
| At 12 months of age evidence of cerebral palsy was present in 7/15 (47%) of children with SNHL vs 2/30 (7%) of children without SNHL.(p=0.022)
Palta 2000 20096107 | CP 12.6%. | | | | | | | | (None) | Study was government funded
(CNS+Eye) | Independent predictors of CP and functional outcome: | | | | | | | | | No ophthalmology results were reported
| IVH OR 2.3 per grade (95 % CI 1.8–2.8)
| BPD OR 2.3 (95% CI 1.2–4.6)
| Percent of the children scoring at least 2 SDs below the normative means for the following functional outcomes:
| Self-care 11.7%
| Mobility 29.5%
| Social function 10.7%
Torrioli 2000 20275419 | Movement ABC: | | | | | | | | Did not give the size of the control group. | Study was privately funded
(CNS+Eye) | Study: | 15.58±7.96 | | | | | | | Baseline demographic data not presented.
| Control: | 7.08±4.61 | P<0.001
| Bell test rapidity:
| Study: | 19.08±7.92
| Control: | 22.02 ±7.36 | P<0.05
| Bell test rapidity:
| Study: | 57.34±19.67
| Control: | 69.08 ± 18.10 | P<0.05
| Visual function (stereopsis %):
| Study: | 41.7
| Control: | 66.7 | P<0.05
Valkama 2000 20233239 | 51 BW < 1500g GA <34 wks: | | | | | | | | (None) | Study was privately funded
| Severe CP: 5; Mod CP: 3; mild CP: 1
| 14 SGA: 2/14 CP (14%)
| 16 EVLBW<1000g: 6/16 CP (0.34)
| <29 wks : 12 CP
| Abnormal MRI 11/19
| Delayed myelination 3/8
Vohr 2000 20295211 | Studied effect of early IVH at 5 to 11 hours of age on IQ distribution and presence of cerebral palsy (CP). Assessed at 36 months CA. | | | | | | | | IVH rates seems high | No data on funding source
| | | Early IVH present | | Early IVH absent | | P value
| | N | 29 | | 249
| Binet IQ | | 78.7 (25) | | 87.5 (20) | | 0.09
| Binet IQ < 70 | | 38% | | 19% | | 0.03
| PPVT-R | | 76.6 (28) | | 86.0 (21) | | 0.15
| CP at 36 months | | 25% | | 8% | | 0.01
| Later IVH had effect on Binet IQ similar to early IVH.
Dammann 2001 21334215 | CP prevalence: | | | | | | | | (None) | Study was privately funded
| BW ≤ 1500g & AGA: 16%
| BW ≤ 1500g & SGA: 4% | | P=0.005
| In this skewed population, 16 % of AGA infants and 4 % of SGA infants had CP at 6 years.
Gaillard 2001 21221175 | Predictors for Neurodevelopmental outcome: | | | | | | | | In First component: | No data on funding source
| 1) Shorter length of ventilation (beyond 27(but not 50) postnatal days) was associated with better neurodevelopmental outcome : | | | | | | | | retrospective cases control design:
| 59% (33/56) neurodevelopmentally normal or only mildly disabled survivors vs 25% (7/28) with more prolonged ventilation( > 49 ds ) | | | | | | | | 1) the 2 groups were unmatched for possible confounders, thus cannot exclude false associations
| Ventilated beyond 27 (but not 50)ds vs Ventilated beyond 49 ds | | | | | | | | 2) Cannot exclude selection bias as only 62 survivors were analyzed from the 84 initially included in the 2 groups
| Total: 56 vs 28 | | | | | | | | In the Second component:
| Survived: 48/56 (86%) vs 14/28 (50% | | | | | | | | 3) Problems of confounders due to historical control group could be even greater
| Normal neurodevelopmentally: 26/48 (54%) vs 5/14 (36%) | | | | | | | | Failed to report % of antenatal use in each group.
| Mild disability: 7/48 (15%) vs 2/14 (14%) | | | | | | | | Demographic data included babies that died prior to neurologic evaluation, possible source of bias.
| Moderate disability: 11/48 (23%) vs 4/14 (29%) | | | | | | | | No information on comorbidities that may have led to prolonged intubation with no attempt to adjust for these
| Severe disability: 4/48 (8%) 3/14 (21%)
| 2) Number of days “off”" ventilator was not associated with the neurodevelopmental outcome at 3 yrs neither in the groups of 27–49 postnatal ds ventilation nor in the group of >49ds ventilation
| Ventilated beyond 27 (but not 50)ds and O ds “off” ventilator vs 1–7 ds “off” ventilator vs > 7 ds off ventilator
| Total: 18 vs 17 vs 21
| Survived: 13 (72%) vs 15 (88%) vs 20 (95%)
| Neurodevelopmentally normal: 8 (44%) vs 7 (41%) vs 11 (52%)
| Mild disability: 2 (11%) vs 2 (12%) vs 3 (14%)
| Moderate disability: 3 (17%) vs 4 (24%) vs 4 (19%)
| Severe disability: 0 vs 2 (12%) vs 2 (10%)
| (In the second component: comparison of the retrospective cohort withthe historical control)
| 3) Birth in a period where antenatal steroids and exogenous surfactant was more routinely used was associated with better neurodevelopmental outcome (69% vs 40% and 45% respectively in the 2 historical control cohorts)
Horwood 2001 20574647 | Assessed influence of breastfeeding (BF) duration on outcome at 7–8 years age. | | | | | | | | Retrospective collection of breast feeding data | Study was government funded
| IQ scores before adjusting for covariates | | | | | | | | 17 children could not be tested because of sensorineural problems | Goal of study was to assess predictive value of NBRS (neurobiologic risk score) and neonatal neurologic inventory, NNI , with respect to long- outcome of preterms between 25–34 weeks. term neurodevelopment outcome of preterms between 25–34 weeks.
| Group | | n | | Verbal IQ | | Performance IQ | | No information about perinatal medical condition
| Not BF | | 76 | | 94.4 (18.4) | | 8.7 (19.6) | | Not clear if examiners were aware of feeding history
| BF < 4 mo | | 99 | | 97.2 (18.4) | | 101.4 (15.6)
| BF 4–7 mo | | 46 | | 101.7 (17.3) | | 101.1 (14.0)
| BF > 8 mo | | 59 | | 104.6 (14.7) | | 104.9 (15.3)
| Adjustment for covariates of maternal education, two parent families, higher income families, non-smoking during pregnancy and non-Polynesian ethnicity did not change the hierarchy of results. Verbal IQ beta value = 0.12, P < 0.05 and performance IQ beta value 0.08 with P > 0.15
Nadeau 2001 21163667 | EP/ VLBW, n = 61 and controls, n = 44. | | | | | | | | (None) | No data on funding source
| | | EP/ VLBW | | Control | | Significance | | | Data on neuromotor and intellectual functioning only collected once
| Normal neuromotor function | | 67% | | 97% | | NS
| Abnormal neuromotor function | | 33% | | 3%
| McCarthy IQ [mean (SD)] | | 100.3 (19.1) | | 112.8 (16.2) | | P <0.01 | | | Data on behavior collected once
| Behavioral ratings at 7 years age:
| Peers rated EP/ VLBW's as significantly more sensitive/ isolated than controls
| Teachers rated EP/ VLBW's as significantly more inattentive than controls
| Parents rated EP/ VLBW's as more hyperactive than controls
| Significantly = P < 0.01
Pierrat 2001 27221167 | Overall, majority of premature infants with cystic PVL are not normal. Cystic-PVL (both Gr II and Gr III) is highly associated with CP. 29 of 30 infants with c-PVL + Ventriculomegaly at 40 wk PMA had CP. | | | | | | | | (None) | No data on funding source
| The following show differences in outcome based on whether the infant had cystic PVL (Grade II) or cystic PVL (Grade III):
| | | c-PVL (Gr II) | | c-PVL (Gr III)
| No motor sequelae | | 24% | | 3%
| CP | | 76% | | 97%
| Independent walking | | 22/29 | | 3/26

Evidence Table 4. Studies Evaluating Treatment Effects of LBW and Cerebral Palsy and Neurological Outcomes Part I

Author, Year UI# | Demographics | Inclusion Criteria | Exclusion Criteria | Disease/Condition Type (N) | Study Design (Duration)
Als 1994 94358983 | Location: US | BW < 1250 g | ND | Experiment: VLBW infants participated in individualized developmental care (20) | Randomized controlled trial
(CNS+Pulmonary) | Years of Birth: ND | GA < 30 weeks and more than 24 weeks of estimated GA at birth | | Controls: VLBW infants received standard care (18) | (2 weeks and 9 months)
| Median GA (range), wk: | Mechanical ventilation starting within the first 3 hrs after birth and lasting longer than 24 hrs in the first 48 hrs
| Experiment: 27.1±1.6 | Alive at 48 hrs
| Control: 26.5±1.4 | Absence of chromosomal or other major genetic anomalies, congenital infections, and known fetal exposure to drugs of addiction
| Median BW (range), g: | Singleton
| Experiment: 827±173 | At least one family member with some English-language facility
| Control: : 862±145 | Telephone access
| Male: | Living within the greater Boston area
| Experiment: 45%
| Control: 61%
| Race: Black
| Experiment: 40%
| Control: 17%
| SES I, II/III/IV, and V:
| Experiment: 45%, 20%, 35%
| Control: 56%, 17%, 27%
| Enrolled: 43
| Evaluated: 38
| Number of sites: 1
Corbet 1995 95264244 | Location; USA | Born alive | ND | Sample 1: | Combination of 3 multicenter, randomized, double blind studies of synthetic surfactant vs air placebo [1 yr]
| Years of Birth: 1986-1989 | Qualifying BW (not specified in this publication) | | Synthetic surfactant: [314]
| Mean GA: | That were intubated and assigned randomly to receive either synthetic surfactant or air placebo as part of their participation in 3 multicenter RCTS. | | Sample 2:
| Sample 1: 27 ± 2 | Had follow up at 1 yr of age | | Air placebo [283]
| Sample 2: 27 ± 2
| Mean BW:
| Sample 1: 934 ± 179
| Sample 2: 931 ± 191
| Males:
| Sample 1: 50%
| Sample 2: 50%
| Race:
| Sample 1: whites: 41%, blacks: 37%, others: 22%
| Sample 2: whites: 46%, blacks: 36%, others: 18%
| Enrolled: 1046
| Evaluated: 597
| Number of sites: Multicenter
Allan 1997 97336492 | Location: US | BW 600–1250g | Died by age of 1 year | Experiment Indomethacin group (173) | Randomized Controlled Trial
Ment 1996 97040638 | Years of Birth: 1989-1992 | Age< 6 hours | Lost to follow-up | Controls: Placebo (170) | (36, and 54 months)
Ment 2000 20164956 | Median GA (range), wk: | No IVH presence at 6–12 hours | Presence of IVH in sonogram between 6–12 hr of age | [underlined: At 36 months]:
(CNS+All) | Experiment: 27.7±1.9 | | Bilingual or non-English speaking at home | Experiment: Indomethacin group (173)
| Control: 28.4±2.0 | | | Controls: Placebo (170)
| Median BW (range), g: | | | [underlined: At 54 months]:
| Experiment: 945±191 | | | Experiment: Indomethacin group (170)
| Control: : 988±164 | | | Controls: Placebo (167)
| Male:
| Experiment: 56%
| Control: 57%
| Race: ND
| Enrolled: 505
| Evaluated: 431 ? 343 at 36 months ? 337 at 54 months
| Number of sites: 3
Van Wassenaer 1997 98103082 | Location: Amsterdam | Premature : 25–30 wks | Congenital malformations | Sample 1 | Prospective comparative study
| Years of Birth: 1991-1993 | Admitted to their NICU within first 24 hrs of life | Maternal endocrine disorders | Thyroxine (8 ?g/kg BW once daily) for the first 6 wks of life starting during the first 12–24 [82] | (The initial study was a randomized, double blind, placebo-controlled trial but in the current comparative component the patients in the subgroups of different GA that were compared were no longer randomly assigned)
| Mean GA: ND | Admitted between 1991-1993 | Maternal illicit drug use | Subgroup 1: 25–26 GA [13]
| Mean BW: | | | Subgroup 2: 27 GA [17]
| Sample 1/subgr 1: 856 ±153 | | | Subgroup 3: 28 GA [23]
| Sample 1/subgr 2: 1048 ± 195 | | | Subgroup 4: 29 GA [29]
| Sample 1/subgr 3: 1140 ± 156 | | | Sample 2: Placebo [ 76]
| Sample 1/subgr 4: 1160 ± 246 | | | Subgroup 1: 25–26 GA [18]
| Sample 2/subgr 1: 914 ± 111 | | | Subgroup 2: 27 GA [13]
| Sample 2/subgr 2: 914 ± 137 | | | Subgroup 3: 28 GA [ 21]
| Sample 2/subgr 3: 1173 ± 156 | | | Subgroup 4: 29 GA [24]
| Sample 2/subgr 4: 1285 ± 236
| Males:
| Sample 1/subgr 1: 54%
| Sample 1/subgr 2: 41%
| Sample 1/subgr 3: 44%
| Sample 1/subgr 4: 59%
| Sample 2/subgr 1: 56%
| Sample 2/subgr 2: 23%
| Sample 2/subgr 3: 38%
| Sample 2/subgr 4: 50%
| Race: ND
| Enrolled: 200 (100 in thyroxine group and 100 in placebo group)
| Evaluated: 158
| Number of sites: 1
O'Shea 1999 99318938 | Location: Korea | BW < 1501 g | Parental refusal | Experiment | Randomized controlled trial (1 year)
| Years of Birth: 1992-1995 | Age 15–25 days old | Survived to 1-year adjusted age | Dexamethasone × 42 days (50)
| Median GA (range), wk: | Not wearing ventilator, no sepsis; no PDA , an echocardiogram indicating the absence of a patent ductus arteriosus | | Controls: Placebo (45)
| Experiment: 25 (23–29)
| Control: 26 (23–31)
| Median BW (range), g:
| Experiment: 747 (420–1362)
| Control: 775 (495–1324)
| Male:
| Experiment: 48%
| Control: 51%
| Race: African-American
| Experiment: 34%
| Control: 49%
| Enrolled: 118
| Evaluated: 95
| Number of sites: 2

Evidence Table 4. Studies Evaluating Treatment Effects of LBW and Cerebral Palsy and Neurological Outcomes Part II

Author, Year | Predictors | Predictor Measures | Outcomes | Outcome Measures
Als 1994 94358983 | Other: | The psychologist and clinical nurse specialist provided ongoing support for the care teams and parents of the infants in the experimental group in jointly planning and implementing individually supportive care and environments. | CNS: | Baley Scale of Infant Development at 9 months of age
| Participation in individualized developmental care staffing by specially educated nurses | | Neurodevelopmental: | Assessed by double-blind review of cranial US scans by a consultant senior radiologist
| | | Cognitive delay
| | | Pulmonary:
| | | BPD severity
Corbet 1995 95264244 | General: | Not further specified | Growth: | Assessment at 1 yr of corrected age
| 1) Synthetic surfactant (single dose via ET tube of 5 mg/kg vs air placebo) | | Growth status at 1 yr: | Not further specified
| | | 1) Weight
| | | 2) Height,
| | | 3) HC and percentiles distribution
| | | Other:Health status at 1 yr:
| | | 1) Surgeries
| | | 2) Readmissions to hospital
| | | 3) CLD, medications for CLD
| | | 4) Respiratory support on exam day
| | | 5) Medications for chronic neurologic disease
| | | 6) Asthma, Eczema
| | | CNS:Neurodevelopmental outcome
| | | 1) MDI
| | | 2) PDI
| | | 3) Impairments: Present absent
| | | 4) Severity of impairment
| | | 5) Type of impairment (MDI<69, MDI 69–84)
| | | 6) CP
| | | Audiology
| | | 1) B/L sensorineural deafness
| | | 2) Deafness not requiring amplification
| | | Ophthalmology(worst exam and last)
| | | 1) B/L blindness
| | | 2) Visual defect
| | | 3) No ROP, mild/moderate ROP, severe ROP)
| | | 4) Treatment for ROP (surgery, cryotherapy)
Allan 1997 97336492 | General: SGA/IUGR, Antenatal steroids; Apgar score, Gender | Diagnoses according to radiologic assessments. | CNS: | Neurologic examination
Ment 1996 97040638 | CNS : | The grading system for hemorrhages was: grade 1, blood in the periventricular germinal matrix regions; grade 2, blood within the lateral ventricular system without ventricular dilation; grade 3, blood within and distending the lateral ventricles; and, grade 4, blood within the ventricular system and parencyhmal involvement. | Cerebral palsy | [underlined: At 36 months:]
Ment 2000 20164956 | Intracranial/Intraventricular hemorrhage | | Neurodevelopmental: | Stanford-Binet IQ
(CNS+All) | Indomethacin | | Cognitive delay | PPVT-R
| Seizures | | Mental retardation | [underlined: At 54 months:]
| Indomethacin | | Behavioral Disorders | Cognitive delay: WPPSI-R or PPVT-R (Full scale IQ<70)
| Pulmonary: bronchopulmonary dysplasia | | Seizure disorder | Vineland adaptive checklist and child behavior checklist
| Other: multiple birth, MgSO4, Surfactant | | Ophthalmology:Blindness
| | | Audiology:Deafness
Van Wassenaer 1997 9810382 | Other/General: | Thyroxine administration started at 12–24 hrs of life in a fixed dose of 8 ?g/kg BW, once daily | CNS | Neurodevelopmental outcome:
| 1) Thyroxine administration during first 6 weeks of life (vs placebo) | | 1) Neurologic outcome | Described in another publication
| 2) GA | | 2) Developmental outcome | Abnormal if:
| | | (Assessment at 24 mo corrected age) | 1) Severe abnormality of tone
| | | | 2) Severe abnormality of posture
| | | | 3) Severe abnormality of movement
| | | | Leading to functional impairment or Delay in motor development
| | | | Suspect if:
| | | | 1) Moderate abnormality of tone
| | | | 2) Moderate abnormality of posture
| | | | 3) Moderate abnormality of movement
| | | | Leading to mild or moderate functional impairment or developmental delay
| | | | MDI (Mental Development Index by Bayley)
| | | | PDI (Psychomotor development index by Bayley)
| | | | According to Dutch standards
| | | | 1) Abnormal if: < 2 SDs below mean Or if score< 68
| | | | 2) Suspect if < 1 SD or score: 68–84
| | | | 3) Normal if score> 83
O'Shea, 1999 99318938 | Other: Dexamethasone | ND | CNS: | CP was diagnosed only if both a pediatrician and a physical therapist agreed with impaired motor function
| | | CP | Bayley scale
| | | Neurodevelopmnetal: | Based on subjective assessment of the physician and therapist, the neurologic exam was classified into no, mild, moderate, and severe abnormality.
| | | Cognitive delay | “Mild abnormality” - hypotonia (which typically was most prominent in the truncal musculature) but not CP
| | | Neurological exam | No definition for moderate and severe abnormality.

Evidence Table 4. Studies Evaluating Treatment Effects of LBW and Cerebral Palsy and Neurological Outcomes Part III

Author, Year | Associations found | | | | | Potential Biases | Comments
Als 1994 94358983 | Studied effect of an individualized developmental care plan on Bayley score at 9 months age and occurrence and severity of BPD. | | | | | Small number of babies studied | Study was government funded
| | | | | | Only one NICU
| | | Experimental group | Controls | P value | Only one neurodevelopmental assessment at 9 months of age
| N | | 20 | 18 | | Reported timing of IVH different from many other studies
| Bayley MDI | | 118.30(17.35) | 94.38(23.31) | <0.001 | High potential for contamination
| Bayley MDI | | 100.6(20.19) | 83.56(17.97) | <0.01
| NO BPD | | 2/20 | 3/18
| Mild BPd | | 13/20 | 7/18
| Moderate BPD | | 5/20 | 2/18
| Severe BPD | | 0 | 6/18 | 0.03
Corbet 1995 95264244 | GROWTH AT 1 YR: Mean measurements of Height (74 cm), weight (9.1 kg) and HC (46 cm) and growth percentiles were equivalent in the 2 groups. | | | | | 1) The incidence of severe impairment in the 19% of infants who did not return for evaluation at the age of 1 yr may be higher than in those who were evaluated. | Source of funding not reported.
| HEALTH STATUS AT 1 YR: No difference in parameters between 2 groups | | | | | | 1) The neurodevelopmental evaluation of infants at 1 yr may not be absolutely reliable for the estimation of later outcome.
| 1) Surgeries (33% vs 34%) | | | 2)Readmission to hospital (45% vs 39%) | | | 2) The estimated mental retardation is likely to be low, and the estimated CP is likely to be high, compared to estimates at 2 and 3 yrs.
| 2) CLD (11% vs 10%) | | | 4) Medications for CLD (14% vs 14%)
| 3) Respiratory support (4% vs 2%)
| 4) Med. for chronic neurologic problems (1% vs 2%)
| 5) Asthma (this only was s/s : 9% vs 3%) | | | 8) Eczema (2% vs 1%)
| NEURODEVELOPMENTAL OUTCOME: No difference in the outcomes between the 2 groups in these parameters.
| 1) Mean MDI (values <50= 49): | | | 2) Mean MDI (only children with MDI>69)
| 2) Number of children with MD | | | 4) Number of children with PDI<69
| 3) Mean PDI (values<50=49) | | | 6) Mean PDI (only children with PDI>69)
| CNS IMPAIRMENT: No difference in any impairments between 2 groups
| 1) Present: 43% vs 37% | | | 2) Absent: 57% vs 63%
| 2) Mild/moderate: 20% vs 14% | | | 4) Severe:23% vs 23%
| 3) MDI<69: 17% vs 16% | | | 6) MDI: 69–84: 18% vs 14%
| 4) 4) CP mild: 8% vs 7% | | | 8) CP moderate/severe: 7% vs 7%
| Audiology:
| 1) B/L sensorineural hearing deafness: 0% vs 1%
| 2) Deafness not needing amplification: 0% vs 1%
| Ophthalmology:
| 1) B/L blindness: 3% vs 2% | | | 2) Visual defect: 8% vs 8%
| Worst examination
| 2) No ROP: 30% vs 33% | | | 2) Mild/moderate ROP: 53% vs 52%
| 3) Severe ROP: 17% vs 15% | | | 4) Surgical treatment for ROP:10% vs 12%
| 4) Cryotherapy for ROP: 5% vs 6%
| Last examination
| 5) No ROP: 69% vs 72% | | | 2) Mild/moderate ROP: 26% vs 22%
| 6) Severe ROP: 5% vs 6% | | | 4) Surgical treatment for ROP: 4% vs 4%
| 7) Cryotherapy for ROP: 2% vs 3%
| Infants who survived after treatment at birth with single-dose synthetic surfactant fare as well in terms of growth, development and late morbidities as infants who survive without treatment. No difference in medical history during first year of life, growth, incidence of visual or auditory defects, CP, neurodevelopmental delay at 1 yr adjusted age.
Allan 1997 97336492 | Antecedents of Cerebral Palsy (CP). | | | | | Stanford-Binet testing limited to monolingual, English-speaking families | Study was government funded
Ment 1996 97040638 | Risk Factor | | n | Percent with CP | P value
Ment 2000 20164956 | BPD | Yes | 177 | 15% | | | Study in a follow-up of originally randomized cohort; followed at 36 and 54 months age, corrected
(CNS+All) | | No | 203 | 4% | <0.001
| Surfactant | Yes | 245 | 13%
| | No | 136 | 4% | 0.003
| Grade 3 or 4 IVH | Yes | 15 | 53%
| | No | 366 | 8% | <0.001
| PVL | Yes | 25 | 53%
| | No | 352 | 6% | <0.001
| Ventriculomegaly | Yes | 17 | 59%
| | No | 328 | 7% | <0.001
| Assessed at 36 months corrected age:
| No significant differences between placebo and indo. for: Presence of CP/ abnormal neurologic exam (8% vs. 8%, Placebo vs. Indo); Blindness (1% in each); Deafness (1% in each); Stanford-Binet IQ (85.0±20.8 vs. 89.6±18.9, Placebo vs. Indo)
| Presence of IVH was associated with a significant decrease in Stanford-Binet IQ: IVH absent, 84.4 ±19.6 vs. IVH present 80.2 ±20.9 (P = 0.03)
| Assessed at 54 months corrected age:
| | | Indomethacin | Placebo | P-value
| N | | 170 | 167
| Blind | | 1(<1%) | 1(<1%) | ns
| Deaf | | 1(<1%) | 1(<1%) | ns
| Seizures | | 1(1%) | 5(3%) | ns
| CP | | 7% | 7% | ns
| WPPSI Full IQ<70 | | 9% | 17% | 0.035
| WPPSI Full IQ 70–80 | | 12% | 18%
| PPVT-R IQ<70 | | 12% | 26% | 0.02
| PPVT-R IQ70–80 | | 19% | 6%
| N | | 119 | 114
| Vineland Total Score *There was no significant difference between groups: Communication; Daily living skills; Socialization; Motor skills
| For CBCL results, children in Indo. group has significant lower score in Withdrawn subscale than children in Placebo group (52.7 vs. 54.6, p=0.02). There is no significant difference found in the other subscales of CBCL.
Van Wassenaer 1997 9810382 | 1) In infants of 25–26 wks GA, thyroxine administration during the first 6 weeks after birth is associated with an improvement in mental developmental outcome/MDIs.(p<0.01) | | | | | 1) In this study, many pot hoc exploratory subgroup analyses were done: Small number of patients in each subgroup and although the patients were randomly assigned in the original 2 groups, this does not continue to be the same for the subgroups of different GA analyzed. | It should be taken into consideration that the initial RCT with 200 infants less than 30 wks had shown no clear association between thyroxine administration and neurodevelopmental outcome.
| 2) Thyroxine administration does not improve and might even harm mental (but not psychomotor/PDIs or neurological ) outcomes in infants 27–20 wks. | | | | | 2) Thus association proposed for beneficial effect of T4 particularly for the subgroup of infants less than 27, weeks and only for the MDI scores; and not for the PDI scores or the neurological outcomes; must be viewed cautiously.
| 3) There was also a trend towards a better psychomotor and neurologic outcome (normal, suspect, abnormal). | | | | | 3) Except for Thyroxine and GA the effect of the other covariates/predictors included in the linear regression model was not discussed.
O'Shea, 1999 99318938 | | | Dexamethasone (N=50) | Placebo (N=45) | P | (None) | Study was government funded
| Definite Cerebral Palsy | | 12 | 3
| Possible CP | | 5 | 2
| Overall CP | | 17 | 5 | 0.006
| Neuro exam severe
| Abnormal | | 4 | 2
| Mild abnormal | | 16 | 6
| Overall abnormal
| Neuro exam | | 20 | 8 | 0.03

Evidence Table 5A. Studies Evaluating Association of LBW to Speech and Language Disorders Part I

Author, Year UI# | Demographics | Inclusion Criteria | Exclusion Criteria | Disease/Condition Type (N) | Study Design (Duration)
Wood 2000 20373840 | Location: UK and Ireland | GA 20–25 weeks survivors | ND | Preterm infants (283) | Prospective cohort (30 [28–40] months)
| Years of Birth: 1995-1996
| Mean GA (range), wk: 22–25
| Mean BW (range), g: ND
| Male: ND
| Race: ND
| Enrolled: 314
| Evaluated: 283
| Number of sites: 276
Lefebvre 1998 98387703 | Location: Canada | GA<28 weeks | ND | Preterm infants (121): | Prospective cohort (CA 18.6 ±1.2 [17–19] months)
| Years of Birth: 1987-1992 | 3 or more cranial ultrasounds | | Low risk (50)
| Mean GA (range), wk: 27.0±1.2 | Survival to discharge | | Moderate risk (37)
| Mean BW (range), g: 961±179 (585–1450) | | | High risk (34)
| Male: 52%
| Race: ND
| Enrolled: 139
| Evaluated: 121
| Number of sites: 1
Wolke 1999 10075095 | Location: Germany | Cases: 1) Requiring admission to 1 of 17 hospitals in S. Bavaria within first 10 days. 2) Assessments at 5 and 20 months, 4 years 8 months, and 6 years 3 months. 3) VLBW (very preterm) GA≤32 weeks at birth. | ND | Cases: | Non-randomized comparison trial
| Years of Birth: 1985-1986 | Controls: 1) Control group (full term) GA>36 weeks at birth. | | Sample 1: VLBW (or very preterm): 264
| Description of group: | For all groups: German-speaking | | Controls:
| Sample 1: VLBW | | | Sample 2: Full term/ controls: 264
| Sample 2: Full term/ controls | | | Sample 3: Normative: 311
| Sample 3: Normative sample
| Mean GA (range), wk:
| VLBW: 29.5± .2 (29.3–29.7)
| Control: 39.6± .1 (39.5–39.7)
| Mean BW (range), g:
| VLBW: 1288±42 (1247–1330)
| Control: 3407±58 (3351–3463)
| Male (%):
| VLBW: 56.4%
| Control: 56.4%
| Normative: 51%
| Race: ND
| Enrolled:
| VLBW: 560
| Control: 916
| Normative: 311
| Evaluated:
| VLBW: 264
| Control: 264
| Normative: 311
| Number of sites: 17 (hospitals)
Smith 1996 97081985 | Location: US | Cases: 1)VLBW≤1600 g 2)Female primary caregiver 3)Completed both a 6 and 12 mos. home visit. 4)GA≤ 36 weeks at birth. | 1) Primary caregiver age<16, drug abuser, or not English-speaking. | Cases: | Non-randomized comparison trial
| Years of Birth: 1990-1992 | Sample 1: HR VLBW: one or more severe medical complications: bronchopulmonary dysplasia (BPD) defined as need for O2 for more than 28 days, severe IVH with progressive dilitation defined as a Grades III or IV subependymal hemorrhage, and/or periventricular leukomalacia characterized by ischemic lesions. | 2) Sensory impairment, meningitis, encephalitis, congenital syphilis, congenital abnormality of the brain, cardiac abnormalities, NEC or HIV antibody positive. | Total VLBW: 211
| Description of group: | Sample 2: LR VLBW: one or more less severe medical complications, including transient respiratory distress where O2 is required for less than 28 days and/or mild IVH without dilitation- Grades I and II. | | Sample 1: HR VLBW: 88
| Sample 1: High risk VLBW | Controls: | | Sample 2: LR VLBR: 123
| Sample 2: Low risk VLBW | Sample 3: FT: GA: 37–42 weeks with normal pregnancy history and physical examination at birth. | | Controls:
| Sample 3: Full term (controls) | | | Sample 3: Full-term
| Mean GA (range), wk: | | | infants: 128
| HR VLBW: 28± 2
| LR VLBW: 30.9±2
| FT: 39.1±5.9
| Mean BW (range), g:
| HR VLBW: 930±233
| LR VLBW: 1263±202
| FT: 3187±767
| Male (%):
| HR VLBW: 50%
| LR VLBW: 41%
| FT: 50%
| Race (% African-American):
| HR VLBW: 57%
| LR VLBW: 62%
| FT: 62%
| Enrolled:
| HR VLBW: 89
| LR VLBW: 123
| FT: 128
| Evaluated:
| HR VLBW: 88
| LR VLBW: 123
| FT: 128
| Number of sites: 2
Sajaniemi 2001 11227991 | Location: Finland | Cases: 1) Mothers referred to University Central Hospital in Helsinki for threatened pre-term delivery 2) Assessments at 2 and 4 months, 3) VLBW (very preterm) GA≤29.4± 3 weeks at birth. | Major disabilities (CP or mental retardation) | Cases: | Prospective (single arm) cohort
| Years of birth:1989-1991 | | | VLBW (or very preterm): 63
| Description of group: VLBW | | | No control group
| Mean GA (range), wk: 29.4± 3
| Mean BW (range), g: 1246±472
| Male: ND
| Race: ND
| Days of mechanical ventilation: 12.3±26
| Enrolled: 138
| Evaluated: 63
| Number of sites: 1
Briscoe 1998 98300800 | Location: UK | Cases: Preterm infants, GA<32 weeks, from an Avon Premature Infant Project, Marlow, 1997. | ND | Cases: Preterm infants (26) | Case-control study
| Years of Birth: 7/91– 7/92 | Free of major and minor physical impairment at 2 years of age | | Controls: Full term infants (26)
| Mean GA (range), wk: 28±1.9 (26–32) | Controls: Children age between 3years 7 months and 4 years 5 months born full-term, GA>37 weeks.
| Mean BW (range), g: 1206±345 (815–1985)
| Male: ND
| Race: ND
| Enrolled: 26 (26 controls)
| Evaluated: 26 (26)
| Number of sites: 1
Saigal 2001 21376729 | Location: Canada | ELBW survivors, BW= 501–1000g | ND | Cases: ELBW infants (154) | Prospective cohort (followed to 12–16 years age)
| Years of Birth: 1977-1982 | Controls: term infants recruited at 8 years of age from a random list obtained through the directors of 2 school boards and matched for gender, age, and SES to each case | (Died after discharge (10) | Controls: Term infants (125)
| Mean GA (range), wk: | | Lost to follow-up (8)
| Cases: 27±2 | | Refusal (5)
| Controls: “Term” | | Unable to be reached (2)
| Mean BW (range), g: | | Controls:
| Cases: 835±124 | | Lost to follow-up (10)
| Controls: 3401±481 | | Refusal (8)
| Male: | | Unable to be reached (2))
| Cases: 31%
| Controls: 36%
| Race: ND
| SES: middle class
| Cases: 30%
| Controls: 30%
| Enrolled: 179 (145 controls)
| Evaluated: 154 (125)
| Number of sites: 1
Schendel 1997 98033417 | Location: US | Singleton livebirths in MMIHS study population, survived to 1 year of age | ND | Sample 1: VLBW infants (367) | Case-control study
| Years of Birth: 12/1/89 to 3/31/91 | Cases: MLBW infants, BW 1500–2499g; VLBW infants, BW<1500g | | Sample 2: MLBW infants (553)
| Mean GA (range), wk: | Controls: NBW infants randomly selected from the birth certificate files on the basis of frequency matching with cases by maternal race, age, and residence | | Controls: NBW infants (555)
| Sample 1: 28.4 ±3.0
| Sample 2: 35.6 ±2.8
| Controls: 39.4 ±1.5
| Mean BW (range), g:
| Sample 1: 1088±268
| Sample 2: 2184±267
| Controls: 3417±432
| Male:
| Sample 1: 49%
| Sample 2: 46%
| Controls: 52%
| Race: Black
| Sample 1: 37%
| Sample 2: 37%
| Controls: 41%
| Enrolled: 920 (555 controls)
| Evaluated: 920 (555)
| Number of sites: 5

Evidence Table 5A. Studies Evaluating Association of LBW to Speech and Language Disorders Part II

Author, Year | Predictors | Predictor Measures | Outcomes | Outcome Measures
Singer 2001 21163669 | Cardiovascular or pulmonary predictors: | BPD: preterm,<1500g BW, oxygen for >28 days with radiographic evidence of CLD | CNS outcomes: | Bayley scale of infant development
| 1) Bronchopulmonary dysplasia | | Cerebral palsy | Language (speech/communication) measured by Battelle Developmental Communication Subscale Domain→receptive, expressive and total communication scores converted to DQ mean 100 and SD 15.
| General : BW, Neurologic risk | | Cognitive delay
| Other: Race, Socioeconomic status | | Mental retardation
| | | Ophthalmology outcomes:
| | | Visual impairment
| | | Audiology outcomes:
| | | Hearing disorders
| | | Speech
| | | Language
| | | Communication disorder
Wood 2000 20373840 | General: | ND | CNS: | Bayley scales
| 1) GA | | Motor delay
| 2) Gender | | Cognitive delay
| Other: Perinatal Factors→Multiple gestation | | Seizure disorder
| | | Overall development
| | | Ophthalmology:
| | | Visual impairment
| | | Blindness
| | | Audiology:
| | | Hearing disorders
| | | Deafness
| | | Speech
| | | Communication disorder
| | | Other:
| | | Severely disabled | Severe disability = need of physical assistance to perform daily activities.
| | | Other disability | If disability didn't fit into this category = “other disability”
| | | No disability
| | | Disability of hearing, vision, or communication
Lefebvre 1998 98387703 | Other: Neurobiologic risk score (NBRS) | Items in NBRS: ventilation, PH, surgeries, IVH< PVL, infection, hypoglycemia-items scored zero or greater in progression | CNS: | Neurologic exam
| | | Cerebral palsy | Griffith's mental development scale
| | | Cognitive delay- | Mental retardation-Griffith's mental development scale
| | | Other: neurodevelopmental impairment | 1) Global developmental quotient (DA)
| | | Ophthalmology:Blindness | 2) Mild/moderate: DA 80–89 or CP
| | | Audiology:hearing disorders-free fetal audiogram | 3) Severe: DA<80, severe CP unilateral blindness or severe hearing defect
| | | | 4) Normal: more of the above
| | | | Areas of Griffith's Developmental Scales:
| | | | - Locomotor
| | | | - Personal-social
| | | | - Hearing and speech
| | | | - Eye and hand coordination
| | | | - Performance
| | | | Control mean DA=110+or-in literature
Wolke 1999 10075095 | General predictors: GA | Gestational age GA≤32 for VLBW, GA>36 weeks for full term control group. | Audiology outcomes: | I. [underlined: Language development]:
| | | 1) Language development | a) Heidelberger Sprachentwicklungstest (HSET) (German test)
| | | 2) Prereading skills | II. [underlined: Prereading skills:]
| | | 3) Cognitive status | a) Rhyming and sound-to-word- matching tasks
| | | | III. [underlined: Cognitive status:]
| | | | a) Kaufman Assessment Battery for Children (K-ABC) for cognitive assessment.
| | | | Intelligence was measured with the Mental Processing Composite (MPC): simultaneous and sequential information processing subtests (SGD and SED), and The Achievement Score (AS)
Smith 1996 97081985 | General predictors: Illness acuity, grouped into LR VLBW and HR VLBW, and maternal behavior, warm sensitivity and maintaining of infants interests and directiveness. | Gestational age GA≤36 weeks at birth. | Audiology outcomes: | I. [underlined: Cognitive skills:]:
| | | 1) Cognitive skills | a) Bayley Scales of infant Development expressed as mental age
| | | 2) Language development | II. [underlined: Language development:]
| | | 3) Living skills | a) Sequenced Inventory of Communication Development
| | | | III. [underlined: Living Skills:]
| | | | a) Daily Living Skills subscale from the Vineland Adaptive Behavior Scale
Sajaniemi 2001 11227991 | General predictors: | Gestational age GA≤29.4±3 | Audiology outcomes: | I. [underlined: Temperamental characteristics:]
| | | 1) Temperamental characteristics (at 2 years of age) | a) Toddler Temperament Questionnaire (TTQ), measuring activity, rhyhmicity, approach, adaptability, intensity, mood, persistence, distractability, and sensory threshold.
| | | 2) Behavioral characteristics (at 2 years of age) | II. [underlined: Behavioral characteristics:]:
| | | 3) Cognitive precursors (at 2 and 4 years of age) | a) Infant Behavior Record (IBR) of the Bayley Scales, measuring fearfulness, emotional tone, activity, attention span, and goal directness.
| | | 4) Neuropsychological assessment (at 4 years of age) | III. [underlined: Cognitive precursors:]
| | | | a) Mental Development Index (MDI) from the Bayley Scales of Infant Development was used to measure cognitive level at 2 years.
| | | | a) Wechsler Preschool-Primary Scale of Intelligence (WPPSI) (Finnish version) was used at 4 years of age.
| | | | IV. [underlined: Neuropsychological assessment:]
| | | | a) pre-standard version of the Finnish Neuropsychological Investigation for Children (NEPSY-r, extended version)
Briscoe 1998 98300800 | General predictors: GA | Gestational age < 32 weeks based on expected date of delivery | Audiology outcomes: | II. [underlined: Vocabulary knowledge:]:
| | | 1) Language | a) British picture vocabulary scales
| | | 2) Short-term memory | b) Oral vocabulary component of McCarthy scales of Children's Abilities
| | | 3) General non-verbal ability | c) Bus Story test of Continuous speech tested expressive language ability (retelling story using pictures as on aid)
| | | | III. [underlined: Phonological short-term memory:]:
| | | | a) Digit span: set of pseudo-random numbers to repeat
| | | | b) Non-word repetition
| | | | IV. [underlined: Non-verbal ability:]:
| | | | a) Raven's Progressive Coloured Matrices adapted for use here under 5 years of age
| | | | V. [underlined: Early Development Assessment]:
| | | | a) Griffith's mental development scales
Saigal 2001 21376729 | Birth weight | ELBW=500–1000 g | CNS: | Reported previously in the authors' other paper
| GA | | Motor delay
| | | Cognitive delay
| | | Other: neurosensory impairment
| | | Ophthalmology: | Growth reference population was using the age- and gender-specific reference data provided by the NCHS growth chart
| | | Visual impairment
| | | Growth:
| | | Height
| | | Weight
| | | Head circumferences
| | | BMI (wt/ht2)
| | | Other:
| | | Health status and problems; current and past
| | | Extra health care expenses
| | | Utilization and health care resources
Schendel 1997 98033417 | General Predictors | ND | CNS: | Developmental delay measured by Denver Developmental Screening Test II.
| 1) Birth Weight 3 groups | | Other: Developmental Delay | “DELAY” defined by 9 measures of performance on Denver Developmental Screening Test II at age 15 months corrected.
| VLBM ( very low birth wt) | | Pulmonary:
| MLBW (moderately low birth wt.) | | Birth weight
| NBW (normal birth wt)
| Other Predictors
| 1)Other: married at birth
| 2)Other: Medicaid recipient

Evidence Table 5A. Studies Evaluating Association of LBW to speech and Language Disordes Part III

Author, Year | Associations found | | | | Potential Biases | Comments
Singer 2001 21163669 | Evaluation at 36 months corrected age. VLBW, VLBW with BPD, full term (FT). | | | | Single region, but at least it is a region | Study was government funded
| | | Bayley MDI | % with MDI below 70 | Unclear if examiners were blinded to groups' status
| VLBW | | 90 ± 16 (38–126) | 11%
| VLBW w/ BPD | | 84 ± 24 (10–116) | 21%
| FT | | 96 ± 12 (57–127) | 4%
| P = 0.001 for VLBW vs. VLBW w/ BPD
| | | Bayley PDI | % with PDI below 70
| VLBW | | 98 ± 20 (33–122) | 9%
| VLBW w/ BPD | | 84 ± 29 (8–127) | 9%
| FT | | 103 ± 15 (58–128) | 1%
| P = 0.001 for VLBW vs. VLBW w/ BPD
| At 3 years BPD predicted poorer motor outcome but not poorer mental outcome.
| Receptive DQ: BPD < VLBW < Term, p < 05
| Receptive DQ < 85: BPD 49%, VLBW 34%, Term 30%, BPD < VLBW + Term p < .05
| Expressive DQ: BPD < VLBW + Term, p < .05
| Expressive DQ<85: BPD 44%, VLBW 25%, Term 25% BPD < VLBW + Term p < .05
| Communication DQ: BPD < VLBW + Term, p < .05
| Communication DQ < 85: BPD 43%, VLBW 31%, Term 28%, NS
| Rank order listing of risk factors in order of magnitude of effect and the number of communication DQ lowered by the risk factor: PDA lowered DQ by 13 points, Minority race by 6 points, lower socioeconomic status by 5 points, and higher neurologic risk by 5 points. p .001
| Bayley Scales MDI:
| BPD 83.7 ± 24, VLBW 90 ±16, Term 96.4 ± 12, BPD < VLBW < Term, p< 0.05
| Bayley Scales PDI:
| BPD 84.1 28, VLBW 97.4 19, Term 102.8 14
| BPD < VLBW + Term, p< .05
| ROP: BPD 43%, VLBW 4%, p= .001
| Seizures: BPD 7%,
| Neurologic score: BPD 1.3 ± 2, VLBW 58 ± 1, p < .001
Wood 2000 20373840 | Infants 22–25 weeks GA developmentally assessed at median 30 months | | | | (None) | Severe disability common
| • 138/283 had disability (49%:64 met criteria for severe disability) | | | | | Children born extremely premature
| • 49% no disability
| • 53/283 severely delayed 19%(Bayley below 3 SD)
| • 32/283 2–3 below SD 11%
| • 28 severe neuromotor disability 10%; 7 blind or perceived light only 2%
| • 8 hearing loss that was uncorrectable or required hearing aids 3%
| Survived without overall disability
| 22 wks----------0.7 %
| 23 wks----------5%
| 24 wks----------12%
| 25 wks----------23%
| Severe disability at 30 months
| 22 -------------0.7%
| 23 -------------3%
| 24--------------6%
| 25--------------9%
| • no relation between morbidity pattern and either gestational age &multiple birth; boys were likely to be disabled than girls
Lefebvre 1998 98387703 | Assessed at 18 months corrected age. Divided into low, moderate and high risk group based on Neurobiologic risk score (NBRS). Tested with Griffith's Developmental Scales. | | | | (None) | Study was privately funded
| | Griffiths Developmental Score Category
| Risk Group | n | Severe impairment, <80 | All < 80
| Low | 50 | 0% | 12%
| Moderate | 37 | 22% | 24%
| High | 34 | 50% | 71%
| Significance: for severe or any delay the NBRS was predictive, P < 0.0001
| Risk Group | n | Severe CP(+) | Any CP
| Low | 50 | 0% | 4%
| Moderate | 37 | 13% | 19%
| High | 34 | 26% | 41%
| Significance: NBRS predictive of CP, severe CP, P < 0.0009, any CP P< 0.0001
Wolke 1999 10075095 | • Preterm birth is significantly associated with deficits in wide range of abilities including all measures of cognition, language comprehension and expression, articulation, and prereading skills compare to full-term controls. | | | | Drop-out rate <25%. | Internal validity: A
| • Specific intellectual deficit is in simultaneous central information processing
| • Specific language deficits include problems with grammatical rules, detecting semantically incorrect sentences, motor aspects of speech, articulation, and pronunciation
| • Specific prereading skills deficits include problems with rhyming tasks, sound-to-word matching and naming or number/letters.
| • Deafness 0% in the preterm group
Smith 1996 97081985 | • HR infants have a significantly lower mental age (cognitive skills) at 6 and at 12 mos. then either FT controls or LR infants. | | | | The overwhelming majority of HR VLBW's were HR because of BPD with or without IVH. | Study was privately funded
| • HR infants scored lower in living skills at 6 mos. than FT's but not LR infants. There was no difference between groups at 12 mos. | | | | Low socioeconomic status, inner city population
| • HR infants scored lower for language development at 6 and 12 mos. than FT controls
Sajaniemi 2001 11227991 | • Cognition, behavior and temperament as early as 2 year of age predicted impaired language functioning at age 4 years in infants without major disabilities. | | | | No full-term controls | Internal validity B
| • Preterm children were temperamentally less active, less persistent, and less goal-directed with passive attitude toward environmental stimulus.
| • Preterm infants were less cooperative and highly distractable.
Briscoe 1998 98300800 | When comparing short-term memory and language outcomes, across all measures, preterm infants performed at a lower level, typically one half SD lower. | | | | No difference in regard to social class, maternal education or single parent status. | Study was privately funded
| • 2/3 of preterm infants had normal cognitive profiles. | | | | No GA less than 26 weeks
| • “at risk” subgroup of preterms for language impairment can be identified using an expressive screening tool at an early age (less than 5 yrs) when intervention can be effective(Bus Story Test). | | | | Small sample made effect of IVH/PVL difficult to interpret
| • Meta-analysis 80 studies, preterm IQ lower than full terms but still in the normal range. | | | | “Most” children were recruited through friends and relatives (excluding siblings) of the preterm children in order to minimize social and economic disparity
Saigal 2001 21376729 | Neurosensory Impairment:: ELBW 28%, FT Controls 2%, p= 0.001 | | | | Didn't specify exclusion criteria but these are implied based on clear industry criteria units; to generalizability: different era of natural care 2 white race 3 access to universal health care in Canada | Study was privately funded
| Growth: Weight: diff. between ELBW and FT (mean z scores ) -5.78 (p<0.0001)
| Visual Problems: ELBW 57%, FT Controls 21%, p=<0.001 (OR 5.1, CI 2.89–9.05)
| Current Health Problems (multiple/patient): >3 Health Problems: ELBW 35%, FT Controls 7%, p<0.0001
| Past Health Problems:
| Seizures: ELBW 11%, FT Controls 2%, p<0.005
| Asthma: ELBW 25%, FT Controls 14%, p=0.05
| Recurrent bronchiolitis/pneumonia: ELBW 14%, FT Controls 3%, p=0.005
| Current (at 12–16 yr age) Functional Limitation (Table 4 page 411) (multiple/patient)
| Visual difficulty: ELBW 57%, FT Controls 21%, p<0.001
| Hearing Difficulty: ELBW 7%, FT Controls 5%, ns.
| Emotional problems: ELBW 4%, FT Controls 1%, ns
| Mental problems: ELBW 4%, FT Controls 1%, ns.
| Clumsiness: ELBW 25%, FT Controls 1%, p<0.001
| Developmental Delay: ELBW 26%, FT Controls 1%, p<0.001
| Learning Disability: ELBW 34%, FT Controls 10%, p<0.001
| Hyperactivity: ELBW 9%, FT Controls 2%, p=0.04
| Reduced self-abilities: ELBW 5%, FT Controls 0%, p=0.02
| Limitation in school or in normal activity: ELBW 31%, FT Controls 9%, p<0.002
| Any functional limitation: ELBW 81%, FT Controls 42%, p<0.001
| Functional limitation/child [Mean (SD)]: ELBW 2.0 (1.8), FT Controls 0.6 (0.8), p<0.001
| Utilization of Health Care Resources:
| Pediatrician: ELBW 34%, FT Controls 14%, p<0.0002
| Ophthalmologist: ELBW 62%, FT Controls 34%, p<0.0001
| Ear/nose/throat: ELBW 14%, FT Controls 6%, p<0.05
| Occupational therapist: ELBW 7%, FT Controls 1%, p=0.002
| Speech therapist: ELBW 8%, FT Controls 0%, p<0.002
| Special Education: ELBW 48%, FT Controls 10%, p<0.0001
| Prescription Glasses: ELBW 36%, FT Controls 10%, p<0.001
Schendel 1997 98033417 | Even apparently well VLBW infants with no overt physical impairment are consistently at higher risk for all measures of DELAY than MLBW or NBW infants. VLBW have DELAY in all areas of function with greatest risk for delay in gross motor domain. | | | | The people administering the Denver test were not blinded and were aware of degree of prematurity. | Study was government funded
| “Abnormal” - VLBW 10.9%, NBW 2.9%, p = 0.001 | | | | The adjusted age at f/u had very wide range 9–34 months
| Personal-Social =1 delays: VLBW 7.1%, NBW 2.2%, p = 0.001
| Language = 1delays: VLBW 8.8%, NBW 4%, p = 0.01
| Fine motor-adaptive = 1 delays: VLBW 7.9%, NBW 2.2%, p = 0.001
| Gross motor =1 delays: VLBW 10.7%, NBW 1.8%, p = 0.001

Evidence Table 5B. Studies Evaluating Association of LBW of Audiology Outcomes Part II

Author, Year UI# | Demographics | Inclusion Criteria | Exclusion Criteria | Disease/Condition Type (N) | Study Design (Duration) | Predictors | Predictor Measures | Outcomes | Outcome Measures
Northern Neonatal Nursing Initative Trial Group 1996 96304894 | Location: UK | GA <32 weeks; resident in northern UK | ND | Experiment 1: fresh frozen plasma treatment (257) | Randomized controlled trial (2 years) | Cardiovascular or Pulmonary | ND | CNS Outcomes: | Motor delay: Griffith's gross motor quotient >350 below mean
| Years of Birth: 1990-1992 | | | Experiment 2: gelatin plasma substitute (261) | | Predictors: use of FFP or plasma substitute to expand vascular volume prophylactically | | Motor delay | Griffith's quotient for speech + hearing >350 below mean
| Mean GA (range), wk: 29 (27–31) | | | Glucose controls (258) | | | | Cerebral palsy
| Mean BW (range), g: 1253 (965–1543) | | | | | | | Seizure disorder
| Male: 39% | | | | | | | Post hemorrhagic hydrocephalus
| Race: ND | | | | | | | Ophthalmology:
| Enrolled: 776 | | | | | | | Visual impairment
| Evaluated: 776 | | | | | | | Blindness
| Number of sites: 16 | | | | | | | Audiology Outcomes:
| | | | | | | | Hearing disorders
| | | | | | | | Speech
| | | | | | | | Other outcomes:
| | | | | | | | Blind, deaf, or unable to walk - combined outcome
| | | | | | | | No severe disability - combined outcome
| | | | | | | | Overall developmental quotient - Griffith's
Hack 1996 97066007 | Location: US | BW 500–759 g | ND | Sample 1: VLBW survived infants born in 1990-1992 (surfactant/dex era) (114) | Prospective cohort (followed to 20 months corrected age) | General: Birth Weight | 500–750 gm | CNS: | Neurosensory status BSID: MDI, PDI
| Years of Birth: 7/1982–6/1988, 1/1990–12/1992 | Survived to 20 months corrected | | Sample 2: VLBW survived infants born in 1982-1988 (surfactant and less dex. era) (166) | | | | Cerebral palsy
| Mean GA (range), wk: | Age | | | | | | Motor and cognitive delay
| Sample 1: 25.9±2 (22–31) | | | | | | | Ophthalmology: Blindness
| Sample 1: 25.7±2 (22–31) | | | | | | | Audiology: Deafness
| Mean BW (range), g:
| Sample 1: 688.6±73 (560–740)
| Sample 2: 670.6±56 (502–742)
| Male:
| Sample 1: 28%
| Sample 2: 29%
| Race: White
| Sample 1: 31%
| Sample 2: 37%
| Enrolled: 280
| Evaluated: 280
| Number of sites: 1
Hack 2000 20358826 | Location: US | BW<1000g | Major congenital malformations | VLBW infants (221) | Prospective cohort | General: | ND | CNS: | Neurologic abnormality- includes: CP, hypotonia, hypertonia
| Years of Birth: : 1/1/1992–2/31/1995 | | | | | 1) Birth weight | | Cerebral palsy | Shunt-dependent hydrocephalus
| Mean GA (range), wk: 26.4±1.8 | | | | | 2) GA | | Motor delay
| Mean BW (range), g: 813±125 | | | | | 3) SGA/IUGR | | Cognitive delay MDI score<70
| Male: 43% | | | | | 4) Antenatal steroids | | Post hemorrhagic Hydrocephalus
| Race: ND | | | | | 5) Jaundice | | Ophthalmology: Blindness
| Enrolled: 333 | | | | | CNS: | | Audiology: Deafness
| Evaluated: 221 | | | | | 1) Intracranial/Intraventricular Hemorrhage
| Number of sites: 1 | | | | | 2) Periventricular leukomalacia
| | | | | | 3) Ventriculomegaly/ ventricular dilation
| | | | | | Cardiovascular/Pulmonary: Chronic lung disease
| | | | | | Gastrointestinal: Necrotizing “entroclitis”
| | | | | | Other:
| | | | | | 1) Infectious Disease
| | | | | | 2) Dexamethasone
| | | | | | 3) Perinatal factors (chorioamnionotis)
| | | | | | 4) Multiple birth
| | | | | | 5) C-section
| | | | | | 6) Social risk
| | | | | | 7) Male sex
Wood 2000 20373840 | Location: UK and Ireland | GA 20–25 weeks survivors | ND | Preterm infants (283) | Prospective cohort (30 [28–40] months) | General: | ND | CNS: | Bayley scales
| Years of Birth: 1995-1996 | | | | | 1) GA | | Motor delay | Severe disability = need of physical assistance to perform daily activities.
| Mean GA (range), wk: 22–25 | | | | | 2) Gender | | Cognitive delay | If disability did not fit into this category = “other disability”
| Mean BW (range), g: ND | | | | | Other: Perinatal Factors→Multiple gestation | | Seizure disorder
| Male: ND | | | | | | | Overall development
| Race: ND | | | | | | | Ophthalmology:
| Enrolled: 314 | | | | | | | Visual impairment
| Evaluated: 283 | | | | | | | Blindness
| Number of sites: 276 | | | | | | | Audiology:
| | | | | | | | Hearing disorder
| | | | | | | | Deafness
| | | | | | | | Speech
| | | | | | | | Communication disorder
| | | | | | | | Other:
| | | | | | | | Severely disabled
| | | | | | | | Other disability
| | | | | | | | No disability
| | | | | | | | Disability of hearing, vision, or communication
Singer 1997 98049057 | Location: US | Cases (sample 1&2): premature infants, BW < 1500g | Major congenital abnormality | Sample 1: VLBW infants with BPD infants (122) | Prospective cohort (followed to 3 years corrected age) | Cardiovascular or pulmonary predictors: | BPD: preterm,<1500g BW, oxygen for >28 days with radiographic evidence of CLD | CNS outcomes: | Bayley scale of infant development
Singer 2001 21163669 | Years of Birth: 1989-1991 | Controls: term infants with no diagnosed medical illness or abnormalities at birth, >36 weeks, GW>2500g | Drug exposure | Sample 2: VLBW without BPD (84) | | 1) Bronchopulmonary dysplasia | | Cerebral palsy | Language (speech/communication) measured by Battelle Developmental Communication Subscale Domain→receptive, expressive and total communication scores converted to DQ mean 100 and SD 15.
| Mean GA (range), wk: | | Maternal illness | Sample 3: Full term infants (123) | | General : BW, Neurologic risk | | Cognitive delay
| Sample 1: 27±2 | | HIV | | | Other: Race, Socioeconomic status | | Mental retardation
| Sample 2: 30±2 | | Maternal mental retardation | | | | | Ophthalmology outcomes:
| Controls: 40±2 | | >2 hours driving time from hospital | | | | | Visual impairment
| Mean BW (range), g: | | | | | | | Audiology outcomes:
| Sample 1: 956±248 | | | | | | | Hearing disorders
| Sample 2: 1252±178 | | | | | | | Speech
| Controls: 3451±526 | | | | | | | Language
| Male: | | | | | | | Communication disorder
| Sample 1: 52%
| Sample 2: 43%
| Controls: 50%
| Race: White
| Sample 1: 55%
| Sample 2: 48%
| Controls: 51%
| SES: Hollingshed classification:
| Sample 1: 3.5±1
| Sample 2: 3.6±1
| Controls: 3.6±1
| Enrolled: 464
| Evaluated: 206 (123 controls)
| Number of sites: 3
Schmidt 2001 21298249 | Location: Canada, USA, Australia, New Zealand, Hong Kong | BW: 500–999g | Excluded total 981 (not eligible) | Sample 1: Indomethacin group [574] | Randomized, multicenter, placebo/controlled, double-blind trial | 1) Prophylactic indomethacin administration : 0.1 mg/kg Q24 hrs × 3 days (vs NS placebo) in VLBW infants, during first 6 hrs of life | Nor further specified | Primary outcomes at 18 months of age: | 1) Death before a corrected age of 18 months or documentation in survivors of one of the following: CP, Cognitive delay, Hearing loss requiring amplification, B/L blindness
| Years of Birth: 1996-1998 | 2 hrs old | Unable to administer study drug within 6 hrs of birth, n=469 | Sample 2: Placebo group [569] | [18 mo CA] | | | 1) Composite outcome: death or impairment | 2) Cerebral palsy diagnosed if had nonprogressive motor impairment with abnormal muscle tone and decreased range or control of movements.
| Mean GA: | Born in 1 of the 32 participating centers in Canada, USA or Australia. | Structural heart disease | | | | | 2) Death before 18 mo corrected age | 3) Cognitive delay: as MDI less than 70 (2SD below the mean of 100) on the Bayley scale between 85–114: classified as normal, Scores below 70: marked cognitive delay.
| Sample 1: 25.9 ±1.8 | Born during 1/1996–3/1998 | Renal disease or both, or strongly suspected (n=24) dysmorphic feature or congenital abnormalities likely to affect life expectancy or neurologic development or to be associated with structural heart disease or renal disease (n=49) | | | | | 3) Cerebral palsy | 4) Documentation of composite primary outcome: required documentation that the infant had died or had survived with one of the 4 types of impairment. A single missing component of the f/up assessment would result in designation of missing for primary outcome. A priori criteria for definitions of presence or absence of component of the primary outcome.
| Sample 2: 26 ±1.9 | | Maternal tocolytic therapy with indomethacin or another prostaglandin inhibitor within 72hr before delivery (n=245) | | | | | 4) Cognitive delay (MDI<70) | 5) In cases it was difficult to obtain Audiologic test results, deafness requiring amplification was assumed to be absent if no such indication was present during the Bayley test. (n=27)
| Mean BW: | | Overt clinical bleeding at more than one site (n=8) | | | | | 5) Hearing loss requiring amplification | 6) Blindness: a corrected visual Acuity of less than 20/200. F/up evaluation around 18 mo: allowed range 18–21 mo
| Sample 1: 782 ±131 | | Platelet count <50.000 (n=25) | | | | | 6) Bilateral blindness | (Home visits were permitted when necessary)
| Sample 2: 783 ± 130 | | Hydrops (n=9) | | | | | Secondary long term outcomes outcomes:
| Male: 51% | | Not considered viable (n=171) | | | | | 1) Hydrocephalus, necessitating the placement of shunt
| Race: | | Unlikely to be available for f/up (n=31) | | | | | 2) Seizure disorders
| Sample 1:White: 69%, black: 13%, Asian: 5%, other: 12% | | | | | | | 3) Microcephaly (HC<3 d %)
| Sample 2: White: 67%, black: 14%, Asian: 7%, other: 12%
| Enrolled: 2756
| Evaluated: 1202
| Number of sites: 32
Battin 1998 99002694 | Location: British Columbia, Canada | Prospective cohort: | Cases of therapeutic termination of pregnancies for lethal congenital anomalies | Prospective cohort of ELGA born during a period when antenatal steroids, surfactant and dexamethasone for BPD had become an accepted treatment [44] | Prospective observational cohort study and a comparative study with an historical control group (18 months) | General: | ND | CNS: | Neurologic exam
| Enrollment period: 1991-1993 | Birth at British Children's Hospital and British Womens' Hospital Born during 1991-1993 | Outborns | | | 1) GA (23–25 wks) | | Neurodevelopmental outcome | Bayley scale: MDI, PDI
| Mean GA: ND (range: 23–25 wks) | Extremely low gestational age (ELGA): 23–25 wks | | | | In comparative component with historical control group | | CP | Formal hearing test
| Mean BW: ND | Had follow up at 18 mo of age | | | | General: | | Low MDI (below 2 SDs) | Ophthalmologic examination
| (Mean BW for the 333 live births during the study period : for GA of 23 wks: 581, for GA of 24 wks:648, for GA of 25 wks: 764) | Historical control group: | | | | 1) Birth during a period with routine use of: antenatal steroids, surfactant and dexamethasone for BPD (vs birth in presurfactant, presteroid period) | | Ophthalmology- Audiology:
| Male: ND | Born at the same institution | | | | | | Blind, Deaf
| Race: ND | Born between 1983-1989
| Enrolled: 333 | GA: 23–25 wks
| (total live births GA: 23–28 wks)
| Evaluated : 44
| (out of 49 of GA 23–25 surviving to NICU discharge)
| Number of sites: 2
Vohr 2000 20295211 | Location: US | Live born BW 401–1000 g | ND | 1151 extremely low birth weight survivors cared for in the 12 participating centers of the National Institute of Child Health and Human Development Neonatal Research Network | Prospective cohort (18–22 months corrected age) | General: | GR 3 to 4 IVH. PVL undefined sepsis undefined | CNS: | “normal Neurologic exam”: no abnormalities on neurologic exams
| Years of Birth: 1/93–12/94 | | | | | 1) Birth weight | | Cerebral palsy
| Median GA (range), wk: | | | | | 2) Maternal disease (HTN) | | Neurodevelopmental:
| Mean BW (range), g: ND | | | | | 3) Antenatal steroids | | Motor delay (sitting, walking, picer grasp, feeding)
| Male: ND | | | | | CNS: | | Seizure disorder
| Race: ND | | | | | 1) Intracranial/Intraventricular hemorrhage ( GR 3 to $ IVH/PVL) | | Post hemorrhagic Hydrocephalus (PHH) and shunt
| Enrolled: ND | | | | | Cardiovascular or Pulmonary: | | Other: Neurologic exam (normal; abnormal)
| Evaluated: ND | | | | | 1) Chronic lung disease (oxygen requirement at 36 weeks) | | Development (MDI and PDI by Bayley II Scale)
| Number of sites: 12 | | | | | 2) Other: postnatal steroids | | Ophthalmology :
| | | | | | 3) Other: Surfactant | | Visual impairment (any)
| | | | | | Gastrointestinal: | | Blindness (unilateral, bilateral)
| | | | | | 1) Necrotizing “enterocolitis” | | Audiology:
| | | | | | Other: | | Hearing disorders
| | | | | | 1) Other: male sex
| | | | | | 2) Other: Race (white)
| | | | | | 3) Other: sepsis (early and late onset)
| | | | | | 4) Other: maternal education
Piecuch 1997 98012134 | Location: US | 24, 25 or 26 week GA | ND | Sample 1: GA 24 weeks (18) | Prospective cohort (at 12 months, 18 months, 2 ½ years, 4 ½ years. 7–8 years) | General predictors: | CLD - at 36 weeks PCA, requirement for supplemental O_2_ | CNS outcomes: | Visual - Near point tests or Snellen eye charts
| Years of Birth: 1990-1994 | Non-anomalous | (Died after discharge (2) Accidental severe central nervous system insult after discharge (1) | Sample 2: GA 25 weeks (30) | | 1) GA | IVH grade 3 or 4 & PVL, according to sonogram | Cerebral palsy | Audiologic - behavioral testing followed by BAER or pure tone audiometry.
| Mean GA (range), wk: | Born at University of California, San Francisco | Lost to follow-up (5)} | Sample 3: GA 26 weeks (38) | | CNS predictors: | Social risk economic - maternal education <12 grade; complete unemployment in household; or government assistance for health insurance | Cognitive delay | Cognitive outcome - Bayley scales at 12 and 18 months; Stanford-Binet at 2.5–4 years; McCarthy scales at 4–6 years.
| Sample 1: 24 | | | | | 1) intracranial/ intraventricular hemorrhage | Social risk substance abuse - positive toxicology screens or confirmed history of drug or alcohol abuse | Ophthalmology outcomes: | Abnormal neurological outcome - CP, quadriplegia, dysplegia, hemiplegia
| Sample 2: 25 | | | | | 2) periventricular leukomalacia | | Visual impairment | Suspicious neurological outcome - clumsiness, tremors
| Sample 3: 26 | | | | | Cardiovascular or pulmonary predictors: | | Audiology outcomes: | Severe neurosensory abnormalities - Bilateral hearing loss, blindness
| Mean BW (range), g: | | | | | 1) chronic lung disease | | Hearing disorders | Mild neurosensory abnormalities - high frequency hearing loss without hearing aids, visual deficit without glasses
| Sample 1: 668±91 (450–850) | | | | | Other predictors:
| Sample 2: 790±115 (550–1000) | | | | | 1) social risk: economic
| Sample 3: 842±158 (505–1260) | | | | | 2) social risk: substance abuse
| Male:
| Sample 1: 50%
| Sample 2: 73%
| Sample 3: 50%
| Race: ND
| SES: high social risk
| Sample 1: 89%
| Sample 2: 43%
| Sample 3: 68%
| Enrolled: 94
| Evaluated: 86
| Number of sites: 1
Victorian Infant Collaborative study Group, 1997 97466059 | Location: Australia | ELBW infants, BW 500–999 g born outside the level III perinatal centers in Victoria, Australia survived to age of 2 years | Excluded infants born in 1979-1980 for current review | ELBW infants (36): | Retrospective cohort (2 years) | Other: time period of birth | ND | CNS: | CP neurologic exam
Arch Dis Child | Years of Birth: 1979-80, 1985-87, 1991-92 | | | Sample 1: born in 1985-1987 (19) | | | | Cerebral Palsy | Bayley MDI, PDI scores
| Mean GA (range), wk: ND | | | Sample 2: born in 1991-1992 (16) | | | | Cognitive delay | Blindness-not stated
| Mean BW (range), g: ND | | | | | | | Post Hemorrhagic Hydrocephalus (PHH) | Deafness-not stated
| Male: ND | | | | | | | Ophthalmology: Blindness | Degrees of sensorineural delay are defined as an aggregate measure and are approximated.
| Race: ND | | | | | | | Audiology: Deafness
| Enrolled: 36 | | | | | | | Other:
| Evaluated: 35 | | | | | | | Sensorineural disability: severe, mental, moderate, none.
| Number of sites: 3
Victorian Infant Collaborative study Group, 1997 98026322 | | | | | | General: BW | Each sample were subdivided into BW=500–749 g and BW=750–999 g 1985-1987 vs. 1991-1992 | CNS: | CP was not defined
| | | | | | Other: period of time when born | | Cerebral palsy | Bayley Scales of Infant Development
| | | | | | | | Neurodevelopmental: | DQ, using the published mean and SD
| | | | | | | | Cognitive and motor delay | Disability: “Sever” - bilateral blindness, cerebral palsy with the child unlikely ever to walk, or a DQ score <-3SD; “Moderate” - bilateral sensorineural deafness requiring hearing aids, cerebral palsy in children not walking at 2 but expected to walk, or a DQ score from -3SD to <-2 SD; “Mild” - cerebral palsy but walking at 2 , or a DQ score form -2 SD to <-1 SD.
| | | | | | | | Disability
| | | | | | | | Ophthalmology: Blindness
| | | | | | | | Audiology: Deafness or hearing aid
Ambalavanan 2000 21031370 | Location: US | ELBW infants, BW <1000 g | ND | ELBW infants (218) | Retrospective cohort (followed to 18 months of age) | General: BW, GA, Antenatal steroids, Apgar score | Extensive list of the 21 predictor variables | CNS: | Barley scales
| Years of Birth: 1/1990 to 12/1994 | | | | | Other: Race, Gender Multiple gestation, Maternal education, Maternal age | | Motor delay | Major handicap-presence of one or any poor outcome (i.e. CP, deadness, blindness). Mental retardation (MDI or PDI <70), PHH requiring sheet
| Mean GA (range), wk: 26±2 | | | | | CNS: | | Cerebral palsy
| Mean BW (range), g: 829±123 | | | | | Intracranial hemorrhage | | Cognitive delay
| Male: 45% | | | | | Periventricular/Ventricular | | Mental retardation
| Race: African-American 66% | | | | | Dilafion | | PHH
| Enrolled: 218 | | | | | Bronchopulmonary dysplasia | | Neurologic exam
| Evaluated: 218 | | | | | GI: Necrotizing “entrocolitis” | | Major handicap
| Number of sites: 1 | | | | | Interinal perforation, | | Ophthalmology:
| | | | | | Chorioamnionitis | | Visual impairment
| | | | | | Multiple gestation | | Blindness
| | | | | | Maternal education | | Audiology:
| | | | | | Maternal age | | Hearing disorders
| | | | | | | | Deafness
Cheung 1999 99146391 | Location: Canada | BW<1250 gm | Major congenital abnormalities, syndromes | Sample 1: | Prospective cohort (followed to 24 months adjusted age) | General predictors: | ND | CNS outcomes: | Bayley scores
| Years of Birth: 1990-1993 | GA < 32 weeks | Infants with neurologic insult after discharge from NICU. | BW 500–749 g (26) | | 1) BW | | Motor delay | Stanford-Binet Intelligence Scale
| Mean GA (range), wk: | Mild or no significant respiratory disease (O_2_ < 30%, RR < 70) | | Sample 2: | | 2) GA | | Cerebral palsy | Peabody Developmental Motor Scale
| Sample 1: 25 (22–29) | | | BW 750–999 g (63) | | 3) Apgar score | | Cognitive delay | Neurodevelopmental disability: "children with 1 or more of a) cerebral palsy b) legal blindness c) hearing loss d) convulsive disorder e) cognitive delay
| Sample 2: 26 (24–30) | | | Sample 3: | | CNS predictors: | | Mental retardation
| Sample 3: 28 (23–32) | | | BW 1000–1249 g (75) | | 1) intracranial/ intraventricular hemorrhage | | Seizure disorder
| Mean BW (range), g: | | | | | Cardiovascular or pulmonary predictors: | | Neurodevelopmental disability
| Sample 1: 660±56 | | | | | 1) days of ventilation | | Ophthalmology outcomes:
| Sample 2: 873±73 | | | | | 2) days of O_2_ use | | Blindness
| Sample 3: 1127±71 | | | | | Other predictors: | | Audiology outcomes:
| Male: total 57% | | | | | 1) frequency of apnea | | Hearing disorders
| Race: ND | | | | | 2) mean desaturation of apnea | | Growth outcomes:
| Enrolled: 187 | | | | | 3) mean frequency of apnea | | Weight > 2 SD below the mean
| Evaluated: 164 | | | | | 4) Blisten index (socioeconomic status) | | Height > 2 SD below the mean
| Number of sites: 2 | | | | | | | HC > 2 SD below the mean
Doyle 2001 21326609 | Location: Australia | Cases: GA 23–27 weeks, survived to 2 and 5 years of age | ND | Sample 1: | Prospective cohort (Doyle - 5 years; Victorian - 2 years) | General predictors: | 1) SGA/IUGR - BW ratio <0.8 | CNS: | 1) motor delay, cognitive delay - WPPSI-R and alternative IQ tests
Victorian Infant Collaborative study Group, 1997 97290716 | Years of Birth: 1991-92 | Controls: randomly selected Contemporaneous normal birth weight controls (BW > 2499 g) | | Pretem survivors (N= 401) | | 1) GA | 2) intracranial/ intraventricular hemorrhage - Papille system | Motor delay | 2) cerebral palsy - not walking or walking with difficulty
*some subjects were overlapped with 20307288 (stated in text) | Mean GA (range), wk: 23–27 | | | Controls: Randomly selected contemporaneous normal birth weight controls (BW>2499 grams) (N=265) | | 2) SGA/IUGR | 3) periventricular leukomalacia - cystic lesions in PVWM dx < discharge | Cerebral palsy | 3) mental retardation - IQ < 2 SD below mean for NBW group
*possibly overlapped with 98026322 | Mean BW (range), g: ND | | | | | 3) antenatal steroids | 4) bronchopulmonary dysplasia - ROS + O_2_ Rx after 28 days age | Cognitive delay
| Male: ND | | | | | 4) gender (female) | 5) dexamethasone - postnatal steroid use | Mental retardation
| Race: ND | | | | | 5) postnatal age | | Ophthalmology outcomes:
| Enrolled: 225 | | | | | CNS predictors: | | Blindness
| Evaluated: 225 (265 controls) | | | | | 1) intracranial/ intraventricular hemorrhage | | Audiology outcomes:
| Number of sites: 1 | | | | | 2) periventricular leukomalacia | | Hearing disorders
| | | | | | Cardiovascular or pulmonary predictors: | | Deafness
| | | | | | 1) bronchopulmonary dysplasia | | Other:
| | | | | | Other predictors: | | Survival without major disability at 5 years age
| | | | | | 1) dexamethasone | | Survival with major neurosensory disability at 5 years age
| | | | | | 2) perinatal factors
| | | | | | a) multiple birth
| | | | | | b) cesarian section
| | | | | | 3) socioeconomic variables
| | | | | | i) Asian mother
| | | | | | ii) higher SEC
| | | | | | iii) no English-speaking at home
| | | | | | 4) surgery in primary hospital
| | | | | | 5) patient with no adverse events
Corbet 1995 95264244 | Location; USA | Born alive | ND | Sample 1: | Combination of 3 multicenter, randomized, double blind studies of synthetic surfactant vs air placebo | General: | Not further specified | Growth: | Assessment at 1 yr of corrected age
| Years of Birth: 1986-1989 | Qualifying BW (Not specified in this publications) | | Synthetic surfactant:[314] | [1 yr] | 1) Synthetic surfactant (single dose via ET tube of 5 mg/kg vs air placebo) | | Growth status at 1 yr: | Not further specified
| Mean GA: | That were intubated and assigned randomly to receive either synthetic surfactant or air placebo as part of their participation in 3 multicenter RCTS. | | Sample 2: | | | | 1) Weight
| Sample 1: 27 ± 2 | Had follow up at 1 yr of age | | Air placebo [283] | | | | 2) Height,
| Sample 2: 27 ± 2 | | | | | | | 3) HC and percentiles distribution
| Mean BW: | | | | | | | Other: Health status at 1 yr:
| Sample 1: 934 ± 179 | | | | | | | 1) Surgeries
| Sample 2: 931 ± 191 | | | | | | | 2) Readmissions to hospital
| Males: | | | | | | | 3) CLD,Medications for CLD
| Sample 1: 50% | | | | | | | 4) Respiratory support on exam day
| Sample 2: 50% | | | | | | | 5) Medications for chronic neurologic disease
| Race: | | | | | | | 6) Asthma, Eczema
| Sample 1: whites: 41%, blacks: 37%, others: 22% | | | | | | | CNS: Neurodevelopmental outcome
| Sample 2: whites: 46%, blacks: 36%, others: 18% | | | | | | | 1) MDI
| Enrolled: 1046 | | | | | | | 2) PDI
| Evaluated: 597 | | | | | | | 3) Impairments: Present absent
| Number of sites: Multicenter | | | | | | | 4) Severity of impairment
| | | | | | | | 5) Type of impairment (MDI<69, MDI 69–84)
| | | | | | | | 6) CP
| | | | | | | | Audiology
| | | | | | | | 1) B/L sensorineural deafness
| | | | | | | | 2) Deafness not requiring amplification
| | | | | | | | Ophthalmology: (worst exam and last)
| | | | | | | | 1) B/L blindness
| | | | | | | | 2) Visual defect
| | | | | | | | 3) No ROP, mild/moderate ROP, severe ROP)
| | | | | | | | 4) Treatment for ROP (surgery, cryotherapy)
Gerdes 1995 95264241 | Location: US | Mothers who were expected to deliver premature infants with BW 700–1100 g | All exclusion prenatal. | Experiment 1: One doses surfactant (244) | Randomized comparison trial (1 year) | Cardiovascular or Pulmonary: Surfactant use | ND | CNS: | Mental retardation Bayley Scales MDI<69
| Years of Birth: 3/1989–4/1990 | | 1) Proven fetal lung maturity | Experiment 2: Three doses surfactant (264) | | | | Cerebral palsy
| Mean GA (range), wk: | | 2) Known malformation or chromosome anomaly | | | | | Cognitive delay
| Experiment 1: 27.2±1.7 | | 3) Fetal growth retardation | | | | | Mental retardation
| Experiment 2: 27.2±1.8 | | 4) Hydrops | | | | | Ophthalmology: Visual impairment, Blindness
| Mean BW (range), g: | | 5) Purulent amnionitis | | | | | Audiology: Hearing Disorder, Deafness
| Experiment 1: 907±121 | | 6) Maternal heroin addiction | | | | | Pulmonary:
| Experiment 2: : 911±125 | | 7) Obstetric decision not to support fetus | | | | | 1) Asthma
| Male: | | Postnatal exclusions: | | | | | 2) e/o CLD
| Experiment 1: 55% | | 1) Major malformation | | | | | 3) respiratory support @ 1yr
| Experiment 2: 56% | | 2)≥3 minor anomalies | | | | | Growth: Height, Weight, HC
| Race: | | 3) Hydrops | | | | | Other: hospital re-admissions, h/o surgery
| Experiment 1: White 55%, Black 37%, Hispanic 4%, Other 5%
| Experiment 2: White 60%, Black 30%, Hispanic 5%, Other 5%
| Enrolled: 826
| Evaluated: 508
| Number of sites: 33
Marlow 2000 20150342 | Location: UK | For sensorineural hearing loss (SNHL) group | ND | Sample 1: | Retrospective case control study with a longitudinal component (unclear if retrospective or prospective) | General: 1) Birth weight | Not further specified | In case control component: | Cases of SNHL were identified if the hearing loss had been identified within 3 months of discharge home, (within 9 mo from birth); after excluding cases with conductive hearing loss, possible congenital cause, or had neonatal bacterial meningitis
| Years of Birth: 1990-1994 | GA: <33 wks | | SNHL group [15] | (12 mo CA) | 2) Apgar score 3) CRIB scores | | Audiology:
| Mean GA: ND | Family resident of Greater Bristol area | | Sample 2: | | CNS: | | 1) Sensorineural hearing loss (SNHL) of 50 dB within 9 months from birth
| (Median and Range) | Records at Hearing Assessment Center of Royal Hospital for Sick children. | | Control group [30] | | 1) Maximum bilirubin level | | In Longitudinal component:
| Sample 1: 28 (26–31) | Born during 1990-1994 | | Matched with cases for sex, GA, admission dates in NICU | | 2) Abnormal cerebral US scan | | CNS:
| Sample 2: 28 (26–31) | Diagnosis of SNHL of 50 dB | | | | Audiology: | | 1) Cerebral palsy at 12 months of age in the 2 groups (SNHL and control group)
| Mean BW: ND | For control group: | | | | 1) Sensorineural hearing loss
| (Median and range) | Matched controls 2:1 to cases | | | | Cardiovascular/Pulomonary:
| Sample 1: 960 (600–2914) | Admitted to the same NICUs as cases | | | | 1) Duration of intubation, respiratory support, oxygen, pH<7.2, base excess
| Sample 2: 1026 (410–2814) | Matched for sex and GA and next and preceding matching children in the admission books of St Michael's and Sothmead hospitals | | | | 2) Dopamine 3) Furosemide
| Male: ND | | | | | 4) Indomethacin use
| Race: ND | | | | | Other:
| Enrolled : 27 | | | | | 5) Netilmicin 6) Vancomycin
| Evaluated: 15 | | | | | 7) Positive blood cultures
| Number of sites: 1 | | | | | 8) Bilirubin >200 mmol/l
| | | | | | 9) Bilirubin>GA × 10
| | | | | | 10)Creatinine >60 mmol/l
| | | | | | 11)Netilmicin 12) Vancomycin
| | | | | | Combination of the above:
| | | | | | 1) Bili.200 + acidosis
| | | | | | 2) Bili> 200 + sepsis
| | | | | | 3) Bili >200+ netilmicin
| | | | | | 4) Bili> 200+ vancomycin
| | | | | | 5) Bili>200+ furosemide
| | | | | | 6) Peak bil+ acidosis
| | | | | | 7) Peak bili+ sepsis
| | | | | | 8) Peak bili+ netilmicin
| | | | | | 9) Peak bili+ furosemide
| | | | | | 10)Creatinine>60+ netilmicin or vancomycin or furosemide
| | | | | | 11)Netilmicin+furosemide
| | | | | | 12)Vancomycin+ furosemide
Lee 1998 98442293 | Location: Canada | For cases: | Neonates with major congenital anomalies | Sample 1: | Retrospective longitudinal comparative study with case control design and cases defined based on exposure to candidemia and matched controls (f/up between 37 and 70 mo CA) | General: | Diagnosis of Candidemia: by at least one positive Blood Culture | CNS: | 1) Bayley Scales of Infant development; MDI, PDI for ages < 24 mo.
| Years of Birth: 1990-1995 | Prematures with BW<1250 g | | Premature infants <1250 with candidemia and/ or candida meningitis (25) | Average age at assessment: for cases:31 ±19 mo, and for controls: 28 ±20 mo | 1) Candidemia and/or Candidal meningitis | Diagnosis of Candidal meningitis: | 1) Neurodevelopmental disabilities (NDDs) | 2) Stanford-Binet Intelligence Scale and Peabody Development Motor Scales for ages > 24 mo.
| Mean GA: ND | Admitted in the NICU s of UAH and RAH from 1990-1995 | | Sample 2: | | | by isolation of Candida in the CSF or >45×10^6^ WBCs in the CSF and candidemia. | 2) Cognitive delay | 3) Scores obtained by psychologists, psychometricians, pediatricians specialized.
| Mean BW: | Diagnosis of candidemia: by at least one positive blood culture | | Premature neonates with BW <1250 matched with cases for BW, GA, sex and admission dates, without candidal infection (25) | | | | 3) Cerebral palsy | Neurodevelopmental Disabilities:
| Sample 1: 763 ±157 | Diagnosis of candidal meningitis: | | | | | | Ophthalmology: | 1) Cerebral palsy (all types and severity)
| Sample 2: 807±176 | By isolation of candida in the CSF or >45×10^6^ WBCs in the CSF and candidemia. | | | | | | 1) Legal blindness | 2) Legal blindness (corrected VA of the better eye<20/200)
| Male: ND | For controls: | | | | | | Audiology: | 3) Hearing loss (neurosensory hearing loss in the better ear > 30 dB) (done by certified audiologist
| Race: ND | Prematures with BW <1250 g | | | | | | 1) Hearing loss | 4) And/or cognitive delay (MDI>3 SDs below the mean)
| Enrolled: ND (total N not given, data only for enrolled cases with candidemia: N= 29) | Admitted to the same NICUs during the same period without candidal infection | | | | | | Growth: | Growth retardation: Weight, Height, HC > 2 SDs below the mean
| Evaluated: 50 | | | | | | | 1) Growth retardation | (Between 3–6 yrs CA)
| Assessed for outcome: 35 (14 cases and 21 controls)
| Number of sites: 2
DeReginer 1997 98041177 | Location: US | BW =1500 g survived until Discharged | Presence of independent of chronic lung disease known to adversely affect neurodevelopment, sensory, or growth, i.e. severe intracranial abnormalities, congenital anomalies or viral infections, etc. | Sample 1: | Retrospective chart review with marched subject group | Cardiovascular/ Pulmonary: Chronic lung disease | Classification based on the duration of supplemental oxygen requirements. | General: | Bayley PDI & MDI
| Years of Birth: 1987-1991 | Able to match to a patient in other two respiratory groups | Unable to match to a patient in other groups | No chronic lung disease (58) | (1 year of adjusted age) | | “No CLD” - breathing room air at 28 days | Motor and cognitive delay
| Mean GA (range), wk: | | Died after discharged (6) | Sample 2: | | | “Mild CLD” - requiring supplemental oxygen at 28 days but not at 36 weeks PMA | Cerebral palsy
| Sample 1: 28.0±1.5 | | Lost to follow-up (4) | Mild chronic lung disease (58) | | | Sever CLD” - reqiring oxygen at 28 days and 36 weeks PMA | Opthalmology:
| Sample 2: 27.1±1.2 | | | Sample 3: | | | | Visual impairment
| Sample 3: 27.5±1.7 | | | Severe chronic lung disease (58) | | | | Blindness
| Mean BW (range), g: | | | | | | | Audiology:
| Sample 1: 1030±140 | | | | | | | Hearing loss
| Sample 2: 1007±122 | | | | | | | Deafness
| Sample 3: 1007±140 | | | | | | | Growth:
| Male: ND | | | | | | | Weight Z score
| Race: ND | | | | | | | Length Z score
| Enrolled: 174 | | | | | | | Head circumference Z score
| Evaluated: 164 | | | | | | | Other: any adverse outcome
| Number of sites: 2
Kurkinen-Raty 1998 98387235 | Location: Finland | Preterm PROM between 17–30 weeks gestation; singleton; delivered > 2 hr after rupture | Rupture unconfirmed or transient | Sample 2: Preterm rupture (78) | Retrospective cohort | General : PROM | Diagnose was through clinical assessment or with the use of a PROM-test, which detects insulin growth factor binding protein-1 in the cervico-vaginal secretions, or with the use of a nitrazine test. | CNS: | Neurologic exams
(All+Lung) | Years of Birth: 1990-1996 | Controls: preterm no PROM; spontaneous preterm delivery matched for GA and year of delivery. | | Sample 2: Preterm delivery no rupture (78) | | | | Motor delay | Diagnosis of CLD was made if infants required oxygen, continuous bronchodilator, or steroid tx because of respiratory signs and symptoms.
*sample from the same big population as 20284814 | Mean GA (range), wk: | | | | | | | Cerebral delay | Diagnoses of RDS were made based on need for respiratory support, radiologic findings, and clinical assessments
| Cases: 28.2 (23.8– 37.2) | | | | | | | Ophthalmology: Visual Blindness
| Controls: 28.4 (22.9–36.9) | | | | | | | Audiology: Hearing disorders
| Mean BW (range), g: | | | | | | | Pulmonary: Chronic lung disease
| Cases: 1138.3±434 | | | | | | | Growth: weight percent
| Controls: 1272.4±547.2 | | | | | | | Other:
| Male: ND | | | | | | | Days of re-hospitalization
| Race: ND | | | | | | | Steroid therapy at followed up
| Enrolled: 78 (78 controls)
| Evaluated: 78 (78)
| Number of sites: 1
Kurkinen-Raty, 2000 20284814 | Location: Finland | Casarean delivered singleton, GA 24–33 weeks | ND | Sample 1: Indicated preterm (i.e., preterm birth ‘indicated’ for maternal/fetal reasons (103) | Retrospective cohort | General predictors: | BPD diagnoses were based on radiologic finding | CNS: | Motor delay = abnormalities of tone or reflexes but functionally normal or borderline
*sample from the same big population as 98197235 | Years of Birth: 1990-1997 | Controls: spontaneous delivered singleton after regular contractions and/or preterm rupture of the membranes no more than 24 hrs before. The mothers were matched one-to-one by gestational age at delivery plus or minus 1 week. | | Sample 2: Spontaneous preterm delivery due to preterm labor (103) | | Birth weight | | Motor delay | CP = spastic diplegia or hemiplegia or spastictetraplegia
| Mean GA (range), wk: | | | | | GA | | Cerebral palsy | Diagnosis of CLD was made if infants required oxygen, continuous bronchodilator, or steroid tx because of respiratory signs and symptoms.
| Cases: 30.5±2.1 | | | | | Antenatal steroids | | Ophthalmology
| Controls: 30.4±2.1 | | | | | Cord pH | | Visual impairment
| Mean BW (range), g: | | | | | Bronchopulmonary dysphasia (BPD) | | Audiology
| Cases: 1294±469 | | | | | Other predictors: | | Hearing disorder
| Controls: 1605±427 | | | | | Indicated preterm delivery | | Pulmonary
| Male: ND | | | | | Spontaneous perterm delivery | | Chronic lung disease (CLD) at 1 year
| Race: ND | | | | | | | Growth:
| Enrolled: 103 (103 controls) | | | | | | | Wt, Ht, HC
| Evaluated: 103 (103)
| Number of sites: 1

Evidence Table 5B. Studies Evaluating Association of LBW to Audiology Outcomes Part III

Author, Year | Associations found | | | | | | | | Potential Biases
Northern Neonatal Nursing Initiative Trial Group 1996 96304894 | No significant differences by Griffith's Developmental quotients, incidence of CP, seizures, hearing disorders. Initial demographics available in an earlier study. | | | | | | | | Study was government and private funded
Hack 1996 97066007 Pediatrics | | MR (MDI<84) | CP | Blind | Deaf | Major Neurosensory abnormal +MDI<80 | | | No data on funding source
| 1982-1988 | 52% | 10% | 10% | - | 49%
| 1990-1992 | 34% | 10% | 2% | 6% | 35%
| 20-month Neurodevelopmental outcomes did not change appreciably between the 2 eras.
| 20% of infants had subnormal cognitive function (MDI<70) and 10% had CP during 1990-1992 period. One third of infants with BW 500–750 gram had major neurosensory abnormalities and / or MDI<80.
Hack 2000 20358826 | MDI Score < 70: | | | | | | | | The authors concluded that there is an urgent need for research into the etiology and prevention of neonatal morbidity.
| CLD:55% (49/89); 2.18(1.20–3.94)
| MDI Score<70 (multi stepwise logistic regression)
| Male sex: | 2.73 (1.52–4.92)
| Social risk: | 1.48 (1.09–2.00)
| CLD: | 2.18 (1.20–3.94)
| OR adjusted for sex, social risk & BW:
| Gr III–IV IVH:
| 50% (16/32); | 8.55 (3.52–20.76)
| 50% (8/16); | 4.45 (1.54–12.84)
| 50% (17/34); | 5.48 (2.41–12.47)
| CLD: 30% (27/89); | 3.09 (1.51–6.35)
| Sepsis: 14% (13/93); | 3.47 (1.16–10.36)
| Jaundice: 26% (6/23); | 5.15 (1.63–16.22)
| Mult. Stepwise Logistic regression:
| Male sex: | 2.79 (1.02–7.62)
| Sepsis: | 3.15 (1.05–9.48)
| Jaundice: | 4.80 (1.46–15.73)
| Predictors of neurologic abnormality were a severely abnormal finding on cerebral ultrasound (OR, 8,09; 95% CI 3.69–17.71) and chronic lung disease (OR 2.46; 95% CI 1.12–5.40); predictors of deafness were male sex (OR 2.79 95% CI 1.02–7.62), sepsis (OR 3.15 95 % CI 1.05–9.48), and jaundice (maximal bilirubin level >171)
Wood 2000 20373840 | Infants 22–25 weeks GA developmentally assessed at median 30 months | | | | | | | | Severe disability common; children born extremely premature
| • 138/283 had disability 49%(64 met criteria for severe disability)
| • 49% no disability
| • 53/283 severely delayed 19%(Bayley below 3 SD)
| • 32/283 2–3 below SD 11%
| • 28 severe neuromotor disability 10%
| • 7 blind or perceived light only 2%
| • 8 hearing loss that was uncorrectable or required hearing aids 3%
| Survived without overall disability
| 22 wks--------------0.7%
| 23 wks--------------5%
| 24 wks--------------12%
| 25 wks--------------23%
| Severe disability at 30 months
| 22-------------------0.7%
| 23--------------------3%
| 24---------------------6%
| 25---------------------9%
| • no relation between morbidity pattern and either gestational age &multiple birth
| • boys were likely to be disabled than girls
Singer 1997 98049057 | Evaluation at 36 months corrected age. VLBW, VLBW with BPD, full term (FT). | | | | | | | | Single region, but at least it is a region
Singer 2001 21163669 | | Bayley MDI | | % with MDI below 70 | | | | | Unclear if examiners were blinded to groups status
| VLBW | 90±16 (38–126) | | 11% | | | | | Study was government funded
| VLBW w/BPD | 84±24 (10–116) | | 21%
| FT | 96 ± 12 (57–127) | | 4%
| P = 0.001 for VLBW vs. VLBW w/ BPD
| | Bayley PDI | | % with PDI below 70
| VLBW | 98 ± 20 (33–122) | | 9%
| VLBW w/BPD | 84 ±29 (8–127) | | 9%
| FT | 103 ± 15 (58‐128) | | 1%
| P = 0.001 for VLBW vs. VLBW w/ BPD
| At 3 years BPD predicted poorer motor outcome but not poorer mental outcome.
| Receptive DQ: BPD < VLBW < Term, p < 05
| Receptive DQ < 85: BPD 49%, VLBW 34%, Term 30%,
| BPD < VLBW + Term p < .05
| Expressive DQ: BPD < VLBW +Term, p < .05
| Expressive DQ<85: BPD 44%, VLBW 25%, Term 25%
| BPD < VLBW +Term p < .05
| Communication DQ: BPD < VLBW + Term, p < .05
| Communication DQ < 85: BPD 43%, VLBW 31%, Term 28%, NS
| Rank order listing of risk factors in order of magnitude of effect and the number of communication DQ lowered by the risk factor: PDA lowered DQ by 13 points, Minority race by 6 points, lower socioeconomic status by 5 points, and higher neurologic risk by 5 points. p .001
| Bayley Scales MDI:
| BPD 83.7 ± 24, VLBW 90 ±16, Term 96.4 ± 12, BPD < VLBW < Term, p< 0.05
| Bayley Scales PDI:
| BPD 84.1 28, VLBW 97.4 19, Term 102.8 14
| BPD < VLBW + Term, p< .05
| ROP: BPD 43%, VLBW 4%, p= .001
| Seizures: BPD 7%,
| Neurologic score: BPD 1.3 ± 2, VLBW 58 ± 1, p < .001
Schmidt 2001 21298249 | 1) There was no difference in primary outcomes between the 2 groups at 18 months of age. | | | | | | | | 1) By using the Bayley test at 18 mo the authors found that more than one quarter of all surviving infants had moderate to severe cognitive delays, defined by MDIs< 70. The validity of the MDI score at this age as a predictor of later intellectual functioning remains to be determined.
| 2) Among the 574 infants who were assigned to prophylaxis with indomethacin, 271 (47%) died or survived with impairment as compared with 261 of 569 infants (46%) assigned to placebo (OR: 1.1; 95% Confidence intervals; 0.8–1.4) | | | | | | | | 2) At a post hoc calculation the study had a 90% power to detect a 20% reduction in risk, had it existed
| 3) In VLBW infants, prophylaxis with indomethacine does not improve the rate of survival without neurosensory impairments at 18 months of age | | | | | | | | 3) Authors report that the outcome assessments were done blindly by investigators unaware of treatment groups assignments
| 4) There was no difference in any of the secondary outcomes between the 2 groups, at 18 months of age. | | | | | | | | 4) Authors report that they had almost complete ascertainment for the primary outcome at 2 yrs of age.
| Primary: Composite / CNS Outcomes: | | | | Indomethacin vs. Placebo
| • Death or impairment | | | | 271/574(47%) vs. 261/569 (46%)
| • Death before 18 mo | | | | 121/595 (21%) vs 111/594 (19%)
| • Cerebral palsy | | | | 58/467 (12%) vs 55/477 (12%)
| • Cognitive delay (MDI<70 by Bayley scale | | | | 118/444 (27%) vs 117/457 (26%)
| Audiology outcome:
| • Hearing loss requiring amplification | | | | 10/456 (2%) vs 10/466 (2%)
| Ophthalmology outcome:
| • Bilateral blindness | | | | 9/456 (2%) vs 7/472 (1%)
| (Odds ratios adjusted for BW stratum and Center)
| Secondary CNS outcomeswere not affected by indomethacin administration:
| • Hydrocephalus requiring shunt | | | | 15/470 (3%) vs 9/480 (2%)
| • Seizure disorder | | | | 8/470 (2%) vs 7/483 (1%)
| • Microcephaly | | | | 49/461 (11%) vs 54/475 (11%)
| Kaplan Meier estimates of survival in the 2 groups:
| • 0 months | | | | n= vs 601
| • 6 months | | | | n= (80%) vs 490 (82%)
| • 12 months | | | | n= (79%) vs 487 (81%)
| • 18 months | | | | n= (78%) vs 483 (80%)
Battin 1998 99002694 | CNS outcomes: | | | | | | | | 1) During 1991-93 period there is no concurrent control group for the comparative assessment of neurodevelopmental outcome
| Major impairment was present in 36% of infants born at 23–25 wks GA, during 1991-1993 (N=44) | | | | | | | | 2) Group of infants of 23–25 wks GA, born during 1991-1993, was not matched to the historical control group born during 1983-1989. Possibility of confounders cannot be excluded.
| 1) Cerebral palsy | | | | 9/44 (20%) | | | | 3) No data were given on the number of infants in the historical control group that had f/up at 18 mo of age.
| 2) Low MDI | | | | 8/44 (18%) | | | | No data on source of funding
| Ophthalmology outcome:
| 1) Blind | | | | 4/44 (9%)
| Audiology outcome:
| 1) Deaf | | | | 4/44 (9%)
| Combined outcome:
| 1) Overall impaired | | | | 16/44 (36%)
| 2) Multiple handicaps | | | | 6/16 (38%)
| Analysis of only 24–25 wks GA infants (N=43):
| Major handicaps: 15/44 (34%)
| The percentage of infants with major impairments and/ or multiple handicaps, for the 23–25 wks GA group, was the same in 1991-1993 and 1983-1989 periods
| (However, no data on the number of infants from this cohort that were actually followed up at 18 mo of age)
Vohr 2000 20295211 | Studied effect of early IVH at 5 to 11 hours of age on IQ distribution and presence of cerebral palsy (CP). | | | | | | | | IVH rates seems high
| Assessed at 36 months CA. | | | | | | | | No data on funding source
| | Early IVH present | Early IVH absent | P value
| N | 29 | 249
| Binet IQ | 78.7 (25) | 87.5 (20) | 0.09
| Binet IQ < 70 | 38% | 19% | 0.03
| PPVT-R | 76.6 (28) | 86.0 (21) | 0.15
| CP at 36 months | 25% | 8% | 0.01
| Later IVH had effect on Binet IQ similar to early IVH.
Piecuch 1997 98012134 | Mean age at follow-up was 32 months. Bayley exams were done at 18 months. | | | | | | | | All inborn infants
| Neurologic abnormalities and CP did not differ significantly across the gestational ages of 24 to 26 weeks. | | | | | | | | No data on funding source
| Between 67% and 89% were normal in each gestational age group.
| Significant differences (P = 0.036) related to gestational age were found in 18 month Bayley exam scores when group as normal borderline or deficient
| | Normal | | Deficient
| 24 wk | 28% | | 39%
| 25 wk | 47% | | 30%
| 26 wk | 71% | | 11%
| Significant differences (P = 0.008) related to gestational age were found in the combined end point of CP or an abnormal Bayley exam score:
| | Neither | | One | | Both
| 24 wk | 28% | | 39% | | 33%
| 25 wk | 47% | | 23% | | 30%
| 26 wk | 63% | | 34% | | 3%
Victorian Infant Collaborative study Group, 1997 97466059 | All children born outside the level III perinatal centers. Assessment at 2 years corrected age. | | | | | | | | Incomplete reporting of demographic data, methods and results.
| | | | 1985-1987 | | 1991-1992 | | | Study was government fundes
| n | | | 19 | | 16
| Cerebral Palsy | | | 19.1% | | 12.5%
| Cognitive delay | | | 19.1% | | 18.8%
| Blind | | | 5.6% | | 6.2%
| Deaf | | | 0 | | 0
| Sensorineural disability
| | Mild | | 15.8% | | 6.2%
| | Moderate | | 0 | | 0
| | Severe | | 5.3% | | 12.5%
Victorian Infant Collaborative study Group, 1997 98026322 | Birth weight < 1000g; assessed at 2 years corrected age. | | | | | | | | Incomplete reporting of demographic data, methods and results.
| Cohort | n | DQ < -3 SD | DQ <-3 to -2 SD | | DQ -2 to -1 SD | | DQ> -1 SD | Study was government funded
| '91-'92 | 237 | 5.9% | 6.3% | | 13.9% | | 73.4%
| '85-'87 | 211 | 6.2% | 4.3% | | 14.2% | | 75.4%
| Cohort | n | Mild CP | Mod. CP | Severe CP | Any CP | Blindness | Deaf
| '91-'92 | 237 | 3.8% | 1.7% | 3.8% | 9.3% | 2.1% | 0.8%
| '85-'87 | 211 | NS | NS | NS | 6.6% | 4.3% | 0.5%
| Cohort | No disability | Mild Disability | Moderate disability | | Severe disability
| '91-'92 | 71.3% | 14.8% | 7.2% | | 6.8%
| n = 237
| '85-'87 | 71.6% | 15.6% | 6.2% | | 6.6%
| n = 211
Ambalavanan 2000 21031370 | ELBW: | | | | | | | | Retrospective, relatively small sample size (218).
| MDI<68 : 12% | | | | | | | | No data on funding source
| PDI<68: 20%
| Major handicap: 28%
| CP:28%
| MR 16%
| Post-hemorrhagic hydrocephalus: 5%
| Deaf 1.4%
| Blindness 1%
| Predictors of major handicap (Low MDI and/or PDI): Grade of IVH, PVL, absence of chorio (in this population, not in most others), NEC≥II; race; multiple gestation, BPD, maternal education
| For ELBW infants without IVH, the prevalence of major handicap, low MDI, and Low PDI was 25%, 17%, 16%, respectively.
| For ELBW infants with grade III IVH, the prevalence of major handicap, low MDI, and Low PDI was 33%, 29%, 24% respectively.
| For ELBW infants with grade IV IVH, the prevalence of major handicap, low MDI, and Low PDI was 69%, 44%, 63% respectively.
| This study identifies major determinants of adverse neurodevelopmental outcome (i.e. major handicaps, low MDI, low PDI) of ELBW (<1 kg) infants born 1990-1994. Grade of IVH is strong predictor of adverse outcome. But note large % of ELBW without IVH who had major handicap, low MDI, and Low PDI.BPD was a significant determinant of low MDI and PDI. Mat education level was significant determinant of neurodevelopmental outcome. NEC, race, multiple gestation, PVL independently contributed to poor outcome in ELBW infant. Lower BW predicted low PDI.
Cheung 1999 99146391 | Mental score: | | | | | | | | No data on funding source
| Days of ventilation: (N=64) <0.0001
| Motor Score:
| Days of ventilation: (N=164) <0.004
| Mental Score:
| Grade of IVH: (N=164) 0.003
| Motor Score:
| Grade of IVH: (N=164) <0.0001
| Mental Score:
| Infants <1250g with gr. 3 or 4 IVH: (N=50) <0.001
| Motor Score:
| Infants <1250g with gr. 3 or 4 IVH: (N=50) <0.001
Doyle 2001 21326609 | Evaluation at 5 years corrected age: | | | | | | | | Perinatal data lacking on some infants,
Victorian Infant Collaborative study Group, 1997 97290716 | CP: 23–27 wk survivors (11.3%) 25/221 | | | | Blindness : 23–27 wk (1.8%) 4/221 | | | | Especially outborn (in level II or I)
*some subjects were overlapped with 20307288 (stated in text) | FT controls (0%) | | | | FT control 0% | | | | Different methods of testing IQ
*possibly overlapped with 98026322 | Deafness : 23–27 wk (0.9%) 2/221 | | | | | | | | Different times of assessing
| FT control 0% | | | | | | | | Neurodevelopmental outcome
| IQ <-2 SD: 23–27 wk (15.4%) 34/221 | | | | | | | | Some children not evaluated at 5 years (evaluated at 2 years)
| Major neurosensory disability | | | | | | | | 210/401 preterm infants were assessed at both 2 and 5 years
| 23–27 wk (19.6%) 44/225 | | | | FT control (4.1%) 10/245 | | | | The classification of disability or no disability was the same at both 2 and 5 years (90.5% agreement; k=0.691)
| Major disability among survivors | | | | | | | | Inadequate discussion of study population demographics
| 23 wk GA: 2/5 (40%) | | | | 24 wk GA: 7/21 (33%) | | | | Also various surrogate data
| 25 wk GA: 13/51 (25%) | | | | 26 wk GA: 17/71 (24%) | | | | Study was government funded
| 27 wk GA: 5/79 (6%) | | | | Overall 23–27 wk: 19%
| OR for survival with major disability at 5 years:
| OR each 1 wk increase in GA = 0.59 (95% CI 0.43, 0.8)
| Prognostic factors with major disability at 5 years: IVH, cystic PVL, surgery during primary hospitalization, postnatal steroid treatment.
| Rates of survival free of major disability for surviving PT infants:
| None 96/103 =93% | | | One 59/71 | | =83 %
| Two 23/43 =53 % | | | Three 3/9 | | =33%
| Four 0/1 = 0
| Evaluation at 2 years corrected age. Data shown are for births in 1991-1992.
| Gestational age | | Sensorineural disability (% of survivors)
| | n | Severe | Moderate | Mild | None
| 23 weeks | 5 | 29% | 20% | 40% | 20%
| 24 weeks | 21 | 14.3% | 19% | 33.3% | 33.3%
| 25 weeks | 51 | 5.9% | 21.6% | 25% | 47%
| 26 weeks | 68 | 8.8% | 11.8% | 20.6% | 58.8%
| 27 weeks | 74 | 1.4% | 10.8% | 23% | 64.9%
| Overall | 219 | 6.4% | 14.6% | 24.2% | 54.8%
| Decrease in disability with increase in gestational age was significant, p = 0.014.
| Also showed significant fall in severe disability with increase in gestational age, Odds ratio = 0.58 (0.36–0.94) Comparison of cohorts born in 1985-1987 vs. 1991: 1992 did not demonstrate any difference between cohorts.
Corbet 1995 95264244 | Growth AT 1 YR: Mean measurements of Height (74 cm), weight (9.1 kg) and HC (46 cm) and growth percentiles were equivalent in the 2 groups. | | | | | | | | The incidence of severe impairment in the 19% of infants who did not return for evaluation at the age of 1 yr may be higher than in those who were evaluated.
| Health Status AT 1 YR: No difference in parameters between 2 groups | | | | | | | | Source of funding not reported.
| 1) Surgeries (33% vs 34%) | | | 2) Readmission to hospital (45% vs 39%) | | | | | The neurodevelopmental evaluation of infants at 1 yr may not be absolutely reliable for the estimation of later outcome.
| 2) CLD (11% vs 10%) | | | 4) Medications for CLD (14% vs 14%) | | | | | The estimated mental retardation is likely to be low, and the estimated CP is likely to be high, compared to estimates at 2 and 3 yrs.
| 3) Respiratory support (4% vs 2%)
| 4) Med. for chronic neurologic problems (1% vs 2%)
| 5) Asthma (this only was s/s : 9% vs 3%) | | | 8) Eczema (2% vs 1%)
| Neurodevelopmental Outcome: No difference in the outcomes between the 2 groups in these parameters.
| 1) Mean MDI (values <50= 49): | | | 2) Mean MDI (only children with MDI>69)
| 2) Number of children with MDI<69: | | | 4) Number of children with PDI<69
| 3) Mean PDI (values<50=49) | | | 6) Mean PDI (only children with PDI>69)
| CNS Impairment: No difference in any impairments between 2 groups
| 1) Present: 43% vs 37% | | | 2) Absent: 57% vs 63%
| 2) Mild/moderate: 20% vs 14% | | | 4) Severe:23% vs 23%
| 3) MDI<69: 17% vs 16% | | | 6) MDI: 69–84: 18% vs 14%
| 4) CP mild: 8% vs 7% | | | 8) CP moderate/severe: 7% vs 7%
| Audiology:
| 1) B/L sensorineural hearing deafness: 0% vs 1%
| 2) Deafness not needing amplification: 0% vs 1%
| Ophthalmology:
| 1) B/L blindness: 3% vs 2% | | | 2) Visual defect: 8% vs 8%
| Worst examination
| 2) No ROP: 30% vs 33% | | | 2) Mild/moderate ROP: 53% vs 52%
| 3) Severe ROP: 17% vs 15% | | | 4) Surgical treatment for ROP:10% vs 12%
| 4) Cryotherapy for ROP: 5% vs 6%
| Last examination
| 5) No ROP: 69% vs 72% | | | 2) Mild/moderate ROP: 26% vs 22%
| 3) Severe ROP: 5% vs 6% | | | 4) Surgical treatment for ROP: 4% vs 4%
| 7) Cryotherapy for ROP: 2% vs 3%
| Infants who survived after treatment at birth with single dose synthetic surfactant fare as well in terms of growth, development and late morbidities as infants who survive without treatment. No difference in medical history during first year of life, growth, incidence of visual or auditory defects, CP, neurodevelopmental delay at 1 yr adjusted age.
Gerdes 1995 95264241 | Severe ROP: | | | | | | | | 25% loss to follow up, equal in both groups; 1 year follow-up does not predict long-term outcome from all infants
| 1 dose: 47(16) | 3 dose: 35(11) | | | | | | | No data on funding source
| Physical evidence of CLD: | | | | | | | | “Prenatal and postantal exclusion criteria were identical to those used in an earlier prophylactic trial of this synthetic surfactant”
| 1 dose: 43(18) | 3 dose: 40(15) | | | | | | | Died by 1-year adjusted age
| Medication for CLD: | | | | | | | | Lost to follow-up
| 1 dose: 35(14) | 3 dose: 30(11)
| Medication for chronic neurologic disease:
| 1 dose: 12(5) | 3 dose: 3(1)
| Index<2 SD (%):
| 1 dose: 29(15) | 3 dose: 30(13)
| Impairment present:
| 1 dose: 106(44) | 3 dose: 92(35)
| No impairment:
| 1 dose: 123(51) | 3 dose: 155(59)
| Severity of impairment:
| Mild/moderate:
| 1 dose: 40(17) | 3 dose: 39(15)
| Serious:
| 1 dose: 66(27) | 3 dose: 53(20)
| Types of impairments:
| MDI<69:
| 1 dose: 40(16) | 3 dose: 38(14)
| Moderate/severe CP:
| 1 dose: 22(9) | 3 dose: 16(6)
| Bilateral sensorineural deafness:
| 1 dose: 5(2) | 3 dose: 10(2)
| Deafness not requiring amplification:
| 1 dose: 5(2) | 3 dose: 2(1)
| Bilateral blindness:
| 1 dose: 10(4) | 3 dose: 4(2)
| Visual defect:
| 1 dose: 24(10) | 3 dose: 22(8)
Marlow 2000 20150342 | Pulmonary and Other predictors evaluation for Audiology outcome. | | | | | | | | 1) Very small sample size (cases with SNHL only 15)
| Children with sensorineural hearing loss [15] as compared to control group[30] had longer periods of: | | | | | | | | 2) Analyzed too many predictors and combination thereof, for very few outcomes. Very wide confidence intervals; and even those predictors found to be associated with the SNHL this may have been due to chance.
| 1) Intubation, (14 ds vs 2 ds) | | | | | | | | 3) The association found between SNHL and cerebral palsy was [underlined: not]based on an adjusted analyses for possible confounders;
| 2) Ventilation (34 ds vs 6 ds) | | | | | | | | 4) The 2 groups were different in many factors that were associated with both SNHL and CP
| 3) Oxygen therapy (57 ds vs 10 ds) | | | | | | | | Not reported source of funding
| 4) Acidosis (12 ds vs 0.5 ds), and
| 5) More treatments with dopamine (33% vs 7%)or
| 6) Furosemide (87% vs 53%)
| 7) Neither P/T of aminoglycosides
| 8) nor duration of jaundice
| 9) or level of bilirubin varied between the 2 groups.
| SNHL was more likely when :
| 1) netilmicin use coexisted with the peak of bilirubin (87% vs 14%)_
| 2) when acidosis occurred when bilirubin was over 200 ?mol/l, (31% vs 4%)
| 3) when furosemide was used in the face of high creatinine levels (64% vs 27%)
| 4) when furosemide was used with netilmicin (67% vs 37%)
| CNS outcome at 12 mo:
| At 12 months of age evidence of cerebral palsy was present in 7/15 (47%) of children with SNHL vs 2/30 (7%) of children without SNHL.(p=0.022)
Lee 1998 98442293 | Growth, CNS and Audiology, and ophthalmology outcomesfor prematures<1250 g with candidemia/candida meningitis | | Cases | | | Controls | | | Cannot exclude missed association due to the small number of patients analyzed n both groups
| Growth:
| 1) No difference in Growth retardation: | | 7/14 survivors(50%) | | | 11/21 survivors (50%)
| CNS:
| 1) No difference in MDIs of survivors | | 83 ±20 | | | 90 ±20 (p>0.05)
| 2) Lower PDIs in survivors | | 71 ±21 | | | 87±18 (p<0.05)
| 3) No difference in overall Neurodevelopmental disabilities (NDDs) | | 4/14 (29%) | | | 3/21 (14%) (p>0.05)
| 4) Cerebral palsy | | 4/14 (29%) | | | 3/21 (5%)
| Ophthalmology:
| 1) Vision loss: | | 2/14 (14%) | | | 1/21 (5%)
| Audiology:
| 1) Hearing loss | | 2/14 (14%) | | | 1/21 (5%)
| (All the children with NDDs had Cerebral palsy with or without visual or hearing deficit)
| Prematures<1250 g with candidemia/candida meningitis had: Higher Combined mortality and NDDs | | 60% (OR=3.9; 1.2–12.6) | | | 28% (p< 0.05)
DeReginer 1997 98041177 | Chronic lung disease | | | | | | | | Matching scheme used is likely to be ineffective
| Any adverse outcome: | | | | | | | | Large proportion of study population excluded by their matching strategy: subjects excluded were:
| 2/54 | | | | | | | | 329/387=85% with no chronic lung disease; 53/111=47.7% with mild chronic lung disease; 122/180=68% with severe chronic lung disease
| 12/54 | P<0.001 | | | | | | | No data on funding source
| 18/56
| Sensorineural hearing loss:
| 0/54
| 0/54 | P<0.05
| 3/56
| Low MDI<2 SD from mean:
| 0/54
| 4/54 | P<0.05
| 5/56
| Low PDI<2 SD from mean:
| 1/54
| 4/54 | P<0.05
| 7/56
| Weight Z-score:
| No numbers given | | <0.05
| Chronic lung disease and cerebral palsy, unilateral blindness, length Z-score, head circumference Z-score are not significant.
Kurkinen-Raty 1998 98387235 | Retrospective controlled cohort study of early PROM between 17 and 30 weeks of gestation. Assements at one year corrected age. N = 55 for early PROM and 56 for control | | | | | | | | No data on funding source
| Outcome | Early PROM | Control | OR (CI)
| Cerebral palsy | 18% | 16% | 1.2 (0.4, 3.1)
| Delayed motor
| Development | 9% | 16% | 0.5 (0.2, 1.7)
*sample from the same big population as 20284814 | Visual disability | 4% | 4% | 1.0 (0.1, 7.5)
| Hearing loss | 7% | 9% | 0.8 (0.2, 3.2)
| Good nuerosensory development | 67% | 61% | 1.2 (0.6, 2.2)
| Early PROM seems to be a major obstetric and neonatal problem with pulmonary ramifications extending beyond the neonatal period. However, most of these infants can be saved.
Kurkinen-Raty, 2000 20284814 | CLD at 1 year age: | | | | | | | | | Outcome not well defined
| Indicated PT delivery: (81) | | 12/81 (15%) | | | | | | Difficult to know if lack of difference between groups is due to sample size or event rate
| Spontaneous PT delivery: (94) | | 3/94 (3%) | | | | | | No data on funding sourc
| RR 4.6 (1.4, 1.6)
*sample from the same big population as 98197235 | Growth:
| Indicated PT delivery: (81)
| Spontaneous PT delivery: (94)
| Weight RR =0.03 (-5.3, 0.3)
| L RR = 0.002
| HC RR = 0.03
| CP:
| Indicated PT delivery: (81) | | 5/81 (6%)
| Spontaneous PT delivery: (94) | | 10/94 (11%)
| RR=0.6 (0.25–1.6)
| Delayed motor:
| Indicated PT delivery: (81) | | 8/81 (6%)
| Spontaneous PT delivery: (94) | | 8/94 (9%)
| RR 1.2 (0.5–3.0)
| Visual disability:
| Indicated PT delivery: (81)
| Spontaneous PT delivery: (94)
| RR =1.9 (0.5, 7.8)
| Hearing loss:
| Indicated PT delivery: (81)
| Spontaneous PT delivery: (94)
| RR =1.9 (0.5, 7.8)
| This study demonstrated that premature infants who were born due to ‘indicated maternal/fetal reasons’ vs. spontaneous preterm delivered infants had worse pulmonary outcome a 1 yr age. More infants in ‘indicated’ group were SGA and were significantly smaller than control group at 1 yr in Wt, HT, and HC. There was no difference between groups in neurosensory outcomes.

Evidence Table 6A. Studies Evaluating Association of LBW to Behavioral Disorders Part I

Author, Year UI# | Demographics | Inclusion Criteria | Exclusion Criteria | Disease/Condition Type (N) | Study Design (Duration)
Nadeau 2001 21163667 | Location: Canada | Cases: GA<29 weeks, BW<1500 g | Cases: | Cases: EP/VLBW infants (86? 61) | Prospective cohort (at 18 months, 5 years 9 months, and age 7)
| Years of Birth: 1987-1990 | Controls: Normal BW children , born at the same hospital during the same time period | Lost to follow-up at 5 years 9 months: families had moved away (33), parents' refusal (10)
| Median GA (range), wk: | | Lost to follow-up at age 7: families had moved away (10), parents' or school's refusal (13)
| Cases: 27.4±1.1
| Control: 39.8±1.6
| Median BW (range), g:
| Cases: 1024.3±204.2
| Control: 3453.4±497.8
| Male:
| Cases: 51%
| Control: 50%
| Race: ND
| Enrolled: 129
| Evaluated: 86? 61 (50 controls)
| Number of sites: 1
Robson 1997 9055145 | Location: Canada | LBW cohort: ≤ 2500 g | Significant visual or motor impairments or any other gross neurological or physical anomalies. | Cases: 85 LBW infants | Prospective single-arm cohort study
| Years of Birth: ND | Admitted to neonatal intensive care units at 2 hospitals in a mid-sized Canadian city. | | No control group
| Mean GA (range), wk: 32.6±3.4 | English-speaking mothers.
| Mean BW (range), g: 1758.7±521.7 | Families lived within 100 km of either hospital.
| Male: 36% | Assessments at 7 mos and 12 mos of age.
| Race: ND
| Enrolled: 132
| Evaluated: 85
| Number of sites: 2
Breslau 1996 8836807 | Location: US | LBW cohort: ≤ 2500 g | From the target sample: Children with severe neurologic impairment: severe mental retardation, severe cerebral palsy, blindness. | At 6 yrs (823): | Nonrandomized comparison study (6 years)
| Years of Birth: 1983-1985 | NBW cohort: > 2500 g | | Cases:
| Mean GA (range), wk: ND | Born between 1983-85, 6–7 yrs old during 1990-92 when the fieldwork took place. | | LBW 473:
| Mean BW (range), g: | From 2 major hospitals in southeast Michigan: one urban and one suburban. | | Urban LBW (238)
| Urban LBW: 14.7%<1500 g, 21.4% 1501–2000 g, 63.9% 2001–2500 g. | (In each hospital, random samples of LBW and NBW children were drawn). | | Suburban LBW (235)
| Suburban LBW: 17.4%<1500 g, 17.9% 1501–2000 g, 64.7% 2001–2500 g. | | | Controls:
| Urban NBW: ND | | | NBW 350:
| Suburban NBW: ND | | | Urban NBW (176)
| Male: | | | Suburban NBW (174)
| Urban LBW: 42%
| Suburban LBW: 52%
| Urban NBW: 48%
| Suburban NBW: 54%
| Race (% African-American):
| Urban LBW: 80%
| Suburban LBW: 11%
| Urban NBW: 48%
| Suburban NBW: 3%
| Enrolled: 1095
| Evaluated: 823
| Urban LBW: 238
| Suburban LBW: 235
| Urban NBW: 176
| Suburban NBW: 174
| Number of sites: 2
Breslau 2000 20298367 | Location: US | LBW cohort: ≤ 2500 g | From the target sample: Children with severe neurologic impairment: severe mental retardation, severe cerebral palsy, blindness. | At 11 yrs (717): | Nonrandomized comparison study (11 years)
| Years of Birth: 1983-1985 | NBW cohort: > 2500 g | | Cases:
| Mean GA (range), wk: ND | Born between 1983-85, 6–7 yrs old during 1990-92; when the initial assessment took place. Follow-up assessment at age 11 (1995-1997). | | LBW 411:
| Mean BW (range), g: ND | From 2 major hospitals in southeast Michigan: one urban and one suburban. (in each hospital, random samples of LBW and NBW children were drawn). | | Urban LBW (217)
| Male: ND | | | Suburban LBW (194)
| Race (% African-American): | | | Controls:
| Urban LBW: 80% | | | NBW 306:
| Suburban LBW: 11% | | | Urban NBW (164)
| Urban NBW: 74% | | | Suburban NBW (142)
| Suburban NBW: 3%
| Enrolled: 1095
| Evaluated: 823→717
| Number of sites: ND
Hille 2001 21319264 | Location: US, Canada, Germany, Netherlands | Survivors from 4 population based cohorts of ELBW infants in 4 countries: | No assessments of CBCL at age 8–19 | Cases: | Prospective single-arm cohort study
| Years of Birth: | US - the neonatal brain-hemorrhage cohort (NBH): BW<2000 g | | ELBW infants from 4 population based cohorts in 4 countries (108):
| US: 1984-1987 | Canada - McMaster ELBW cohort (McM): BW<1000 g | | USA (80)
| Canada: 1977-1982 | Germany - Bavarian longitudinal study of children at biological risk (BLS): BW<1500 g and GA<32 weeks | | Canada (150)
| Germany: 1985-1986 | Netherlands - the project on preterm and small for gestational age infants (POPS): BW<1500 g and GA<32 weeks | | Germany (78)
| Netherlands: 1983 | | | Netherlands (100)
| Mean GA (range), wk: | | | Controls/Normative Samples:
| US: 27±2.3 | | | USA had 1200 4 – 11 year old normative controls.
| Canada: 27±2.3 | | | Netherlands had 1172 11 year old normative controls.
| Germany: 29±2.0 | | | Canada had 145 full-term controls
| Netherlands: 29±2.3 | | | Germany had 335 full-term controls.
| Mean BW (range), g:
| US: 853±114
| Canada: 834±126
| Germany: 888±101
| Netherlands: 882±105
| Male:
| US: 40%
| Canada: 45%
| Germany: 45%
| Netherlands: 42%
| Race: White 93%
| Enrolled: 523
| Evaluated: 408
| Number of sites: 1
Katz 1996 97145056 | Location: UK | ≤34 weeks, no major congenital anomaly, 3 cranial u/s in first week of life | Lost to follow-up | Cases: Preterm infants (64) | Prospective cohort (6–8 years)
| Years of Birth: 5/83–4/85 | | Too impair due to multiple cognitive, sensory, or motor disabilities, to complete testing | Controls: Full-term comparison sample (40)
| Median GA (range), wk: 29.2±2.5 (26–34)
| Mean BW (range), g: 1227.5±341.4 (740–2240)
| Male:
| Cases: 52%
| Controls: 55%
| Race:
| Cases: 75% White, 19% Black, 6% Asian
| Controls: 75% White, 12.5% Black, 12.5% Asian
| Enrolled: 212
| Evaluated: 64 (40 controls)
| Number of sites: 2
Sajaniemi 1998 99041674 | Location: Finland | For Preterm Group (sample 1): | For Preterm group | Sample 1: | Retrospective comparative study (24 mo CA)
| Years of Birth: 1989-1991 | GA: 23–34 wks | If mothers had chorioamnionitis | Preterm infants (80)
| Mean GA: | Mother referred to University Central Hospital of Helsinki for threatened preterm delivery Born between 1989-1991 | If mother had insulin dependent diabetes | Sample 2
| Sample 1: 28.9 (23–35) | For Full term group (Sample 2): | Children with congenital anomalies, by U/S | Full term enrolled at:
| Sample 2: 39.4 (36–43) | Born in Metropolitan Helsinki Visiting pediatric services in Helsinki for acute infectious diseases | For Full term group | 20–28 mo of age (80)
| Mean BW: | | Chronic diseases
| Sample 1: 1205 (560–2360) | | Developmental delay
| Sample 2: 3461 (2510–5360)
| Male: ND
| Race: ND
| Enrolled: ND
| Evaluated : 160
| Number of sites: 1

Evidence Table 6A. Studies Evaluating Association of LBW to Behavioral Disorders Part II

Author, Year UI# | Predictors | Predictor Measures | Outcomes | Outcome Measures
Nadeau 2001 21163667 | General: GA | Evaluated at 5 years 9 months, was developed using SES data such as the family status (two-parent, single-parent, blended), age of each parent, their respective levels of education, and professional occupations. 0=low ~ 7=high | CNS: | Neuromotor development index:
| Other: Family adversity Index | | Neurodevelopmental: | Huttenlocher neurological task test
| | | Motor function | McCarthy Scales of Children's Abilities
| | | Cognitive delay | Behaviors wre assessed by peers, teachers, and parents: RCP, TRF, parent's CBCL
| | | Behavioral disorders
| | | Behavior
Robson 1997 9055145 | Developmental status | Development measured by The Bayley Scales of Infant Development | Behavior at 5.5 years of age: | McCarthy Scales of Children's Abilities by the examiner
| Quality of home environm | Quality of Home environment at 7 and 12 mos of age: The HOME Inventory, paternal education, The Blishen Index, preschool version of the HOME Inventory in early childhood | Inattention | Parental report from the Child Behavior Checklist
| Early Medical risk | Early Medial Risk measured by the Morbidity Scale | Impulsivity | Task performance test, vigilance tasks
| Infant temperament | Infant Temperament and Development: The Carey Infant Temperament Questionnaire when the infants are 7 months of age corrected for prematurity. | | Matching Familiar Figures Test
Breslau 1996 8836807 | General: | BW <2500g | ADHD (attention deficit hyperactivity disorder) | The National Institute of Mental Health Diagnostic Interview Schedule for Children-Parent
| 1) LBW (vs Normal BW=NBW) | Racial composition, whether mothers completed high school, marital status, maternal smoking during pregnancy, maternal substance abuse/dependence during pregnancy. | Separation anxiety disorder | Teacher Report Form
| 2) Urban (vs suburban setting) | | Simple phobia
| 3) Maternal smoking during pregnancy | | Overanxious disorder
| | | Oppositional defiant disorder
Breslau 2000 20298367 | General: | BW <2500g | Behavior assessment at 11 yrs of age. (Assessment at 6 yrs: reported in 1996 publication) | Mother's rating was done with: Child Behavior Checklist (CBCL)
| 4) LBW (vs Normal BW=NBW) | Racial composition, whether mothers completed high school, marital status, maternal smoking during pregnancy, maternal substance abuse/dependence during pregnancy. | 1) Behavioral problems in 3 domains: Attention, Externalizing behaviors, Internalizing behaviors | Teacher's rating was done with Teacher Report Form (TRF) (teachers were blind to the BW information of the child)
| 5) Urban (vs suburban setting) | | 2) Severe attention problems (above a cutoff point of 67) | Assessments at 11 yrs were conducted blindly to the results of assessments at 6 yrs (reported in another publication)
| 6) Maternal smoking during pregnancy | | | 1) Attention problem subscale; 20 items
| | | | 2) Externalization problem subscale: 2 subclasses
| | | | 3) Internalization problem subscale: 3 subclasses
Hille 2001 21319264 | Birth weight | ND | Behavior | CBCL - Parents: Total problem score Internalizing behavior (anxious, Socratic), Externalizing behavior (aggressive and delinquent), Social, thought, attention problems
| | | Attention
Katz 1996 97145056 | General: GA | IA IVH: no lesion= consistently NC scans. | CNS:
| CNS: | Mild lesion = germinal hem or small IVH or PVD or mild vent dilation without hem. | Neurodevelopmental:
| 1) Intracranial/ Intraventicular hemorrhage | Severe lesion: blood distends the vents or in parenchyma, or multicystic PVC. | Attention | Measured by CPT test (Continuous Performance Test), measuring errors of omission or commission.
| 2) Periventricular leukomalacia (cystic PVD) | | IQ | Is also measured by CBCC (Child Behavior Check List): parents check off behavior related to attention and hyperactivity.
| 3) PVD (if unilateral or bilateral periventicular echogenic lesions present on at least 3 scans) | | | Measured by British Abilities Scale
Sajaniemi 1998 99041674 | General: | Not further specified | CNS: | Neurologic outcome:
| 1) Prematurity per se | | Neurologic outcome | 1) Cerebral palsy
| 2) Premature with BW< 1000 g vs premature with BW > 1000 g | | Developmental outcome | 2) Free of major disabilities
| 3) Preeclampsia | | Temperament profile | Developmental outcome:
| 4) SGA | | Behavioral profile | 1) Bayley Scales of Infant Development
| 5) Duration of NICU stay | | | 2) Mental Development Index (MDI)
| CNS: | | | Temperament: Toddler Temperament questionnaire (TTQ) (contains 97 statements) 9 temperament dimensions:
| 1) PVL | | | 1) Activity
| 2) IVH | | | 2) Rhythmicity
| Pulmonary: | | | 3) Approach
| 1) Duration of ventilation | | | 4) Adaptability
| | | | 5) Intensity
| | | | 6) Mood Persistence
| | | | 7) Distractability
| | | | 8) Threshold
| | | | Behavior: Infant Behavior Record:
| | | | 1) Social responsiveness
| | | | 2) Attention
| | | | 3) Affect
| | | | 4) Energy level
| | | | 5) Goal directedness during the test
| | | | (24 mo CA)

Evidence Table 6A. Studies Evaluating Association of LBW to Behavioral Disorders Part III

Author, Year | Associations found | | | | Potential Biases
Nadeau 2001 21163667 | EP/ VLBW, n = 61 and controls, n = 44. | | | | No data on funding source
| | EP/ VLBW | Control | Significance | Data on neuromotor and intellectual functioning only collected once
| Normal neuromotor function | 67% | 97% | NS | Data on behavior collected once
| Abnormal neuromotor function | 33% | 3%
| McCarthy IQ [mean (SD)] | 100.3 (19.1) | 112.8 (16.2) | P < 0.01
| Behavioral ratings at 7 years age:
| Peers rated EP/ VLBW's as significantly more sensitive/ isolated than controls
| Teachers rated EP/ VLBW's as significantly more inattentive than controls
| Parents rated EP/ VLBW's as more hyperactive than controls
| Significantly = P < 0.01
Robson 1997 9055145 | • Developmental status and the quality of the home environment correlate with hyperactivity. | | | | | Internal validity B
| • Medical risk, infant temperament, quality of home environment and developmental status correlate with attention.
| • A nurturing home environment fosters development of self-regulating behaviors in LBW.
Breslau 1996 8836807 | • LBW was significantly associated with ADHD but not with separation anxiety disorder, simple phobia, overanxious disorder, or oppositional defiant disorder. | | | | Parent ratings, questionnaire results are biased but corroborated by teachers who are blinded to BW of children helps to corroborate. | Internal validity B
| • Both the mothers' and teachers' ratings significantly correlated with increased ADHD in LBW infants and this relationship is stronger in urban than in suburban communities.
| • LBW children with the lowest IQ have highest incidence of ADHD.
| • The urban group was primarily black, more mothers had not completed high school and more were single.
| However, maternal marital status, history of substance abuse/dependence and smoking during pregnancy were not associated with ADHD.
Breslau 2000 20298367 | 1) Information from mothers and teachers on children's behavior problems at age 11 revealed that the effect of LBW on attention problems differed between urban and suburban settings. | | | | 1) Recollection bias: The Hx of maternal smoking during pregnancy was elicited when the child was 6 yrs old. This bias would have resulted in underestimation of the confounding effect of smoking during pregnancy.
| 2) LBW children had an excess of attention problems in the urban disadvantaged communities and not in the suburban middle class communities. | | | | 2) Diagnosis bias: Although there was correspondence of the findings of teachers reports (who were blind to the LBW status of children) and the mothers reports, mothers report could have definitely been biased (worse scores from mothers of LBW infants)
| 3) LBW infants in the urban setting had twice as high incidence of attention problems than in urban NBW.
| 4) In suburban setting there was no difference in severe attention problems between LBW and NBW children.
| 5) LBW children had externalizing problems both in the urban and suburban settings (however this effect was mainly accounted for by maternal smoking in pregnancy).
| 6) No LBW effect was observed with respect to internalizing problems
| 7) Regardless of LBW status, maternal smoking during pregnancy was associated with an increase in externalizing problems
| 8) No association found between maternal smoking during pregnancy and internalizing or attention problems
| OVERALL SCORES | [underlined: Attention scores] | [underlined: Internalizing] | [underlined: Externalizing]
| MOTHER'S SCORES
| Urban
| • LBW (n=217) | 58.8 | 52.7 | 52.2
| • NBW (n=164) | 55.8 | 51.5 | 50.4
| Suburban
| • LBW (n=194) | 55.1 | 50.4 | 48.4
| • NBW (n=142) | 53.8 | 48.6 | 46.3
| TEACHER'S SCORES
| Urban
| • LBW (n=186) | 56.9 | 50.3 | 53.9
| • NBW (n=151) | 54.7 | 48.8 | 48.5
| Suburban
| • LBW (n=180) | 53.7 | 49.0 | 48.5
| • NBW (n=135) | 54.0 | 48.7 | 48.3
Hille 2001 21319264 | ELBW vs. Controls | | | | (None) | Study was privately funded
| Total problem score:
| Boys: 3.3–9.8 points higher in ELBW vs. norm/ control
| Girls: 3.7–5.9 points higher in ELBW vs. norm/ control
| Social, thought, and attention difficulty scales were 0.5–1.2 SD higher in ELBW children vs. norm/control
| Internalizing and externalizing behavior scores: no difference for all 4 groups (except for one cohort for internalizing scores)
| ELBW children had higher total problem scores than normative/control children (statistical significance in European countries). Study identified similar types of behavioral problems in all 4 countries in ELBW infants. This suggests that problems with attention, social, and thought problems are a function of experiences of children who were born ELBW, and not to cultural differences.
Katz 1996 97145056 | Attention deficit is measured by the CPT test (error of omission). Hyperactivity and impulsivity is measured by the CPT test (error of commission). | | | | Exactly how FT controls were selected in an unbiased way is not described. | No data on funding source
| There were no differences among the preterm infants with mild, moderate and severe intracranial lesions. However, there was a significant increase in both errors of commission and omission in preterm with mild lesions compared to full term infants as well as in preterm with severe lesions compared to full term infants. With increasing severity of lesions in preterm infants, increasing percentage in each group commit errors of commission. Even in the absence of detectable intracranial lesions, preterm infants are still at higher risk for developing attention deficits than full term infants. | | | | | This study does not explore relationship of attention deficits identified with CPT test with actual school performance and achievement in this group of preterm infants.
| | | | | | This study includes older preterm 26–34 weeks and does not include the extremely preterm 24–25 wk infants.
Sajaniemi 1998 99041674 | The neurological outcome of preterm infants was: | | | | • Post hoc multiple comparisons were done between preterms and full terms for the multiple individual items of the tests used.
| For Cerebral palsy: | Free from major disabilities | MDI | | • Cannot exclude selection bias
| 1) All prematures: 17.5% | 82.5% | 103 | | • No matching between groups cannot exclude the presence of confounders.
| 2) Prematures < 1000 gs: 23.5% | 23.5% | 98 | | • Interactions between
| 3) Prematures > 1000 gs: 13.5% | 85.6% | 107 | | • Predictor may have masked some real associations; Possible interactions were not formally tested
| The developmental outcome: Preterm infants had significantly lower MDI scores when compared to full terms (Full terms 124 ) | | | | • Cannot exclude
| When temperament was considered: the premature children were significantly less active; more adaptive; less intensive; more positive in mood and had lower sensory threshold than the healthy control term children. When behavior was assessed (Infant's Behavior Records): the preterms were significantly less goal directed; less attentive, and had lower endurance than the controls. | | | | | | | Diagnosis bias, as no information is given on the blinding of the personnel doing the outcome evaluation, of the child's PMHx.
| When Bayley neurodevelomental was assessed:
| 1) the preterms performed significantly less well than the controls.
| 2) Low Bayley scores correlated with temperament scores of high rhythmicity, positive mood, low persistence and high threshold
| 3) Low Bayley scores correlated with IBR scores
| 4) No strong relationship between temperament characteristics and cognitive performance. Preterm infants had significantly lower MDI compared to full terms:
| • Preterm infants were different in 5/9 items of temperament profile compared to full terms: less active (p<0.008), more adaptive (p<0.02), less intense (p<0.01), more positive in mood (p<0.0004), lower in threshold to respond (p<0.0003)
| • Preterm infants were different in 3/5 items in IBR profile when compared to full terms: less goal directed, less attentive, lower in endurance
| Predictors evaluation:
| • From the perinatal risk factors: preeclampsia, SGA, PVL and IVH were not associated with developmental outcome or temperament profiles.
| • PVL, IVH were associated with shorter attention span (1/5 items in IBR profile); when preterms compared to full terms.
| • Duration of NICU stay was not associated with Bayley score
| • Duration of ventilation was not associated with Bayley score
| • Duration of ventilation and days in NICU were associated with the 5 items of IBR profile; Duration of ventilation was associated with 1/9 items of temperament profile

Evidence Table 6B. Studies Evaluating Association of LBW to School Performance and Learning Disabilities Part I

Author, Year UI# | Demographics | Inclusion Criteria | Exclusion Criteria | Disease/Condition Type (N) | Study Design (Duration)
Hille 1994 8071753 | Location: Netherlands | Cases: Participants of the Project on Preterm and Small for Gestational Age Infants, a nationwide collaborative study 2) Perinatal data collection and follow-up until 2 years of age and assessments at 5 and 9 years 3) VLBW (very preterm) GA< 32 weeks at birth | ND | Cases: | Prospective (single arm) cohort
| Year of birth:1983 | BW<1500 g. | | VLBW (or very preterm): 813
| Description of group: VLBW | | | No control group
| Mean GA (range), wk: <32 weeks
| Mean BW (range), g: <1500 g
| Male: ND
| Race: ND
| Enrolled: 1338
| Evaluated: 813
| Number of sites: 1
Stathis 1999 99325758 | Location: Australia | BW 500–999g survived to discharge | ND | ELBW survived infants (87) | Prospective cohort (followed at 4, 8, 12, months)
| Years of Birth: :1977-1986 | Cared for in study NICU
| Median GA (range), wk: 27.7(27.3–28.1) | Enrolled in follow-up programs
| Mean BW (range), g: 860 (837–833)
| Male: 36%
| Race: ND
| Enrolled: 124
| Evaluated: 87
| Number of sites: 1
Cherkes-Julkowski 1998 98262696 | Location: ND | Preterm: | ND | Preterms (28) | Retrospective cohort
| Years of Birth: ND | <38 wks, BW<5 lbs, no congenital disorders, no retrolenteal fibroplasia, discharge from hospital prior to 42 wks conceptional age, mother willing to participate | | Controls: full term infants (20)
| Mean GA (range), wk: ND | Controls: participats were enrolled in a longitudinal sudy before their second month of age
| Mean BW (range):
| Cases: 4.14±1.87 lbs
| Controls: 7.30±1.87 lbs
| Male:
| Cases: 61%
| Controls: 50%
| Race: ND
| SES: “middle class”
| Enrolled: 48
| Evaluated: 28 (20 controls)
| Number of sites: 1
Marlow 1993 8466264 | Location: UK | Cases: VLBW ≤ 1250g at birth and without cerebral palsy at 6 years. | Major disabilities (CP or major sensory impairment) | Cases: VLBW: 51 | Nonrandomized comparison trial
| Years of birth:1980-1981 | Controls: 1) Control group (full term) matched for age, race, and sex, and school-matched. | | Controls: Full term/ controls: 59
| Description of group: VLBW
| Mean GA (range), wk: ND
| Mean BW (range), g: ≤1250 g
| Male: ND
| Race: ND
| Enrolled: 72
| Evaluated: 51
| Controls: 59
| Number of sites: 1

Evidence Table 6B. Studies Evaluating Association of LBW to School Performance and Learning Disabilities Part II

Author, Year | Predictors | Predictor Measures | Outcomes | Outcome Measures
Hille 1994 8071753 | General predictors: | Assessment at 5 years of age: | At 9 years of age : | Questionnaire: kind of school (mainstream or special education), grade and need for extra help from teachers, remedial teaching, or speech therapy.
| 1. BW | 1. Neurologic examination according to Touwen | School performance
| 2. GA | 2. Dutch test of speech and language development | Special education
| 3. Gender | 3. Visual fields, acuity
| 4. Perinatal factors: congenital malformations, Apgar scores, intracranial hemorrhage, septicemia, assisted ventilation >7 days, serum bilirubin, thyroxine levels. | 4. Audiometry
| 5. Socioeconomics | 5. Groningen Neurobehavioral concentration test
| 6. Performance at 5 years of age: Development, neuromotor function, speech/language, hyperactivity and school performance. | 6. Child Behavior Checklist
| | 7. Handedness
| | 8. Kind of school
| | 9. School results
Stathis 1999 99325758 | CNS Predictors | Self-explanatory | CNS: | Academic problems--Answer questionnaires given to teacher
| 1. Other: head circumference category | | Neurodevelopmental: | ADHD--Dr. Paul rating scale
| 2. Head growth velocity | | Cognitive delay | McCarthy's scales
| | | Behavioral disorders-ADHD
| | | School problems
| | | Learning disabilities
Cherkes-Julkowski 1998 98262696 | General: GA | ND | CNS: | Cognitive delay, measured by Stanford-Binet
| Other: Mother perception of child competence | | Cognitive delay | School programs (school concerns = SC)
| | | Neurodevelopmental | Learning disabilities (LD)
| | | School problem | Neurological Impairment (NI)
| | | Neurological Impairment (NI) | Attention deficit Disorder (ADD)
| | | Attention Deficit Disorder (ADD) | Language impairment = LI - dx made by speech and language clinician
| | | Audiology:
| | | Language
Marlow 1993 8466264 | General predictors: VLBW | BW ≤ 1250g | At 8 years of age: | [underlined: School performance:] mathematics test (NFER Nelson), Schonell S1 graded word spelling test, Suffolk reading test, handwriting, fine motor skills.
| | | School performance | [underlined: Behavior Measurements:] parental questionnaire Rutter A(2), and teacher questionnaire using Rutter B(2) and Connors hyperactivity scale.
| | | Behavior disorder

Evidence Table 6B. Studies Evaluating Association of LBW to School Performance and Learning Disabilities Part III

Author, Year | Associations found | | | Potential Biases | Comments
Hille 1994 8071753 | • School performance at 9 years of age is best predicted by performance at 5 years of age. | | | Children labeled as having difficulty in school early in education (i.e. at 5 years of age) may continue to be treated as such within the system. Therefore independent evaluation of these children's performance at 9 years of age may reveal more useful information. | Internal validity A
| • At 9 year of age, 19% were in special education and 81% in mainstream education. | | | | According to this study, early school problems are not transient.
| • At 9 years of age, only 44% of the nondisabled prematurely born children were in mainstream education at an age-appropriate level without special assistance.
| • GA <28 wks, BW < 1250 g, male gender and socioeconomics were significantly related to education outcome. Neonatal illnesses were not associated with school outcome at 9 years of age.
| • Majority of children having difficulty in school at 5 years of age had difficulty in school at 9 years of age.
Stathis 1999 99325758 | Head circumference category at 8 months corrected age related to learning delay greater than one year when assessed at 6 years: | | | One nursery | Study was privately funded
| HC Category | n | % with delay | High rate of patients lost to follow-up (30%)
| < 3^rd^ percentile | 23 | 61% (39, 80) | Small numbers: limited ability to detect small differences; high chances of type 2 error
| 3^rd^ to 10^th^ | 13 | 77% (46, 95) P = 0.004
| > 10^th^ | 40 | 30% (17, 47)
| Head circumference category at 12 months CA did predict McCarthy General Cognitive index at six years, but head circumference category at 24 months CA did not significantly predict McCarthy CGI at 6 years.
| Head circumference and head growth velocity was not shown to have a relationship with attention deficit hyperactivity disorder.
| Head circumference category < 10^th^ vs. greater than 10^th^ percentile at four and 8 months corrected age were significantly associated with McCarthy CGI at 6 years age
Marlow 1993 8466264 | • Even in the presence of normal IQ, premature children are more likely to underachieve in school compared to full-term peers. | | | | Internal validity B
| • Forty-eight percent in preterm group had difficulty in one or more subjects compared with 19% in full term group.
| • Both teachers and parents report behavior problems of restlessness, hyperactivity, inattention, unresponsive/apathetic, fearful/afraid of new situations.
| • Motor difficulties and mathematics test best correlate with later school performance problems.

Evidence Table 7. Studies Evaluating Association of LBW to Opthalmologic Outcomes Part I

Author, Year UI# | Demographics | Inclusion Criteria | Exclusion Criteria | Disease/Condition Type (N) | Study Design (Duration)
Page 1993 94051493 | Location: Canada | BW<1250 g admitted to Toronto's | No 12-month follow-up reports | VLBW infants at 12-month follow-up (110) | Retrospective cohort (12, 24 months)
| Years of Birth: 1986-1987 | Hospital for sick children | | VLBW infants at 24-months follow-up (50)
| Mean GA (range), wk: 27±1.8 (237–32) | Survived the neonatal periods and had at least one eye examination between 28 and 42 of life that documented the severity of ROP
| Mean BW (range), g: 942±197 (400–1250)
| Male: 38%
| Race: White 100%
| Enrolled: 138
| Evaluated: 110 ? 50
| Number of sites: 1
Cryo-ROP 1994 94304375 | Location: US | BW < 1251 g | Death <28 days; serious ocular anomaly or systemic malformations, lack of consent; first eyes exam with 4 qd | Zone and Stage of ROP (2759): | Prospective cohort (1 year)
*The original large population of CRYO-ROP | Years of Birth: 1/1986 to 11/1987 | Survived at least 28 days | Death (264) | Zone I (46)
| Mean GA (range), wk: 26.0±1.9 to 29.6±2.1 | No serious ocular anomaly, such as cataract, glaucoma, or chorioretinitis, and no major systemic malformations | Lost to follow-up (1076) | Zone II, stage 3+, 9–12 sectors (139)
| Mean BW (range), g: 781±156 to 1061±144 | Parental consent | | Zone II, stage 3+, 5–8 sectors (64)
| Male: 48% | Initial eye examination by a study-certified ophthalmologist by 49 days after birth | | Zone II, stage 3+, 1–4 sectors (47)
| Race: White 56%, Black 35%, Hispanic 6%, Other 3% | | | Zone II, stage 3 (241)
| Enrolled: 4099 | | | Zone II, stage 2 (484)
| Evaluated: 2759 | | | Zone II, stage 1 (500)
| Number of sites: 23 | | | Zone III (319)
| | | | Other ROP (22)
| | | | No ROP (896)
Keith 1995 95288128 | Location: UK | ELBW infants, BW < 1000g | ND | Sample 1: ELBW survivors born 1977-1984 (145) | Prospective cohort (16 years)
| Years of Birth: 1977-1992 | Survival to hospital discharge | Not seen by the ophthalmologist: transferred to another level-3 center for ongoing care (17); unknown reasons (6) | Sample 2: ELBW survivors born 1985-1992 (312)
| Mean GA (range), wk: | Eye exams done
| Sample 1: 26.0±2.3
| Sample 2: 26.1±2.2
| Mean BW (range), g:
| Sample 1: 783±136
| Sample 2: 786±133
| Male: ND
| Race: ND
| Enrolled: 457
| Evaluated: 434
| Number of sites: 1
Foreman 1997 97271716 | Location: UK | Healthy preterm infants | ND | Healthy preterm infants (16) | Prospective cohort (6.1 years)
| Years of Birth: 4/1994–4/1996 | GA 27–32 weeks; weight within the normal range for GA | | Controls: Matched full term controls (16)
| Mean GA (range), wk: | Normal on all criteria of Standard child health surveillance program from 7.5 to 48 months
| Cases: 29.38 | Each could be matched with FT control on gender, post-natal age at testing, and on SEC. Healthy controls from School population
| Controls: 39.88 | Controls: children drawn from a school population who were known to have been full-term, normal delivered and whose uneventful medical and developmental histories were confirmed by parents, general practitioners, and teachers
| Mean BW (range), g:
| Cases: 1413±302
| Controls: 3437±625
| Male: 63%
| Race: ND
| Enrolled: 114
| Evaluated: 16 (16 controls)
| Number of sites: 1
Tin 1998 99046171 | Location: North of England | GA 23–31 weeks | ND | 1983 cohort (230): | Prospective cohort
*also in CNS table | Years of Birth: 1983, 1990-1991 | | | Child reviewed without difficulty (204) | *2 Cohorts of different time periods
| Median GA (range), wk: ND | | | Child traced with difficulty (14)
| Mean BW (range), g: ND | | | Child seen with difficulty after child was traced (12)
| Male: ND | | | 1990 to 1991 (566): Child reviewed without difficulty (505)
| Race: ND | | | Child traced with difficulty (26)
| Enrolled: 1983 (230); 1990-1 (566) | | | Child seen with difficulty after child was traced (35)
| Evaluated: 1983 (230); 1990-1 (566)
| Number of sites: 5
Dogru 1999 99168711 | Location: Japan | Premature infants (BW < 1500 g, GA < 37 weeks) with ROP | Physical and mental disabilities or any CNS and ocular disorder | Premature infants: | Prospective cohort (18–24 months)
| Years of Birth: 4/1994–4/1996 | | | (Sample 1, 2, and 3):
| Mean GA (range), wk: | Controls: randomly selected premature subjects with no ROP | | Premature infants with ROP (78)
| Sample 1: 27.6±2.9 | | | Sample 1: ROP stage 1 (53)
| Sample 2: 26.9±1.4 | | | Sample 2: ROP stage 2 (11)
| Sample 3: 26.3±3.1 | | | Sample 3: ROP stage 3 (14)
| Controls: 29.6±2.6 | | | Controls: Premature infants without ROP (66)
| Mean BW (range), g:
| Sample 1: 1016±207
| Sample 2: 836±178
| Sample 3: 874±218
| Controls: 1193±241
| Male: 49%
| Race: ND
| Enrolled: 144
| Evaluated: 78 (66 controls)
| Number of sites: 1
Pennefather 1999 20002011 | Location: UK | All surviving children <32wk GA born in geographically deprived region in Northern UK | No examined at age 2 years old | Preterm infants (558) | Prospective cohort and retrospective review of patient records (2–3 years)
Pennefather 2000 20217908 | Years of Birth: 1/1/90–12/31/91 | Survived to 2 years old
* This study also should be mentioned in multiple outcome and CNS table | Mean GA (range), wk: ND
| Mean BW (range), g: ND
| Male: ND
| Race: ND
| Enrolled: 566
| Evaluated: 558
| Number of sites: ND
Tin 2001 21143595 | Location: North of England | GA < 28 weeks | ND | Sample 1: Preterm infants, SpO_2_ 88–98% (123) | Prospective cohort
*1990-1991 sample is same as 99046171 | Years of Birth: 1990-1994 | Surviving (born 1990-1991) when 2 years old | | Sample 2: Preterm infants, SpO_2_ 70–90% (126)
| Median GA (range), wk: 23–27 | Surviving (born 1992-1994) when 18 months
| Mean BW (range), g: ND | Assessed for CP and ophthalmic
| Male: ND | For current review, only SpO_2_ 88–98% and SpO_2_ 70–90% groups were included
| Race: ND
| Enrolled: 1990-1 (781); 1992-1994 (ND)
| Evaluated: 249 (for current review)
| Number of sites: ND

Evidence Table 7. Studies Evaluating Association of LBW to Ophthalmologic Outcomes Part II

Author, Year | Predictors | Predictor Measures | Outcomes | Outcome Measures
Page 1993 94051493 | General predictors: | ROP - ICROP | Ophthalmology outcomes: | Myopia - spherical equivalent of ? 0.25 diopters
| 1) Birth weight | Others not defined | Visual impairment | High Myopia - spherical equivalent of ? 4.0 diopters
| 2) GA | Myopic - >0.25 D | Strabismus | Astigmatism - > 1 diopter in any meridian or cycloplegic refraction
| CNS predictors: | | Refractive error | Anisometropia - spherical equivalent >2 D between eyes (both refracted)
| 1) Intracranial/ Intraventricular hemorrhage | | Myopia
| 2) Periventricular leukomalacia | | Astigmatism
| Ophthalmology predictors:
| 1) Retinopathy of prematurity
| 2) Myopic at 12 months post-term
| Cardiovascular or pulmonary predictors:
| 1) PDA
| 2) Days ventilated
| 3) Days in O_2_
Cryo-ROP 1994 94304375 | Ophthalmology predictors: | ROP defined by examination according to the ICROP | Ophthalmology: | ROP outcomes (structural):
*The original large population of CRYO-ROP | Retinopathy of prematurity | | Visual impairment | I. Only peripheral changes, no mascular distortion
| | | Structural outcome
| | | | II. Mascular displacement
| | | | III. Retinal fold involving macula
| | | | IV. Retrolental opacity entotal retinal detachment and/or total pupillary occlusion to retinal detachment
| | | | Functional outcome:
| | | | a. Normal fixation
| | | | b. Presence/absence of nystagmus
| | | | c. Strabismus
| | | | d. Refractive error (spherical equivalence)
Keith 1995 95288128 | General predictors: | ND | Ophthalmology outcomes: | Eye exam with ICROP classification.
| Birth cohort: 1977-1984 vs. 1985-1999 | | 1) blindness | Sheridan-Gardner test - visual outcome.
| | | 2) severe ROP | Snellen's eye chart - visual outcome.
Foreman 1997 97271716 | GA | 28–32 week prematurity vs. full term controls | CNS Attention skill | Point-to-Target test
| | | Ophthalmology | Complex visual search test
| | | Visual-perceptual skills | Cartoon comparison test
| | | Visual-motor skills | Overlapping figures
| | | | Goillin incomplete figures
Tin 1998 99046171 | General: GA (23–31 wks) | ND | CNS: CP | Definition of “severe disability” and “severe sensorimotor disability” were not given in this article . They referred to the wrong reference for these definitions, therefore, I am unable to find the definitions.
*also in CNS table | | | Neurodevelopmental: | Reference population for Griffith's scales were “preterm babies in the study S serious sensorimotor disability”
| | | Mental retardation (IQ < 75)
| | | Other; disability (severe, sever sensorimotor)
| | | Other: development - assessed by Griffith's mental and developmental scales
| | | Ophthalmology
| | | Visual impairment
| | | Blindness
| | | Other: Severe ROP with Cryotherapy
Dogru 1999 99168711 | ROP | Staging of retinopathy was based on International Classification of Retinopathy of Prematurity (The Committee for the Classification of Retinopathy of Prematurity, 1984) | Ophthalmology: | Preferential looking method
| | | Visual acuity
Pennefather 1999 20002011 | General Predictor: GA | ND | CNS:Cerebral palsy | Retrospective review of patient records
Pennefather 2000 20217908 | CNS: | | Ophthalmology: | Visual acuity, visual fields
* This study also should be mentioned in multiple outcome and CNS table | 1) IVH | | Visual impairment (cortical)(CVI)
| 2) Periventricular leukomalacia | | Cicatricial ROP
| 3) Ventriculomegaly/Ventricular Dilation | | Strabismus
| Ophthalmology:
| 1) ROP
| 2) Refractive error
| Other: Family Hxg strabismus, Developmental disability, CP
Tin 2001 21143595 | General predictors: | SpO_2_ policies were obtained retrospectively | CNS: | Threshold ROP: (Cryo-ROP definition) stage 3 plus acute ROP extensive permanent cicatricial retinal scanning
*1990-1991 sample is same as 99046171 | GA | | Cerebral palsy
| Other predictors: | | Ophthalmology:
| SpO_2_ policies (88–98% vs.70–90%) | | Blindness
| | | Severe ROP Rx with cryotherapy

Evidence Table 7. Studies Evaluating Association of LBW to Ophthalmologic Outcomes Part III

Author, Year | Associations found | | | | Potential Biases | Comments
Page 1993 94051493 | Outcome: Incidence of myopia at 12 mo postterm age: | | | | Retrospective NB and ophthalmic chart review 36% eye reports available at 24 months. Also 24 month sample was biased toward children at greatest risk of myopia. Children with normal eye results at 12 months age were discharged from further follow-up at 18 months post-term age. This may have led to underdiagnosis of myopia due to lack of detection of progressive myopia. | No data on funding source
| Overall incidence of myopia in cohort (BW<1251 g) was 15% (4.5% severe myopia) | | | | Infants born 1986-1987 (not a bias, but a limitation) | This study demonstrates the importance of low birth weight, ROP severity, and IVH in the development of myopia and strabismus.
| At 12 months age: | | | | Used other pop reference figures for norms
| Increased severity of ROP predicted increased severity of myopia (p=0.001)
| Overall, 16% of infants had myopia, and 4.5% had severe myopia at 12 months age.
| To show incidence of myopia according to severity of ROP:
| 10% of infants with No or Stage 1 ROP had myopia
| 54% of infants with Stage 3 ROP had myopia
| 23% of infants with Stage 3 ROP had severe myopia
| The likelihood of myopia at 12 months age doubled with each increment in ROP stage.
| - At 24 months age: 80% of 50 children showed deteriorating vision.
| - 13 of 16 (81%) showed worsening of their myopia after 12 months age.
| Overall, the incidence of myopia and severe myopia increased among 50 infants followed to 2 years: 38% had myopia 0.25–4 Diopters; 24% had myopia >4 Diopters.
| BW was negatively associated with incidence of myopia (p=0.002).
| BW<750 g 3.2 fold odds of myopia vs. 751–1000 g.
| - BW <750 g 10 fold odds of myopia vs. 1001–1250 g.
| Incidence of strabismus was positively associated with severity of ROP (e.g. no ROP 6% vs. Strabismus at 12 mo in infants who had Stage 3 ROP 38%). There was further increased diagnosis of strabismus at 24 months age.
| Months of age in infants who had had Stage 3 ROP (38% to 62%). 100% of infants who had Grade III or IV IVH had strabismus
Cryo-ROP 1994 94304375 | The more posterior the zone of ROP and /or the greater the extent of Stage 3+ ROP, the worse the structural and functional ophthalmic outcomes. Zone II without plus disease, Zone III, or no ROP was associated with low rate of unfavorable outcome. CNS injury may affect ophthalmic function (e.g. nystagmus and strabismus). | | | | (None) | Study was government and privately funded Biweekly or weekly eye exams until fully vascularized or until threshold ROP (>5 contiguous or 8 cumulative clock hours) stage 3 with plus disease.
*The original large population of CRYO-ROP | Visual function by ROP Classification | | | | | Only data from eyes that served as controls (untreated) are included in this segment.
| ICROP | Abnl. Fixation | %Nystagmus | %Strabismus
| Zone I | 44% | 6% | 25%
| Zone II
| Stage 3, 9–12 sectors | 57% | 39% | 33%
| Zone II,
| Stage 1 | 2% | 1% | 10%
| No ROP | 1% | 1% | 6%
| % of Eyes with refractive error (≥2 diopters myopia) by ROP severity
| No or Stage 1 ROP (<5%)
| Zone II, Stage3+, 9–12 sectors (62%)
| Zone I (40%)
Keith 1995 95288128 | Any ROP: | | | | Data are from care center | No data on funding source
| Birth Cohort | | | | No outborn infants in either cohort so data are not generalizable to outborn ELBW infants | 16 year study; 1001 ELBW infants; 457 survived to discharge; 434 seen by same ophthalmologist. Twenty children not seen by ophthalmologist.
| 1977-1984 (141) 68/141 | | 48.2 %
| 1985-1992 (293) 105/293 | | 35.6% | OR=0.60(0.40–0.90)P<0.02
| Severe ROP: | | | | Twenty-three surviving ELBW's could not be located to determine ROP status.
| 1977-1984 (141) 36/141 | | 25.4 %
| 1985-1992 (293) 52/293 | | 17.4% | OR=0.62 (0.38–1.02) NS
| Blindness:
| 1977-1984 (141) 2/141 | | 1.4 %
| 1985-1992 (293) 2/293 | | 0.6% | OR=0.43 (0.05–3.5) NS
Foreman 1997 97271716 | Visual-motor coordination: | | | | Small sample size | No data on funding source
| PT v. FT NS diff | | | | Incomplete data analysis
| Visual-spatial attention skill: Significant difference between Preterm and Full term in complex visual search scores (failure to find figure and latency to find) and cartoon comparisons
| PT 2.94 FT 0.81 P<0.05
| Visual-form perception: NS difference between Preterm and full term in latency to respond to overlapping figure and Gollin incomplete figure tests.PT 22.2% FT 21.9% NS diff
| Compared to matched, FT controls, the PT school age group performed poorly on 2 measures visual-motor tests. Thus in the absence of detectable disability, prematurity is associated with visual-motor and attentional impairments that persist through 16 years age.
Tin 1998 99046171 | Result of 1983 cohort at 6 years: | | | | No definitions of outcome, incomplete methods description, wrong reference | Study was privately funded
*also in CNS table | Severe disability:
| Sample 1: 4.4%, Sample 2 : 2.1%, Sample 3: 50%
| IQ < 75 without sensorimotor disability:
| Sample 1 : 4.9%, Sample 2 : 0, Sample 3 : 25%
| Severe sensorimotor disability:
| Sample 1 : 5.9%, Sample 2 : 21.4%, Sample 3 : 41.7%
| Severe sensorimotor or cognitive disability:
| Sample 1 : 8.4% (5 – 13.1%, 95% CI)
| Sample 2 : 21.4% ( 4.7–50.8%)
| Sample 3: 41.7% (15.2–72.3%)
| Result of 1990 cohort at 2 years:
| Severe disability:
| Sample 1: 7.9%, Sample 2: 15.4%, Sample 3: 57.1%
| High f/u rate is critical because it may underestimate incidence of the outcome.
Dogru 1999 99168711 | Stage 3 ROP had significantly lower visual acuity scores compared to stage 1–2 or no ROP at 18–24 months (P<0.0001) | | | | (None) | No data on funding source
Pennefather 1999 20002011 | Strabismus in 70/558 (12.5%) infants GA<32 week | | | | Prospective evaluation but retrospective collection of neonatal data; therefore, probable incomplete collection of variable reason for present and absent data | No data on funding source
| The incidence of strabismus increased with decreasing GA (p=0.0004), increasing severity of ROP (p=0.0001), and decreasing general developmental quotient (GMDS) (p<0.0001). | | | | No demographic data was report (the cohort was described elsewhere)
Pennefather 2000 20217908 | Stabismus present in 28 (52%) of patients with CP (P< 0.001)
* This study also should be mentioned in multiple outcome and CNS table | OR (95% CI) of Strabismus if following predictor was present:
| Cicatricial ROP: 4.94 (1.1–22.12), p0.037
| Fam Hx of Strabismus: 4.15 (2.19–7.88), p<0.00005
| Refractive Error: 2.71 (1.3–5.66), p=0.008
| GMDS 78–100: 3.34 (1.46–7.64), p=0.004
| GMDS <77: 46.2 (17.1–125), p<0.00005
| This study confirms findings of other studies that strabismus is increased in premature infants with decreasing GA and is increased with increasing severity of ROP and CP. Independent factors related to strabismus are cicatricial ROP, refractive error, family hx of strabismus, and developmental delay (especially delayed hand-eye coordination)
Tin 2001 21143595 | Premature infants who had oxygen saturation range (SpO2) between 88–98% for at least first 8 weeks of life developed severe ROP requiring treatment with cryotherapy four times greater than infants who had SpO2 range between 70–90. | | | | Different pulse oximeters | ROP screening conformed to national guidelines
*1990-1991 sample is same as 99046171 | Incidence of severe ROP with Cryotherapy (SpO2 range 88–98%)=28% | | | | No attempt to document real SpO_2_ or how often SpO_2_ fell outside recommended ranges (or vice versa). Narrow limits broached often >wider limits.
| Incidence of severe ROP with Cryotherapy (SpO2 range 70–80%)=6%
| Incidence of Blindness in the two study groups:
| Premature infants with SpO2 range 88–98%: 4 / 65
| Premature infants with SpO2 range 70–80%: 0 / 65
| Incidence of CP in the two study groups:
| Premature infants with SpO2 range 88–98%: 17%
| Premature infants with SpO2 range 70–80% 15%
| The lower SpO2 range was not associated with difference in CP.
| Differences in SpO2 policies (70–90% vs. 88–98%) did have a major impact on the proportion who developed severe ROP, but had no effect on survival or on incidence of CP among premature survivors.

Evidence Table 8. Studies of Treatment Effects for LBW Infants with Retinopathy of Prematurity (ROP) Part I

Author, Year UI# | Demographics | Inclusion Criteria | Exclusion Criteria | Disease/Condition Type (N) | Study Design (Duration)
Cryo-ROP, 1990, 1996, and 2001 (×3) 91024693, 96180078, 21375786, 21375787, 21375788 | Location: US | BW < 1251 g | ND | At 1-year exam: VLBW infants with ROP (241) | Randomized controlled trial (1, 5.5, 10 years)
Repka 1998 98426775 | Years of Birth: from 1/1986 to 11/1987 | Survived at least 28 days | [underlined: {(At 1-year follow-up:] | At 5.5-year exam:
*sample from the large population of 94304375 (CRYO-ROP) | Mean GA (range), wk: | Diagnosis of threshold ROP | Died before the 1-year follow-up (36) | VLBW infants with ROP (234) - bilateral threshold ROP (191); asymmetric threshold ROP (43)
| 1 yr follow-up: 26.3±1.8 | | Unable to follow-up for the 1-year exam (14) | At 10-year exam:
| 5.5 yr follow-up: 26.3±1.7 (bilateral threshold ROP; 26.3±1.8 (asymmetric threshold ROP) | | [underlined: At 5.5-year & 10-year follow-up:] | VLBW infants with ROP (234)
| 10 yr follow-up: 26.3±1.8 | | Died before the 5.5-year & 10-year exam (36)}
| Mean BW (range), g: | | Lost to follow-up for the 10-year exam (8)
| 1 yr follow-up: 800±165
| 5 yr follow-up: 801±165 (bilateral threshold ROP; 800±165 (asymmetric threshold ROP)
| 10 yr follow-up: 800±165
| Male: ND
| Race: ND
| Enrolled: 291
| Evaluated: 246 (at 1-year exam), 234 (at 5.5-year exam), 247 (at 10-year exam)
| Number of sites: 23
Cryotherapy for Retinopathy of Prematurity Group 1993 93191597 | Location: US | All infants <1251g, who participated in CRYO-ROP Multicenter trial and had threshold (severe) ROP. | See original study | Infants with threshold ROP (236) | 3.5 years
| Years of Birth: 1986-1987
| Mean GA (range), wk: 26.3±1.8
| Mean BW (range), g: 800±165
| Male: ND
| Race: ND
| Enrolled: 236
| Evaluated: 236
| Number of sites: 23
Algawi 1994 95001766 | Location: UK | Premature infants with threshold ROP (stage 3+ disease of 5 or more contiguous clock hours [30° sector] or 8 cumulative clock hours) or more | ND | Sample 1: Laser Treatment (12) | Prospective cohort
| Years of Birth: | | | Sample 2: Cryotherapy Treatment (20)
| Sample 1: 2/1992–11/1992
| Sample 2: 1/1987–2/1992
| Mean GA (range), wk:
| Sample 1: 24–32
| Sample 2: 25–30
| Mean BW (range), g:
| Sample 1:700–1200
| Sample 2: 620–1500
| Male: 53%
| Race: ND
| Enrolled: 32
| Evaluated: 32
| Number of sites: 1
Ling 1995 95391616 | Location: UK | All premature infants in 1 unit who developed threshold ROP and treated with diode laser therapy | ND | Infants with ROP treated with Diode laser (13) | Before and after trial (6, 12, and 18 months)
| Years of Birth: 1992-1993
| Median GA (range), wk: 25.5 (24–27)
| Median BW (range), g: 725 (589–887)
| Male: 38%
| Race: White 100%
| Enrolled: 13
| Evaluated: 13
| Number of sites: 1
Connolly 1998 984267776 | Location: US | Premature infants with symmetric threshold ROP underwent bilateral treatment | ND | Sample 1: Laser Treatment (21 eyes) | RCT and follow-up (5.8 [4.3–7.6] years)
| Years of Birth: 11/1989–5/1992 | | (Stage 4 or 5 ROP in one or both eyes | Sample 2: Cryotherapy Treatment (21 eyes)
| Mean GA (range), wk: 25.4 (23–32) | | Refused to cooperate with monocular occlusion during Snellen testing
| Mean BW (range), g: 731 (440–1318) | | Limited cognitive ability that precluded Snellen or illiterate e-chart acuity testing)
| Male: 44%
| Race: ND
| Enrolled: 52
| Evaluated: 25
| Number of sites: 1
Shalev 2001 21331013 | Location: US | Threshold ROP treated with laser or cryotherapy | ND | Infants with threshold ROP (10) | RCT with prospective follow-up (7 years and 6 months)
| Years of Birth: 1991-1992 | | Lost to follow-up (2)
| Mean GA (range), wk: 24.8 (23.4–27.0) | | Died at 4 months of age (2)
| Mean BW (range), g: 631 (540–846) | | Refusal (3)
| Male: 60%
| Race: 30%
| Enrolled: 19
| Evaluated: 10
| Number of sites: 1
O'Connor 2002 21635822 | Location: UK | All infants <1701g, who survived 3 weeks. Born to mothers who were residents in the study areas, admitted to one of 5 NICUs. | ND | Premature infants (254) | 10–12 years
| Years of birth: 1985-1987 | | | Control (169)
| Mean GA (range), wk: 31.06±3.09
| Mean BW (range), g: 1400 (iqr 1150, 1562)
| Male: ND
| Race: ND
| Enrolled: 505
| Evaluated: 505
| Number of sites: 5

Evidence Table 8. Studies of Treatment Effects for LBW Infants with Retinopathy of Prematurity (ROP) Part II

Author, Year | Predictors | Predictor Measures | Outcomes | Outcome Measures
Cryo-ROP, 1990, 1996, and 2001 (×3) 91024693, 96180078, 21375786, 21375787, 21375788 | Ophthalmology predictors: | At least 5 contiguous clock hours or 8 cumulative clock hours of stage 3 ROP in zone 1 or 2 in the presence of “plus disease” (dilation and tortuosity of the posterior retinal vessels) | Ophthalmology: | Visual acuity -
Repka 1998 98426775 | Threshold retinopathy of prematurity | Monocular visual acuity (using log of minimal angle of resolution visual acuity chart) | Visual impairment (visual acuity) | • “normal”;: ?1.6 cycles per degree
*sample from the large population of 94304375 (CRYO-ROP) | At 5.5-year & 10-year follow-up: Cryotherapy vs. No Cryotherapy | | Structural outcome | • “below normal”: 8.0 to <1.6 cycles per degree
| | | Blindness | • “poor”: <0.8 cycles per degree
| | | Distance snellen acuity | • “blind”: eyes judged to have no light perception, eyes for which the tester was unable to estimate acuity, which were judged by a physician to have total retinal detachment
| | | Near snellen acuity | Structural outcome -
| | | Visual field | •Posterior retinal fold
| | | Medical and surgical ophthalmologic interventions | • Retinal detachment involving zone 1 of the posterior pole
| | | Cerebrospinal fluid shunting surgery | • Retrolental tissue or “mass” obscuring the view of the posterior pole
| | | | Favorable Functional outcome:
| | | | Favorable visual acuity: better than 20/200
| | | | Unfavorable visual acuity: worse than 20/200 or blind
| | | | Goldmann perinmetry to measure visual field extent along 8 meridian using V4e and III 4 e stimuli
Cryotherapy for Retinopathy of Prematurity Group 1993 93191597 | Retinopathy of Prematurity (ROP) (Specifically threshold ROP treated with cryotherapy or no cryotherapy) | Threshold ROP as per CRYO-ROP definition. | Visual impairment | Visual acuity (HOTV, Grating)
| | | Blindness | Unfavorable outcome (HOTV 20/200 or worse, Grating <6.4 cycles per degree; blind): this outcome is combination of poor + blind
| | | | Myopia:≥2 <6 diopters; ≥ 6 diopters
Algawi 1994 95001766 | Ophthalmology | ND | Ophthalmology: | Visual functions were assessed by either fixation pattern or preferential looking technique
| Retinopathy | | Visual impairment:
| | | Refractive error
| | | Visual fixation
| | | Preferential looking
Ling 1995 95391616 | ROP | Threshold as for Cryo-ROP trial | Ophthalmology | Favorable outcome (anatomical) defined as a normal posterior funus on BIO exam performed by observer who had not done Rx. Functional outcomes assessed using Keeler preferential looking cords acuity greater or equal to 0.8 cycles per degger defined 1 yr. Age
| | | Visual function
Connolly 1998 984267776 | ROP | Threshold as for Cryorop trial - 5 or more contiguous or 8 cumulative clock-hours of stage 3 ROP in zone I or II in the presence of “plus” disease | Ophthalmology Outcomes: | Visual acuity 20/50 or better =good
| | | Visual impairment | Visual acuity 20/60 or worse = poor
| | | Refractive error
| | | Visual acuity
Shalev 2001 21331013 | ROP | Threshold as for Cryorop trial | Ophthalmology | Favorable outcome = normal posterior fundus.
| | | Visual function outcome | Refraction by retinoscopy
| | | Structural outcome | Functional outcomes: Keeper preferential looking cards . Favorable function was grating acuity greater than or equal to 0.8 cycles/degree (as per CRYO ROP study at 1 year)
O'Connor 2002 21635822 | Birth weight | BW self-explanatory (grams) | Visual impairment | Visual acuity: Normal (20/20); ≥Moderately reduced=worse than 20/40
| ROP | ROP not stated, but c/w ICROP | Blindness | Contrast sensitivity (Pelli Robson chart)
| | | | Steroacuity (TNO plates)
| | | | Perimetry (visual fields) (Damato campimeter)
| | | | Color vision (desaturated D15 test)
| | | | Strabismus (cover test and prism test)
| | | | Refractive error (cycloplegic refraction)
| | | | Eye size and dimensions of its components (N.D.)

Evidence Table 8. Studies of Treatment Effects for LBW Infants with Retinopathy of Prematurity (ROP) Part III

Author, Year | Associations found | | | | | | | Potential Biases | Comments
Cryo-ROP, 1990, 1996, and 2001 (×3) 91024693, 96180078, 21375786, 21375787, 21375788 | [underlined: At 1-year follow-up:] | | | | | | | (None) | Study was government and private funded 5½ year follow-up of preterm infants with BW <1251 g with Threshold ROP randomized to cryotherapy vs. no cryotherapy groups. Both had high incidence of blindness, impaired visual acuity, and unfavorable outcome.
Repka 1998 98426775 | Fundus photography: Unfavorable posterior pole outcome at 1 yr | | | | | | | | Unfavorable outcomes were significantly less in cryotherapy group vs. control group.
*sample from the large population of 94304375 (CRYO-ROP) | Cryotherapy Rx | | 191 eyes | | 25.7% | | | | Excellent long-term (10 yr) ophthalmic follow-up of PT infants with severe ROP.
| Control | | 194 eyes | | 47.4% | | P<0.001 | | Cryotherapy assoc with significantly less unfavorable visual function outcome and less unfavorable structural outcome. >44% of cryo Rx eyes have unfavorable visual outcome and 62% have unfavorable structural outcome. Threshold ROP with or without Rx is high for adverse long-term outcome. Infants with BW<1251 g with ROP underwent a large number of ophthalmic interventions through the first 5.5 years of life. Longterm costs of extreme prematurity and ROP include initial ablative therapy for ROP and societal loss due to visual impairment or blindness and ongoing costs for caring for eye problems.
| Unfavorable structural outcome (retinal detachment, macular fold, etc) at 1 yr
| Cryotherapy Rx | | 208 eyes | | 49%
| Control | | 203 eyes | | 66%
| Unfavorable functional (Teller Visual Acuity) outcome at 1 yr
| Cryotherapy Rx | | 160 | | 35%
| Control | | 158 | | 56.3%
| [underlined: At 5.5-year follow-up:]
| Visual acuity Unfavorableoutcome:
| Threshold ROP (control: no cryotherapy) 62%
| Threshold ROP CRYOtherapy 47%
| Greater reduction in unfavorable visual acuity outcome in cryo group (P<0.005)
| Unfavorable structural outcome
| Threshold ROP (control: no cryotherapy) 45%
| Threshold ROP CRYOtherapy 27%
| Greater reduction in unfavorable structural outcome in cryotherapy group (P<0.001)
| Blindness
| Threshold ROP (control: no cryotherapy) 48%
| Threshold ROP CRYOtherapy 32%
| Greater reduction in blindness in cryotherapy group (P<0.001)
| Visual acuity 20/40 or better
| Threshold ROP (control: no cryotherapy) 17%
| Thresdhold ROP CRYOtherapy 13%
| No significant difference between groups with respect to proporation of infants with visual acuity 20/40 or better (P=0.19)
| Among children who had Threshold ROP treated with cryotherapy: 226 / 257 had ocular intervention in addition to cryotherapy (0.9% interventions per child)
| Vitrectomy 26% (66/257); Scleral buckling 3% (8/257); Lensectomy 18%; Glaucoma medical treatment 4%; Glucoma surgery 2%; amblopia treatment 20%; Strabismus surgery 10%; Cataract surgery 2%; Enucleation 2%; Ventriculoperitoneal shunt (VPS) 11% Among children in the Natural History Cohort with variable ROP: 239 ocular interventions (0.4% interventions per child) Strabismus 6%; Amblyopia Rx 7% (3% if no ROP); VPS 3%
| [underlined: At 10-year follow-up:]
| Unfavorable Visual outcomes (functional) in Threshold ROP. Comparison of Threshold ROP eyes treated with CRYO vs. Control
| Distance Snellen Acuity (≥20/200)
| CRYO Rx | | 44%
| Control | | 62%
| Near Snellen Acuity
| CRYO Rx | | 43%
| Control | | 62%
| Blindness
| CRYO Rx | | 33%
| Control | | 50%
| Unfavorable Visual Acuity
| Zone I/Threshold ROP/ CRYO Rx | | | | 94%
| Zone I/Threshold ROP/Control | | | | 94%
| Unfavorable structural outcome
| Zone I/Threshold ROP/ CRYO Rx | | | | 88%
| Zone I/Threshold ROP/Control | | | | 94%
| Although cryotherapy was beneficial in reducing unfavorable structural and functional outcome vs. no treatment in Threshold ROP eyes, infants with threshold ROP still were at high risk for unfavorable outcome even with cryotherapy, especially infants with Threshold Zone 1 ROP.Vii
| Visual fields at 10 years age in children enrolled in the CRYO ROP trial who had history of Threshold ROP (cryotherapy vs. control). Visual fields (with or without cryotherapy) were significantly smaller with severe ROP Visual fields in treated eyes were reduced by 30–37% vs. no ROP. Visual fields in control eyes were reduced by 27–33% compared to no ROP. Cryotherapy vs. control preserved sight and visual field in infants with severe ROP. Visual field area was 24 to 26% larger in CRYO Rx eyes vs. Control. Comparison of sighted treated eyes vs. sighted control eyes revealed that cryotherapy reduced visual field by small amount (5%).
Cryotherapy for Retinopathy of Prematurity Group 1993 93191597 | Predictors/Conditions | N | Outcome Category | Outcome of Interest/ Instruments used | % with Outcome | | Methods of Correlation
| Cryotherapy | 203 | vision | Unfavorable outcome | 47% | | Cryo group had 19% reduction in unfavorable outcome for HOTV
| | | | HOTV acuity
| No Cryotherapy | 203 | vision | Unfavorable outcome | 58% unfavorable outcome | | (p<0.01)
| | | | HOTV acuity
| Cryotherapy | 193 | vision | Unfavorable outcome | 52% | | Cryo group had 20% reduction in unfavorable outcome for grating (p<0.01)
| | | | Grating acuity
| No Cryotherapy | 193 | vision | Unfavorable outcome | 66%
| | | | Grating acuity
| Cryotherapy | | vision | Myopia [underlined: :≥2 <6 diopters] | 20% | | More treated eyes had myopia than control eyes.
| No Cryotherapy | | vision | Myopia [underlined: :≥2 <6 diopters] | 15.5% | | Data not shown is that more control eyes could not be refracted.
| Cryotherapy | | vision | [underlined: Myopia ≥6 diopters] | 37.7%
| No Cryotherapy | | vision | Myopia [underlined: : ≥6 diopters] | 27.2%
Algawi 1994 95001766 | Myopia | | | | | | | Small sample size | No data on funding source
| Treat with Laser 6/15 (40%) (Spher Equiv-1.5 to-3.5D) | | | | | | | Cohorts treated at different time, not concurrent and not randomized | There is a high incidence of myopia following treatment for threshold ROP. Myopia occurred less often in the laser treated group vs. cryotherapy treated group.
| Treat with Cryotherapy 23/25 (92%) (Spher Equiv-0.5 to-8.0D)
| Significantly more myopia in cryotherapy vs. laser group (P=0.0006)
| Hypermetropia <+3.0 Diopters
| Treat with Laser 9/15 (60%)
| Treat with Cryotherapy 2/25 (8%)
| Clinical significant astigmatism (no significant difference between groups (P=0.4)
| Treat with Laser 5/15
| Treat with Cryotherapy 5/25
Ling 1995 95391616 | Visual outcome of Threshold ROP treated with diode laser: Structural Outcome (as defined by Cryotherapy Multicenter Trial) at 19.5 months age (range 9.7–25.5. mo) was favorable in all 13 patients (25 eyes). Functional outcome at the same follow-up (n=13): 3 with strabismus; 1 myopic; grating visual acuity (Keeler preferential looking cards) ranged 2.9–14.5 cycles per degree. 7 uniocular and 6 binocular acuity assessments fell within the CRYO-ROP definition of favorable acuity at 1 year of age (≥0.8 cycles per degree uniocular) | | | | | | | (None) | No data on funding source
Connolly 1998 984267776 | | | Laser Treated Threshold ROP | | Cryotherapy Treated Threshold ROP | | Total | Excluded large numbers of subjects | No data on funding source
| Visual Acuity 20/50 or better | | 17 | | 8 | | 25
| Visual Acuity 20/60 or worse | | 4 | | 13 | | 17
| Total | | 21 | | 21 | | 42
| 81% of laser-treated vs. 38 % of cryotherapy treated Threshold ROP had good visual acuity outcome (VA 20/50 or better). The odds that a laser treated eye had a good visual outcome were 6.91 greater than threshold ROP eyes treated with cyrotherapy (95% CI 1.7–28).
| Refractive Error: On average, 23 cryotherapy eyes had a mean spherical equivalent of- -5.08 Diopters vs. -3.05 Diopters for 23 laser treated eyes P=0.0072). Thus, cryotherapy eyes had greater amount of myopia than laser treated eyes.
| Summary: The odds that eyes treated with laser therapy would have best-corrected visual acuity of 20/50 or better was almost 7 times greater than cryotherapy treated eyes. Also, laser treated eyes had less myopia than cryotherapy treated eyes. Thus, the results suggest that laser photocoagulation for threshold ROP was more likely to result in good visual outcome with less myopia compared to cryotherapy treatment.
Shalev 2001 21331013 | Associations: | | | | | | | Small numbers for randomized comparison. | No data on funding source
| All 10 Laser treated eyes had favorable structural outcome; 2 of 8 cryotherapy eyes had unfavorable structural outcome | | | | | | | It is not clear how similar were the groups in terms of original threshold ROP (zone I vs. II)
| Laser-treated vs. cryotherapy treated threshold eyes had more favorable outcome
| | | Laser | | Cryotherapy | | P
| Geometric visual acuity | | 20/33 | | 20/133 | | 0.03
| Range | | (20/20–20/70) | | (20/25 to phthisis)
| Mean refractive error(D) | | -6.5 | | -8.25 | | 0.27
| Conclude: Laser therapy for threshold ROP may have long-term visual function advantages over cryotherapy
O'Connor 2002 21635822 | | Predictors/Conditions | N | Outcome Category | Outcome of Interest/ Instruments used | % with Outcome | Methods of Correlation
| Full term | Control | 169 | Visual function | Distance Acuity (Left eye) | -0.08 (-0.1,0.01)
| BW<1701 all | Premature cohort | 254 | Visual function | Distance Acuity (Left eye) | 0.0 (-0.08,0.1)
| No ROP | Premature cohort | 126 | Visual function | Distance Acuity (Left eye) | 0.0(-0.08,0.04)
| Stage 3 or 4 ROP | Premature cohort | 7 | Visual function | Distance Acuity (Left eye) | 0.34(0.21,0.605)
| Full term | Control | 169 | Visual function | Binocular Distance Acuity | Normal 93% | P<0.001 between control vs. premature cohort
| | | | | | ≥Moderately reduced 0%
| BW<1701 all | Premature cohort | 254 | Visual function | Binocular Distance Acuity | Normal 76%
| | | | | | ≥Moderately Reduced 3.5%

Evidence Table 9. Studies Evaluating Association of LBW and Pulmonary Outcome

Author, Year UI# | Demographics | Inclusion Criteria | Exclusion Criteria | Disease/Condition Type (N) | Study Design (Duration)
Als 1994 94358983 | Location: US | BW < 1250 g | ND | Experiment: VLBW infants participated in individualized developmental care (20) | Randomized controlled trial (2 weeks and 9 months)
(CNS+ Pulmonary) | Years of Birth: ND | GA < 30 weeks and more than 24 weeks of estimated GA at birth | | Controls: VLBW infants received standard care (18)
| Median GA (range), wk: | Mechanical ventilation starting within the first 3 hrs after birth and lasting longer than 24 hrs in the first 48 hrs
| Experiment: 27.1±1.6 | Alive at 48 hrs
| Control: 26.5 ±1.4 | Absence of chromosomal or other major genetic anomalies, congenital infections, and known fetal exposure to drugs of addiction
| Median BW (range), g: | Singleton
| Experiment: 827±173 | At least one family member with some English-language facility
| Control: : 862±145 | Telephone access
| Male: | Living within the greater Boston area
| Experiment: 45%
| Control: 61%
| Race: Black
| Experiment: 40%
| Control: 17%
| SES I, II/III/IV, and V:
| Experiment: 45%, 20%, 35%
| Control: 56%, 17%, 27%
| Enrolled: 43
| Evaluated: 38
| Number of sites: 1
Chye 1995 95314864 | Location: Australia | Cases: 26–33 week GA infants with BPD and discharged home | Cases: Trisomy 21 (2) | Cases: Preterm infants with BDP (78) | Case-control study
| Years of Birth: 1989 to 1990 | Controls: 26–32 week GA infants without BPD admitted to the hospital within 1 year of the cases, matched for BW with the cases in broad categories (<1000 g, 1000–1499 g and =1500 g) | | Sample 2: Preterm infants without BPD (78)
| Mean GA (range), wk: | | | Subgroups of cases at 12 months corrected
| Cases: 28±1.58 | | | age follow-up:
| Controls: 28.63±1.26 | | | Sample 1: BPD no
| Mean BW (range), g: | | | Home O_2_ (58)
| Cases: 1055±234 | | | Sample 2: BPD with Home O_2_ (20)
| Controls: 1077±215
| Male: 56%
| Race: ND
| Enrolled: 80
| Evaluated: 78 (78 controls)
| Number of sites: 1
Kraybill 1995 95264242 | Location: USA | Premature VLBW: 700–1350 g (Detailed description available in another article) | ND | At 1 yr f/up | Randomized placebo-controlled double blind trial (at 1 year and at 2 years CA)
| Years of Birth: 1986-1989 | | | Sample 1: Synthetic Surfactant at Birth via ET tube: 5 ml/kg (136)
| Mean GA: (F/up at 1 year) | | | Sample 2: Air placebo via ET tube at birth (122)
| Sample 1: 28.2±1.9 | | | At 2 yr F/up:
| Sample 2: 28.1±2.0 | | | Sample 1: Synthetic surfactant at birth (57)
| Mean BW: | | | Sample 2: Air placbo (61)
| Sample 1: 1022±177
| Sample 2: 1028±184
| Male:
| Sample 1: 51%
| Sample 2: 52%
| Race:
| Sample 1: White: 21%, Black: 53%, Hispanic: 23%, Other; 4%
| Sample 2: White: 34%, Black: 42%, Hispanic: 22%, Other: 2%
| Enrolled: 323 (survivors at 1 yr)
| Evaluated: 258 (at 1 yr f/up)
| Mean GA (F/up at 2 years of age)
| Sample 1: 28.3±1.8
| Sample 2: 28.1±1.8
| Mean BW:
| Sample 1: 1043±165
| Sample 2: 1005±184
| Male:
| Sample 1: 49%
| Sample 2: 43%
| Race:
| Sample 1: White: 35%, Black: 60%, Other:5%
| Sample 2: White: 43%, Black: 54%, Other: 3%
| Enrolled: 136 (survivors at 2 yrs)
| Evaluated: 118
| Number of sites: 2
Santuz 1995 96023205 | Location: Italy | Cases: Premature, RDS with mechanical vent > 7 days; met criteria for BPD; agreed to cooperate | Cerebral palsy; too young to cooperate | Cases: Preterm infants with BPD (12) | Case-control study (6–12 years)
| Years of Birth: 1981-1987 | Control: healthy term school children matched for age, height, weight, habitual level of physical activity | | Controls: Healthy term infants (16)
| Mean GA (range), wk:
| Cases: 30±2 (27–32)
| Controls: 39±1 (37–40)
| Mean BW (range), g:
| Cases: 1400±335 (890–1900)
| Controls: 3335±418 (2800–4100)
| Male:
| Cases: 75%
| Controls: 69%
| Race: ND
| Enrolled: 12 (16 controls)
| Evaluated: 12 (16)
| Number of sites: 1
Iles 1997 97280982 | Location: UK | Premature birth | Refused consent | Premature infants with CLD (33) | Prospective cohort
| Years of Birth: ND | Continuous supplemental O2 for 28 days after birth | Returned to referring hospital
| Mean GA (range), wk: ND
| Median BW (range), g: 900 (589–1891)
| Male: ND
| Race: ND
| Enrolled: 40
| Evaluated: 33
| Number of sites: 1
Cheung 1998 99059896 | Location: Canada | VLBW survivors, BW < 1500 g, requiring inhaled nitrous oxide(INO) (continues to be hypoxemic at >90% O_2_ and MAP 15±2) | Mosaic trisomy 18 | VLBW infants treated with INO (10) | Prospective cohort
| Years of Birth: 12/93–10/97 | | Potter's syndrome survived to 1 year of chronological age
| Mean GA (range), wk: 25 (24–30)
| Median BW (range), g: 860 (340–1460)
| Male: 67%
| Race: ND
| Enrolled: 24
| Evaluated: 10
| Number of sites: 1
Gross 1998 98375435 | Location: US | All live-born babies 24–31 wk gestation cared for at Crouse Memorial Hospital, survived to discharge | ND | (Sample 1&2): Preterm infants (96) | Prospective cohort (7 years)
| Years of Birth: 1985-1986 | Controls: FT AGA, 38–42 wk GA. | | Sample 1: Preterm infants with BPD (43) | Cases: 8 died after discharge because of complications of chronic lung disease (2), pneumonia (2), nonrespiratory conditions (4), lost to follow-up (6), and neurodevelopmental delays (23)
| Mean GA (range), wk: | PT matched to FT for sex, mat. Race, mat. Educa. and marital status (sociodemographic factors). | | Sample 2: Preterm infants without BPD (53) | Controls: lost to follow-up (12), neurodevelopmental delays (5)
| Sample 1: 28.2±2.1 | | | Controls: Full term infants (108)
| Sample 2: 28.4±2.0
| Controls: 40±1.1
| Mean BW (range), g:
| Sample 1: 1173±345
| Sample 2: 1179±354
| Controls: 3565±427
| Male:
| Sample 1: 53%
| Sample 2: 51%
| Controls: 57%
| Race: White
| Sample 1: 86%
| Sample 2: 85%
| Controls: 89%
| Enrolled: 133 (125 controls)
| Evaluated: 96 (108)
| Number of sites: 1
Kurkinen-Raty 1998 98387235 | Location: Finland | Preterm PROM between 17–30 weeks gestation; singleton; delivered > 2 hr after rupture | Rupture unconfirmed or transient | Sample 2: Preterm rupture (78) | Retrospective cohort
(All+Lung) | Years of Birth: 1990-1996 | Controls: preterm no PROM; spontaneous preterm delivery matched for GA and year of delivery. | | Sample 2: Preterm delivery no rupture (78)
*sample from the same big population as 20284814 | Mean GA (range), wk:
| Cases: 28.2 (23.8–37.2)
| Controls: 28.4 (22.9–36.9)
| Mean BW (range), g:
| Cases: 1138.3±434
| Controls: 1272.4±547.2
| Male: ND
| Race: ND
| Enrolled: 78 (78 controls)
| Evaluated: 78 (78)
| Number of sites: 1
Subhedar 1999 20257096 | Location: UK | Sample 1: Preterm infants with CLD | ND | Sample 1: Preterm infants with CLD (54) | Prospective cohort
| Years of Birth: 6/1995–5/1999 | Sample 2: Preterm infants without CLD received mechanical ventilation <24 hours + 02< 72 hours | | Sample 2: Healthy preterm infants (44)
| Mean GA (range), wk:
| Sample 1: 28 (24–34)
| Sample 2: 30 (26–34)
| Mean BW (range), g:
| Sample 1: 1055 (510–2310)
| Sample 2: 1420 (840–2150)
| Male:
| Sample 1: 52%
| Sample 2: 52%
| Race: ND
| Enrolled: 98
| Evaluated: 98
| Number of sites: 1
Kurkinen-Raty 2000 20284814 | Location: Finland | Cesarean delivered singleton, GA 24–33 weeks | ND | Sample 1: Indicated preterm I.e. preterm birth ‘indicated’ for maternal/fetal reasons (103) | Retrospective cohort
*sample from the same big population as 98197235 | Years of Birth: 1990-1997 | Controls: spontaneously delivered singleton after regular contractions and/or preterm rupture of the membranes no more than 24 hrs before. The mothers were matched one-to-one by gestational age at delivery plu7s or mines 1 week. | | Sample 2: Spontaneous preterm delivery due to preterm labor (103)
| Mean GA (range), wk:
| Cases: 30.5±2.1
| Controls: 30.4±2.1
| Mean BW (range), g:
| Cases: 1294±469
| Controls: 1605±427
| Male: ND
| Race: ND
| Enrolled: 103 (103 controls)
| Evaluated: 103 (103)
| Number of sites: 1
Brooks 2001 21153125 | Location: US | < 4 year old selected from randomized, systematic population based sample, weighted to be nationally representative of sampling of African-American and LBW infants who had initial (1988) and follow-up (1991) surveys and asthma reports | ND | VLBW infants (<1500g), MLBW (1500–2499g); NBW (=2500) infants from NMIHS population (8071) | Prospective cohort
| Years of Birth: 1988 | | | | Follow-up 3 years
| Mean GA (range), wk: ND | | | | 1988-1991
| Mean BW (range), g: ND
| Male: ND
| Race: ND
| Enrolled: 8071
| Evaluated: 8071
| Number of sites: 1
Doyle 2001 21064379 | Location: Australia | Sample 1: 86 consecutive ELBW survivors (BW 500–999g) born during the 63 months from 1/1/1977 | ND | Sample 1: Preterm ELBW infants, BW 500–999g (78) | Prospective cohort (14 years)
*overlapped sample with Ford, 2000 20380862 in growth table | Years of Birth: 1/1977 to 3/1982 | Sample 2: 124 consecutive ELBW survivors (BW 1000–1500g) born during the 18 months from 1/10/1980 | | Sample 2: Preterm ELBW infants, BW 1000–1500g (102)
| Mean GA (range), wk: | Control: 60 randomly selected term infants with BW>2499g born within the Royal Women's Hospital during the last 6 months of the recruitment phase | | Control: Term infants, BW >2499g (42)
| Sample 1: 27.5±2.3
| Sample 2: 29.6±1.5
| Controls: 39.9±1.0
| Mean BW (range), g:
| Sample 1: 859±100
| Sample 2: 1248±145
| Controls: 3420±427
| Male:
| Sample 1: 45%
| Sample 2: 54%
| Controls: 62%
| Race: ND
| Enrolled: 210 (60 controls)
| Evaluated: 180 (42 controls)
| Number of sites: 1

Evidence Table 9. Studies Evaluating Association of LBW and Pulmonary Outcomes Part II

Author, Year | Predictors | Predictor Measures | Outcomes | Outcome Measures
Als 1994 94358983 | Other: Participation in individualized developmental care staffing by specially educated nurses | The psychologist and clinical nurse specialist provided ongoing support for the care teams and parents of the infants in the experimental group in jointly planning and implementing individually supportive care and environments. | CNS: | Baley Scale of Infant Development at 9 months of age
| | | Neurodevelopmental: | Assessed by double-blind review of cranial US scans by a consultant senior radiologist
| | | Cognitive delay
| | | Pulmonary:
| | | BPD severity
Chye 1995 95314864 | Bronchopulmonary dysplasia | Diagnoses of BPD was based on Bancalari's BPD definition | Growth | Growth was based on sex-specific National Center of Health Statistics growth chart
| BPD with Home O_2_ | Home oxygen therapy program — infants who were well, feeding satisfactorily and gaining weight, but were unable to maintain adequate oxygenation (93–97% saturation) in room air, and were therefore discharged from hospital under the home oxygen therapy | Re-hospitalization
| BPD without Home O_2_
Kraybill 1995 95264242 | General: | As soon as after birth, infants were treated either with 5 ml/kg of surfactant or air placebo, via ET tube. | At 1 yr assessment (NCMH and HCHD cohort): | No further specifications given, except for the followings:
| Surfactant (single dose 5 ml/kg given via ET tube at birth) | | General: | Oxygen via Nasal canula : providing alveolar O2 concentrations of : 26%–40%, based on NC flow and NC O2 concentration
| | | Overall survival | Bayley Scale of Infant Development:
| | | Pulmonary: | • MDI= Mental Development Index Score
| | | Need for O2 via Nasal canula | • PDI: Psychomotor Development Index Score
| | | Need for O2 via CPAP | ROP : (not further definitions)
| | | CLD | • No ROP,
| | | At 2 yr assessment (NCMH cohort) | • Mild/moderate
| | | General: | • Severe
| | | Overall survival | CP (no further definitions)
| | | Hospitalization for respiratory illness | • Mild
| | | Pulmonary: | • Moderate/Severe
| | | Bronchodilator regular use | Severity of impairments:
| | | Tracheostomy | • Severe
| | | At 1 and 2 yr assessment: | • Mild/Moderate
| | | Growth: | Types of impairments:
| | | Height for age | • MDI<69
| | | Weight for age | • MDI: 69–84
| | | HC for age | • Moderate/severe CP
| | | Mean MDI score | • Mild CP
| | | MDI scores < 2 SDs | • Bilateral sensorineural deafness
| | | Mean PSI score | • Deafness not requiring amplification
| | | PDI scores < 2 SDs | • Bilateral blindness
| | | Severity of impairments | • Visual defect
| | | Types of Impairments | (1 yr and 2 yr CA)
| | | Any surgery (between 28 ds–1 yr or 1yr to 2 yr)
| | | Assessment between 28 ds–12mo:
| | | Ophthalmology:
| | | ROP (No ROP, Mild/moderate, Severe)
| | | Tx for ROP( surgery or cryotherapy)
| | | ROP presence at latest exam
| | | Severe ROP
Santuz 1995 96023205 | General Predictor: GA | Chronic Lung Disease defined as oxygen dependency for at least 28 days and beyond 36 postmenstrual weeks in association with an abnormal chest radiograph. | Other Outcomes: | Measured as AT/RVET ratio = Doppler derived acceleration time to right ventricular ejection time ratio
| Cardiovascular | | Cardiovascular: pulmonary hypertension
| 1) Chronic Lung Diseases
| 2) Other: duration of supplemental oxygen
Iles 1997 97280982 | Cardiovascular or Pulmonary Predictors: | DaAO_2_ in 50% O_2_ | Pulmonary: | ND
| Bronchopulmonary dysplasia | PaCO_2_ | Requirement for supplemental O_2_ at one year CA; alternately phrased by authors as SaO_2_ < 90% in RA
| Other Predictors: | PFT testing to determining V_max_ FRC | Other outcomes: Hospital readmission
| ECG with RVH
Cheung 1998 99059896 | Cardiovascular or Pulmonary Predictors: | ND | Pulmonary: | PDI + MDI of Bayley Scales of Infant Developmental Index were used.
| Inhaled nitric oxide (INO) | | BPD or CLD (with or without meds) | “Neurodevelopmental” outcomes:
| | | Aspiration pneumonia | Disability: one of more of:
| | | | 1) CP (all types or severity)
| | | | 2) Legal blindness (corrected visual acuity of the better eye <20/200
| | | | 3) Hearing loss (sensorineural hearing loss of >30 dB in the better ear)
| | | | 4) Severe mental retardation (MDI >3 SD below the mean)
| | | | Delay: does not have disability and either MDI or PDI was >2 SD below the mean.
| | | | Normal: free of disability or delay and MDI and PDI were within 2 SD of the mean.
Gregoire 1998 95264241 | Cardiovascular/Pulmonary: | ND | CNS: | Giffith's Mental Development Scales
| 1) Chronic Lung Disease | | Cerebral palsy | Neurologic examinations
| 2) Bronchopulmonary dysplasia | | Motor and cognitive delay
| Compared O_2_ dependence at 28 days with O_2_ dependence at 36 wk | | Audiology: Hearing Disorders→
| | | Free field audiograms
| | | Pulmonary:
| | | Respiratory readmissions
| | | PICU admission
| | | Growth: Weight, height, head circumference
| | | Other: Health Outcomes
Gross 1998 98375435 | General: GA | PT 247ndash;31 wk GA | Pulmonary: | Lung function testing was performed on SensorMedics 2200 (SensorMedics, Anaheim, Calif) by investigators blinded to children's GA and medical histories
| Cardiovascular: | BPD if infants were dependent on supplemental oxygen @ 35 wk PMA | Respiratory symptoms (wheeze, chronic cough, chest congestion)
| Bronchopulmonary dysplasia @ 30 wk | | Restriction in activity, Use of respiratory medicines, 7-year pulmonary function studies
| Other: social data, health data | | Bronchodilator responsivness
| | | Other:
| | | Re-hospitalization
| | | Metabolic measures
Kurkinen-Raty 1998 98197235 | General : PROM | Diagnose was through clinical assessment or with the use of a PROM-test, which detects insulin growth factor binding protein-1 in the cervico-vaginal secretions, or with the use of a nitrazine test. | CNS: | Neurologic exams
| | | Motor delay | Diagnosis of CLD was made if infants required oxygen, continuous bronchodilator, or steroid tx because of respiratory signs and symptoms.
| | | cerebral delay | Diagnoses of RDS were made based on need for respiratory support, radiologic findings, and clinical assessments
| | | Ophthalmology: Visual Blindness
| | | Audiology: Hearing disorders
| | | Pulmonary: Chronic lung disease
| | | Growth: weight percent
| | | Other:
| | | Days of re-hospitalization
| | | Steroid therapy at follow-up
Subhedar 1999 20257096 | Cardiovascular/Pulmonary: | CLD was defined as oxygen dependency for at least 28 days and beyond 36 PMA in association with an abnormal chest radiograph | Pulmonary: | Measures OR aerobic power: a) maximum O2 consumption b) max O2 consumption at anaerobic threshold C) running time
| Chronic lung disease | | 1) Pulmonary function-forced vital capacity
| | | 2) Minor ventilation forced expiratory volume, forced expiratory flow
| | | Other: Heat rate during exercise
Kurkinen-Raty 2000 20284814 | General predictors: | BPD diagnoses were based on radiologic finding | CNS: | Motor delay = abnormalities of tone or reflexes but functionally normal or borderline
| Birth weight | | Motor delay | CP = spastic diplegia or hemiplegia or spastictetraplegia
| GA | | Cerebral palsy | Diagnosis of CLD was made if infants required oxygen, continuous bronchodilator, or steroid tx because of respiratory signs and symptoms.
| Antenatal steroids | | Ophthalmology
| Cord pH | | Visual impairment
| Bronchopulmonary dysphasia (BPD) | | Audiology
| Other predictors: | | Hearing disorder
| Indicated preterm delivery | | Pulmonary
| Spontaneous preterm delivery | | Chronic lung disease (CLD) at 1 year
| | | Growth:Wt, Ht, HC
Brooks 2001 21153125 | General: | Predictors self-explanatory. Poverty variable based on family income and number of household members, categorized by standard national poverty levels. | Pulmonary:M.D. diagnosed asthma in 1^st^ 3 years of life | Diagnosis of asthma based on response of parent to question, “Have you been told by a MD/ RN/other health provider that your child has asthma?”
| Birth weight
| Sex
| Other:
| SEC factors (mat age, race, education, SEC status, mat wt gain, mat smoking, poverty status variable)
| Prenatal history
| Developmental outcomes
Doyle 2001 21064379 | General: Birth weight | ND | Pulmonary: | Lung function testing, Jaeger
*overlapped sample with 20380862 | Cardiovascular/Pulmonary: Bronchopulmonary | | 1) Asthma | Bodyscreen II-Bodybox (Jaeger, Germany), with Masterlab (ML3) software
| | | 2) Lung function testing
| | | 3) readmission to hospital for asthma or pneumonia
| | | Growth: height
| | | Other: hospital readmission

Evidence Table 9. Studies Evaluating Association of LBW and Pulmonary Outcomes Part III

Author, Year | Associations found | | | | Potential Biases | Comments
Als 1994 94358983 | Studied effect of an individualized developmental care plan on Bayley score at 9 months age and occurrence and severity of BPD. | | | | Small number of babies studied | Study was government funded
| | Experimental group | Controls | P value | Only one NICU
| N | 20 | 18 | | Only one neurodevelopmental assessment at 9 months of age
| Bayley MDI | 118.30 (17.35) | 94.38 (23.31) | < 0.001 | Reported timing of IVH different from many other studies
| Bayley PDI | 100.6 (20.19) | 83.56 (17.97) | < 0.01 | High potential for contamination
| No BPD | 2/20 | 3/18
| Mild BPD | 13/20 | 7/18
| Moderate BPD | 5/20 | 2/18
| Severe BPD | 0 | 6/18 | 0.03
Chye 1995 95314864 | Rehospitalization rate (overall) | | | | (None) | Study was privately funded
| BPD (78) | 58%
| Control (75) | 35% | RR 1.7 (1.2–2.4)
| Rehospitalization for respiratory illness
| BPD (78) | 39%
| Control (75) | 20% | RR 1.9 (1.1– 3.2)
| Rehospitalization for poor growth
| BPD (78) | 14%
| Control (75) | 1% | RR=1.4 (1.7–82)
| Rehospitalization for failure to thrive
| BPD on home O_2_ (20) | 30%
| Control no home O_2_ (58) | 9% | RR=3.3 (1.2–8.9)
| Growth (wt in kg) : NS diff between BPD and control
| BPD | M 9.08 | F 8.4
| Control | M 9.37 | F 8.82
| Growth (Ht in cm): NS diff
| BPD | M 73.0 | F 72.1
| Control | M 74.4 | F 72.6
| Growth (HC in cm): NS diff
| BPD | M 46.7 | F 46.0
| Control | M 47.0 | F 454.
| There was a significant increase in any rehospitalization in 1^st^ year of life in preterm infants with BPD vs. preterm infants with no BPD.
| There was a significant increase (2-fold) in rehospitalization for respiratory illness in the 1^st^ year of life in preterm infants with BPD vs. preterm infants with no BPD.
| BPD infants with Home O2 (N=20) had ~3 fold increased re-hospitalization for failure to thrive.
| Growth failure was common in both preterm groups (i.e. in infants with no BPD and with BPD <10% in weight at 1 yr age). Re-hospitalization was high in both preterm groups (with and without BPD).
Kraybill 1995 95264242 | Single dose Surfactant tx at birth was not associated with the physical and neurodevelopmental status of VLBW premature infants at 1 yr of corrected age Placebo group vs Surfactant group, at 1 yr of age:
| 1. Overall survival at 1 yr:
| 2. Oxygen via NC
| 3. Oxygen via CPAP:
| 4. CLD
| 5. Distribution of pts in both groups across different percentiles:
| Ht/age, Weight/age and HC/age: were not s/s different across the two groups.
| 6. Mean MDI score:
| 7. MDI scores< 2SDs
| 8. Mean PDI score:
| 9. PDI scores < 2 SDs:
| 10. No impairment:
| 11. Impairment present (total )
| 12. Severe impairment:
| 13. Mild/Moderate impairment:
| 14. Types of impairment:
| MDI<69: | | MDI: 69–84:
| Moderate/severe CP: | | Mild CP:
| Bilateral sensorineural deafness: | | Deafness not requiring amplification
| Bilateral blindness: | | Visual defect:
| Assessment from 28ds-12 mo:
| • No ROP:
| • Present ROP overall:
| • Mild/Moderate ROP:
| • Severe ROP:
| • Treatment for ROP overall:
| Surgery:
| Cryotherapy:
| In the NCMH cohort there was no difference in impairments, the severity of impairments and the types of impairments at the 1yr of age assessment
Santuz 1995 96023205 | Forced vital capacity (FVC): | | | | Small study | No data on funding source
| BPD: (N=12) | 87±10 | | | Far from comprehensive; likely substantial section bias
| Without BPD: (N=16) | 96±8 | | | Compares prematures with BPD to term infants without BPO; unclear if results are due to BPD or prematurity
| <0.05
| Forced expiratory volume(1 sec)(FEV1):
| BPD: | 83±12
| Without BPD: | 100±8
| <0.01
| FEF 25–75 (forced expiratory flow between 15–7520 vc):
| BPD: | 77±30
| Without BPD: | 110±14
| <0.01
| Oxygen consumption (ml/?/?):
| BPD: | 25.2±10.3
| Without BPD: | 37.1±10.4
| <0.01
| Running time (minutes):
| BPD: | 6.1±1.3
| Without BPD: | 7.9±2.6
| <0.05
| Minute ventilation:
| BPD: | 20±9.4
| Without BPD: | 30.7±9
| <0.01
| Max heat rate during exercise:
| BPD: | 192±7.9
| Without BPD: | 194±8
| Not significant
| Running time:
| BPD: | 6.1±1.3
| Without BPD: | 7.9±2.6
| P <0.05
Iles 1997 97280982 | Study of chronic lung disease (CLD) leading to a persistent requirement for supplemental oxygen at one year of age. | | | | Small number of infants | Study was privately funded
| | | N | % requiring oxygen at one year age | No information regarding early neonatal course
| Supplemental O2 at discharge | | 6 | 50% | No control groups of preterms without CLD
| RVH on ECG | | 3 | 100%
| Alveolar arterial oxygen gradient > 29 kPa in 50% hood oxygen at 35 to 40 weeks PCA predicted need for supplemental oxygen at one year with sensitivity 0.85 and specificity 0.88. PaCO2 greater than 7 kPa at 35 to 40 weeks PCA predicted supplemental oxygen requirement at one year with sensitivity 0.78 and specificity 0.88
Cheung 1998 99059896 | Mean MDI 81 ± 21, PDI 64 ± 22 | | | | Very small sample size | No data on funding source
| Normal development 31% | | | | Descriptive study with no control group for comparison
| Neurodevelopmental delay 20%
| Disabled 50%
| Severe mental retardation 10%
| Spastic diplegic CP 30%
| Hemiplegic CP 10%
| <3^rd^%ile for weight 20%
| <3^rd^%ile for height 40%
| <3^rd^%ile HC 30%
| BPD 80%
| Need bronchodilators for CLD 10%
| Recurrent wheezing but did not need meds 40%
| Grade 4 IVH 20%
| Grade 3 IVH 20%
| VP shunt 30%
| PVL 10%
| Sensorineural hearing loss 10%
Gross 1998 98375435 | Rehospitalization during 1st 2 years | | | | (None) | No data on funding source
| PT with BPD | 23/43 (53%)
| PT without BPD | 14/53 (26%)
| FT | 3/108 (3%)
| Respiratory symptoms in PT with BPD were greater than symptoms in PT without BPD, and both were greater than FT group
| Pulmonary function Tests: Multiple tests revealed significantly worse PFTs in PT with BPD at rest and after exercise compared to either PT without BPD or FT group.
| Exercise results:
| No difference in baseline HR, VO2, RQ, Max VO2, Max RQ, endurance among groups
| Asthma:
| PT with BPD | 20/43 (47%)
| PT without BPD | 13/53 (25%)
| FT | 23/108 (21%)
| PT with BPD vs. FT: P<0.001
| School age children who were former preterm infants with BPD demonstrated abnormal pulmonary function at 7 years age in contrast to school age children who were preterm infants without BPD or FT AGA control. The children who were preterm infants without BPD had similar pulmonary function as children who were FT AGA controls.
Kurkinen-Raty 1998 98387235 | Retrospective controlled cohort study of early PROM between 17 and 30 weeks of gestation. Assements at one year corrected age. N = 55 for early PROM and 56 for control. | | | | (None) | No data on funding source
| [underlined: Outcome] | [underlined: Early PROM] | [underlined: Control] | [underlined: OR (CI)]
| Cerebral palsy | 18% | 16% | 1.2 (0.4, 3.1)
| Delayed motor Development | 9% | 16% | 0.5 (0.2, 1.7)
| Visual disability | 4% | 4% | 1.0 (0.1, 7.5)
| Hearing loss | 7% | 9% | 0.8 (0.2, 3.2)
| Good nuerosensory development | 67% | 61% | 1.2 (0.6, 2.2)
| Early PROM seems to be a major obstetric and neonatal problem with pulmonary ramifications extending beyond the neonatal period. However, most of these infants can be saved
Subhedar 1999 20257096 | AT/RVET ratio much lower in CLD group p< 0.01. | | | | Does not state whether the Doppler evaluators were blinded to the groups | Study was private funded
| Pulmonary arterial pressure remains persistently elevated in CLD infants until the end of first year of life.
Kurkinen-Raty 2000 20284814 | CLD at 1 year age: | | | | Outcome not well-defined | No data on funding source
| Indicated PT delivery: (81) | | 12/81 (15%) | | Difficult to know if lack of difference between groups is due to sample size or event rate.
| Spontaneous PT delivery: (94) | | 3/94 (3%)
| RR 4.6 (1.4, 1.6)
| Growth:
| Indicated PT delivery: (81)
| Spontaneous PT delivery: (94)
| Weight | RR =0.03 (-5.3, 0.3)
| L | RR = 0.002
| HC | RR = 0.03
| CP:
| Indicated PT delivery: (81) | | 5/81 (6%)
| Spontaneous PT delivery: (94) | | 10/94 (11%)
| RR=0.6 (0.25–1.6)
| Delayed motor:
| Indicated PT delivery: (81) | | 8/81 (6%)
| Spontaneous PT delivery: (94) | | 8/94 (9%)
| RR 1.2 (0.5–3.0)
| Visual disability:
| Indicated PT delivery: (81)
| Spontaneous PT delivery: (94)
| RR =1.9 (0.5, 7.8)
| Hearing loss:
| Indicated PT delivery: (81)
| Spontaneous PT delivery: (94)
| RR =1.9 (0.5, 7.8)
| This study demonstrated that premature infants who were born due to ‘indicated maternal/fetal reasons’ vs. spontaneous preterm delivered infants had worse pulmonary outcome a 1 yr age. More infants in ‘indicated’ group were SGA and were significantly smaller than control group at 1 yr in Wt, HT, and HC. There was no difference between groups in neurosensory outcomes
Brooks 2001 21153125 | Diagnosis asthma by age 3 years | | | | Retrospective classification of BPD may have been limited compared to prospective classification. | Study was government funded
| BW ≥ 2500 gm 6.7% | | | | Potential for selection bias | Objective of study was to estimate the independent contribution of BW to asthma prevalence among children <4 years age. This study found a strong, independent association between low birth weight and asthma.
| BW≥1500–2499gm 10.9% OR=1.4 (1.1–1.8) | | | | a. identifying asthma children based on parental report of physician-diagnosed asthma. (Evidence of high specificity and PPV)
| BW < 1500 (VLBW) 21.9% OR=2.9 (2.3–3.6) | | | | b. defining asthma may vary by physician practice
| African-American 12% OR=1.9 (1.6–2.4)
| VLBW/African-American OR 2.5 (2.0–3.3)
| VLBW/white OR=3.1 9 ( 2.2–4.3)
| Chronic lung disease (8058) 20.4% OR 3.4 (2.4–4.8)
| 68% attributable risk for asthma in VLBW children was due to birth weight.
Doyle 2001 216464379 | Respiratory health and lung function in these preterm children <1501g were mostly normal and comparable with normal control term infants at 14 years | | | | (None) | Study was privately funded
*overlapped sample with 20380862

Evidence Table 10. Studies Evaluating Association of LBW and Bone and Growth Outcomes Part I

Author, Year UI# | Demographics | Inclusion Criteria | Exclusion Criteria | Disease/Condition Type (N) | Study Design (Duration)
Forslund 1992 93044002 | Location: Sweden | ND | ND | Cases: Preterms (41) | Unclear (the study design was described in detail in previous papers)
| Years of Birth: ND | | | Controls: Term infants (24)
| Median GA (range), wk: ND
| Mean BW (range), g: ND
| Male: ND
| Race: ND
| Enrolled: ND
| Evaluated: 41 (24 controls)
| Number of sites: ND
Chye 1995 95314864 | Location: Australia | Cases: 26–33 week GA infants with BPD and discharged home | Cases: Trisomy 21 (2) | Cases: Preterm infants with BDP (78) | Case-control study
| Years of Birth: 1989 to 1990 | Controls: 26–32 week GA infants without BPD admitted to the hospital within 1 year of the cases, matched for BW with the cases in broad categories (<1000 g, 1000–1499 g and =1500 g) | | Sample 2: Preterm infants without BPD (78)
| Mean GA (range), wk: | | | Subgroups of cases at 12 months corrected age follow-up:
| Cases: 28±1.58 | | | Sample 1: BPD no Home O_2_ (58)
| Controls: 28.63±1.26 | | | Sample 2: BPD with Home O_2_ (20)
| Mean BW (range), g:
| Cases: 1055±234
| Controls: 1077±215
| Male: 56%
| Race: ND
| Enrolled: 80
| Evaluated: 78 (78 controls)
| Number of sites: 1
DeReignier 1997 98041177 | Location: Netherlands | VLBW infants , BW < 1500 g, survived until discharge | Condition independent of CLD known to adversely affect neurosensory status, development, growth; significant congenital anomalies; congenital viral infections; SGA; NEC requiring enterostomy | Matched VLBW infants (89): | Retrospective cohort (followed until 1 year adjusted age)
| Years of Birth: 1/1/1987-12/31-1991 | Matched sever CLD and no CLD infants to mild CLD infants for BW, race, and sex. | | No CLD (58)
| Median GA (range), wk: 27.5 | | | Mild CLD (58)
| Mean BW (range), g: 1015 | | | Severe CLD (58)
| Male: 48%
| Race: 38% Black
| Enrolled: 678
| Evaluated: 174
| Number of sites: 1
Gosch 1997 97379896 | Location: US | Participants in a early intervention and family care for blind infants and preschoolers | ND | Cases: Blind children born preterm (5) | Retrospective cohort (24, 36, 48, and 58 months)
| Years of Birth: 1989 to 1994 | Blind children | | Controls: Blind children born full term (5)
| Mean GA (range), wk:
| Cases: 27.6 (26–29)
| Controls: 39 (36–40)
| Mean BW (range), g:
| Cases: 880
| Controls: 3466
| Male: 50%
| Race: ND
| Enrolled: 5 (5 controls)
| Evaluated: 5 (5)
| Number of sites: 1
Ladd 1998 98357452 | Location: US | 249 babies with NEC who had their initial surgical care at the James Whitcomb Riley Hospital for Children Indiana University Medical Center campus, with the diagnosis of NEC from 1/1/1908–12/31/1995 were included in the study | Infants with focal, isolated perforations of the ileum were excluded | Infants with NEC (249) | Retrospective cohort (16 years)
| Years of Birth: 1980-1995
| Mean GA (range), wk: 30 (23–42)
| Mean BW (range), g: 1500 (272–4840)
| Male: 53%
| Race: ND
| Enrolled: 249
| Evaluated: 249
| Number of sites: 1
Wang 1998 98244087 | Location: Canada | VLBW infants, BW<1250g, survived to NICU D/C | Missing more than one measurement | VLBW infants (514) | Prospective cohort (36 months)
| Years of Birth: 1/1977 to 5/1992
| Mean GA (range), wk: 27.7±2.3
| Mean BW (range), g: 954.6±185.9
| Male: 48%
| Race: Caucasian 88.5%
| SES: low SES category (Blishen index=40) 47.2%
| Enrolled: 1007
| Evaluated: 514
| Number of sites: 1
Connors 1999 99250892 | Location: Australia | ELBW survived infants, BW <1000 g | Died by 2 years corrected age (1) | ELBW infants (198): | Prospective cohort (2 year CA)
| Years of Birth: 1/1987 to 12/1992 | | Lost to follow-up (12) | Sample 1: ELBW with low perinatal risk factors (128)
| Mean GA (range), wk: 27±2.2 | | Transferred interstate and limited information was available (4) | Sample 2: ELBW with high perinatal risk factors (70)
| Mean BW (range), g: 822.8±125
| Male: 45%
| Race: ND
| Enrolled: 226
| Evaluated: 198
| Number of sites: 1
French 1999 99115141 | Location: Australia | Singleton live-born infants GA <33 weeks | ND | Sample 1: Antenatal steroids × 0 course (311) | Prospective cohort (3 years)
(CNS + Growth+All) | Years of Birth: 1990-1992 | | | Sample 2: Antenatal steroids × 1 course (123)
| Median GA (range), wk: | | | Sample 3: Antenatal steroids × 2 courses (20)
| Sample 1: 30 (26–32) | | | Sample 4: Antenatal steroids × > 3 courses (23)
| Sample 2: 29 (27–31)
| Sample 3: 30 (28.5–31.5)
| Sample 4: 31 (29–32)
| Mean BW (range), g:
| Sample 1: 1435 (905–1810)
| Sample 2: 1345 (1000–1735)
| Sample 3: 1517.5 (1210–1660)
| Sample 4: 1455 (1080–1715)
| Male: total 57%
| Race: ND
| Enrolled: 652
| Evaluated: 477
| Number of sites: 1
Ford 2000 20380862 | Location: Australia | Cases: Preterm ELBW infants (<1500g) who survived to discharge | Children with CP at age 14 years | At 14-year follow-up: | Prospective cohort (14 years)
*overlapped sample with Doyle, 2001 21064379 in Lung table | Years of Birth: 1/1977 to 3/1982 | Control: Full term NBW (BW>2499g) infants group who survived to discharge | Lost to follow-up | Cases (Sample 1&2): Preterm ELBW infants (179)
| Mean GA (range), wk: | | | Sample 1: Preterm infants, BW<1000g (79)
| Sample 1: 27.5±2.3 | | | Sample 2: Preterm infants, BW 1000–1499g (100)
| Sample 2: 29.6±1.5 | | | Control: Full term NBW infants (42)
| Controls: 39.9±1.0
| Mean BW (range), g:
| Sample 1: 859±100
| Sample 2: 1248±145
| Controls: 3420±427
| Male: 56%
| Race: ND
| Enrolled: 206 (60 controls)
| Evaluated: 179 (42 controls)
| Number of sites: 1
Morley 2000 20167446 | Location:UK | Premature | ND | GroupA: | Two Randomized clinical trials
| Centers:5 | BW< 1850 g | | Prematures/ fed banked breast milk until weight 2000 g or discharge from the NICU | Trial 1 and 2, with 2 parallel arms in each trial
| Enrollment period: ND | Survivors of participants in the two RCTs with 2 parallel arms each ( assessing effect of different neonatal diets of growth) | | N=207 | (The results for each trial are presented for the combination of the 2 parallel arms)
| Age at assessement:7.5–8 yrs | Age 7.5–8 yrs | | Mean BW: 1397±297
| Trial 1: conducted in 3 centers | | | Mean GA:31.1
| Total enrolled in trial 1 and 2: N=926 infants with BW< 1850 g | | | % of SGA:30%
| Long term f/up at 7.5–8 yrs of age: N=781 of 833 (94%) survivors | | | Males: 53%
| | | | Group B: | Trial 1 had : Follow up
| | | | Prematures/ preterm formula | At 9 mo
| | | | N=213 | At 18 mo
| | | | Mean BW:1387±278 | At 7.5–8 yrs
| | | | Mean GA:31
| | | | % of SGAs:35%
| | | | Males:52%
| | | | (both groups included 2 parallel arms with or without supplementation with mother's own milk )
Avila-Diaz 2001 21334039 | Location: Mexico | Informed consent | ND | Sample 1: Full term infants (48) | Prospective cohort (6 months)
| Years of Birth: ND | 48 full-term “healthy” infants and 34 pre-term infants who were predominantly breast-fed | | Sample 2: Preterm infants (34)
| Mean GA (range), wk:
| Sample 1: 39±0.9
| Sample 2: 30±2.6
| Mean BW (range), g:
| Sample 1: 3195±323
| Sample 2: 1294±167
| Male: 51%
| Race: ND
| Enrolled: 82
| Evaluated: 82
| Number of sites: 1

Evidence Table 10. Studeies Evaluating Association of LBW and Bone and Growth Outcomes Part II

Author, Year | Predictors | Predictor Measures | Outcomes | Outcome Measures
Forslund 1992 93044002 | General: GA | Not given, resulted from previous papers of study with same group | CNS: | Motor performance was tested by a physiotherapist: used TMI (test of motor impairment)
| | | Neurodevelopmental | Measurement of height
| | | Motor delay | Weight and head circumference by an experienced RN.
| | | Growth in height, weight and head circumference
Chye 1995 95314864 | Bronchopulmonary dysplasia | Diagnoses of BPD was based on Bancalari' BPD definition | Growth | Growth was based on sex-specific National Center of Health Statistics growth chart
| BPD with Home O_2_ | Home oxygen therapy program -infants who were well, feeding satisfactorily and gaining weight, but were unable to maintain adequate oxygenation (93–97% saturation) in room air, and were therefore discharged from hospital under the home oxygen therapy | Re-hospitalization
| BPD without Home O_2_
DeReignier 1997 98041177 | General: GA | No CLD- room air at 28 days | CNS: | Motor and cognitive delay: corrected MDI or PDI scores were >2SD below mean (ie correct score <68)
| Cardiovascular/Pulmonary: Chronic lung disease | Mild CLD- requiring 02 at 28 days but not at 36 wks PCA. | Motor delay | Mental retardation
| Gastrointestinal: Necrotizing “enterocolitis” | Severe CLD- requiring 02 at 28 days and 36 wks PCA | Cerebral palsy | Growth: Weight, Length, Head circumference
| Other: Osteomalcia = Socioeconomic status | Not included in CLD if 02 used only for prevention of apnea | Cognitive delay | Development: Pediatrician & physical therapist agreed on presence of definitely abnormal position & posture from impaired neuromotor function
| | | Mental retardation | Hospital readmission in 1^st^ year
| | | Growth:
| | | Weight
| | | Height
| | | Head circumference
| | | Other: Hospital readmissions
Gosch 1997 97379896 | Ophthalmology | Self-explanatory | CNS: | The scales of BDTB including numbers of items and maximum scores listed on table 1
| 1) Other: Blind ELBW | | Other: BDTB (Bielefeld developmental test for blind infants and pre-schoolers at age 18–48 months)
| 2) Other: blind Term (term control) | | Growth:
| Other Predictors | | Weight
| 1) Nutrition/Growth-lead circumference(cm) | | Height
| 2) Other: days spent in hospital after delivery | | Head circumference
| | | Body mass index
Ladd 1998 98357452 | Gastrointestinal: | ND | Growth predictors: growth | ND
| 1) Short gut
| 2) Necrotizing “enterocolitis”
| 3) Presence of ileocecal valve
| 4) Length of bowel reserve
Wang 1998 98244087 | BW | VLBW = 1250 g | Growth | At the specified age and reference
| | | Weight
| | | Height
Connors 1999 99250892 | Birth weight (i.e.ELBW=BW <1 kg) | High perinatal risk: PVH>Grade 2 + ventriculomegaly, NEC, Home O2. | CNS: CP | Neurodevelopmental outcome assessed by Griffith's Developmental Scales, Motor outcome assessed by Neurosensory Motor Developmental Assessment [NMDA].
| | Low perinatal risk: none of the above risk factors
| Postnatal Nutrition Growth: <3%tile, 3–9%tile,≤10%tile) | | Other adverse neurodevelopmental outcome
| | | Neurological Exam
French 1999 99115141 | Other: Number of courses of antenatal steroids | ND | CNS: | ND
(CNS + Growth+All) | | | Neurodevelopmental
| | | CP | Weight, height, or HC compared to national standard
| | | Growth:
| | | Weight ratio | “Any disability” = cerebral palsy, IQ< 85, deafness, or visual acuity worse than 6/60
| | | Height ratio
| | | Head circumference ratio
| | | Disability
Ford 2000 20380862 | Birth weight | VLBW < 1500g (<1kg and 1–1.5 kg) vs Normal BW (>2.4 kg) | Growth outcome: | Growth scores and variables
*overlapped sample with Doyle, 2001 | | | Height
21064379 in Lung table | | | Weight
| | | Head circumference
| | | Pubertal development
Morley 2000 20167446 | Trial 1: | Not further specified | Trial 1: | Not further specified
| Type of diet in early neonatal period: | | Growth:
| • Banked donor breast milk vs Preterm formula (with or without supplementation with its mother's milk) | | Assessment at 9 and 18 months post-term:
| Trial 2: | | • Weight (kg)
| • Preterm formula vs term formula (with or without supplementation with mother's milk) | | • Length (cm)
| | | • HC
| | | • Subscapular skinfold thickness
| | | • Body mass index
| | | Assessment at 7.5 -8 yrs:
| | | • All of the above
| | | • Also weight to hip ratio
| | | Trial 2:
| | | • Growth at 18 mo
| | | • Growth at 7.5–8 yrs
Avila-Diaz 2001 21334039 | General predictors: | ND | Other outcomes: | BMC was measured monthly for full-term infants during the first 5 months of extrauterine life and bimonthly for pre-term infants during the first 6 months of extrauterine life
| 1) birth weight | | 1) bone mineral contents (BMC)
| 2) preterm vs. full-term | | 2) bone area
| | | 3) changes in bone mineral content over time

Evidence Table 10. Studies Evaluating Associaton of LBW and Bone and Growth Outcomes Part III

Author, Year | Associations found | | | Potential Biases | Comments
Forslund 1992 93044002 | Growth and motor performance assessed in preterm children at 8 years of life. | | | A specific population in a certain are that has been studied before | Study was privately funded
| • Differences for mean values for weight, height and head circumference not significant | | | Lack of data regarding the population, stated birth weight significant but not listed anywhere | Cannot generalize, general lack of data
| • Relationship exists between findings in TMI (test of motor impairment at 4 and 8 years) suggests possibility of identifying motor problems before school age. | | | | The population studied and the study design have been described in detail in previous paper
Chye 1995 95314864 | Rehospitalization rate (overall) | | | (None) | Study was privately funded
| BPD (78) | 58%
| Control (75) | 35% | RR 1.7 (1.2–2.4)
| Rehospitalization for respiratory illness
| BPD (78) | 39%
| Control (75) | 20% | RR 1.9 (1.1–3.2)
| Rehospitalization for poor growth
| BPD (78) | 14%
| Control (75) | 1% | RR=1.4 (1.7–82)
| Rehospitalization for failure to thrive
| BPD on home O_2_ (20) | 30%
| Control no home O_2_ (58) | 9% | RR=3.3 (1.2–8.9)
| Growth (wt in kg): NS diff between BPD and control
| BPD | M 9.08 | F 8.4
| Control | M 9.37 | F 8.82
| Growth (Ht in cm): NS diff
| BPD | M 73.0 | F 72.1
| Control | M 74.4 | F 72.6
| Growth (HC in cm): NS diff
| BPD | M 46.7 | F 46.0
| Control | M 47.0 | F 454.
| There was a significant increase in any rehospitalization in 1^st^ year of life in preterm infants with BPD vs. preterm infants with no BPD.
| There was a significant increase (2-fold) in rehospitalization for respiratory illness in the 1^st^ year of life in preterm infants with BPD vs. preterm infants with no BPD.
| BPD infants with Home O2 (N=20) had ~3 fold increased re-hospitalization for failure to thrive.
| Growth failure was common in both preterm groups (i.e. in infants with no BPD and with BPD <10% in weight at 1 yr age). Re-hospitalization was high in both preterm groups (with and without BPD).
DeReignier 1997 98041177 | Sensorineural Hearing Loss: | | | (None) | No data on funding source
| CLD: No:0
| Mild:0
| Severe: 3 | P<0.05
| Low MDI (Bayley Scale):
| CLD: No: 0
| Mild:4
| Severe:5 | P<0.05
| Low PDI (Bayley Scale):
| CLD: No: 1
| Mild:4
| Severe:7 | P<0.05
| Cerebral Palsy
| No CLD vs Any CLD:
| Odds ratios: 6.4
| 95% CI: (1.05–139.8)
| Weight 2-Score:
| CLD: No: 2 score
| Severe: signify lower weight
| HC+ Length 2-Score:
| No, Mild, Severe: No significant difference
Gosch 1997 97379896 | Blind ELBW infants have developmental delay of 1.5 to 2 years that of term blind controls. | | | Extremely small number of subjects only 5, so statistics not reliable | No data on funding source
| At 48 mos, ELBW blind vs Term blind BDTB scores: Overall score: 169.4±62.4 vs 270.6±50.7, p <0.05 | | | Validity of BDTB scale still in question
| Neuromotor skills: not significant | | | Does not state whether the evaluators were blinded to the groups or whether they were the same throughout the length of study.
| Social maturity: 42±13.4, 67.4±10.1, p < 0.05
| Cognition: 16.8±22.5, 47.5±19.7, p< 0.05
| Linguistic abilities: 11.2±11.7, 29.2±12.5, p< 0.05
| Socioemotional behavior:33±9.6, 44.8±6.3, NS
| Orientation and mobility: 35.6±10.7, 50.8± 5.9, p< 0.05
| ELBW blind infants had significantly lower weight, height, head circumference and body-mass index than term blind infants.
Ladd 1998 98357452 | Death rate of children with NEC was 49% | | | Extraordinary poor study | No data on funding source
| 148 subjects with follow-up more than 2 years was evaluated for the impact of the ICV on severe growth retardation (<10 %tile) found that no association between length of bowel resected or status of the ICV, and sever growth retardation. | | | Populations at follow-up times not described or compared
| | | | Time of follow-up given only for 1 outcome
| | | | Massive Bias
| | | | Results not interpretable
Wang 1998 98244087 | More VLBW infants were classified as “subnormal growth” based on chronologic age vs. adjusted age through 36 months. The % of VLBW children with subnormal growth is therefore affected by adjustment for corrected age through 36 months and varies according to growth references (especially at younger ages 4–8 months). Regardless of adjusted or chronologic age or growth reference, the mean weight and mean height were significantly lower in VLBW (<1250 gm) than term infants at 4 through 36 months age. As infants approach 18 and 36 months age, the deviation from full term infants is less. | | | Large number of infants were not included in the analyses. They were slightly differed from the study sample in that they had higher BW and GA and less BPD and CP in follow-up | Study was privately funded
Connors 1999 99250892 | Weight percentile was strongly associated with lower general growth quotient and lower motor abilities in ELBW infants. | | | (None) | No data on funding source
| Low weight percentile at 2 year was related to adverse developmental outcome in ELBW infants at high perinatal risk or with neurological impairment.
| There was minimal association between postnatal low weight percentile and adverse neurodevelopmental outcome in ELBW infants who were at low perinatal risk and who had normal neurological exam.
| This study confirms strong association between low postnatal weight and adverse neurodevelopmental outcome. This association is stronger in infants with high perinatal risk factors and in infants with CNS impairment
French 1999 99115141 | No significant association between antenatal corticosteroids and cerebral palsy, weight ratio at 3 years (median, IQR), height ratio median (IQR), head circumference ratio (median, IQR), and any disability (number, %) | | | Differential loss to follow-up not assessed | No data on funding source
(CNS + Growth + All) | | | | Small number in severe group
Ford 2000 20380862 | Pubertal development was similar in VLBW and Normal BW infants. At all ages (2,5,8,14 yrs) the children who were VLBW were significantly smaller Wt/ Ht/ HC than normal BW children. | | | (None) | No data on funding source
| Differences in Ht/ Wt/ improved over time, between VLBW and NBW, but VLBW remained smaller than Normal BW.
*overlapped sample with Doyle, 2001 21064379 in Lung table
Morley 2000 20167446 | Trial 1 | Group A: Fed | Group B: Fed
| There was no association between the neonatal diet (banked donor milk vs preterm formula) and the 6 anthropometrics at any follow up point (9 mo, 18 mo and 7.5–8 yrs) | Banked donor milk (with or without supplementation with mother's milk) | preterm formula: (with or without supplementation with mothers' milk)
| (Growth at 9 mo) | N=195 | N=174
| (Growth at 18 months) | N=221 | N=217
| (Growth at 7.5–8 yrs) | N=206 | N=214
| Trial 2
| There was no association between neonatal diet (term vs preterm formula) and the Weight, Height, HC and skinfold thicknesses at any follow up point (18 mo and 7.5 yrs)
| Except for a significantly lower waist to hip ratio at 7.5 yrs in infants fed preterm vs term formula solely (without supplementation with mother's milk) (0.86 vs 0.89, p<0.001)
| (Growth at 18 mo) | N=168 | N=166
| (Growth at 7.5–8 yrs) | N=181 | N=178
Avila-Diaz 2001 21334039 | Study of bone mineral density using DEXA scan. Outcomes at 5 to 6 months; well preterms vs. fullterm. | | | Only “healthy” premature infants enrolled | Study was government funded
| Full term infants (n = 16) had significantly higher (P < 0.05) bone mineral content and bone area in comparison to preterm infants (n = 26). Preterm infants had a significantly higher rate of increase in bone mineral content per day than full term infants suggesting incomplete “catch-up”. | | | Short duration of follow-up - six months | A study of bone mineralization in preterm vs. full-terms.
| | | | Not clear that all preterms were VLBW | Not clear if all preterms were less than 1500 g.

Evidence Table 11. Randomized Controlled Trials in LBW Neonates for Growth Outcomes Part I

Author, Year UI# | Demographics | Inclusion Criteria | Exclusion Criteria | Disease/Condition Type (N) | Study Design (Duration)
Wauben 1998 98387708 | Location: Canada | BWT<1800 | ND | Sample 1: Milk + Fortifier (12) | Randomized controlled trial (3 and 6 months)
| Years of Birth: ND | AGA | | Sample 2: Milk + Calcium phosphorus (13)
| Mean GA (range), wk: | >1 week old | | Sample 3: Preterm formula-fed (12)
| Sample 1: 29.9±1.9 | Full feed 5×5d
| Sample 2: 30.1±1.5 | Established weight gain
| Sample 3: 29.7±1.7 | No GI disease
| Mean BW (range), g: | No long malformation
| Sample 1: 1400±200
| Sample 2: 1300±200
| Controls: 1200±200
| Male: ND
| Race: ND
| Enrolled: 37
| Evaluated: 37
| Number of sites: 1
Morley 2000 20167446 | Location: UK | Premature | Lost to follow-up | Trial 1: | RCT: Trial 1 and 2, with 2 parallel arms in each trial (at 9 months, 18 months, 7.5–8 years)
| Years of Birth: ND | BW< 1850 g | | Group A: Premature infants, breast-fed until weight 2000 g or discharge (207)
| Mean GA (range), wk: | Survivors of participants in the two RCTs with 2 parallel arms each ( assessing effect of different neonatal diets of growth) | | Group B: Premature infants, preterm formula-fed (213)
| Trial 1: | Age 7.5–8 yrs | | Trial 2:
| Group A: 31.1 | | | Group A: Premature infants, standard term formula-fed until weight 2000 g or discharge (181)
| Group B: 31 | | | Group B: Premature infants, premature formula-fed (213)
| Trial 2:
| Group A: 31
| Group B: 31.2
| Mean BW (range), g:
| Trial 1:
| Group A: 1397±297
| Group B: 1387±278
| Trial 2:
| Group A: 1399±301
| Group B: 1416±306
| Male:
| Trial 1:
| Group A: 53%
| Group B: 52%
| Trial 2:
| Group A: 47%
| Group B: 46%
| Race: ND
| Enrolled: 833
| Evaluated: 781
| Number of sites: 5

Evidence Table 11. Randomized Controlled Trials in LBW Neonates for Growth Outcomes Part II

Author, Year | Predictors | Predictor Measures | Outcomes | Outcome Measures
Wauben 1998 98387708 | Other: | ND | Growth: | ND
| Feedings: Breast, Milk+ multinutrient fortifier or breast milk + Ca + P supplement only, or preterm formula | | 1) Weight, length, head circumference
| | | 2) Body mass + body composition
Morley 2000 20167446 | Trial 1: | Not further specified | Trial 1: | Not further specified
| Type of diet in early neonatal period: | | Growth: Assessment at 9 and 18 months post-term: Weight (kg), Length (cm), HC, Subscapular skinfold thickness, Body mass index
| Banked donor breast milk vs Preterm formula (with or without supplementation with its mother's milk) | | Assessment at 7.5–8 yrs: All of the above, Also weight to hip ratio
| Trial 2: | | Trial 2:
| Preterm formula vs term formula (with or without supplementation with mother's milk) | | Growth at 18 mo
| | | Growth at 7.5–8 yrs

Evidence Table 11. Randomized Controlled Trials in LBW Neonates for Growth Outcomes Part III

Author, Year | Associations found | | | | Potential Biases | Comments
Wauben, 1998 | | MM+MNF | MM+CaCP | PTF | Used a “New multinutrient fortifier” design to their specifications. Generalizability? | Study was privately funded
| Term: | | | | No relation examined between feeding + neurodevelopment. Unclear that their findings have or had any potential for clinical significance.
| Weight (kg): | 3.3±0.3 | 3.2±0.4 | 3.5±0.4 | Small study-unlikely to find anything other than major differences
| Length (cm): | 49.6±1.3 | 48.4±1.8 | 49.4±2.3 | Post-discharge crossover between breast fed→formula fed, further dilutes effect or small #'s
| 12 months: | | | | No correction for multiple comparison, although it is desperately needed
| Weight (kg): | 9.0±0.9 | 9.0±0.9 | 9.6±1.4
| Length (cm): | 74.9±3.7 | 75.9±2.5 | 76.0±2.8
| Head circumference (cm) | 46.9±3.9 | 46.8±? | 6.8±2.0
| Whole body BMC (g) | 209.9±27.1 | 223.0±29.2 | 243.9±40.6
| Lean mass (%): | 74.0±5.0 | 73±4.7 | 73.8±5.6
| Fat mass (%): | 23.6±5.0 | 24.3±4.7 | 23.9±5.6
Morley, 2000 | Trial 1: There was no association between the neonatal diet (banked donor milk vs preterm formula ) and the 6 anthropometrics at any follow up point (9 mo, 18 mo and 7.5–8 yrs) | | | | (None) | ? Funding
| Trial 2: There was no association between neonatal diet (term vs preterm formula) and the Weight, Height, HC and skinfold thickness at any follow up point (18 mo and 7.5 yrs). Except for a significantly lower waist to hip ratio at 7.5 yrs in infants fed preterm vs term formula solely (without supplementation with mother's milk) (0.86 vs 0.89, p<0.001)

Evidence Table 12. Studies evaluating association of LBW and Nutritional Outcomes Part I

Author, Year UI# | Demographics | Inclusion Criteria | Exclusion Criteria | Disease/Condition Type (N) | Study Design (Duration)
Kennedy 1999 20076945 | Location: US | Single or twin birth BW less 2000g, follow-up at hospital clinic, completion of 3 screening visits. | ND | Preterm LBW infants (28) | Retrospective cohort (4, 9, 18 months)
| Years of Birth: Jan-Dec 1994
| Mean GA (range), wk: 31±2.6 (26–34)
Also in growth paper | Mean BW (range), g: 1534±371 (810–2000)
| Male: ND
| Race: White 93%
| Enrolled: 28
| Evaluated: 28
| Number of sites: 1

Evidence Table 12. Studies evaluating association of LBW and Nutritional Outcomes Part II

Author, Year | Predictors | Predictor Measures | Outcomes | Outcome Measures
Kennedy 1999 20076945 | General : BW | ND | Growth:
| Other: | | 1) weight and length | 1) Denver II Developmental Test
| 1) Nutrition/Growth | | 2) Head circumference | 2) “2”-Scroes
| 2) Discharge weight

Evidence Table 12. Studies evaluating association of LBW and Nutritional Outcomes Part III

Author, Year | Associations found | Potential Biases | Comments
Kennedy 1999 20076945 | NICU discharge weight:mean “z” score was-2.97+/- 0.53 below mean BW of term infants | Only 2 infants weighed less than 1kg | No data on funding source
| 18 months: mean growth in wt, hc&l:WNL | Lowest GA 26 weeks 26/28 were white
| Denver II:normal at 18 months

Evidence Table 13. Studies Evaluating Association of LBW and Other Outcomes Part I

Author, Year UI# | Demographics | Inclusion Criteria | Exclusion Criteria | Disease/Condition Type (N) | Study Design (Duration)
Saarela 1999 99345620 | Location: Finland | BW<1500 | Death | Sample 1: Preterm infants with nephrocalcinosis 26) | Prospective cohort (6 years)
| Years of Birth: 1990-1994 | GA<34 | Multiple congenital anomalies | Sample 2: Preterm infants without Nephrocalcinosis (103)
| Mean GA: | | Severe toxoplasmosis
| Sample 1: 21.2±2.1 | | Lack of repeat renal n/s
| Sample 2: 29.3±2.4
| Mean BW:
| Sample 1: 993±242
| Sample 2: 1174±238
| Male:
| Sample 1: 62%
| Sample 2: 54%
| Race: ND
| Enrolled: 174
| Evaluated: 129
| Number of sites: 1
Saarela 1999 20069000 | Location: Finland | Cases with nephrocalcinosis: | Urinary incontinence | Sample 1: | Prospective comparative longitudinal study
| Years of Birth: 1990-1994 | VLBW treated in the NICU of Oulu University Hospital | | Cases with Neonatal | [Follow up during early childhood (not specified but the mean age during f/up assessment was 4.6 yrs)
| Mean GA: | Born during 1990-1994 | | Nephrocalcinosis(20)
| Sample 1: 26.7 ±2 | Control cases: | | Sample 2:
| Sample 2: 27.2 ±2 | Matched to the cases | | Controls, matched control cases without neonatal nephrocalcinosis (20)
| Mean BW: | VLBW: nearest to the index cases in the hospital records
| Sample 1: 905 ±209 | Difference from case's BW less than 250 g
| Sample 2: 957 ±226 | Negative renal U/S during neonatal period for nephrocalcinosis
| Male: | Age difference during f/up renal examination less than 8 months from the index cases.
| Sample 1: 30%
| Sample 2: 50%
| Race: ND
| Enrolled : ND for total (enrolled cases: 29)
| Evaluated : 40
| Number of sites: 1
Slonim 2000 20214515 | Location: USA | Patients with prematurity (<37 wks) and either an anatomic defect (congenital heart disease, GI tract anatomic lesion, neurologic complications (e.g., spina bifida, pulmonary lesions e.g., pulmonary agenesis)) or a prematurity related complication (BPD, Hydrocephalus, IVH, Short gut syndrome, trecheostomy, birth asphyxia, cerebral palsy) | Patients admitted in PICU in continuous cardiopulmonary resuscitation. | Sample 1 | Cross sectional study
| Years of Birth: 1992-1994 | Admitted in any of the 16 participating in the study PICUs | Patients not reaching stable vital signs for > 2 hrs | Formerly premature patients admitted in PICU (FPP) (431) | (FPP were assessed at a mean age of 35 mo and formerly nonprematures were assessed at a mean age of 72 mo in the 2 groups respectively)
| Mean GA: | During period 12/1992–12/1994 | | Sample 2
| Sample 1: 1704.3 ±52.7 | | | Their complement formerly nonpremature admitted in PICU (5.319 )
| Sample 2: ND
| Mean BW:
| Sample 1: 30.9 ±0.2
| Sample 2: ND
| Male:
| Sample 1: 57%
| Sample 2: 58%
| Race: ND
| Enrolled: 5927
| Evaluated: 5750
| Number of sites: 16

Evidence Table 13. Studies Evaluating Association of LBW and Other Outcomes Part II

Author, Year | Predictors | Predictor Measure | Outcomes | Outcomes Measures
Saarela 1999 99345620 | General : | ND | Other: | Described natural resolution of nephrocalcinosis
| 1) BW | | Nephrocalcinosis
| 2) GA
| Audiology:
| 1) Furosemide
| Cardiovascular or Pulmonary:
| 1) Chronic Lung disease
| Other:
| 1) Dexamethasone
| 2) Furosemide use
Saarela 1999 20069000 | General: | Nephrocalcinosis defined by the presence of medullay echogenic densities in the renal tubular pyramids | General: | Tubular reabsorption of phospate and maximal tubular reabsorption of phosphate per glomerular filtration rate were calculated from the baseline urine and blood sample data. Creatinine clearance were calculated by the method described by Schwartz
| 1) Neonatal nephrocalcinosis in VLBW infants | | Renal function during early childhood (4–5 yrs)
| | | 1) Renal tubular function
| | | 2) Distal tubular acidification capacity
| | | 3) Renal glomerular function
| | | • Serum electrolytes
| | | • Venous blood pH, pCO2, Base excess, bicarbonates
| | | • Urine pH,
| | | • Urine??2-microglobulin
| | | • Ca/Cr
| | | • Ca/Na
| | | • Acetazolamide acidification test
| | | • Other variables:
| | | • Ccr (ml/min/1.73 m2)
| | | • FENa (%)
| | | • FEK (%)
| | | • Tubular reabsorption of Phosphate (TRP) (%)
| | | • Maximum tubular reabsorption of phosphate per glomerular filtration rate (TmP/GFR: mmol/l)
| | | 4) Kidney growth
| | | 5) Systolic blood pressure
Slonim 2000 20214515 | General: | Anatomic abnormalities: | General: | Chronic care resources utilization:
| 1. Prematurity with anatomic abnormalities and/or complications of prematurity (prematures vs nonprematures) | Congenital heart disease | 1) Characteristics of utilization of chronic care resources, PICU resources and characteristics of their PICU admissions: | Ventilator
| 2. GA (<26 wks vs 26–32 wks vs >32 wks) | Anatomical lesions of the GI tract | 2) Age of PICU admission | Tracheostomy
| | Neurologic abnormalities: such as spina bifida | 3) PICU readmissions during same hospitalization | Gastrostomy
| | Pulmonary lesions: such as pulmonary agenesis | 4) Chronic care resources utilization | Parental nutrition
| | Complications of prematurity: | 5) At least one chronic care resource used | Prior living conditions:
| | BPD | 6) Prior living conditions | Home
| | Birth asphyxia | 7) Discharge location | Institutions
| | Cerebral palsy | 8) PICU resource use | Never discharged
| | | 9) Length of stay in PICU (mean days) | Chronic hospital
| | | 10)PRISM-III score (mean) | Discharge location
| | | | Home
| | | | Routine care
| | | | Intermediate care
| | | | Another PICU
| | | | Chronic care
| | | | PICU resource use:
| | | | Ventilator
| | | | Vasopressors
| | | | Arterial catheter
| | | | Central venous catheter
| | | | PRISM-II scores: at first 24 hrs of PICU admission

Evidence Table 13. Studies Evaluating Association of LBW and Other Outcomes Part III

Author, Year | Associations found | | | | | Potential Biases | Comments
Saarela 1999 99345620 | Occurrence of nephrocalcinosis (NC) by birth weight | | | | | (None) | Study was privately funded
| BW group | n | % without NC | % with peripheral NC | % with extensive NC
| < 750g | 8 | 50% | 25% | 25%
| 751–999 | 36 | 65% | 20% | 15%
| 1000–1249 | 33 | 85% | 5% | 10%
| 1250–1499 | 52 | 90% | 7% | 3%
| Association of BW with NC sigificant at P< 0.001.
| NC was also significantly associated (p<0.001) with: Gestational age, Presence of RDS, Presence of BPD (O2 at 28 days), Presence of CLD (O2 at 36 weeks), Furosemide use, Dexamethasone use
Saarela 1999 20069000 | Predictors of renal outcome at age 4–5 yr
| 1) Neonatal nephrocalcinosis in VLBW children seems to lead to some signs of renal tubular dysfunction in early childhood.
| 2) However, distal tubular acidification, as measured by the actazolamide test
| 3) and glomerular function appears not to be specifically disturbed by nephrocalcinosis
| Renal function during early childhood (mean age: 4.6 yrs)
| Renal tubular function:
| • Urinary calcium /Cr and (p<0.004)
| • ?2-microglobulin/Cr excretion were higher in the children with nephrocalcinosis (p<0.05)
| • There was no difference in the fractional excretion of Na, K, or tubular reabsorption of phospate
| Distal Tubular Acidification capacity:
| • There was no difference in the distal tubular acidification capacity, as tested by the acetazolamide test : Abnormal response:
| Renal glomerular function:
| • Creatinine clearance was no different between the 2 groups
| There was no difference between the 2 groups in the following :
| • Serum electrolytes
| • Venous blood pH, pCO2, Base excess, bicarbonates
| • Urine pH,
| Kidney growth:
| • Kidney growth was impaired by more than 2 SD
| • There was no difference in the systolic blood pressure above 97.5 percentile
| • None of the children had hematuria
Slonim 2000 20214515 | Utilization of chronic care resources and PICU resources and characteristics of their PICU admissions of former prematures with a prematurity-related complication or an anatomical deformity [431] when compared to nonprematures [5319] was: | | | | | There is a strong selection bias in this study as the inclusion criteria used for the selection of the FPPs were strongly correlated with the outcomes studied (the presence of an anatomic abnormality (150/431) or a complication of prematurity (281/483) in FPPs is strongly Correlated with the utilization of chronic care resources) | Funding: Not Reported
| • PICU survivors: 90% vs 94% (p=0.008)
| • Age of PICU admission (mean): 35 mo vs 72 mo (p=0.01)
| • Postoperative care (%): 44% vs 40% (p=0.15)
| • Prior PICU admissions: 11% vs 5.5% (p=0.01)
| Chronic care resources utilization:
| • Ventilator: 7% vs 1% (p=0.001) Tracheostomy: 16% vs 2% (p=0.001)
| • Gastrostomy: 23% vs 4% (p=0.001)
| • Parental nutrition: 3% vs 0.6% (p=0.001)
| At least one chronic care resource used: 30% vs 5.6% , p=0.001
| Prior living conditions:
| • Home: 90% vs 97% (p=0.001) Institutions: 3% vs 1% (p=0.001)
| • Never discharged: 6.5% vs 2% (p=0.002)
| • Chronic hospital: 3% vs 1% (p=0.001)
| Discharge location
| • Home: 11% vs 6% (p=0.001) Routine care: 63% vs 77% (p=0.001)
| • Intermediate care: 15% vs 10% (p=0.03)
| • Another PICU: 1% vs 1.6% (p=0.52)
| • Chronic care: 1.6% vs 0.7% (p=0.02)
| PICU resource use:
| • Ventilator: 45% vs 35% (p=0.007)
| • Vasopressors: 15% vs 16% (p=0.12)
| • Arterial catheter: 28% vs 36% (p=0.006)
| • Central venous catheter: 17% vs 21% (p=0.03)
| Limits to care (%): 5.5% vs 4% (p=0.11)
| Length of stay in PICU (mean days): 5.98 ds vs 3.56 ds (p=0.01)
| PRISM-III score AT 24 HRS (mean): 4.90 vs 4.53 (p=0.80)
| Those born < 26 wks had a higher utilization of chronic care resources (ventilator, trachesostomy, gastrostomy) and chronic hospital care (p< 0.006) as compared to the other prematures.