# References and Bibliography

Miller, G. and Ramer, J. C. (ed.). Static encephalopathies of infancy and childhood. New York: Raven Press; 1992:372
Vermont-Oxford Neonatal Network: Vermont Neonatal Network 2000 Annual Report. 2000. Burlington, Vermont.
Postnatal corticosteroids and sensorineural outcome at 5 years of age. J Paediatr Child Health 2000 Jun;36(3):256–61
Agustines L A, Lin Y G, Rumney P J, et al. Outcomes of extremely low-birth-weight infants between 500 and 750 g. Am J Obstet Gynecol. 2000;182(5):1113-6. [pmid: 10819843].
Akerman B A, Thomassen P A. The fate of “small twins”: a four-year follow-up study of low birthweight and prematurely born twins. Acta Genet Med Gemellol (Roma). 1992;41(23):97-104. [pmid: 1284574].
Algawi K, Goggin M, O'Keefe M. Refractive outcome following diode laser versus cryotherapy for eyes with retinopathy of prematurity. Br J Ophthalmol. 1994;78(8):612-4. [pmid: 7918287]. [pmcid: 504884].
Allan W C, Vohr B, Makuch R W, et al. Antecedents of cerebral palsy in a multicenter trial of indomethacin for intraventricular hemorrhage. Arch Pediatr Adolesc Med. 1997;151(6):580-5. [pmid: 9193243].
Als H, Lawhon G, Duffy F H, et al. Individualized developmental care for the very low-birth-weight preterm infant. Medical and neurofunctional effects. JAMA. Sep 21. 1994;272(11):853-8. [pmid: 8078162].
Ambalavanan N, Nelson K G, Alexander G, et al. Prediction of neurologic morbidity in extremely low birth weight infants. J Perinatol. 2000;20(8 Pt 1):496-503. [pmid: 11190589].
American Association on Mental Retardation. Mental Retardation: Definition, Classification, and Systems of Supports. 9thed. Washington, DC: American Association on Mental Retardation; 1992
Anderson A E, Wildin S R, Woodside M, et al. Severity of medical and neurologic complications as a determinant of neurodevelopmental outcome at 6 and 12 months in very low birth weight infants. J Child Neurol. 1996;11(3):215-9. [pmid: 8734026].
Avila-Diaz M, Flores-Huerta S, Martinez-Muniz I, et al. Increments in whole body bone mineral content associated with weight and length in pre-term and full-term infants during the first 6 months of life. Arch Med Res. 2001;32(4):288-92. [pmid: 11440785].
Bader D, Ramos A D, Lew C D, et al. Childhood sequelae of infant lung disease: exercise and pulmonary function abnormalities after bronchopulmonary dysplasia. J Pediatr. May. 1987;110(5):693-9. [pmid: 3572620].
Bagnato SJ, Campbell TF. Comprehensive neurodevelopmental evaluation of children with brain insults. In: Miller G and Ramer JC, editors. Static encephalopathies of infancy and childhood. New York: Raven Press Ltd; 1992. p. 27–44.
Baraldi E, Monciotti C, Filippone M, et al. Gas exchange during exercise in diabetic children. Pediatr Pulmonol. Jul. 1992;13(3):155-60. [pmid: 1437329].
Baraldi E, Filippone M, Trevisanuto D, et al. Pulmonary function until two years of life in infants with bronchopulmonary dysplasia. Am J Respir Crit Care Med. Jan. 1997;155(1):149-55. [pmid: 9001304].
Barrington K J. The adverse neuro-developmental effects of postnatal steroids in the preterm infant: a systematic review of RCTs. BMC Pediatr. 2001;1(1):1. [pmcid: 29104]. [pmid: 11248841].
Battin M, Ling E W, Whitfield M F, et al. Has the outcome for extremely low gestational age (ELGA) infants improved following recent advances in neonatal intensive care?. Am J Perinatol. 1998;15(8):469-77. [pmid: 9788645].
Bayley N. Bayley Scales of Development. 2ed. New York, NY: Psychology Corporatoin, Harcourt Brace & Co.; 1993
Blayney M, Kerem E, Whyte H, et al. Bronchopulmonary dysplasia: improvement in lung function between 7 and 10 years of age. J Pediatr. Feb. 1991;118(2):201-6. [pmid: 1993945].
Blitz R K, Wachtel R C, Blackmon L, et al. Neurodevelopmental outcome of extremely low birth weight infants in Maryland. Md Med J. 1997;46(1):18-24. [pmid: 9001122].
Bos A F, Martijn A, Okken A, et al. Quality of general movements in preterm infants with transient periventricular echodensities. Acta Paediatr. 1998;87(3):328-35. [pmid: 9560043].
Botting N, Powls A, Cooke R W, et al. Attention deficit hyperactivity disorders and other psychiatric outcomes in very low birthweight children at 12 years. J Child Psychol Psychiatry. Nov. 1997;38(8):931-41. [pmid: 9413793].
Brazy J E, Eckerman C O, Oehler J M, et al. Nursery Neurobiologic Risk Score: important factor in predicting outcome in very low birth weight infants. J Pediatr. 1991;118(5):783-92. [pmid: 2019935].
Brazy J E, Goldstein R F, Oehler J M, et al. Nursery neurobiologic risk score: levels of risk and relationships with nonmedical factors. J Dev Behav Pediatr. 1993;14(6):375-80. [pmid: 8126229].
Breslau N, Brown G G, DelDotto J E, et al. Psychiatric sequelae of low birth weight at 6 years of age. J Abnorm Child Psychol. Jun. 1996;24(3):385-400. [pmid: 8836807].
Breslau N, Chilcoat H D. Psychiatric sequelae of low birth weight at 11 years of age. Biol Psychiatry. 2000;47(11):1005-11. [pmid: 10838069].
Briscoe J, Gathercole S E, Marlow N. Short-term memory and language outcomes after extreme prematurity at birth. J Speech Lang Hear Res. 1998;41(3):654-66. [pmid: 9638929].
Brooks A M, Byrd R S, Weitzman M, et al. Impact of low birth weight on early childhood asthma in the United States. Arch Pediatr Adolesc Med. Mar. 2001;155(3):401-6. [pmid: 11231809].
Buhrer C, Grimmer I, Metze B, et al. The CRIB (Clinical Risk Index for Babies) score and neurodevelopmental impairment at one year corrected age in very low birth weight infants. Intensive Care Med. 2000;26(3):325-9. [pmid: 10823390].
Burguet A, Monnet E, Pauchard J Y, et al. Some risk factors for cerebral palsy in very premature infants: importance of premature rupture of membranes and monochorionic twin placentation. Biol Neonate. 1999;75(3):177-86. [pmid: 9925905].
Casiro O, Bingham W, MacMurray B, et al. One-year follow-up of 89 infants with birth weights of 500 to 749 grams and respiratory distress syndrome randomized to two rescue doses of synthetic surfactant or air placebo. J Pediatr. 1995;126(5 Pt 2):53-60. [pmid: 7745513].
Chen C H, Shen W C, Wang T M, et al. Cerebral magnetic resonance imaging of preterm infants after corrected age of one year. Zhonghua Min Guo Xiao Er Ke Yi Xue Hui Za Zhi. 1995;36(4):261-5. [pmid: 7572168].
Cherkes-Julkowski M. Learning disability, attention-deficit disorder, and language impairment as outcomes of prematurity: a longitudinal descriptive study. J Learn Disabil. 1998;31(3):294-306. [pmid: 9599962].
Cheung P Y, Prasertsom W, Finer N N, et al. Rescue high frequency oscillatory ventilation for preterm infants: neurodevelopmental outcome and its prediction. Biol Neonate. 1997;71(5):282-91. [pmid: 9167849].
Cheung P Y, Peliowski A, Robertson C M. The outcome of very low birth weight neonates (&#60;/=1500 g) rescued by inhaled nitric oxide: neurodevelopment in early childhood. J Pediatr. 1998;133(6):735-9. [pmid: 9842035].
Cheung P Y, Barrington K J, Finer N N, et al. Early childhood neurodevelopment in very low birth weight infants with predischarge apnea. Pediatr Pulmonol. 1999;27(1):14-20. [pmid: 10023786].
Chye J K, Gray P H. Rehospitalization and growth of infants with bronchopulmonary dysplasia: a matched control study. J Paediatr Child Health. 1995;31(2):105-11. [pmid: 7794609].
Cioni G, Bertuccelli B, Boldrini A, et al. Correlation between visual function, neurodevelopmental outcome, and magnetic resonance imaging findings in infants with periventricular leucomalacia. Arch Dis Child Fetal Neonatal Ed. 2000;82(2):134-40. [pmid: 10685987].
Cioni G, Bos A F, Einspieler C, et al. Early neurological signs in preterm infants with unilateral intraparenchymal echodensity. Neuropediatrics. 2000;31(5):240-51. [pmid: 11204281].
Connolly B P, McNamara J A, Sharma S, et al. A comparison of laser photocoagulation with trans-scleral cryotherapy in the treatment of threshold retinopathy of prematurity. Ophthalmology. 1998;105(9):1628-31. [pmid: 9754168].
Connors J M, O'Callaghan M J, Burns Y R, et al. The influence of growth on development outcome in extremely low birthweight infants at 2 years of age. J Paediatr Child Health. 1999;35(1):37-41. [pmid: 10234633].
Contractor C P, Leslie G I, Bowen J R, et al. The Neonatal Neurobiologic Risk Score: does it predict outcome in very premature infants?. Indian Pediatr. 1996;33(2):95-101. [pmid: 8772924].
Cooke R W, Abernethy L J. Cranial magnetic resonance imaging and school performance in very low birth weight infants in adolescence. Arch Dis Child Fetal Neonatal Ed. 1999;81(2):116-21. [pmid: 10448179].
Cooke R W. Trends in incidence of cranial ultrasound lesions and cerebral palsy in very low birthweight infants 1982-93. Arch Dis Child Fetal Neonatal Ed. 1999;80(2):115-7. [pmid: 10448179].
Corbet A, Long W, Schumacher R, et al. Double-blind developmental evaluation at 1-year corrected age of 597 premature infants with birth weights from 500 to 1350 grams enrolled in three placebo-controlled trials of prophylactic synthetic surfactant. J Pediatr. 1995;126(5 Pt 2):5-12. [pmid: 7745511].
Crocker A C. Causes of mental retardation. Pediatr Ann. 1989;18:623-35. [pmid: 2682495].
Cryotherapy for Retinopathy of Prematurity Cooperative Group. Multicenter trial of cryotherapy for retinopathy of prematurity. One-year outcome--structure and function. Arch Ophthalmol. 1990;108(10):1408-16. [pmid: 2222274].
Cryotherapy for Retinopathy of Prematurity Cooperative Group. Multicenter trial of cryotherapy for retinopathy of prematurity. 3 1/2-year outcome--structure and function. Arch Ophthalmol. Mar. 1993;111(3):339-44. [pmid: 8447743].
Cryotherapy for Retinopathy of Prematurity Cooperative Group. The natural ocular outcome of premature birth and retinopathy. Status at 1 year. Arch Ophthalmol. 1994;112(7):903-12. [pmid: 8031269].
Cryotherapy for Retinopathy of Prematurity Cooperative Group. Multicenter trial of cryotherapy for retinopathy of prematurity. Snellen visual acuity and structural outcome at 5 1/2 years after randomization. Arch Ophthalmol. 1996;114(4):417-24. [pmid: 8602778].
Cryotherapy for Retinopathy of Prematurity Cooperative Group. Effect of retinal ablative therapy for threshold retinopathy of prematurity: results of Goldmann perimetry at the age of 10 years. Arch Ophthalmol. 2001;119(8):1120-5. [pmid: 11483077].
Cryotherapy for Retinopathy of Prematurity Cooperative Group. Multicenter Trial of Cryotherapy for Retinopathy of Prematurity: ophthalmological outcomes at 10 years. Arch Ophthalmol. 2001;119(8):1110-8. [pmid: 11483076].
Cryotherapy for Retinopathy of Prematurity Cooperative Group. Contrast sensitivity at age 10 years in children who had threshold retinopathy of prematurity. Arch Ophthalmol. 2001;119(8):1129-33. [pmid: 11483078].
Dammann O, Dammann C E, Allred E N, et al. Fetal growth restriction is not associated with a reduced risk for bilateral spastic cerebral palsy in very-low-birthweight infants. Early Hum Dev. 2001;64(2):79-89. [pmid: 11440821].
de Vonderweid U, Spagnolo A, Corchia C, et al. Italian multicentre study on very low-birth-weight babies. Neonatal mortality and two-year outcome. Acta Paediatr. 1994;83(4):391-6. [pmid: 8025395].
de Vries L S, Eken P, Groenendaal F, et al. Correlation between the degree of periventricular leukomalacia diagnosed using cranial ultrasound and MRI later in infancy in children with cerebral palsy. Neuropediatrics. Oct. 1993;24(5):263-8. [pmid: 8309515].
deRegnier R A, Roberts D, Ramsey D, et al. Association between the severity of chronic lung disease and first-year outcomes of very low birth weight infants. J Perinatol. 1997;17(5):375-82. [pmid: 9373843].
Dezoete J A, MacArthur B A, Aftimos S. Developmental outcome at 18 months of children less than 1000 grams. N Z Med J. 1997;110(1045):205-7. [pmid: 9216603].
Dogru M, Shirabe H, Nakamura M, et al. Development of grating acuity in infants with Retinopathy of Prematurity. Acta Ophthalmol Scand. 1999;77(1):72-5. [pmid: 10071153].
Doyle L W, Casalaz D. The Victorian Infant Collaborative Study Group. Outcome at 14 years of extremely low birthweight infants: a regional study. Arch Dis Child Fetal Neonatal Ed. 2001;85(3):159-64. [pmid: 11668155].
Doyle L W, Cheung M M, Ford G W, et al. Birth weight <1501 g and respiratory health at age 14. Arch Dis Child. Jan. 2001;84(1):40-4. [pmid: 11124782].
Doyle L W. Outcome at 5 years of age of children 23 to 27 weeks' gestation: refining the prognosis. Pediatrics. Jul. 2001;108(1):134-41. [pmid: 11433066].
Duvanel C B, Fawer C L, Cotting J, et al. Long-term effects of neonatal hypoglycemia on brain growth and psychomotor development in small-for-gestational-age preterm infants. J Pediatr. 1999;134(4):492-8. [pmid: 10190926].
Ehrenkranz R A, Walsh-Sukys M. New consensus definition of bronchopulmonary dysplasia predicts pulmonary and neurodevelopmental outcomes in early infancy. Pediatr Res. 2001;49(4):276A.
Ekert P G, Keenan N K, Whyte H E, et al. Visual evoked potentials for prediction of neurodevelopmental outcome in preterm infants. Biol Neonate. 1997;71(3):148-55. [pmid: 9096893].
Emsley H C, Wardle S P, Sims D G, et al. Increased survival and deteriorating developmental outcome in 23 to 25 week old gestation infants, 1990-4 compared with 1984-9. Arch Dis Child Fetal Neonatal Ed. 1998;78(2):99-104. [pmid: 9577278].
Finer N N, Tarin T, Vaucher Y E, et al. Intact survival in extremely low birth weight infants after delivery room resuscitation. Pediatrics. 1999;104(4):e40. [pmid: 10506265].
Finnstrom O, Otterblad Olausson P, Sedin G, et al. Neurosensory outcome and growth at three years in extremely low birthweight infants: follow-up results from the Swedish national prospective study. Acta Paediatr. 1998;87(10):1055-60. [pmid: 9825972].
Ford G W, Doyle L W, Davis N M, et al. Very low birth weight and growth into adolescence. Arch Pediatr Adolesc Med. 2000;154(8):778-84. [pmid: 10922273].
Foreman N, Fielder A, Minshell C, et al. Visual search, perception, and visual-motor skill in “healthy” children born at 27–32 weeks' gestation. J Exp Child Psychol. 1997;64(1):27-41. [pmid: 9126626].
Forslund M. Growth and motor performance in preterm children at 8 years of age. Acta Paediatr. 1992;81(10):840-2. [pmid: 1384828].
French N P, Hagan R, Evans S F, et al. Repeated antenatal corticosteroids: size at birth and subsequent development. Am J Obstet Gynecol. 1999;180(1 Pt 1):114-21. [pmid: 9914589].
Futagi Y, Suzuki Y, Goto M, et al. Neurodevelopmental outcomes of infants with birth weights of less than 1000 g: comparison between periods before and after the introduction of surfactant. Brain Dev. 1999;21(7):453-7. [pmid: 10522521].
Gaillard E A, Cooke R W, Shaw N J. Improved survival and neurodevelopmental outcome after prolonged ventilation in preterm neonates who have received antenatal steroids and surfactant. Arch Dis Child Fetal Neonatal Ed. 2001;84(3):194-6. [pmid: 11320047].
Gaudet L M, Smith G N. Cerebral palsy and chorioamnionitis: the inflammatory cytokine link. Obstet Gynecol Surv. Jul. 2001;56(7):433-6. [pmid: 11435951].
Gerdes J, Gerdes M, Beaumont E, et al. Health and neurodevelopmental outcome at 1-year adjusted age in 508 infants weighing 700 to 1100 grams who received prophylaxis with one versus three doses of synthetic surfactant. J Pediatr. 1995;126(5 Pt 2):26-32. [pmid: 7745508].
Gerhardt T, Hehre D, Feller R, et al. Serial determination of pulmonary function in infants with chronic lung disease. J Pediatr. Mar. 1987;110(3):448-56. [pmid: 3819948].
Gerner E M, Katz-Salamon M, Hesser U, et al. Psychomotor development at 10 months as related to neonatal health status: the Stockholm Neonatal Project. Acta Paediatr Suppl. Apr. 1997;419:37-43. [pmid: 9185901].
Goetz M C, Gretebeck R J, Oh K S, et al. Incidence, timing, and follow-up of periventricular leukomalacia. Am J Perinatol. Sep. 1995;12(5):325-7. [pmid: 8540933].
Goldstein R F, Thompson R J Jr, Oehler J M, et al. Influence of acidosis, hypoxemia, and hypotension on neurodevelopmental outcome in very low birth weight infants. Pediatrics. Feb. 1995;95(2):238-43. [pmid: 7530835].
Gosch A, Brambring M, Gennat H, et al. Longitudinal study of neuropsychological outcome in blind extremely-low-birthweight children. Dev Med Child Neurol. May. 1997;39(5):297-304. [pmid: 9236695].
Gregoire M C, Lefebvre F, Glorieux J. Health and developmental outcomes at 18 months in very preterm infants with bronchopulmonary dysplasia. Pediatrics. May. 1998;101(5):856-60. [pmid: 9565414].
Grether J K, Hoogstrate J, Walsh-Greene E, et al. Magnesium sulfate for tocolysis and risk of spastic cerebral palsy in premature children born to women without preeclampsia. Am J Obstet Gynecol. 2000;183(3):717-25. [pmid: 10992199].
Gross S J, Iannuzzi D M, Kveselis D A, et al. Effect of preterm birth on pulmonary function at school age: a prospective controlled study. J Pediatr. Aug. 1998;133(2):188-92. [pmid: 9709704].
Guyer B, Hoyert D L, Martin J A, et al. Annual summary of vital statistics--1998. Pediatrics. Dec. 1999;104(6):1229-46. [pmid: 10585972].
Hack M, Breslau N, Aram D, et al. The effect of very low birth weight and social risk on neurocognitive abilities at school age. J Dev Behav Pediatr. Dec. 1992;13(6):412-20. [pmid: 1469109].
Hack M, Weissman B, Borawski-Clark E. Catch-up growth during childhood among very low-birth-weight children. Arch Pediatr Adolesc Med. Nov. 1996;150(11):1122-9. [pmid: 8904851].
Hack M, Friedman H, Fanaroff A A. Outcomes of extremely low birth weight infants. Pediatrics. 1996;98(5):931-7. [pmid: 8909488].
Hack M, Wilson-Costello D, Friedman H, et al. Neurodevelopment and predictors of outcomes of children with birth weights of less than 1000 g: 1992-1995. Arch Pediatr Adolesc Med. 2000;154(7):725-31. [pmid: 10891026].
Hack M, Flannery D J, Schluchter M, et al. Outcomes in young adulthood for very-low-birth-weight infants. N Engl J Med. Jan 17. 2002;346(3):149-57. [pmid: 11796848].
Harvey E M, Dobson V, Luna B. Long-term grating acuity and visual-field development in preterm children who experienced bronchopulmonary dysplasia. Dev Med Child Neurol. Mar. 1997;39(3):167-73. [pmid: 9112965].
Hille E T, den Ouden A L, Bauer L, et al. School performance at nine years of age in very premature and very low birth weight infants: perinatal risk factors and predictors at five years of age. Collaborative Project on Preterm and Small for Gestational Age (POPS) Infants in The Netherlands. J Pediatr. Sep. 1994;125(3):426-34. [pmid: 8071753].
Hille E T, den Ouden A L, Saigal S, et al. Behavioural problems in children who weigh 1000 g or less at birth in four countries. Lancet. May 26. 2001;357(9269):1641-3. [pmid: 11425366].
Holling E E, Leviton A. Characteristics of cranial ultrasound white-matter echolucencies that predict disability: a review. Dev Med Child Neurol. Feb. 1999;41(2):136-9. [pmid: 10075101].
Hollingshead A. Four-Factir Index of Social Status. New Haven: Yale University; 1975
Horwood A, Williams B. Does neonatal ocular misalignment predict later abnormality?. Eye. 2001;15(Pt 4):485-91. [pmid: 11767024].
Horwood L J, Darlow B A, Mogridge N. Breast milk feeding and cognitive ability at 7–8 years. Arch Dis Child Fetal Neonatal Ed. 2001;84(1):23-7. [pmid: 11124919].
Hoyt C S, Good W V. The many challenges of childhood blindness. Arch Dis Child. 2001;85(6):452-3. [pmid: 11719325].
Iai M, Takashima S. Thalamocortical development of parvalbumin neurons in normal and periventricular leukomalacia brains. Neuropediatrics. 1999;30(1):14-8. [pmid: 10222455].
Iles R, Edmunds A T. Assessment of pulmonary function in resolving chronic lung disease of prematurity. Arch Dis Child Fetal Neonatal Ed. Mar. 1997;76(2):F113-F117. [pmid: 9135290].
Jacob S V, Lands L C, Coates A L, et al. Exercise ability in survivors of severe bronchopulmonary dysplasia. Am J Respir Crit Care Med. Jun. 1997;155(6):1925-9. [pmid: 9196097].
Jankov R P, Asztalos E V, Skidmore M B. Favourable neurological outcomes following delivery room cardiopulmonary resuscitation of infants &#60; or = 750 g at birth. J Paediatr Child Health. 2000;36(1):19-22. [pmid: 10723685].
Kato E H, Yamada H, Matsumoto Y, et al. Relation between perinatal factors and outcome of very low birth weight infants. J Perinat Med. 1996;24(6):677-86. [pmid: 9120752].
Katz-Salamon M, Gerner E M, Jonsson B, et al. Early motor and mental development in very preterm infants with chronic lung disease. Arch Dis Child Fetal Neonatal Ed. Jul. 2000;83(1):F1-F6. [pmid: 10873161].
Katz K S, Dubowitz L M, Henderson S, et al. Effect of cerebral lesions on continuous performance test responses of school age children born prematurely. J Pediatr Psychol. Dec. 1996;21(6):841-55. [pmid: 8990728].
Keith C G, Doyle L W. Retinopathy of prematurity in extremely low birth weight infants. Pediatrics. 1995;95(1):42-5. [pmid: 7770307].
Kiely M. The prevalence of mental retardation. Epidemiol Rev. 1987;9:194-218. [pmid: 3315717].
Kim J N, Namgung R, Chang W, et al. Prospective evaluation of perinatal risk factors for cerebral palsy and delayed development in high risk infants. Yonsei Med J. Aug. 1999;40(4):363-70. [pmid: 10487140].
Koller H, Lawson K, Rose S A, et al. Patterns of cognitive development in very low birth weight children during the first six years of life. Pediatrics. Mar. 1997;99(3):383-9. [pmid: 9041293].
Korkman M, Liikanen A, Fellman V. Neuropsychological consequences of very low birth weight and asphyxia at term: follow-up until school-age. J Clin Exp Neuropsychol. Apr. 1996;18(2):220-33. [pmid: 8780957].
Krageloh-Mann I, Toft P, Lunding J, et al. Brain lesions in preterms: origin, consequences and compensation. Acta Paediatr. Aug. 1999;88(8):897-908. [pmid: 10503692].
Kraybill E N, Bose C L, Corbet A J, et al. Double-blind evaluation of developmental and health status to age 2 years of infants weighing 700 to 1350 grams treated prophylactically at birth with a single dose of synthetic surfactant or air placebo. J Pediatr. May. 1995;126(5 Pt 2):S33-S42. [pmid: 7745509].
Kuban K C, Leviton A. Cerebral palsy. N Engl J Med. Jan 20. 1994;330(3):188-95. [pmid: 8264743].
Kurkinen-Raty M, Koivisto M, Jouppila P. Perinatal and neonatal outcome and late pulmonary sequelae in infants born after preterm premature rupture of membranes. Obstet Gynecol. Sep. 1998;92(3):408-15. [pmid: 9721780].
Kurkinen-Raty M, Koivisto M, Jouppila P. Preterm delivery for maternal or fetal indications: maternal morbidity, neonatal outcome and late sequelae in infants. BJOG. May. 2000;107(5):648-55. [pmid: 10826581].
Ladd A P, Rescorla F J, West K W, et al. Long-term follow-up after bowel resection for necrotizing enterocolitis: factors affecting outcome. J Pediatr Surg. Jul. 1998;33(7):967-72. [pmid: 9694079].
Lee B E, Cheung P Y, Robinson J L, et al. Comparative study of mortality and morbidity in premature infants (birth weight, < 1,250 g) with candidemia or candidal meningitis. Clin Infect Dis. Sep. 1998;27(3):559-65. [pmid: 9770157].
Lefebvre F, Gregoire M C, Dubois J, et al. Nursery Neurobiologic Risk Score and outcome at 18 months. Acta Paediatr. Jul. 1998;87(7):751-7. [pmid: 9722248].
Leonard C H, Clyman R I, Piecuch R E, et al. Effect of medical and social risk factors on outcome of prematurity and very low birth weight. J Pediatr. Apr. 1990;116(4):620-6. [pmid: 2319409].
Levene M I. Cerebral ultrasound and neurological impairment: telling the future. Arch Dis Child. May. 1990;65(5):469-71. [pmid: 1694069].
Ling C S, Fleck B W, Wright E, et al. Diode laser treatment for retinopathy of prematurity: structural and functional outcome. Br J Ophthalmol. 1995;79(7):637-41. [pmid: 7662625]. [pmcid: 505188].
Lucas A, Morley R, Cole T J, et al. Breast milk and subsequent intelligence quotient in children born preterm. Lancet. 1992;339(8788):261-4. [pmid: 1346280].
Lucas A, Fewtrell M S, Morley R, et al. Randomized outcome trial of human milk fortification and developmental outcome in preterm infants. Am J Clin Nutr. 1996;64(2):142-51. [pmid: 8694013].
Mandich M, Simons C J, Ritchie S, et al. Motor development, infantile reactions and postural responses of preterm, at-risk infants. Dev Med Child Neurol. 1994;36(5):397-405. [pmid: 8168658].
Marlow E S, Hunt L P, Marlow N. Sensorineural hearing loss and prematurity. Arch Dis Child Fetal Neonatal Ed. Mar. 2000;82(2):F141-F144. [pmid: 10685988].
Marlow N, Roberts L, Cooke R. Outcome at 8 years for children with birth weights of 1250 g or less. Arch Dis Child. Mar. 1993;68(3 Spec No):286-90. [pmid: 8466264].
Mattia F R, deRegnier R A. Chronic physiologic instability is associated with neurodevelopmental morbidity at one and two years in extremely premature infants. Pediatrics. 1998;102(3):E35. [pmid: 9724683].
McCormick M C, Gortmaker S L, Sobol A M. Very low birth weight children: behavior problems and school difficulty in a national sample. J Pediatr. Nov. 1990;117(5):687-93. [pmid: 2231200].
McCormick M C, Brooks-Gunn J, Workman-Daniels K, et al. The health and developmental status of very low-birth-weight children at school age. JAMA. Apr 22. 1992;267(16):2204-8. [pmid: 1556798].
Ment L R, Duncan C C, Ehrenkranz R A, et al. Randomized low-dose indomethacin trial for prevention of intraventricular hemorrhage in very low birth weight neonates. J Pediatr. 1988;112(6):948-55. [pmid: 3373405].
Ment L R, Oh W, Ehrenkranz R A, et al. Low-dose indomethacin and prevention of intraventricular hemorrhage: a multicenter randomized trial. Pediatrics. Apr. 1994;93(4):543-50. [pmid: 8134206].
Ment L R, Oh W, Ehrenkranz R A, et al. Low-dose indomethacin therapy and extension of intraventricular hemorrhage: a multicenter randomized trial. J Pediatr. 1994;124(6):951-5. [pmid: 8201485].
Ment L R, Vohr B, Oh W, et al. Neurodevelopmental outcome at 36 months' corrected age of preterm infants in the Multicenter Indomethacin Intraventricular Hemorrhage Prevention Trial. Pediatrics. Oct. 1996;98(4 Pt 1):714-8. [pmid: 8885951].
Ment L R, Westerveld M, Makuch R, et al. Cognitive outcome at 4 1/2 years of very low birth weight infants enrolled in the multicenter indomethacin intraventricular hemorrhage prevention trial. Pediatrics. 1998;102(1 Pt 1):159-60. [pmid: 9714645].
Ment L R, Vohr B, Allan W, et al. The etiology and outcome of cerebral ventriculomegaly at term in very low birth weight preterm infants. Pediatrics. Aug. 1999;104(2 Pt 1):243-8. [pmid: 10429002].
Ment L R, Vohr B, Allan W, et al. Outcome of children in the indomethacin intraventricular hemorrhage prevention trial. Pediatrics. Mar. 2000;105(3 Pt 1):485-91. [pmid: 10699097].
Millet V, Bartoli J M, Lacroze V, et al. Predictive significance of magnetic resonance imaging at 4 months of adjusted age in infants after a perinatal neurologic insult. Biol Neonate. 1998;73(4):207-19. [pmid: 9551187].
Mitchell S H, Teague W G. Reduced gas transfer at rest and during exercise in school-age survivors of bronchopulmonary dysplasia. Am J Respir Crit Care Med. May. 1998;157(5 Pt 1):1406-12. [pmid: 9603115].
Morley R, Lucas A. Randomized diet in the neonatal period and growth performance until 7.5–8 y of age in preterm children. Am J Clin Nutr. Mar. 2000;71(3):822-8. [pmid: 10702179].
Murphy D J, Hope P L, Johnson A. Neonatal risk factors for cerebral palsy in very preterm babies: case-control study. BMJ. Feb 8. 1997;314(7078):404-8. [pmid: 9040385]. [pmcid: 2125924].
Mutch L, Alberman E, Hagberg B, et al. Cerebral palsy epidemiology: where are we now and where are we going?. Dev Med Child Neurol. Jun. 1992;34(6):547-51. [pmid: 1612216].
Myers V S, Gidlewski N, Quinn G E, et al. Distance and near visual acuity, contrast sensitivity, and visual fields of 10-year-old children. Arch Ophthalmol. Jan. 1999;117(1):94-9. [pmid: 9930166].
Nadeau L, Boivin M, Tessier R, et al. Mediators of behavioral problems in 7-year-old children born after 24 to 28 weeks of gestation. J Dev Behav Pediatr. 2001;22(1):1-10. [pmid: 11265917].
Northern Neonatal Nursing Initiative Trial Group. Randomised trial of prophylactic early fresh-frozen plasma or gelatin or glucose in preterm babies: outcome at 2 years. Lancet. Jul 27. 1996;348(9022):229-32. [pmid: 8684200].
O'Connor A R, Stephenson T, Johnson A, et al. Long-term ophthalmic outcome of low birth weight children with and without retinopathy of prematurity. Pediatrics. Jan. 2002;109(1):12-8. [pmid: 11773536].
O'Connor D L, Hall R, Adamkin D, et al. Growth and development in preterm infants fed long-chain polyunsaturated fatty acids: a prospective, randomized controlled trial. Pediatrics. 2001;108(2):359-71. [pmid: 11483801].
O'Shea T M, Klinepeter K L, Goldstein D J, et al. Survival and developmental disability in infants with birth weights of 501 to 800 grams, born between 1979 and 1994. Pediatrics. 1997;100(6):982-6. [pmid: 9374569].
O'Shea T M, Klinepeter K L, Dillard R G. Prenatal events and the risk of cerebral palsy in very low birth weight infants. Am J Epidemiol. 1998;147(4):362-9. [pmid: 9508103].
O'Shea T M, Preisser J S, Klinepeter K L, et al. Trends in mortality and cerebral palsy in a geographically based cohort of very low birth weight neonates born between 1982 to 1994. Pediatrics. Apr. 1998;101(4 Pt 1):642-7. [pmid: 9521949].
O'Shea T M, Kothadia J M, Klinepeter K L, et al. Randomized placebo-controlled trial of a 42-day tapering course of dexamethasone to reduce the duration of ventilator dependency in very low birth weight infants: outcome of study participants at 1-year adjusted age. Pediatrics. Jul. 1999;104(1 Pt 1):15-21. [pmid: 10390254].
Oehler J M, Goldstein R F, Catlett A, et al. How to target infants at highest risk for developmental delay. MCN Am J Matern Child Nurs. 1993;18(1):20-3. [pmid: 7678688].
Oehler J M, Thompson R J Jr, Goldstein R F, et al. Behavioral characteristics of very-low-birth-weight infants of varying biologic risk at 6, 15, and 24 months of age. J Obstet Gynecol Neonatal Nurs. 1996;25(3):233-9. [pmid: 8683358].
Page J M, Schneeweiss S, Whyte H E, et al. Ocular sequelae in premature infants. Pediatrics. 1993;92(6):787-90. [pmid: 8233737].
Palfrey J S, Singer J D, Walker D K, et al. Early identification of children's special needs: a study in five metropolitan communities. J Pediatr. Nov. 1987;111(5):651-9. [pmid: 2444688].
Palmer E A, Flynn J T, Hardy R J, et al. Incidence and early course of retinopathy of prematurity. The Cryotherapy for Retinopathy of Prematurity Cooperative Group. Ophthalmology. 1991;98(11):1628-40. [pmid: 1800923].
Palta M, Sadek-Badawi M, Evans M, et al. Functional assessment of a multicenter very low-birth-weight cohort at age 5 years. Arch Pediatr Adolesc Med. 2000;154(1):23-30. [pmid: 10632246].
Pasman J W, Rotteveel J J, Maassen B, et al. Neonatal risk factors and risk scores including auditory evoked responses. Eur J Pediatr. 1998;157(3):230-5. [pmid: 9537491].
Pelkonen A S, Hakulinen A L, Turpeinen M. Bronchial lability and responsiveness in school children born very preterm. Am J Respir Crit Care Med. Oct. 1997;156(4 Pt 1):1178-84. [pmid: 9351619].
Pennefather P M, Clarke M P, Strong N P, et al. Risk factors for strabismus in children born before 32 weeks' gestation. Br J Ophthalmol. May. 1999;83(5):514-8. [pmid: 10216046]. [pmcid: 1723046].
Pennefather P M, Tin W. Ocular abnormalities associated with cerebral palsy after preterm birth. Eye. Feb. 2000;14(Pt 1):78-81. [pmid: 10755106].
Piecuch R E, Leonard C H, Cooper B A, et al. Outcome of extremely low birth weight infants (500 to 999 grams) over a 12-year period. Pediatrics. Oct. 1997;100(4):633-9. [pmid: 9310517].
Piecuch R E, Leonard C H, Cooper B A, et al. Outcome of infants born at 24–26 weeks' gestation: II. Neurodevelopmental outcome. Obstet Gynecol. Nov. 1997;90(5):809-14. [pmid: 9351769].
Piecuch R E, Leonard C H, Cooper B A. Infants with birth weight 1,000–1,499 grams born in three time periods: has outcome changed over time? [see comments]. Clin Pediatr (Phila). 1998;37(9):537-45. [pmcid: 238101]. [pmid: 9773236].
Pierrat V, Duquennoy C, van Haastert I C, et al. Ultrasound diagnosis and neurodevelopmental outcome of localised and extensive cystic periventricular leucomalacia. Arch Dis Child Fetal Neonatal Ed. May. 2001;84(3):F151-F156. [pmid: 11320039].
Rademaker K J, Groenendaal F, Jansen G H, et al. Unilateral haemorrhagic parenchymal lesions in the preterm infant: shape, site and prognosis. Acta Paediatr. Jun. 1994;83(6):602-8. [pmid: 7919756].
Ramer JC, Miller G. Overview of mental retardation. In: Miller G and Ramer JC, editors. Static encephalopathies of infancy and childhood. New York: Raven Press Ltd; 1992. p. 1–10.
Redline R W, Wilson-Costello D, Borawski E, et al. Placental lesions associated with neurologic impairment and cerebral palsy in very low-birth-weight infants. Arch Pathol Lab Med. Dec. 1998;122(12):1091-8. [pmid: 9870858].
Repka M X, Summers C G, Palmer E A, et al. The incidence of ophthalmologic interventions in children with birth weights less than 1251 grams. Results through 5 1/2 years. Ophthalmology. 1998;105(9):1621-7. [pmid: 9754167].
Robertson C, Sauve R S, Christianson H E. Province-based study of neurologic disability among survivors weighing 500 through 1249 grams at birth. Pediatrics. 1994;93(4):636-40. [pmid: 8134221].
Robson A L, Pederson D R. Predictors of individual differences in attention among low birth weight children. J Dev Behav Pediatr. Feb. 1997;18(1):13-21. [pmid: 9055145].
Rogers B, Andrus J, Msall M E, et al. Growth of preterm infants with cystic periventricular leukomalacia. Dev Med Child Neurol. Sep. 1998;40(9):580-6. [pmid: 9766734].
Roth S, Amess P, Kirkbride V, et al. A comparision of linear-array and mechanical-sector cranial ultrasound scanning techniques to predict neurodevelopmental outcome at 8 years in preterm newborn infants. Ultrasound Med Biol. Apr. 2001;27(4):467-72. [pmid: 11368859].
Saarela T, Vaarala A, Lanning P, et al. Incidence, ultrasonic patterns and resolution of nephrocalcinosis in very low birthweight infants. Acta Paediatr. 1999;88(6):655-60. [pmid: 10419252].
Saarela T, Lanning P, Koivisto M. Prematurity-associated nephrocalcinosis and kidney function in early childhood. Pediatr Nephrol. 1999;13(9):886-90. [pmid: 10603142].
Saarela T, Lanning P, Koivisto M, et al. Nephrocalcinosis in full-term infants receiving furosemide treatment for congestive heart failure: a study of the incidence and 2-year follow up. Eur J Pediatr. 1999;158(8):668-72. [pmid: 10445348].
Saigal S, Stoskopf B L, Streiner D L, et al. Physical growth and current health status of infants who were of extremely low birth weight and controls at adolescence. Pediatrics. Aug. 2001;108(2):407-15. [pmid: 11483807].
Sajaniemi N, Salokorpi T, von Wendt L. Temperament profiles and their role in neurodevelopmental assessed preterm children at two years of age. Eur Child Adolesc Psychiatry. Sep. 1998;7(3):145-52. [pmid: 9826301].
Sajaniemi N, Hakamies-Blomqvist L, Makela J, et al. Cognitive development, temperament and behavior at 2 years as indicative of language development at 4 years in pre-term infants. Child Psychiatry Hum Dev. 2001;31(4):329-46. [pmid: 11227991].
Salokorpi T, Rajantie I, Viitala J, et al. Does perinatal hypocarbia play a role in the pathogenesis of cerebral palsy?. Acta Paediatr. May. 1999;88(5):571-5. [pmid: 10426183].
Santuz P, Baraldi E, Zaramella P, et al. Factors limiting exercise performance in long-term survivors of bronchopulmonary dysplasia. Am J Respir Crit Care Med. Oct. 1995;152(4 Pt 1):1284-9. [pmid: 7551383].
Schaffer D B, Palmer E A, Plotsky D F, et al. Prognostic factors in the natural course of retinopathy of prematurity. The Cryotherapy for Retinopathy of Prematurity Cooperative Group. Ophthalmology. 1993;100(2):230-7. [pmid: 8437832].
Schendel D E, Stockbauer J W, Hoffman H J, et al. Relation between very low birth weight and developmental delay among preschool children without disabilities. Am J Epidemiol. Nov 1. 1997;146(9):740-9. [pmid: 9366622].
Scherjon S A, Oosting H, Smolders-DeHaas H, et al. Neurodevelopmental outcome at three years of age after fetal ‘brain-sparing’. Early Hum Dev. 1998;52(1):67-79. [pmid: 9758249].
Schmidt B, Davis P, Moddemann D, et al. Long-term effects of indomethacin prophylaxis in extremely-low-birth-weight infants. N Engl J Med. Jun 28. 2001;344(26):1966-72. [pmid: 11430325].
Scrutton D. The classification of the cerebral palsies. Dev Med Child Neurol. Sep. 1992;34(9):833. [pmid: 1526354].
Sethi V D, Macfarlane P I. Neurodevelopmental outcome at age two years amongst very low birth weight infants: results from a district general hospital. Public Health. Jul. 1996;110(4):211-4. [pmid: 8757701].
Shalev B, Farr A K, Repka M X. Randomized comparison of diode laser photocoagulation versus cryotherapy for threshold retinopathy of prematurity: seven-year outcome. Am J Ophthalmol. 2001;132(1):76-80. [pmid: 11438057].
Shennan A T, Dunn M S, Ohlsson A, et al. Abnormal pulmonary outcomes in premature infants: prediction from oxygen requirement in the neonatal period. Pediatrics. Oct. 1988;82(4):527-32. [pmid: 3174313].
Shepherd A J, Saunders K J, McCulloch D L, et al. Prognostic value of flash visual evoked potentials in preterm infants. Dev Med Child Neurol. 1999;41(1):9-15. [pmid: 10068044].
Shinwell E S, Karplus M, Reich D, et al. Early postnatal dexamethasone treatment and increased incidence of cerebral palsy. Arch Dis Child Fetal Neonatal Ed. Nov. 2000;83(3):F177-F181. [pmid: 11040164].
Singer L, Yamashita T, Lilien L, et al. A longitudinal study of developmental outcome of infants with bronchopulmonary dysplasia and very low birth weight. Pediatrics. Dec. 1997;100(6):987-93. [pmid: 9374570].
Singer L T, Siegel A C, Lewis B, et al. Preschool language outcomes of children with history of bronchopulmonary dysplasia and very low birth weight. J Dev Behav Pediatr. Feb. 2001;22(1):19-26. [pmid: 11265919].
Slonim A D, Patel K M, Ruttimann U E, et al. The impact of prematurity: a perspective of pediatric intensive care units. Crit Care Med. 2000;28(3):848-53. [pmid: 10752841].
Smith K E, Landry S H, Swank P R, et al. The relation of medical risk and maternal stimulation with preterm infants' development of cognitive, language and daily living skills. J Child Psychol Psychiatry. Oct. 1996;37(7):855-64. [pmid: 8923228].
Speechley K N, Avison W R. Admission to a neonatal intensive care unit as a predictor of long-term health: a 12-year follow-up. J Dev Behav Pediatr. 1995;16(6):397-405. [pmid: 8746548].
Spinillo A, Fazzi E, Stronati M, et al. Early morbidity and neurodevelopmental outcome in low-birthweight infants born after third trimester bleeding. Am J Perinatol. Mar. 1994;11(2):85-90. [pmid: 7515239].
Spinillo A, Fazzi E, Capuzzo E, et al. Meconium-stained amniotic fluid and risk for cerebral palsy in preterm infants. Obstet Gynecol. 1997;90(4 Pt 1):519-23. [pmid: 9380308].
Spinillo A, Capuzzo E, Orcesi S, et al. Antenatal and delivery risk factors simultaneously associated with neonatal death and cerebral palsy in preterm infants. Early Hum Dev. Apr 25. 1997;48(12):81-91. [pmid: 9131309].
Spinillo A, Capuzzo E, Cavallini A, et al. Preeclampsia, preterm delivery and infant cerebral palsy. Eur J Obstet Gynecol Reprod Biol. 1998;77(2):151-5. [pmid: 9578271].
Stathis S L, O'Callaghan M, Harvey J, et al. Head circumference in ELBW babies is associated with learning difficulties and cognition but not ADHD in the school-aged child. Dev Med Child Neurol. Jun. 1999;41(6):375-80. [pmid: 10400171].
Subhedar N V, Shaw N J. Changes in pulmonary arterial pressure in preterm infants with chronic lung disease. Arch Dis Child Fetal Neonatal Ed. May. 2000;82(3):F243-F247. [pmid: 10794795].
Task Force for the Handbook of Psychiatric Measures. Handbook of Psychiatric Measures. American Psychiatric Association; 2000
The Victorian Infant Collaborative Study Group. Improvement of outcome for infants of birth weight under 1000 g. Arch Dis Child. 1991;66(7 Spec No):765-9. [pmid: 1713755].
The Victorian Infant Collaborative Study Group. Changing outcome for infants of birth-weight 500–999 g born outside level 3 centres in Victoria. Aust N Z J Obstet Gynaecol. 1997;37(3):253-7. [pmid: 9325499].
The Victorian Infant Collaborative Study Group. Outcome at 2 years of children 23–27 weeks' gestation born in Victoria in 1991-92. J Paediatr Child Health. Apr. 1997;33(2):161-5. [pmid: 9145362].
The Victorian Infant Collaborative Study Group. Improved outcome into the 1990s for infants weighing 500–999 g at birth. Arch Dis Child Fetal Neonatal Ed. Sep. 1997;77(2):F91-F94. [pmid: 9377152].
Thompson R J Jr, Gustafson K E, Oehler J M, et al. Developmental outcome of very low birth weight infants at four years of age as a function of biological risk and psychosocial risk. J Dev Behav Pediatr. 1997;18(2):91-6. [pmid: 9113589].
Thompson C M, Buccimazza S S, Webster J, et al. Infants of less than 1250 grams birth weight at Groote Schuur Hospital: outcome at 1 and 2 years of age. Pediatrics. May. 1993;91(5):961-8. [pmid: 8474817].
Thompson R J Jr, Goldstein R F, Oehler J M, et al. Developmental outcome of very low birth weight infants as a function of biological risk and psychosocial risk. J Dev Behav Pediatr. 1994;15(4):232-8. [pmid: 7798368].
Thompson R J Jr, Gustafson K E, Oehler J M, et al. Developmental outcome of very low birth weight infants at four years of age as a function of biological risk and psychosocial risk. J Dev Behav Pediatr. Apr. 1997;18(2):91-6. [pmid: 9113589].
Thorndike RL, Hagen EP, Sattler JM. The Stanford-Binet Intelligence Scale: Guide for Administration and Scoring. 4thed. Chicago, IL: Riverside Publishing Company; 1986
Tin W, Fritz S, Wariyar U, et al. Outcome of very preterm birth: children reviewed with ease at 2 years differ from those followed up with difficulty. Arch Dis Child Fetal Neonatal Ed. 1998;79(2):83-7. [pmid: 9828731].
Tin W, Milligan D W, Pennefather P, et al. Pulse oximetry, severe retinopathy, and outcome at one year in babies of less than 28 weeks gestation. Arch Dis Child Fetal Neonatal Ed. Mar. 2001;84(2):F106-F110. [pmid: 11207226].
Torrioli M G, Frisone M F, Bonvini L, et al. Perceptual-motor, visual and cognitive ability in very low birthweight preschool children without neonatal ultrasound abnormalities. Brain Dev. 2000;22(3):163-8. [pmid: 10814898].
Valkama A M, Paakko E L, Vainionpaa L K, et al. Magnetic resonance imaging at term and neuromotor outcome in preterm infants. Acta Paediatr. Mar. 2000;89(3):348-55. [pmid: 10772285].
van Wassenaer A G, Kok J H, Briet J M, et al. Thyroid function in preterm newborns; is T4 treatment required in infants < 27 weeks' gestational age?. Exp Clin Endocrinol Diabetes. 1997;105(Suppl 4):12-8. [pmid: 9439908].
van Wassenaer A G, Kok J H, de Vijlder J J, et al. Effects of thyroxine supplementation on neurologic development in infants born at less than 30 weeks' gestation. N Engl J Med. Jan 2. 1997;336(1):21-6. [pmid: 8970936].
Vohr B, Allan W C, Scott D T, et al. Early-onset intraventricular hemorrhage in preterm neonates: incidence of neurodevelopmental handicap. Semin Perinatol. Jun. 1999;23(3):212-7. [pmid: 10405190].
Vohr B R, Wright L L, Dusick A M, et al. Neurodevelopmental and functional outcomes of extremely low birth weight infants in the National Institute of Child Health and Human Development Neonatal Research Network, 1993-1994. Pediatrics. Jun. 2000;105(6):1216-26. [pmid: 10835060].
Volpe J J. Neurobiology of periventricular leukomalacia in the premature infant. Pediatr Res. Nov. 2001;50(5):553-62. [pmid: 11641446].
Wang J S, Cherng W S, Chen S N. Nursery neurobiologic risk score as a predictor of mortality in premature infants. Zhonghua Min Guo Xiao Er Ke Yi Xue Hui Za Zhi. 1994;35(4):288-93. [pmid: 8085449].
Wang Z, Sauve R S. Assessment of postneonatal growth in VLBW infants: selection of growth references and age adjustment for prematurity. Can J Public Health. Mar. 1998;89(2):109-14. [pmid: 9583252].
Wauben I P, Atkinson S A, Shah J K, et al. Growth and body composition of preterm infants: influence of nutrient fortification of mother's milk in hospital and breastfeeding post-hospital discharge. Acta Paediatr. Jul. 1998;87(7):780-5. [pmid: 9722253].
Whitaker A H, Feldman J F, Van Rossem R, et al. Neonatal cranial ultrasound abnormalities in low birth weight infants: relation to cognitive outcomes at six years of age. Pediatrics. Oct. 1996;98(4 Pt 1):719-29. [pmid: 8885952].
Wildin S R, Anderson A, Woodside M, et al. Prediction of 12-month neurodevelopmental outcome from a 6-month neurologic examination in premature infants. Clin Pediatr (Phila). Jun. 1995;34(6):290-9. [pmcid: 238101]. [pmid: 7656508].
Wildin S R, Smith K, Anderson A, et al. Prediction of developmental patterns through 40 months from 6- and 12-month neurologic examinations in very low birth weight infants. J Dev Behav Pediatr. Aug. 1997;18(4):215-21. [pmid: 9276828].
Wilkinson I, Bear J, Smith J, et al. Neurological outcome of severe cystic periventricular leukomalacia. J Paediatr Child Health. Oct. 1996;32(5):445-9. [pmid: 8933408].
Wodrich D. Children's Psychological Testing: A Guide for Nonpsychologists. Baltimore: Paul H. Brookes Publishing Co.; 1984
Wolke D, Meyer R. Cognitive status, language attainment, and prereading skills of 6-year-old very preterm children and their peers: the Bavarian Longitudinal Study. Dev Med Child Neurol. Feb. 1999;41(2):94-109. [pmid: 10075095].
Wood N S, Marlow N, Costeloe K, et al. Neurologic and developmental disability after extremely preterm birth. EPICure Study Group. N Engl J Med. Aug 10. 2000;343(6):378-84. [pmid: 10933736].