# Acknowledgments

The authors are grateful to the following individuals for their diverse contributions throughout the course of this project: Catherine Cella, Janet Connelly, Kyle Fahrbach, Kimberly James, Michael Rozinsky, members of the Technical Expert Panel, peer reviewers, representatives from the Social Security Administration, and representatives from the Agency for Healthcare Research and Quality.