# Appendix D. Acknowledgments

The Evidence-based Practice Center staff acknowledges the collaboration of the clinical experts who served on the EPC Technical Expert Panel. The EPC also acknowledges the contributions by those who acted as peer reviewers for the evidence report.

## New England Medical Center EPC Project Staff

Joseph Lau, MD; EPC/Project Director

Ethan Balk, MD, MPH, Assistant Project Director and Project Leader, Short Stature

Cynthia Cole, MD, MPH, Coordinating Team Leader

Deirdre DeVine, M Litt, Project Manager

Priscilla Chew, MPH, Project Leader, Failure to Thrive

Kimberly Miller, BA, Research Assistant

Chenchen Wang, MD, MSc, Project Leader, Low Birth Weight

## Technical Expert Panel

Evidence Review Teams, Tufts New England Medical Center

Very Low Birth Weight:

Dr. Cynthia Cole, Project Coordinator and Team Leader

Drs. Geoffrey Binney, John Fiascone, James Hagadorn, and Chiwan Kim Patricia Casey, NNP

Short Stature: Dr. Patricia Wheeler, Team Leader

Drs. Barbara Shephard and Karen Bresnahan

Failure To Thrive: Dr. Ellen Perrin, Team Leader

Drs. Stephan Glicken, Nicholas Guerina, Kevin Petit, Robert Sege, MaryAnn Volpe, and Deborah Frank

James Perrin, MD, Pediatric Consultant to the EPC

Social Security Administration (SSA):

Science Partner: Dr. Paul Burgan, MD, PhD; Regina Connell, MS

Agency for Healthcare Research and Quality (AHRQ)

Marian James, PhD, Task Order Officer

American Academy of Pediatrics

Marilee Allen, MD (Very Low Birth Weight)

Professor

Neonatology, Department of Pediatrics

Johns Hopkins University

Baltimore, Maryland

Joseph Hersh, MD (Short Stature)

Louisville, Kentucky

Michael Farrell, MD (Failure to Thrive)

Chief of Staff

Children's Hospital Medical Center

Cincinnati, Ohio

Carla Herrerias, BS, MPH

Senior Health Policy Analyst

Department of Practice and Research

American Academy of Pediatrics

Elk Grove Village, Illinois

Disability Law Center, Inc.

Linda Landry, Esq.

## Peer Reviewers

### American Academy of Pediatrics

Very Low Birth Weight

- Deborah Campbell, MD
- Hartsdale, New York

- Warren N. Rosenfeld, MD
- Department of Pediatrics
- Winthrop University Hospital
- Mineola, New York

Short Stature

- Susan Rose, MD
- Department of Endocrinology
- Children's Hospital Medical Center of Cincinnati
- Cincinnati, Ohio

Failure to Thrive

- William Cochran, MD
- Department of Pediatric GI/Nutrition
- Geisinger Health System
- Danville, Pennsylvania

### American Association of Clinical Endocrinologists

- A. Jay Cohen, MD
- The Endocrine Clinic, PC
- Memphis, Tennessee

### Lawson Wilkins Pediatric Endocrine Society

- David M. Brown, MD
- Professor of Pediatrics
- University of Minnesota
- Minneapolis, Minnesota

### National Institute of Child Health and Human Development

- Gilman Grave, MD (for Short Stature)
- Chief, Endocrinology, Nutrition and Growth Branch
- Center for Research for Mothers and Children
- Bethesda, Maryland

- Catherine Y. Spong, MD (for VLBW and Failure to Thrive)
- Chief, Pregnancy and Perinatology Branch
- Center for Research for Mothers and Children
- Bethesda, Maryland

- Tonse Raju, MD (for VLBW and Failure to Thrive)
- Pregnancy and Perinatology Branch
- Center for Research for Mothers and Children
- Bethesda, Maryland

### Society for Developmental and Behavioral Pediatrics

- Denis Drotar, MD
- Professor and Chief
- Division of Behavioral Pediatrics and Psychology
- Rainbow Babies and Children's Hospital
- Cleveland, Ohio

- Daniel Kessler, MD
- Phoenix, Arizona