# Appendix C: Acronyms and Abbreviations

AA | Arachidonic acid
AGA | Appropriate for gestational age
ADIT | Auditory discriminating test
BPD | Bronchopulmonary dysplasia
BSCP | Bilateral spastic cerebra palsy
BWVK | Bourdon-Wiersma-Vos concentration test for infants
BW | Birth weight
CBCL | Child Behavior Check List
CLD | Chronic lung disease
CNS | Central Nervous System
CP | Cerebral Palsy
CRIB | Clinical Risk Index for Babies
CRYO ROP | Multicenter Trial of Cryotherapy for ROP
dBHL | Decibels
DHA | Docosahexaenoic acid
DDST | Development Screening test
DQ | Developmental quotient
DR-CPR | Delivery room resuscitation
EHM-T | Exclusively human milk-fed until term CA
ELBW | Extremely Low Birth Weight
GA | Gestational age
GM | Isolated germinal matrix hemorrhage
IBR | Infant behavior record
ICH | Intracranial hemorrhage
IQ | Intelligence quotient
IUGR | Intrauterine growth retardation
IVH | Intraventricular hemorrhage
LBW | Low Birth Weight
MDI | Mental Development Index
MR | Mental Retardation
NBRS | Neurobiologic Risk Score
NBW | Normal Birth Weight
NCHS | National Center for Health Statistics
ND | No data
NEC | Necrotizing enterocolitis
NICHD | National Institute of Child Health and Development
NICU | Neonatal Intensive Care Unit
NS | Not significant
PDA | Patent ductus arteriosus
PDI | Psychomotor Developmental Indexes
PEV | Periventricular echodensities
PL | Parenchymal lesions
PMA | Postmenstrual age
PPVT | Peabody Picture Vocabulary Test
PROM | Premature rupture of membranes
PVL | Periventricular leukomalacia
RCP | Revised Class Play
RDS | Respiratory distress syndrome
ROP | Retinopathy of Prematurity
SGA | Small for gestational age
SNHL | Sensorineural hearing loss
TRF | Teacher Report Form
US | Ultrasound
VE | Ventricular enlargement
VLBW | Very Low Birth Weight
VMI | Visual-motor integration test
VM | Ventriculomegaly
WISC-R | Wechsler Intelligence Scale for Children-Revised
WMD | White Matter Damage
WPPSI | Wechsler Preschool and Primary Scale of Intelligence