# Appendix B: Data Abstraction Form

General instructions for LBW data extraction:

The form has been designed to collect all the relevant information from each article. The data on the form will allow us to fully evaluate each study's population, basic methods, relevant results (relevant for the SSA project), applicability to other children with the condition of interest, and overall quality.

For each line (or section), please circle the appropriate answer to the question (in bold) or fill in the data on the lines provided. Questions proceeded by an * can have multiple answers (such as study performed in UK and France). Please circle “N.D (no data).” if the answer to the question is not provided (eg, if information on the age of the subjects is not provided).

Study Characteristics: Self-explanatory for Country and number of sites.

Length of Following up time: Enter corrected age and average duration.

Corrected age mean: age from the obstetric due date to follow-up evaluation date.

Demographics: Enter all relevant demographic information when provided (eg, mean, standard error and range).

If median is provided, cross out mean and write in median.

For weight, please fill in the relevant data as reported in the article.

For gender and race, fill in the percentages (or the fraction).

Study population: Enter inclusion and exclusion criteria (may need to check abstract,results, and discussion sections for completeness).

Enter total number of subjects with low birth weight enrolled (including those eventually excluded or who withdrew, etc.). If only the number of subjects evaluated is reported, circle N.D.Enter final sample size (the total number of subjects with low birth weight evaluated)

Enter total number of control subjects (presumably of normal Birth weight) enrolled and evaluated.

If reported, list reasons for withdrawal, etc. (Consider this in the assessment of possible bias later on.)

Assess Applicability of study to population of interest:

Consider all the data that has just been entered (study characteristics, demographics, inclusion/exclusion criteria, sample size, number and reasons for withdrawal) to determine how applicable the study is to the population of interest to us. Note that this may be a different population than the population of interest to the study authors.

First circle the question that the study is most relevant for.

Then choose one of the categories:

Category I. If sample is representative of the whole population of babies with prematurity and low birth weight condition relevant to the topic question (eg, whole population of preterm babies and infants with BW 1200–2000g). This implies a reasonable sample size, a diverse group of infants with the condition, and inclusion/exclusion criteria that will capture the whole group. Consider both who the study aimed to recruit and also who they actually included.

Category II. A relevant sub-group or subgroups of very low birth weight and prematurity, (only those with a specific, though common, condition eg: BW 1200–1500g).

Category III. A very narrow group of subjects who are a limited sample of very low birth weight and prematurity (only those with a relatively rare condition, or a non-representative demographic group e.g. crack babies)).

If Category II or III chosen, please indicate reason not in Category I (i.e., why not fully generalizable)

Methodology:

Study design: Provide one answer per line:

What is study design? (For RCT, ensure that authors state “randomized”). Prospective or retrospective cohort studies, retrospective case-control and case series may have one or more arms (i.e. treatment vs placebo).

Predictors of Disability Examined

Please circle or write in the predictors of disability that were examined in the study. These can include the factors or combination of factors predict future disability in the low birth weight and prematurity babies.

Note that the study might not clearly list the predictors evaluated. You may need to check the methods, results and discussion section to figure this out.

If provided, give the definitions the authors used for the various predictors. This may be as simple as Birth weight 1200 gms, or it may be a detailed description of their definition of HIE. This can be kept succinct.

Are the definitions used appropriate?

Outcomes Examined

Similar to predictors, circle or write in the outcomes examined.

Not all examined outcomes are necessary. Include only those that are relevant to the Topic question).

Define outcomes and determine appropriateness.

Results

The tables provided should be able to accommodate most (hopefully all) studies. Even if no statistical analysis was done by the authors, the table should be completed.

Each row will represent specific condition/predictor combination.

In a study with these four groups of subjects, each group would be put on a separate row in the first column of the table.

For each condition/predictor put the number of subjects evaluated in the second column.

In each row, write in the specific outcome evaluated. Each different outcome of interest should have its own row, or group of rows, write the instruments that being used. (How to measure outcome).

In the fourth column, give the results. What percentage of subjects in each group had the outcome of interest. You can also enter the fraction (or number of subjects), if that is easier. If other results are reported (such as odds ratio (OR)) write that in. However, please clarify what the outcome being reported is, if it's not percentage.

If there were results that are of interest, that do not conform to the table, write them in below.

Biases/Limitations:

Write down biases or limitations

Quality of Methods:

Grade quality of study (methods and reporting, not results) in 3 categories, A, B, or C.

Consider methods, definitions used, statistical analyses done, biases, etc.

A. Prospective study that is clearly reported, uses explicit and appropriate eligibility criteria, uses appropriate definitions of predictors and outcomes that are properly measured or estimated, uses appropriate statistical and analytical methods, and is free of obvious bias. Retrospective studies, irrespective of other aspects of quality, cannot be in category A. Study size should not be a factor for quality.
B. Prospective or retrospective study that does not meet qualifications of category A but deficiencies are unlikely to cause major bias.
C. Major deficiencies that cannot exclude possibility of significant bias Insufficiently reported information.
  If B or C, indicate briefly what the deficiency or deficiencies are in the paper.

Please check data information:

Check abstract numbers, tables, results and discussion for discrepancy (e.g. add them all