# Appendix A: MEDLINE, ERIC, PsycInfo and Healthstar Search Strategies

MEDLINE - CNS search

1. exp Infant, Low Birth Weight/
2. low birth weight.tw.
3. exp Infant, Premature/
4. 1 or 2 or 3
5. exp infant, low birth weight/ or exp infant, premature/
6. (small for gestational age or SGA).tw.
7. (preterm infant$ or infant or prematur$ or newborn).tw.
8. disab$.af.
9. limitation$.af.
10. handicap$.af.
11. impair$.af.
12. follow-up studies/
13. follow-up.tw.
14. exp Case-Control Studies/
15. case-control.tw.
16. exp Longitudinal Studies/
17. longitudinal.tw.
18. exp Cohort Studies/
19. cohort.tw.
20. (random$ or rct).tw.
21. exp Randomized Controlled Trials/
22. exp random allocation/
23. exp Double-Blind Method/
24. exp Single-Blind Method/
25. randomized controlled trial.pt.
26. clinical trial.pt.
27. (clin$ adj trial$).tw.
28. ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw.
29. exp PLACEBOS/
30. placebo$.tw.
31. exp Research Design/
32. Comparative Study/
33. exp Evaluation Studies/
34. exp Prospective Studies/
35. 5 or 6 or 7
36. 35 and (8 or 9 or 10 or 11)
37. limit 36 to (clinical trial or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or guideline or meta analysis or practice guideline or randomized controlled trial or review or review literature or review, academic or review, multicase or review, tutorial)
38. 36 and (12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34)
39. 37 or 38
40. limit 39 to human
41. limit 40 to english language
42. neuro$.tw.
43. white matter damage.tw.
44. exp intracranial hemorrhages/ or exp leukomalacia, periventricular/
45. exp Retinopathy of Prematurity/
46. ROP.tw.
47. 43 or 44
48. 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34
49. 2 or 5 or 6 or 7
50. 48 and 49 and 47
51. 42 or 43 or 44
52. 48 and 49 and 51
53. limit 50 to (addresses or bibliography or biography or comment or dictionary or directory or editorial or festschrift or guideline or lectures or legal cases or letter or meta analysis or news or periodical index or practice guideline or review or review literature or review of reported cases or review, academic or review, multicase or review, tutorial)
54. 52 not 53
55. limit 54 to human
56. limit 55 to english language

Eric search

1. follow-up studies/
2. follow-up.tw.
3. exp Case-Control Studies/
4. case-control.tw.
5. exp Longitudinal Studies/
6. longitudinal.tw.
7. exp Cohort Studies/
8. cohort.tw.
9. (random$ or rct).tw.
10. exp Randomized Controlled Trials/
11. exp random allocation/
12. exp Double-Blind Method/
13. exp Single-Blind Method/
14. randomized controlled trial.pt.
15. clinical trial.pt.
16. (clin$ adj trial$).tw.
17. ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw.
18. exp PLACEBOS/
19. placebo$.tw.
20. exp Research Design/
21. Comparative Study/
22. exp Evaluation Studies/
23. disab$.af.
24. exp disabilities/
25. limitation$.af.
26. handicap$.af.
27. impair$.af.
28. exp PHYSICAL DISABILITIES/ or exp SEVERE DISABILITIES/ or exp DEVELOPMENTAL DISABILITIES/ or exp LEARNING DISABILITIES/ or exp MILD DISABILITIES/ or exp MULTIPLE DISABILITIES/
29. (small for gestational age or SGA).tw.
30. exp birth weight/
31. exp premature infants/
32. (preterm infant$ or infant or prematur$ or newborn).tw.
33. 23 or 24 or 25 or 26 or 27 or 28
34. 33 and (29 or 30 or 31 or 32)
35. 34 and (1 or 2 or 4 or 6 or 8 or 9 or 16 or 17 or 19 or 20 or 21)

GI search

174. exp enterocolitis/

175. exp cholestasis/

176. exp short bowel syndrome/

177. enterocolitis$.tw.

178. NEC.tw.

179. necrot$.tw.

180. (Total parenteral nutrition or TPN).tw.

181. cirrhosis.tw.

182. (gastrostomies or GERD or Fundoplication).tw.

183. short bowel syndrome.tw.

184. cholestasis.tw.

185. short gut.tw.

186. necrotizing.tw.

187. exp cirrhosis/

Health Care

174. rehospitalization.af.

175. costs.af.

176. costs.tw.

177. physical therapy.af.

178. exp *Occupational Therapy/

179. exp *Physical Therapy/

180. orthopedic.tw.

181. occupational therapy.af.

189. Health care resource.mp. or utilization.af. [mp=title, abstract, registry number word, mesh subject heading]

190. arthopedic.af.

191. orthopedic.af.

Healthstar

1. exp infant, low birth weight/ or exp infant, premature/
2. (small for gestational age or SGA).tw.
3. (preterm infant$ or infant or prematur$ or newborn).tw.
4. disab$.af.
5. limitation$.af.
6. handicap$.af.
7. impair$.af.
8. follow-up studies/
9. follow-up.tw.
10. exp Case-Control Studies/
11. case-control.tw.
12. exp Longitudinal Studies/
13. longitudinal.tw.
14. exp Cohort Studies/
15. cohort.tw.
16. (random$ or rct).tw.
17. exp Randomized Controlled Trials/
18. exp random allocation/
19. exp Double-Blind Method/
20. exp Single-Blind Method/
21. randomized controlled trial.pt.
22. clinical trial.pt.
23. clin$ adj trial$).tw.
24. ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw.
25. exp PLACEBOS/
26. placebo$.tw.
27. exp Research Design/
28. Comparative Study/
29. exp Evaluation Studies/
30. exp Prospective Studies/
31. 1 or 2 or 3
32. 31 and (4 or 5 or 6 or 7)
33. limit 32 to (clinical trial or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or guideline or meta analysis or practice guideline or randomized controlled trial or review or review literature or review, academic or review, multicase or review, tutorial)
34. 32 and (8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30)
35. 33 or 34
36. limit 35 to human
37. limit 36 to english language
38. limit 37 to nonmedline

Immune

174. exp *Immunologic Diseases/ or exp *Autoimmune Diseases/ or exp *Collagen Diseases/ or exp *Immunologic Deficiency Syndromes/

Perinatal

174. antenatal steroid.tw.

175. Chorioamnioni$.tw.

176. chorionic villous sampling.tw.

177. diabet$.tw.

178. pre-eclamp$.tw.

179. 174 or 175 or 176 or 177 or 178

PsycInfo

1. follow-up studies/
2. follow-up.tw.
3. exp Case-Control Studies/
4. case-control.tw.
5. exp Longitudinal Studies/
6. longitudinal.tw.
7. exp Cohort Studies/
8. cohort.tw.
9. (random$ or rct).tw.
10. exp Randomized Controlled Trials/
11. exp random allocation/
12. exp Double-Blind Method/
13. exp Single-Blind Method/
14. randomized controlled trial.pt.
15. clinical trial.pt.
16. (clin$ adj trial$).tw.
17. ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw.
18. exp PLACEBOS/
19. placebo$.tw.
20. exp Research Design/
21. Comparative Study/
22. exp Evaluation Studies/
23. exp Prospective Studies/
24. exp Premature Birth/
25. exp birth weight/
26. (small for gestational age or SGA).tw.
27. (preterm infant$ or infant or prematur$ or newborn).tw.
28. exp DISABILITY EVALUATION/
29. exp disabled/
30. disab$.af.
31. limitation$.af.
32. exp Mentally Retarded/
33. exp Behavior Problems/
34. exp communication skills/
35. handicap$.af.
36. impair$.af.
37. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23
38. 24 or 25 or 26 or 27
39. 37 and 38
40. 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36
41. 39 and 40
42. 38 and 40
43. limit 42 to (“0840 follow up study” or “0850 longitudinal study” or “0860 treatment outcome study” or “0900 errata/retractions” or 1300 literature review/research review or 1400 meta-analysis)
44. 41 or 43
45. limit 44 to human
46. limit 45 to english language

ROP

174. (retinopathy of prematur$ or POP).tw.

175. exp retinopathy of prematur$/ or POP/

176. (visu$ impair$ or blindness).tw.

177. Hypoxic-Ischemic encephalopathy.tw.

Acuity

174. SNAP.tw.

175. CRIB.tw.

176. 174 or 175

Audiology

174. Lasix.tw.

175. exp lasix/

176. hearing disorder$.tw.

177. aminoglycosides.tw.

Infection

174. RSV.tw.

175. exp meningitis/

176. meningitis.tw.

177. exp sepsis/

178. (sepsis or septic).tw.

179. congenit$.tw.

180. acquired.tw.

Lung dz

174. chronic lung disease$.tw.

175. Bronchopulmonary dysplasia$.tw.

176. asthma$.tw.

177. exp asthma/

178. pulmonary function$.tw.

179. tracheostomy.tw.

180. upper airway.tw.

181. reactive airway.tw.

182. exercise tolerance.tw.

183. exp upper airway/

184. exp tracheostomy/

191. exp *Lung Diseases/ or exp *Hypertension, Pulmonary/ or exp *Lung Diseases, Obstructive/ or exp *Bronchopulmonary Dysplasia/

192. upper airway.af.

193. asthma.af.

194. pulmonary function$.af.

Medication

174. dexamethasone.tw.

175. 50-02-2.rn.

176. dexamethasone.af.

Nutrition

174. exp nutrition/

175. nutrition.tw.

176. growth disorder$.tw.

177. exp growth disorder$/

184. exp Child Nutrition Disorders/

185. exp PARENTERAL NUTRITION, TOTAL/ or exp INFANT NUTRITION DISORDERS/