# Acknowledgments

We owe a major debt of gratitude to the following teams of multidisciplinary experts who assisted us in preparing this report.

## Technical Experts

Our 11-member panel of technical experts played an active role throughout the preparation of this report, particularly in these areas:

- Selecting the research questions
- Suggesting the types of data to be abstracted from pertinent studies
- Guiding selection of relevant data to include in the evidence tables
- Reviewing the draft report
- Suggesting effective methods to disseminate the final report to health professionals, policymakers, and consumers

- Rachel Churchill, MSc
- Institute of Psychiatry
- London, UK
- Representing: Cochrane Collaboration
- Depression, Anxiety, and Neurosis Review Group

- Paul Gerber, MD
- Department of Medicine
- Dartmouth Medical School
- Representing: American College of Physicians

- Thomas T. Gilbert, MD, MPH
- Department of Family Medicine
- Boston Medical Center
- Representing: American Academy of Family Practice

- Enid Hunkeler
- Kaiser Permanente
- Representing: a consortium of health maintenance organizations

- Mauricio Silva de Lima, MD, MSc, PhD
- Universidade Federal de Pelotas, RS, Brazil
- Representing: Cochrane Collaboration
- Depression, Anxiety, and Neurosis Review Group

- Ricardo Muñoz, PhD
- Department of Psychiatry
- University of California, San Francisco
- Representing: American Psychological Association

- Matthew V. Rudorfer, MD
- National Institute of Mental Health
- Division of Services and Intervention Research
- Representing: National Institute of Mental Health

- Glen Stimmel, PharmD, FCCP
- University of Southern California
- Schools of Pharmacy and Medicine
- Representing: American Pharmaceutical Association

- Gail Stuart, RN, PhD, CS
- Medical University of South Carolina
- Center for Health Care Research
- Representing: American Psychiatric Nurses' Association

- Kay York
- President, National Depressive and Manic Depressive Association of Houston and Harris County
- Representing: National Depressive and Manic Depressive Association

- Deborah Zarin, MD
- Deputy Director
- American Psychiatric Association
- Representing: American Psychiatric Association

## Peer Reviewers

In addition to the technical experts, the following professionals peer-reviewed the draft report:

- Mary Ann Cohen, MD
- New York, New York

- Eduardo Colón, MD
- Hennepin County Medical Center
- Minneapolis, Minnesota

- Rodney Copeland, MD
- State of Vermont
- Department of Developmental and Mental Health Services

- Kenneth Covinsky, MD
- San Francisco VA Medical Center

- Allen Dietrich, MD
- Dartmouth Medical Center
- hanover, New Hampshire

- Rosemary K. Emmons, RN, BSW
- Regions Hospital
- St. Paul, Minnesota

- John Geddes, MD
- University of Oxford
- United Kingdom

- Mark S. Gold, MD
- Shands Cancer Center
- Gainesville, Florida

- Grace Hayes, PharmD
- Atascadero State Hospital
- Atascadero, California

- Michael W. Jann, PharmD, FCCP
- Mercer University School of Pharmacy
- Atlanta, Georgia

- Nathaniel S. Lehrman, MD
- Roslyn, New York

- Michael K. Popkin, MD
- Hennepin County Medical Center
- Minneapolis, Minnesota

- Lynn P. Rehm, PhD
- University of Houston
- Houston, Texas

- Mark Sullivan, MD
- University of Washington at Seattle
- Seattle, Washington

- Michael Von Korff, ScD
- Center for Health Studies
- Seattle, Washington

### Methodology Reviewer

- Jesse Berlin, ScD
- University of Pennsylvania School of Medicine
- Philadelphia, PA

### Criticism Editor

- Patricia Huston, MD, MPH
- Ottawa Heart Institute
- Ottawa Ontario CANADA

## Other external groups and individuals who provided assistance and support

- The Cochrane Collaboration Depression, Anxiety, and Neurosis Review Group provided the database of articles that was our primary literature source. Our thanks for their expertise and support go to Drs. Simon Charles Wessely and Hugh McGuire of King's College School of Medicine and Institute of Psychiatry in London and to Mark Oakley-Browne at the University of Auckland in New Zealand.
- The San Francisco Evidence-based Practice Center helped coordinate the peer review of the report. Our thanks to Drs. Lisa Bero, Drummond Rennie, and Andrea Clark.
- Betsy Anagnostelis of the Royal Free Hospital School of Medicine in London performed our very large EMBASE search on uncommon but serious side effects.
- The following groups that nominated the topic of newer pharmacotherapies for depression to the Agency for Health Care Policy and Research:
  - State of Vermont
  - Blue Cross and Blue Shield of Massachusetts
  - National Institute of Mental Health
  - American Pharmaceutical Association
  - American Psychiatric Association

## San Antonio Evidence-based Practice Center Partners

- Herb Waxman, MD, FACP
- Senior Vice President, Professional Affairs
- American College of Physicians

- Christel Mottur-Pilson, PhD
- Director, Scientific Policy, Education
- American College of Physicians

- Lisa Anne Bero, PhD
- Co-Director, San Francisco Cochrane Center

- Frank Davidoff, MD, FACP
- Editor, Annals of Internal Medicine
- American College of Physicans

- Marc Silverstein, MD
- Director of the Center for Health Care Research
- Medical University of South Carolina

- Drummond Rennie, MD, MA, B.Chir, FRCP, FACP
- Co-Director, San Francisco Cochrane Center

## San Antonio Evidence-based Practice Center and VERDICT Staff

### Project Leaders

- Cynthia D. Mulrow, MD, Msc
- EPC Center Director

- John W. Williams, Jr., MD, MHS
- EPC Project Director

- Elaine Chiquette, PharmD
- EPC Project Manager

- Madhukar Trivedi, MD
- EPC Specific Content Expert

### Project Staff and Consultants

- Christine Aguilar, MD, MPH
- Robert Badgett, MD
- Valerie Lawrence, MD, MSc
- Kelly Montgomery, MPH
- Polly Hitchcock Noël, PhD
- W. Scott Richardson, MD

### Abstractors

- Catherine Vriend, PhD
- Jayme Trott, PharmD
- Anita McQuillen, PhD
- Lisa Archiniega, PhD

### Statisticians

- John E. Cornell, PhD
- Michael Luther, MS
- Gilbert Ramirez, DrPH
- Shuko Lee-Borgess, MS

### Informatics

- Michael Brand, RN

### Technical Writer

- Karen Stamm

### Librarians

- Gina Harris, MLS
- Martha Harris
- Linn Morgan

### Computer Resources

- Richard Moreno
- Francisco Jose Gonzalez
- Dave Mullins

### Administration

- Liz Oyen
- Annie M. Almanza