# Glossary

Absolute Risk Reduction (ARR): The risk difference in outcome rates between 2 experimental groups. It is the difference between the unexposed or control event rate (CER) and the treated or experimental event rate (EER).

Acute Therapy: The initial treatment of a patient to reduce and whenever possible, remove all signs and symptoms of the depressive syndrome and to restore the patient's functions to an asymptomatic state.

Anxiolytic Agent: Medications used to treat anxiety, typically of the benzodiazepine class.

Augmentation Therapy: A drug regimen consisting of one or more agents, which are not of themselves antidepressants, added to increase the efficacy of an antidepressant drug. An example would be to add pindolol to fluoxetine.

Benzodiazepine: A class of drugs typically used to treat anxiety. These drugs include agents such as chlordiazepoxide (Librium), diazepam (Valium), fluarzepam (Dalmane), and lorazepam (Ativan).

Bias: Systematic error in study design which may skew the truth.

Bipolar Disorders: Bipolar disorders are characterized by the occurrence of one or more manic, hypomanic or mixed episodes. Episodes of elevated mood interspersed with major depressive episodes are the classical presentation of these disorders. The depressive episodes occurring with a bipolar disorder require the same criteria as in major depression, except for the inclusion of a manic, hypomanic or mixed episode. Manic and hypomanic episodes are periods of persistently elevated or irritable mood lasting at least a week for the former and a minimum of 4 days for the latter.

Blinded, Masked, or Unaware: Blinded studies purposely deny access to information in order to keep that information from influencing some measurement, observation, or process. The intent of blinding is to reduce bias.

Cointervention: Interventions other than the treatment under study. If cointerventions, such as the use of hypnotics or anxiolytics, are differentially applied to the newer antidepressant and comparison groups, biased or erroneous interpretations are possible.

Confidence Interval (CI): A range of values consistent with the experimental data that provides a measure of precision or uncertainty. The frequently used 95% CIs is commonly defined as the range of values within which we can be 95% sure that the true value lies for the whole population of patients from whom the study patients were selected. CIs provide us with the "neighborhood" within which the true value likely resides. Clinical research provides a "point estimate" of effect from a sample of patients; and CIs express the degree of uncertainty or imprecision on either side of the point estimate. The width of the CI is largely affected by the square root of the sample size; thus the larger the sample size, the more narrow/precise is the CI.

Confounding Variable: This technical phrase is used for any characteristic of the study subjects, study setting, or interventions that is extraneous to the study question, that could cause (or influence the chance of) the clinical events of interest and that might be unevenly distributed between the treatment groups. For example, in a study of whether gray hair causes death, since advancing age is associated with gray hair, and advancing age is also associated with mortality, then age could be considered a confounding variable.

Continuation Therapy: The stage of treatment of depressive disorders in which the patient has returned to normal mood and treatment is extended for a period of time in order to prevent relapse.

Depression Not Otherwise Specified (Depression NOS): Depression not otherwise specified includes mood conditions with depressive symptoms that do not meet either severity or duration criteria for dsythymia, a major depression, or bipolar disorders. Examples are premenstrual dysphoric disorder, subsyndromal or minor depressive disorder, and recurrent brief depressive disorder.

Depression with Atypical Features: The symptoms associated with atypical depression are assessed for the most recent 2 weeks and consist of: mood brightening in response to events (required), hypersomnia, weight gain, leaden paralysis, and rejection sensitivity (lifetime pattern).

Depression with Melancholic Features: To assess for this specifier, symptoms at the nadir (the worst two week period) of the episode are evaluated. The primary symptoms of melancholic depression are: loss of pleasure in all or almost all activities and/or lack of mood reactivity to usually pleasurable stimuli. Other common symptoms are: early morning wakening, morning worsening, psychomotor retardation/agitation, significant anorexia/weight loss, and a distinct quality of the depressed mood unlike grief.

Depression with Postpartum Onset: The specifier with postpartum onset can be applied to a major depressive episode if symptom onset occurs within 4 weeks after the delivery of a child. Generally, the symptomatology is relatively the same for depressive episodes with postpartum onset as for those without postpartum onset. Women with postpartum depressive episodes often have anxiety, panic attacks, disinterest in their new infant, and insomnia.

Depression with Seasonal Pattern: The principal feature of the seasonal pattern specifier is the onset and remission of major depressive episodes at characteristic times of the year. The episodes usually begin in fall or winter and remit in spring. This pattern of onset and remission must have occurred during the last two years, without any nonseasonal episodes occurring during this period. The occurrence of winter-type seasonal pattern varies with age, geographic latitude and gender.

Depressive Disorder: Consists of disorders characterized by depressive symptoms only, without a history of a manic, mixed or hypomanic episode. Depressive disorders are typically divided into: major depressive disorder, dysthymic disorder, and depression not otherwise specified (NOS).

Diagnostic Statistical Manual: A compilation of standard diagnostic criteria for psychiatric conditions. The editions cited in this report include:

Double Depression: The diagnosis of a major depressive disorder in a patient with a dysthymic disorder.

Dropout: When a study subject withdraws or is removed from a study group for any reason, that subject is termed a dropout.

Dysthymic Disorder: Dysthymic disorder is a chronic condition characterized by depressed mood, less severe than major depression, that is present on more days than not, for a period of two years. During this period, there must also be at least two of the following symptoms: appetite disturbance, insomnia/hypersomnia, decreased energy/fatigue, low self-esteem, decreased concentration or difficulty making decisions, or feelings of hopelessness.

Efficacy: The ability of an agent to produce intentional actions, effects, or results in a therapy situation. Efficacy is commonly used to describe how well an agent works in the controlled settings of research studies, rather than in routine clinical practice.

Endogenous Depression: This phrase has been used to denote depressive disorders in patients without an obvious external precipitant, in contrast to the situation in patients whose depression is judged to be "exogenous" or "reactive" to external events. While not universally abandoned, this phrase is no longer included in the DSM-IV.

Event Rate: Portion of patients in a group in whom an event is observed. Controlled event rate (CER) and experimental event rate (EER) are used to refer to this in control and experimental groups of patients, respectively.

Functional Status: The ability of a person to carry out social, occupational, physical, and other important life activities.

Incidence: Number of new cases of disease occurring during a specified period of time; expressed as a percentage of the number of people at risk.

International Classification of Disease: The World Health Organization classification scheme for all diseases, including psychiatric conditions. Editions cited in this report include:

Maintenance Therapy: A long or short term therapy of antidepressant medication for patients in remission designed to prevent another episode of depression.

Major Depression: The essential feature of a major depressive episode is a period of at least 2 weeks during which there is either depressed mood or the loss of interest or pleasure in almost all activities nearly every day, and during which there is a display of 5 or more of the following symptoms: depressed mood most of the day, marked diminished interest or pleasure in all, or almost all activities most of the day, significant weight loss/weight gain, or decrease/increase in appetite, insomnia/hypersomnia, psychomotor agitation/retardation, fatigue/loss of energy, feelings of worthlessness/excessive or inappropriate guilt, diminished ability to think or concentrate, indecisiveness, recurrent thoughts of death, including thoughts of suicide.

Median Survival: Length of time that one-half of the study population survives.

Melancholic Depression: (see depression with melancholic features)

Meta-Analysis: A systematic review which uses quantitative tools to summarize the results.

Mild Depression: Episodes of a major depressive disorder whose severity is characterized by the presence of only 5-6 depressive symptoms and either mild disability or the capacity to function normally, but with a substantial and unusual effort.

Minor Depression: (see subsyndromal depression)

Mixed Anxiety-Depressive Disorder: The essential feature of mixed anxiety-depressive disorder is persistent dysphoric mood lasting for one month, which must be accompanied by 4 of the following symptoms: difficulty concentrating/mind going blank, sleep disturbance, fatigue/low energy, irritability, worry, being easily moved to tears, hypervigilance, hopelessness, low self-esteem or feelings of worthlessness.

Moderate Depression: Episodes without psychotic features that occur in a major depressive disorder having symptoms that are midway between mild and severe.

Monoamine Oxidase Inhibitors: Non-selective Mono Amine Oxidase (MAOIs): the "older" MAO agents that have the ability to block oxidative deamination of naturally occurring monoamines resulting in greater concentrations of such neurotransmitters as epinephrine, norepinephrine, dopamine, and 5-HT. "Older" MAOI agents produce irreversible inactivation of the enzyme, while the "newer" MAOIs produce a reversible blockade.

Odds Ratio: A ratio of odds that describes the odds that a patient in an exposed or intervention group suffers an adverse event relative to a control patient. When the outcome of interest is infrequent, the odds ratio very closely approximates the relative risk.

Point Estimate: This phrase refers to the actual numerical result of the effect size found in single study or when combining study results. The word "estimate" reminds us that any single experiment result may not be the absolute truth, but rather be an estimate of the true value. Similarly, by pooling study results, the estimate may move closer to the truth, but it remains an estimate of the actual effect size. The modifier "point" refers to the actual calculated result, and to the fact that this result, often represented graphically as a point (or vertical line or diamond) on the horizontal line, shows the 95% confidence interval around the estimate.

Practice Guidelines: Systematically developed statements to assist practitioner and patient decisions about appropriate health care for specific clinical circumstances. They are a set of statements, directions, or principles presenting current clinical rules or policy concerning proper indications for performing a procedure or treatment or for the proper management of specific clinical problems.

Prevalence: Proportion of persons affected with a particular disease at a specified time. Prevalence rates obtained from high quality studies can inform the clinician's efforts to set anchoring pretest probabilities for their patients.

Primary Care Setting: An outpatient non-psychiatric medical setting where care is usually delivered by a general practitioner.

Prognosis: The possible outcomes of a disorder and the frequency with which they can be expected to occur.

Psychiatric Setting: An inpatient or outpatient setting where care is delivered by psychiatric personnel.

Psychosocial: A form of psychotherapy that includes education, support, and/or counseling used to address a patient's psychological and/or social functions.

Psychotic Depression: A depressive episode with psychotic features. Mood symptoms predominate and the psychotic symptoms may fluctuate. The content of psychotic symptoms such as delusions or hallucinations is usually related to sadness or guilt.

Publication Bias: Because studies producing positive results are more likely to be published than those producing negative results, systematic reviews that include only published studies may be susceptible to "publication bias," thus yielding results more positive than the true effect.

Quality of Life: An individual's assessment of his/her well being and functioning in important aspects of life. In health care research, this phrase usually refers to "health related quality of life," that is, the effects of various of health conditions and their impact on daily life and life satisfaction.

Randomized Trial: An experimental research study where the allocation of participants to groups is by a formal chance process such that each patient has an independent fixed (generally equal) chance of selection for either the intervention or comparison group. This process is meant to reduce bias and to provide the fairest and most rigorous comparison of efficacy of drugs.

Recurrent Depression: A new episode of major depression in a patient with one or more prior episodes of depression. There must be an interval of at least 2 consecutive months between episodes in which criteria for major depression are not met.

Relative Risk: This phrase denotes one of several ways to quantitatively describe the strength of association between a suspected cause and its presumed effect. The relative risk is a ratio of two risks, namely the risk of the outcome in those exposed to the suspected cause compared with the risk of the outcome in those not exposed. A relative risk of one represents no association between the suspected cause and the presumed effect. A relative risk above one means the exposure is associated with the outcome, and the larger the number the stronger the association. Conversely, a relative risk smaller than one means the exposure is "negatively associated" with the outcome, which suggests the exposure may protect against the outcome.

Response Rate: The percentage of persons given a particular therapy who improve depressive symptoms by at least 50%.

Risk Difference: The difference between the proportion of adverse events that occur in the intervention group and the proportions that occur in the control group.

Risk Ratio: The measure of the relative risk of an outcome in the intervention group compared to the risk in the control group.

Sensitivity Analysis: Any test of the stability of the conclusions of the health care evaluation over a range of probability estimates, value judgments, and assumptions about the structure of the decisions to be made.

Serious Concomitant Illness: The term used in studies to describe patients who have significant coexisting or comorbid medical conditions such as liver, kidney, or cardiac diseases.

Severe Depression: Characterized by the presence of most of the symptoms of major depression and a clear-cut, observable disability such as the inability to work or care for children.

Statistical Heterogeneity: The term applied when differences between study results are not due to chance alone, suggesting important variances in the studies. Sources of heterogeneity include different types of study participants, varying diagnoses, different treatment strategies, and multiple outcome measures.

Subsyndromal Depressions: Subsyndromal depressions are levels of depressive symptoms that are associated with increased risk of major depression, physical disability, medical illness, and high use of health services but that do not meet the Diagnostic and Statistical Manual of Mental Disorders (DSM-IV), 4th ed., criteria for major depression or dysthymia. They are often cited as minor depression or depression NOS. Other names include: subsyndromal symptomatic depression, subclinical depression, mild depression, subthreshold depression, or minor depressive disorder.

Systematic Review: The overview of a research study that begins with a specific question and summarizes all the primary research that seeks to answer that question according to a rigorous and predefined methodology.

Tricyclic agents: A class of antidepressant drugs that share a similar chemical structure, and hence similar mechanisms of action as well as similar adverse effects.