# Acronyms and Abbreviations

5-HT_1A_ | 5-HT_1A_ receptor agonist
5-HT_2_ | 5-HT_2_ receptor antagonist
AHCPR | Agency for Health Care Policy and Research
CCDAN | Cochrane Collaboration Depression Anxiety and Neurosis
CGI | Clinical Global Impression
CI | confidence interval
Dibenz | dibenzoxazepine
DopAnt | dopamine antagonist
DopRI | dopamine reuptake inhibitor
DSM | Diagnostic and Statistical Manual of Mental Disorders
ECT | electroconvulsive therapy
EPC | Evidence-based Practice Center
FDA | Food and Drug Administration
Gaba | gabamimetics
HAMD | Hamilton Depression Rating Scale
Herbal | herbal remedy
HIV | human immunodeficiency virus
ICD-9 | International Classification of Disease, 9^th^ edition
MADRS | Montgomery Asberg Depression Rating Scale
MAOI | monoamine oxidase inhibitor
MDD | major depressive disorder
Misc | miscellaneous
MIT | modified intention to treat
NK | not known
NOS | not otherwise specified
NRI | norepinephrine reuptake inhibitor
RD | rate difference
RDC | Research Diagnostic Criteria
RIMA | reversible inhibitor of monoamine oxidase A
RR | risk ratio
SIADH | antidiuretic hormone secretion
SNRI | serotonin noradrenaline reuptake inhibitor
SSRI | selective serotonin reuptake inhibitor
t.i.d. | three times per day
TCA | tricyclic agent
Tetra | tetracyclic
Triazo | triazolopyridine