# References

1 Kessler RC, McGonagle KA, Zhao S, Nelson CB, Hughes M, Eshleman S, Wittchen HU, Kendler KS. Lifetime and 12-month prevalence of DSM-III-R psychiatric disorders in the United States: Results from the National Comorbidity Survey. Arch Gen Psychiatry. 1994;51(1):8-19. [pmid: 8279933].
2 Regier DA, Boyd JH, Burke JD, Jr, Rae DS, Myers JK, Kramer M, Robins LN, George LK, Karno M, Locke BZ. One-month prevalence of mental disorders in the United States: Based on five Epidemiologic Catchment Area sites. Arch Gen Psychiatry. 1988;45(11):977-86. [pmid: 3263101].
3 Greenberg PE, Stiglin LE, Finkelstein SN, Berndt ER. Depression: A neglected major illness. J Clin Psychiatry. 1993;54(11):419-24. [pmid: 8270584].
4 Murray CJ, Lopez AD. Global burden of disease. Cambridge (MA): Harvard University Press; 1966.
5 Murray CJ, Lopez AD. Evidence-based health policy: Lessons from the Global Burden of Disease Study. Science. 1996;274(5288):740-3. [pmid: 8966556].
6 Depression in primary care. Vol.1, Detection and diagnosis. Clinical Practice Guideline, No. 5. Rockville (MD): U.S. Department of Health and Human Services, Agency for Health Care Policy and Research. 1993. AHCPR Publication No. 93-0550.
7 Depression in primary care. Vol.2, Treatment of major depression. Clinical Practice Guideline, No. 5. Rockville (MD): U.S. Department of Health and Human Services, Agency for Health Care Policy and Research. 1993. AHCPR Publication No. 93-0551.
8 Muñoz RF, Hollon SD, McGrath E, Rehm LP, VandenBos GR. On the AHCPR depression in primary care guidelines: Further consideration for practitioners. Am Psychol. 1994;49 (1):42-61. [pmid: 8122817].
9 Diagnostic and statistical manual of mental disorder. 4th ed. Washington (DC): American Psychiatric Press; 1994.
10 Osser DN. A systematic approach to the classification and pharmacotherapy of nonpsychotic major depression and dysthymia. J Clin Psychopharmacol. 1993;13 (2):133-44. [pmid: 8463446].
11 Roy-Byrne P, Katon W, Broadhead WE, Lepine JP, Richards J, Brantley PJ, Russo J, Zinbarg R, Barlow D, Liebowitz M. Subsyndromal ("mixed") anxiety-depression in primary care. J Gen Intern Med. 1994;9 (9):507-12. [pmid: 7996294].
12 Rush AJ, Kupfer DJ. Strategies and tactics in the treatment of depression. Vol. 1, Treatments of psychiatric disorders. 2nd ed. Washington (DC). American Psychiatric Press. 1995:p. 1349-68.
13 Blazer DG, Kessler RC, McGonagle KA, Swartz MS. The prevalence and distribution of major depression in a national community sample: The National Comorbidity Survey. Am J Psychiatry. 1994;151(7):979-86. [pmid: 8010383].
14 Simon GE, VonKorff M. Suicide mortality among patients treated for depression in an insured population. Am J Epidemiol. 1998;47(2):155-60.
15 Hays RD, Wells KB, Sherbourne CD, Rogers W, Spritzer K. Functioning and well-being outcomes of patients with depression compared with chronic general medical illnesses. Arch Gen Psychiatry. 1995;52(1):11-9. [pmid: 7811158].
16 Kazis LE, Miller DR, Clark J, Skinner K, Lee A, Rogers W, Spiro A 3d, Payne S, Fincke G, Selim A, Linzer M. Health-related quality of life in patients served by the Department of Veterans Affairs: Results from the Veterans Health Study. Arch Intern Med. 1998;158(6):626-32. [pmid: 9521227].
17 Covinsky KE, Fortinsky RH, Palmer RM, Kresevic DM, Landefeld CS. Relation between symptoms of depression and health status outcomes in acutely ill hospitalized older persons. Ann Intern Med. 1997;126(6):417-25. [pmid: 9072926].
18 Spitzer RL, Kroenke K, Linzer M, Hahn SR, Williams JB, deGruy FV 3d, Brody D, Davies M. Health-related quality of life in primary care patients with mental disorders: Results from the PRIME-MD 1000 study. JAMA. 1995;274(19):1511-7. [pmid: 7474219].
19 Hirschfeld RM, Keller MB, Panico S, Arons BS, Barlow D, Davidoff F, Endicott J, Froom J, Goldstein M, Gorman JM, et al. The National Depressive and Manic-Depressive Association consensus statement on the undertreatment of depression. JAMA. 1997;277(4):333-40. [pmid: 9002497].
20 Rush AJ, Prien RF. From scientific knowledge to the clinical practice of psychopharmacology: Can the gap be bridged?. Psychopharmacol Bull. 1995;1(1):7-20.
21 Persons JB, Thase ME, Crits-Cristoph P. The role of psychotherapy in the treatment of depression: Review of two practice guidelines. Arch Gen Psychiatry. 1996;53(4):283-90. [pmid: 8634003].
22 Thase ME, Greenhouse JB, Frank E, Reynolds CF 3rd, Pilkonis PA, Hurley K, Grochocinski V, Kupfer DJ. Treatment of major depression with psychotherapy or psychotherapy-pharmacotherapy combinations. Arch Gen Psychiatry. 1997;54(11):1009-15. [pmid: 9366657].
23 Conte HR, Plutchik R, Wild KV, Karasu TB. Combined psychotherapy and pharmacotherapy for depression. Arch Gen Psychiatry. 1986;43:471-9. [pmid: 3516110].
24 Persad E. Electroconvulsive therapy in depression. Can J Psychiatry. 1990;35(2):175-82. [pmid: 2180554].
25 Sobin C, Prudic J, Devanand DP, Nobler MS, Sackeim HA. Who responds to electroconvulsive therapy? A comparison of effective and ineffective forms of treatment. Br J Psychiatry. 1996;169(3):322-8. [pmid: 8879718].
26 Peden JG, Jr, Kathol R. Mood disorders and general medical illness. Vol.1, Treatments of psychiatric disorders. 2nd ed. Washington (DC). American Psychiatric Press. 1995:p. 1330-48.
27 Quitkin FM, Rabkin JG, Ross D, McGrath PJ. Duration of antidepressant drug treatment. What is an adequate trial?. Arch Gen Psychiatry. 1984;41(3):238-45. [pmid: 6367689].
28 Canadian Coordinating Office for Health Technology Assessment. Selective serotonin reuptake inhibitors (SSRIs) for major depression. Part I, Evaluation of the clinical literature. CCOHTA Report 1997:3E. Ottawa: Canadian Coordinating Office for Health Technology Assessment; 1997.
29 Hotopf M, Lewis G, Normand C. Are SSRIs a cost-effective alternative to tricyclics?. Br J Psychiatry. 1996;168(4):404-9. [pmid: 8730935].
30 North of England Evidence Based Guideline Development Project. The choice of antidepressants for depression in primary care. University of Newcastle upon Tyne: Centre for Health Services Research; 1998.
31 American Psychiatric Association Practice Guidelines. Practice guideline for major depressive disorder in adults. Am J Psychiatry. 1993;150(4 (Suppl)):iii-25.
32 Martindale W, Reynolds JE, editors. The extra pharmacopoiea. 30th ed. London. The Pharmaceutical Press. 1993.
33 Schlesser JL, editor. Drugs available abroad. A guide to therapeutic drugs available and approved outside the U.S. Detroit: Gale Research, Inc.; 1991.
34 Diprio, JT, et al., editors. Pharmacotherapy. A Pathophysiologic Approach. 3rd ed. Stamford (CN): Appleton & Lange; 1997.
35 Anderson IM, Tomenson BM. Treatment discontinuation with selective serotonin reuptake inhibitors compared with tricyclic antidepressants: A meta-analysis. BMJ. 1995;310:1433-8. [pmid: 7613276].
36 Angst J, Amrein R, Stabl M. Moclobemide and tricyclic antidepressants in severe depression: Meta-analysis and prospective studies. J Clin Psychopharmacol. 1995;5(4 Suppl 2):16S-23S.
37 Anton SF, Robinson DS, Roberts DL, Kensler TT, English PA, Archibald DG. Long-term treatment of depression with nefazodone. Psychopharmacol Bull. 1994;30(2):165-9. [pmid: 7831450].
38 Bremner JD. A double-blind comparison of Org 3770, amitriptyline and placebo in major depression. J Clin Psychiatry. 1995;56(11):519-25. [pmid: 7592505].
39 Brown C, Schulberg HC. The efficacy of psychosocial treatments in primary care: A review of randomized clinical trials. Gen Hosp Psychiatry. 1995;17(6):414-24. [pmid: 8714801].
40 Byrne MM. Meta-analysis of early phase II studies with paroxetine in hospitalized depressed patients. Acta Psychiatr Scand Suppl. 1989;350:138-9. [pmid: 2530768].
41 Churchill R, Wessely S, Lewis G. A systematic review and meta analysis of the effects of combining pharmacotherapy and psychotherapy for the treatment of depression [protocol]. The Cochrane Library: Update. 1998;2.
42 Claghorn JL, Kiev A, Rickels K, Smith WT, Dunbar GC. Paroxetine versus placebo: A double-blind comparison in depressed patients. J Clin Psychiatry. 1992;53(12):434-8. [pmid: 1487471].
43 Cucherat M, Cialdella P. [Meta-analysis of therapeutic trials: Applications in psychiatry]. [French]. Encephale. 1996;22(5):378-87. [pmid: 9035995].
44 DeVane CL, Sallee FR. Serotonin selective reuptake inhibitors in child and adolescent psychopharmacology: A review of published experience. J Clin Psychiatry. 1996;57(2):55-66.
45 Delini-Stula A, Mikkelsen H, Angst J. Therapeutic efficacy of antidepressants in agitated anxious depression -- a meta-analysis of moclobemide studies. J Affective Disord. 1995;35(1-2):21-30.
46 Dunbar GC. Paroxetine in the elderly: A comparative meta-analysis against standard antidepressant pharmacotherapy. Pharmacology. 1995;51(3):137-44. [pmcid: 64637]. [pmid: 7501698].
47 Dunbar GC, Claghorn JL, Kiev A, Rickels K, Smith WT. A comparison of paroxetine and placebo in depressed outpatients. Acta Psychiatr Scand. 1993;87(5):302-5. [pmid: 8517168].
48 Entsuah AR, Rudolph RL, Chitra R. Effectiveness of venlafaxine treatment in a broad spectrum of depressed patients: A meta-analysis. Psychopharmacol Bull. 1995;31(4):759-66. [pmid: 8851650].
49 Fawcett J, Marcus RN, Anton SF, O'Brien K, Schwiderski U. Response of anxiety and agitation symptoms during nefazodone treatment of major depression. J Clin Psychiatry. 1995;56(Suppl 6):37-42.
50 Freemantle N, Long A, Mason J, Sheldon T, Song F, Watson P, Wilson C. The treatment of depression in primary care [bulletin]. Eff Health Care. 1993;5.
51 Freemantle N, Mason J, Eccles MPG Jr, Boynton J. Selective serotonin reuptake inhibitors: An overview of their comparative efficacy in the treatment of depressive disorder [protocol]. The Cochrane Library: Update. 1998;2.
52 Goodnick PJ, Henry JH, Buki VM. Treatment of depression in patients with diabetes mellitus. J Clin Psychiatry. 1995;56(4):128-36. [pmid: 7713850].
53 Greenberg RP, Bornstein RF, Greenberg MD, Fisher S. A meta-analysis of antidepressant outcome under "blinder" conditions. J Consult Clin Psychol. 1992;60(5):664-9. [pmid: 1401382].
54 Greenberg RP, Bornstein RF, Zborowski MJ, Fisher S, Greenberg MD. A meta-analysis of fluoxetine outcome in the treatment of depression. J Nerv Ment Dis. 1994;182(10):547-51. [pmid: 7931201].
55 Hotopf M, Freemenatle N, Boynton J, Churchill R, Eccles MP, Geddes JR, Hardy R, Lewis G, Mason JM. Systematic review of treatment discontinuation in randomised controlled trials comparing the selective serotonin reuptake inhibitors and other new generation antidepressants with tricyclic and related antidepressants [protocol]. The Cochrane Library: Update. 1998;2.
56 Hotopf M, Hardy R, Lewis G. Discontinuation rates of SSRIs and tricyclic antidepressants: A meta-analysis and investigation of heterogeneity. Br J Psychiatry. 1997;170:120-7. [pmid: 9093499].
57 Hotopf M, Lewis G, Normand C. Putting trials on trial -- the costs and consequences of small trials in depression: A systematic review of methodology. J Epidemiol Community Health. 1997;51(4):354-8. [pmid: 9328538].
58 Kasper S. Clinical efficacy of mirtazapine: A review of meta-analyses of pooled data. Int Clin Psychopharmacol. 1995;10(Suppl 4):25-35. [pmid: 8930007].
59 Kasper S, Pletan Y, Solles A, Tournoux A. Comparative studies with milnacipran and tricyclic antidepressants in the treatment of patients with major depression: A summary of clinical trial results. Int Clin Psychopharmacol. 1996;11(Suppl 4):35-9.
60 Lima MS, Hotopf M. A comparison of active drugs for the treatment of dysthymia [protocol]. The Cochrane Library: Update. 1998;11.
61 Lima MS, Moncrieff J. A comparison of drugs versus placebo for the treatment of dysthymia: A systematic review. The Cochrane Library: Update. 1998;2.
62 Linde K, Mulrow CD, Fischer P. St. John's wort for depression [protocol]. The Cochrane Library: Update. 1998;2.
63 Linde K, Ramirez G, Mulrow CD, Pauls A, Weidenhammer W, Melchart D. St John's wort for depression: An overview and meta-analysis of randomised clinical trials. BMJ. 1996;313(7052):253-8. [pmcid: 28684]. [pmid: 8704532].
64 McCusker J, Cole M, Keller E, Bellavance F, Berard A. Effectiveness of treatments of depression in older ambulatory patients. Arch Intern Med. 1998;158(7):705-12. [pmid: 9554676].
65 Montgomery SA. Selecting the optimum therapeutic dose of serotonin reuptake inhibitors: Studies with citalopram. Int Clin Psychopharmacol. 1995;10(Suppl 1):23-7. [pmid: 7622808].
66 Montgomery SA, Henry J, McDonald G, Dinan T, Lader M, Hindmarch I, Clare A, Nutt D. Selective serotonin reuptake inhibitors: Meta-analysis of discontinuation rates. Int Clin Psychopharmacol. 1994;9(1):47-53. [pmid: 8195583].
67 Montgomery SA, Kasper S. Comparison of compliance between serotonin reuptake inhibitors and tricyclic antidepressants: A meta-analysis. Int Clin Psychopharmacol. 1995;9(Suppl 4):33-40. [pmid: 7622822].
68 Montgomery SA, Pedersen V, Tanghøj P, Rasmussen C, Rioux P. The optimal dosing regimen for citalopram: A meta-analysis of nine placebo-controlled studies. Int Clin Psychopharmacol. 1994;9(Suppl 1):35-40.
69 Puech A, Montgomery SA, Prost JF, Solles A, Briley M. Milnacipran, a new serotonin and noradrenaline reuptake inhibitor: An overview of its antidepressant activity and clinical tolerability. Int Clin Psychopharmacol. 1997;12(2):99-108. [pmid: 9219045].
70 Song F, Freemantle N, Sheldon TA, House A, Watson P, Long A, Mason J. Selective serotonin reuptake inhibitors: Meta-analysis of efficacy and acceptability. BMJ. 1993;306(6879):683-7. [pmcid: 420164]. [pmid: 8471919].
71 Stahl S, Zivkov M, Reimitz PE, Panagides J, Hoff W. Meta-analysis of randomized, double-blind, placebo-controlled, efficacy and safety studies of mirtazapine versus amitriptyline in major depression. Acta Psychiatr Scand Suppl. 1997;391:22-30. [pmid: 9265948].
72 Stassen HH, Angst J, Delini-Stula A. Delayed onset of action of antidepressant drugs?. Survey of results of Zurich meta-analyses. Pharmacopsychiatry. 1996;29(3):87-96.
73 Steffens DC, Krishnan KR, Helms MJ. Are SSRIs better than TCAs? Comparison of SSRIs and TCAs: A meta-analysis. Depress Anxiety. 1997;6(1):10-8. [pmid: 9394870].
74 Taylor D. Selective serotonin reuptake inhibitors and tricyclic antidepressants in combination. Interactions and therapeutic uses. Br J Psychiatry. 1995;167(5):575-80. [pmid: 8564311].
75 Trindade E, Menon D. Selective serotonin reuptake inhibitors (SSRIS) for major depression. Part 1, Evaluation of the clinical literature. CCOHTA report 3E. Ottawa: Canadian Coordinating Office for Health Technology Assessment; 1997.
76 Wilson K, Mottram P, Sivananthan A. A review of antidepressant drug trials in the treatment of older depressed people [protocol]. The Cochrane Library: Update. 1998;2.
77 Workman EA, Short DD. Atypical antidepressants versus imipramine in the treatment of major depression: A meta-analysis. J Clin Psychiatry. 1993;54(1):5-12.
78 Hunt DL, McKibbon KA. Locating and appraising systematic reviews. Ann Intern Med. 1997;126(7):532-8. [pmid: 9092319].
79 Cerrahoglu L, Cogalgil S, Senel K, Turkmen MB. The effects of antidepressive therapy in fibromyalgia syndrome. Fiz Tedavi Rehabil Derg. 1995;19(4):212-6.
80 Alby JM, Cabane J, Ferreri M, Bougerol T. Efficacy and acceptability of tianeptine in major depressive disorder and in dysthymia (DSM-IIIR) with somatic complaints: Double blind study versus fluoxetine. Eur Neuropsychopharmacol. 1993;3(3).
81 Ansseau M, Gabriels A, Loyens J, Bartholome F, Evrard J, De Nayer A, Linhart R, Wirtz J, Bruynooghe F, Surinx K, et al. A double-blind comparison of paroxetine and fluvoxamine in major depression. Eur Neuropsychopharmacol. 1993;3(3):323-4.
82 Berlanga C, Heinze G, Campillo C, Torres M, Caballero A, Apiquián R. Nefazodone and flouxetine in major depression: A comparison study. 10th World Congress of Psychiatry, Madrid, Spain; 1996.
83 Bisserbe JC, Boyer P, Soutre E, Hotton JM, Tro S. A six month sertraline fluoxetine comparative study in depressed outpatients: Outcome and costs. 20th Collegium Internationale Neuro-Psychopharmacologicum Congress, Melbourne, Australia; 1996 Jun 23-27.
84 Bisserbe JC, Lane R, Wiseman R. Predictors of response to SSRIs in patients with major depression. 20th Collegium Internationale Neuro-Psychopharmacologicum Congress, Melbourne, Australia; 1996 Jun 23-27.
85 Bourin M. A double-blind comparison of paroxetine and clomipramine in depressed outpatients. 17th Collegium Internationale Neuro-Psychopharmacologicum Congress, Nagahama, Japan; 1990.
86 Catterson ML, Preskorn SH. Double-blind crossover study of mirtazapine, amitriptyline and placebo in patient with major depression. 149th Annual Meeting of the American Psychiatric Association, New York; 1996.
87 Chouinard G, Belanger MC, Saxena B, Ravindran A, Bakish D, Beauclair L, et al. A Canadian multicentre trial of paroxetine and fluoxetine in major depression. 44th Annual Meeting of the Canadian Psychiatric Association; 1994.
88 Cohn CK, Feighner JP, Targum SG, Thein SG. A double-blind comparison of nefazodone and sertraline in highly anxious patients with major depression. 149th Annual Meeting of the American Psychiatric Association; 1996.
89 Cohn C, Fabre L. Gepirone Extended Release (ER) treatment of outpatients with major depression a dose response study. 20th Collegium Internationale Neuro-Psychopharmacologicum, Melbourne, Australia; 1996 Jun 23-27.
90 De Clerq M, Goffinet S, Gillain B, Hoyois P, Henry de Frahan B, Seghers A. Personality disorders and treatment of severe depressive disorder. 10th World Congress of Psychiatry, Madrid, Spain; 1996.
91 Delgado PL, Moreno FA, Buonopane A, Gelenberg AJ, Potter RL. Catecholamine depletion in desipramine and fluoxetine responders. 149th Annual Meeting of the American Psychiatric Association, New York; 1996.
92 Derivan A, Aguiar L, Rudolph R, Entsuah R. A randomized, double-blind placebo-controlled study: Venlafaxine ER capsules in major depression. 20th Collegium Internationale Neuro-Psychopharmacologicum, Melbourne, Australia; 1996 Jun 23-26.
93 Epperson CN, McDougle CJ, Ward-O'Brien D, Price LH. A controlled study of antidepressant treatment of postpartum depression. 149th Annual Meeting of the American Psychiatric Association, New York; 1996.
94 Feiger AD, Bielski RD, Bremner JD, Heiser JF, Trivedi MH. Efficacy of nefazodone in continuation treatment of depression. 149th Annual Meeting of the American Psychiatric Association, New York; 1996.
95 Ferguson JM, Shrivastava RK, Stahl SM, Hartford JJ, Nape B, Borian F. Effects of double-blind treatment with nefazodone or sertraline on re-emergence of sexual dysfunction in depressed patients. 149th Annual Meeting of the American Psychiatric Association, New York; 1996.
96 Freed E, George T, Goldney R, Lambert T, Tiller J. A double-blind multicentre comparison of paroxetine and amitriptyline in Australian general practice. 20th Collegium Internationale Neuro-Psychopharmacologicum, Melbourne, Australia; 1996 Jun 23-26.
97 Garcia-Barriga C. A double-blind study with paroxetine vs fluoxetine in depressive patients. 10th World Congress of Psychiatry, Madrid, Spain; 1996.
98 Guelfi J, Wiseman R. The treatment of dysthymia with sertraline: a double-blind placebo-controlled trial in dysthymic outpatients without major depression. 8th ECNP (European College of Neuropsychopharmacology) Congress, Venice, Italy; 1995.
99 Gurovich IYa, Shmukler AB, Storozhakova YaA. Psycho-social evaluation of antidepressive medication efficacy (quality of life approach). WPA Thematic Conference, Jerusalem; 1997.
100 Isaac MT, Tome MB, Harte R. Serotonergic autoreceptor blockade in the reduction of antidepressant latency -- a controlled trial. 149th Annual Meeting of the American Psychiatric Association, New York; 1996.
101 Isaac M, Maria Tome, de la Granja, Harte R. Reduction of antidepressant latency. 10th World Congress of Psychiatry, Madrid, Spain; 1996.
102 Jacobson AF, Domingueq RA, Goldstein B, de la Gandara J. Comparison of Org 3770 and amitriptyline in depressed outpatients. J Clin Pharmacol. 1990;30.
103 Kremer CME, Zivkov M. Patterns of mood improvement with mirtazapine. 20th Collegium Internationale Neuro-Psychopharmacologicum, Melbourne, Australia; 1996 Jun 23-26.
104 Lara C, Heinze G, de la Fuente JR. The quality of life of depressed patients. 10th World Congress of Psychiatry, Madrid, Spain; 1996.
105 Lara-Munoz C, Heinze G, De La Fuente JR. Do the antidepressants have effects on quality of life independently of their antidepressant actions?. 149th Annual Meeting of the American Psychiatric Association, New York; 1996.
106 Latimer PR, Ravindran AV, Bernatchez J-P, Fournier J-P, Gojer JA, Barratt K, Buttars J. A six month comparison of toleration and efficacy of sertraline and fluoxetine treatment of major depression. 20th Collegium Internationale Neuro-Psychopharmacologicum, Melbourne, Australia; 1996 Jun 23-26.
107 Latimer PR, Ravindran AV, Bernatchez J-P, Fournier J-P, Gojer JA, Hadrava V, Barratt K. Sertraline versus fluoxetine treatment in major depression. 10th World Congress of Psychiatry, Madrid, Spain; 1996.
108 Lupine J, Wiseman R. Treatment of severe major depression: A double-blind study of sertraline and clomipramine. 20th Collegium Internationale Neuro-Psychopharmacologicum, Melbourne, Australia; 1996 Jun 23-26.
109 Malt UF, Robak OH, Bakke O, Madsbu HP, Loeb M, Smedsrud T. Efficacy of clinical management versus drug treatment of depression in general practice. 149th Annual Meeting of the American Psychiatric Association, New York; 1996.
110 Malt UF, Madsbü HP, Bakke O, Robak O, Loeb M, Smedsrud T. Clinical management vs drug management of depression in primary care. 10th World Congress of Psychiatry, Madrid, Spain; 1996.
111 McEntee W, Ko G, Richter E. Sertraline and nortriptyline: Heart rate, cognitive improvement and quality of life in depressed elderly. 20th Collegium Internationale Neuro-Psychopharmacologicum, Melbourne, Australia; 1996 Jun 23-26.
112 Mendels J, Fabre L, Kiev A. A double-blind parallel comparison of citalopram and placebo in out-patients with major depression or bipolar disorder, depressed. Meeting of the American Psychiatric Association; 1990.
113 Nardi E, Capponi R, Costa DA, Magistris H, Ucha Udabe R, Versiani M. Moclobemide compared with imipramine in the treatment of chronic depression (dysthymia DSM-III-R). A double-blind, placebo controlled trial. Clin Neuropharmacol. 1992;15(Suppl 1, Pt B).
114 Newhouse P, Ko G, Richter E. Comparison of sertraline and fluoxetine in depressed geriatric outpatients: Plasma levels and efficacy. 20th Collegium Internationale Neuro-Psychopharmacologicum, Melbourne, Australia; 1996 Jun 23-26.
115 Nicolini H, Herrera K, Pßez F, Camarena B, Guajardo R, De la Fuente JR. Temperament, character, and molecular genotypes as predictors of antidepressant response. 20th Collegium Internationale Neuro-Psychopharmacologicum, Melbourne, Australia; 1996 Jun 23-26.
116 Rioux P, Kibleur Y, Frachon O, von Frenckell R, Zarifian E. A double-blind comparison of nefazodone and fluoxetine in depressed patients. 149th Annual Meeting of the American Psychiatric Association, New York; 1996.
117 Postolache T, Rosenthal RN, Hellerstein D, Aromin R, Londono J, Kelton G, Yanowitch P, Muran JC. Methylphenidate and sertraline for major depression. 10th World Congress of Psychiatry, Madrid, Spain; 1996.
118 Prasko J, Johanovská E, Klár I, et al. Cognitive behavioral therapy and pharmacotherapy in the treatment of in-patients with unipolar recurrent depression. 10th World Congress of Psychiatry, Madrid, Spain; 1996.
119 Radmayr E. Combination therapy of viloxazine and propranolol in depressive disorders. 14th Collegium Internationale Neuro-Psychopharmacologicum Congress, Florence, Italy; 1984.
120 Sechter D, Troy S, Rioux P. A double blind comparison of sertraline and fluoxetine in the treatment of major depressive episode in out patient. 20th Collegium Internationale Neuro-Psychopharmacologicum Congress, Melbourne, Australia; 1996 Jun 23-26.
121 Settle EC Jr, Stahl SM, Batey SR, Johnston JA, Ascher JA. Safety and tolerability of the sustained-release formulation of bupropion in depression: Results of three clinical trials. 149th Annual Meeting of the American Psychiatric Association; 1996.
122 Shaw DM, Crimmins R. A multicentre trial of citalopram and amitriptyline in major depressive illness. 22nd Nordiske Psykiater Kongres, Reykjavik, Iceland; 1988.
123 Shillingford JS, Hindmarch I, Clarke A, Vince MJ. A double-blind comparison of paroxetine and dothiepin on efficacy and tolerability in depressed community patients. 17th Collegium Internationale Neuro-Psychopharmacologicum Congress, Kyoto, Japan; 1990.
124 Stahl SM. The designer approach to antidepressant efficacy. 10th World Congress of Psychiatry, Madrid, Spain; 1996.
125 Steiner M, Dunn E, Coote M, Browne G. Dysthymia and the serotonergic cascade. 10th World Congress of Psychiatry, Madrid, Spain; 1996.
126 Stott PC, Blagden MD, Aitken CA. Depression and associated anxiety in primary care: A double-blind comparison of paroxetine and amitriptyline. Eur Neuropsychopharmacol. 1993;3(3):324-5.
127 Szádóczky E, Németh A, Arató M. Sertraline vs amitriptyline treatment in major depression. 10th World Congress of Psychiatry, Madrid, Spain; 1996.
128 Tourigny-Rivard M-F, Nair VK, Vincent P. Fluvoxamine vs desipramine in elderly depressed patients. 10th World Congress of Psychiatry, Madrid, Spain; 1996.
129 Van den Berg J. Fluvoxamine prevents recurrence of depression. 10th World Congress of Psychiatry, Madrid, Spain; 1996.
130 Warner R, Appleby L, Whitton A, Faragher B. A controlled study of fluoxetine and cognitive behavioural counselling in the treatment of post-natal depression. Winter Meeting of the Royal College of Psychiatrists, Cardiff, Wales; 1997.
131 Anonymous. Citalopram. A double-blind parallel group comparison with placebo in depressed outpatients. Unpublished/LUNDBECK; 1995.
132 Carman JS. Double-blind parallel comparison of citalopram, imipramine and placebo in patients with major depression or bipolar disorder, depressed. Unpublished/LUNDBECK.
133 Chakravarti SK. Double-blind comparison of citalopram versus amitriptyline in the treatment of depressive illness in Great Britain. Unpublished/LUNDBECK.
134 Cohn JB. [Double-blind trial of fluoxetine and placebo in depression]. Unpublished.
135 Cole. [Double-blind trial of fluoxetine and doxepin in depression] (1). Unpublished.
136 Coleman BS, Block BA, Vause EW. A double-blind placebo-controlled randomized multicenter comparison of fluvoxamine and imipramine in patients with primary depression. Unpublished; 1983.
137 Coleman BS, Block BA. A double-blind placebo-controlled randomized comparative study of fluvoxamine and imipramine in out-patients with primary depression. Unpublished; 1981.
138 Coleman BS, Doogan DP. Medical report on a double-blind comparative study of fluvoxamine and chlorimipramine in institutionalized patients with bipolar and unipolar depression. Unpublished; 1981.
139 Davis, Feighner JP, Rosenbaum, Stokes. [Double-blind trial of fluoxetine and imipramine in depression]. Unpublished.
140 Deakin JFW. A double-blind, controlled phase III of citalopram versus placebo in the treatment of depressive illness. Unpublished/LUNDBECK.
141 Doogan DP, Van Beek AA. Fluvoxamine (DU23000) and Chlorimipramine (Anafranil) in hospitalized patients with depressive syndromes. A double-blind, randomized, comparative clinical study. Unpublished; 1981.
142 Elliot AJ, Roy-Byrne PP, Uldall KK, Russo J, Claypoole K, Bergam K. A placebo-controlled trial of paroxetine versus imipramine in depressed HIV-positive outpatients. Unpublished; 1997.
143 Feighner JP, Kiev A, Masco HL. [Double-blind trial of fluoxetine and doxepin in depression]. Unpublished.
144 Friedhoff. [Double-blind trial of fluoxetine and doxepin in depression]. Unpublished.
145 Hansen J. A clinical study of citalopram and nortriptyline in patients with depressive illness. Unpublished/LUNDBECK.
146 Herrington RN. A controlled clinical comparison of citalopram and placebo in depressed patients. Unpublished/LUNDBECK.
147 Hoppenbrouwers ML. Comparison of ritanserin and placebo in 55 subjects. Unpublished.
148 Johnson DA. A controlled, clinical comparison of citalopram and imipramine in depressed patients. Unpublished/LUNDBECK.
149 Mann. [Double-blind trial of fluoxetine and nortriptyline in depression]. Unpublished.
150 Prudic J, Sackeim HA, Rifas S. Medication resistance, response to ECT, and prevention of relapse. Psychiatr Ann.
151 Ravindran A, Wiseman R. A double-blind, placebo-controlled study of sertraline in the treatment of outpatients with dysthymia. Unpublished; 1997.
152 Van Beek AA, Sharp D. Medical report fluvoxamine and imipramine in hospitalized patients and depressive syndromes. A double-blind, randomized, multicentre clinical study. Unpublished; 1981.
153 White K, Tynes LL, Waternaux. A 6-week double-blind comparison of fluvoxamine vs desipramine. Unpublished.
154 Anonymous. Paroxetine versus maprotiline study. Unpublished/SmithKline Beecham Pharma MDB/29060/111/5. (Study terminated prematurely as per correspondence from pharmaceutical company.).
155 Bignamini A, Rapisarda V. A double-blind multicentre study of paroxetine and amitriptyline in depressed outpatients. Italian Paroxetine Study Group. Int Clin Psychopharmacol. 1992;6(Suppl 4):37-41. [pmid: 1431009].
156 Brasseur R. A multicentre open trial of fluoxetine in depressed out-patients in Belgium. Int Clin Psychopharmacol. 1989;4(Suppl 1):107-11. [pmid: 2644335].
157 Casacchia M, Moll E. Moclobemide (Ro 11-1163) versus imipramine in the treatment of depression. Acta Psychiatr Scand Suppl. 1990;360.
158 Cattiez PH, Dierick M, Troisfontaines B, Van Audenrode L, Defleur J, Hermans W, Roelandts A, Stenier P, Wolfrum C. Moclobemide (Ro 11-1163) vs. clomipramine in the treatment of depression: A double-blind multicenter study in Belgium. Drug Dev Res. 1990;21(4):325-32.
159 Gisselmann A. [Activity and acceptability of indalpine in a double-blind study versus placebo]. [French]. Encephale. 1984;10(5):231-4. [pmid: 6151492].
160 Goodnick PJ, Fieve RR, Peselow ED, Schlegel A. Pattern analysis of antidepressant response to fluoxetine: A replication. Psychopharmacol Bull. 1987;23(3):508-9.
161 Harto NE, Spera KF, Branconnier RJ. Fluoxetine-induced reduction of body mass in patients with major depressive disorder. Psychopharmacol Bull. 1988;24(2):220-3. [pmid: 3264922].
162 Hellerstein DJ, Yanowitch P, Rosenthal J, Hemlock C, Kasch K, Samstag LW, Winston A. Long-term treatment of double depression: A preliminary study with serotonergic antidepressants. Prog Neuropsychopharmacol Biol Psychiatry. 1994;18(1):139-47. [pmid: 8115668].
163 Rosenthal J, Hemlock C, Hellerstein DJ, Yanowitch P, Kasch K, Schupak C, Samstag LW, Winston A. A preliminary study of serotonergic antidepressants in treatment of dysthymia. Prog Neuropsychopharmacol Biol Psychiatry. 1992;16(6):933-41. [pmid: 1513932].
164 Rossel L, Moll E. Moclobemide versus tranylcypromine in the treatment of depression. Acta Psychiatr Scand Suppl. 1990;360:61-2. [pmid: 2248075].
165 Tyrer P, Marsden CA, Casey P, Seivewright N. Clinical efficacy of paroxetine in resistant depression. J Psychopharmacol. 1987;1(4):251-7.
166 Warnecke G. Venereal disease law (GFR). Z Allgemeinmedizin. 1986;62(31):1111-3.
167 Aguglia E, Casacchia M, Cassano GB, Faravelli C, Ferrari G, Giordano P, Pancheri P, Ravizza L, Trabucchi M, Bolino F, et al. Double-blind study of the efficacy and safety of sertraline versus fluoxetine in major depression. Int Clin Psychopharmacol. 1993;8(3):197-202. [pmid: 8263318].
168 Ahlberg B, Palm O, Honore PL. Femoxetine in the treatment of patients with depressive illness: A randomized comparison with amitriptyline. Nord Psykiatr Tidsskr. 1982;36(6):329-33.
169 Alby JM, Ferreri M, Cabane J, De Bodinat C, Dagens V. Efficacy of tianeptine (Stablon © ) for the treatment of major depression and dysthymia with somatic complaints. A comparative study versus fluoxetine (Prozac ©). Ann Psychiatrie. 1993;8(2):136-44.
170 Allain H, Lieury A, Brunet-Bourgin F, Mirabaud C, Trebon P, Le Coz F, Gandon JM. Antidepressants and cognition: Comparative effects of moclobemide, viloxazine and maprotiline. Psychopharmacology (Berl). 1992;106(Suppl):S56-S61. [pmcid: 161672]. [pmid: 1546142].
171 Altamura AC, Mauri MC, Girardi T, Panetta B. Alcoholism and depression: A placebo controlled study with viloxazine. Int J Clin Pharmacol Res. 1990;10(5):293-8. [pmid: 2079386].
172 Andersen G, Vestergaard K, Lauritzen L. Effective treatment of poststroke depression with the selective serotonin reuptake inhibitor citalopram. Stroke. 1994;25(6):1099-104 (See Andersen 1994, Appendix 1. [pmid: 8202964].
173 Ansseau M, Darimont P, Lecoq A, De Nayer A, Evrard JL, Kremer P, Devoitille JM, Dierick M, Mertens C, Mesotten F, et al. Controlled comparison of nefazodone and amitriptyline in major depressive inpatients. Psychopharmacology (Berl). 1994;115(1-2):254-60. [pmcid: 161672]. [pmid: 7862904].
174 Ansseau M, Gabriels A, Loyens J, Bartholome F, Evrard JL, De Nayer A, et al. Controlled comparison of paroxetine and fluvoxamine in major depression. Hum Psychopharmacol. 1994;9:329-36.
175 Ansseau M, Papart P, Troisfontaines B, Bartholome F, Bataille M, Charles G, Schittecatte M, Darimont P, Devoitille JM, De Wilde J, et al. Controlled comparison of milnacipran and fluoxetine in major depression. Psychopharmacology (Berl). 1994;114(1):131-7. [pmcid: 161672]. [pmid: 7846195].
176 Appleby L, Warner R, Whitton A, Faragher B. A controlled study of fluoxetine and cognitive-behavioural counselling in the treatment of postnatal depression. BMJ. 1997;314(7085):932-6. [pmcid: 167160]. [pmid: 9099116].
177 Arminen SL, Ikonen U, Pulkkinen P, Leinonen E, Mahlanen A, Koponen H, Kourula K, Ryyppo J, Korpela V, Lehtonen ML, et al. A 12-week double-blind multi-centre study of paroxetine and imipramine in hospitalized depressed patients. Acta Psychiatr Scand. 1994;89(6):382-9. [pmid: 8085467].
178 Aylward M, Maddock J, Dewland PM, Lewis PA. Sulpiride in depressive illness. Adv Biol Psychiatr. 1981;7:154-65.
179 Baker B, Dorian P, Sandor P, Shapiro C, Schell C, Mitchell J, Irvine MJ. Electrocardiographic effects of fluoxetine and doxepin in patients with major depressive disorder. J Clin Psychopharmacol. 1997;17(1):15-21. [pmid: 9004052].
180 Bakish D, Bradwejn J, Nair N, McClure J, Remick R, Bulger L. A comparison of moclobemide, amitriptyline and placebo in depression: A Canadian multicentre study. Psychopharmacology (Berl). 1992;106(Suppl):S98-S101. [pmcid: 161672]. [pmid: 1546154].
181 Bakish D, Cavazzoni P, Chudzik J, Ravindran A, Hrdina PD. Effects of selective serotonin reuptake inhibitors on platelet serotonin parameters in major depressive disorder. Biol Psychiatry. 1997;41(2):184-90. [pmid: 9018388].
182 Bakish D, Lapierre YD, Weinstein R, Klein J, Wiens A, Jones B, Horn E, Browne M, Bourget D, Blanchard A, et al. Ritanserin, imipramine, and placebo in the treatment of dysthymic disorder. J Clin Psychopharmacol. 1993;13(6):409-14. [pmid: 8120154].
183 Baldwin DS, Hawley CJ, Abed RT, Maragakis BP, Cox J, Buckingham SA, Pover GH, Ascher A. A multicenter double-blind comparison of nefazodone and paroxetine in the treatment of outpatients with moderate-to-severe depression. J Clin Psychiatry. 1996;57(Suppl 2):46-52.
184 Barge-Schaapveld DQ, Nicolson NA, van der Hoop RG, De Vries MW. Changes in daily life experience associated with clinical improvement in depression. J Affect Disord. 1995;34(2):139-54. [pmid: 7665806].
185 Bascara L. A double-blind study to compare the effectiveness and tolerability of paroxetine and amitriptyline in depressed patients. Acta Psychiatr Scand Suppl. 1989;350:141-2. [pmid: 2530771].
186 Battegay R, Hager M, Rauchfleisch U. Double-blind comparative study of paroxetine and amitriptyline in depressed patients of a university psychiatric outpatient clinic (pilot study). Neuropsychobiology. 1985;13(1-2):31-7. [pmid: 3162108].
187 Beasley CM Jr, Dornseif BE, Pultz JA, Bosomworth JC, Sayler ME. Fluoxetine versus trazodone: Efficacy and activating-sedating effects. J Clin Psychiatry. 1991;52(7):294-9. [pmid: 2071559].
188 Beasley CM Jr, Holman SL, Potvin JH. Fluoxetine compared with imipramine in the treatment of inpatient depression. A multicenter trial. Ann Clin Psychiatry. 1993;5(3):199-207. [pmid: 8281243].
189 Beaumont G, Gringras M, Hobbs FD, Drury VW, Freeling P, Tylee A, Shanley DF, Comber H, Little S, Hill S. A randomized, double-blind, multi-centre, parallel-group study comparing the tolerability and efficacy of moclobemide and dothiepin hydrochloride in depressed patients in general practice. Int Clin Psychopharmacol. 1993;7(3-4):159-65. [pmid: 8468438].
190 Behan PO, Hannifah H. 5-HT reuptake inhibitors in CFS. EOS Riv Immunol Immunofarmacol. 1995;5(1-2):66-9.
191 Benkert O, Grunder G, Wetzel H, Hackett D. A randomized, double-blind comparison of a rapidly escalating dose of venlafaxine and imipramine in inpatients with major depression and melancholia. J Psychiatr Res. 1996;30(6):441-51. [pmid: 9023787].
192 Bennie EH, Mullin JM, Martindale JJ. A double-blind multicenter trial comparing sertraline and fluoxetine in outpatients with major depression. J Clin Psychiatry. 1995;56(6):229-37. [pmid: 7775364].
193 Bergmann R, Nussner J, Demling J. Therapy of minor and moderate depressions. TW Neuro Psychiatrie. 1993;7(4):235-40.
194 Berman RM, Darnell AM, Miller HL, Anand A, Charney DS. Effect of pindolol in hastening response to fluoxetine in the treatment of major depression: A double-blind, placebo-controlled trial. Am J Psychiatry. 1997;154(1):37-43. [pmid: 8988956].
195 Bersani G, Rapisarda V, Ciani N, Bertolino A, et al. A double-blind comparative study of sertraline and amitriptyline in outpatients with major depressive episodes. Hum Psychopharmacol Clin Exp. 1994;9(1):63-8.
196 Berzewski H, Van Moffaert M, Gagiano CA. Efficacy and tolerability of reboxetine compared with imipramine in a double-blind study in patients suffering from major depressive episodes. Eur Neuropsychopharmacol. 1997;7(Suppl 1):S37-S47. [pmid: 9169309].
197 Besancon G, Cousin R, Vuitton B, Lavergne F. [Double-blind study of mianserin and fluoxetine in ambulatory therapy of depressed patients]. [French]. Encephale. 1993;19(4):341-5. [pmid: 8275922].
198 Blumenfield M, Levy NB, Spinowitz B, Charytan C, Beasley CM Jr, Dubey AK, Solomon RJ, Todd R, Goodman A, Bergstrom RF. Fluoxetine in depressed patients on dialysis. Int J Psychiatry Med. 1997;27(1):71-80. [pmid: 9565715].
199 Botte L, Evrard JL, Gilles C, Stenier P, Wolfrum C. Controlled comparison of RO 11-1163 (moclobemide) and placebo in the treatment of depression. Acta Psychiatr Belg. 1992;92(6):355-69. [pmid: 1345409].
200 Bouchard JM, Delaunay J, Delisle JP, Grasset N, Mermberg PF, Molczadzki M, Pagot R, Richou H, Robert G, Ropert R, et al. Citalopram versus maprotiline: A controlled, clinical multicentre trial in depressed patients. Acta Psychiatr Scand. 1987;76(5):583-92. [pmid: 3324648].
201 Bowden CL, Schatzberg AF, Rosenbaum A, Contreras SA, Samson JA, Dessain E, Sayler M. Fluoxetine and desipramine in major depressive disorder. J Clin Psychopharmacol. 1993;13(5):305-11. [pmid: 8227488].
202 Boyer P, Lecrubier Y. Atypical antipsychotic drugs in dysthymia: placebo controlled studies of amisulpride versus imipramine versus amineptine. Eur Psychiatry. 1996;11(Suppl 3):135S-140S.
203 Bremner JD. Double-blind comparison of mirtazapine, amitriptyline and placebo in major depression. NerVenheilkunde. 1996;15(8):533-40.
204 Brown WA, Arato M, Shrivastava R. Pituitary-adrenocortical hyperfunction and intolerance to fluvoxamine, a selective serotonin uptake inhibitor. Am J Psychiatry. 1986;143(1):88-90. [pmid: 3079969].
205 Buchsbaum MS, Wu J, Siegel BV, Hackett E, Trenary M, Abel L, Reynolds C. Effect of sertraline on regional metabolic rate in patients with affective disorder. Biol Psychiatry. 1997;41(1):15-22. [pmid: 8988791].
206 Burke WJ, Hendricks SE, McArthur-Campbell D, Jacques D, Stull T. Fluoxetine and norfluoxetine serum concentrations and clinical response in weekly versus daily dosing. Psychopharmacol Bull. 1996;32(1):27-32. [pmid: 8927671].
207 Byerley WF, Reimherr FW, Wood DR, Grosser BI. Fluoxetine, a selective serotonin uptake inhibitor, for the treatment of outpatients with major depression. J Clin Psychopharmacol. 1988;8(2):112-5. [pmid: 3286684].
208 Cassano GB, Conti L, Massimetti G, Mengali F, Waekelin JS, Levine J. Use of a standardized documentation system (BLIPS/BDP) in the conduct of a multicenter international trial comparing fluvoxamine, imipramine, and placebo. Psychopharmacol Bull. 1986;22(1):52-8. [pmid: 3088668].
209 Chiu HJ, Hong CJ, Chan CH. Paroxetine in the treatment of Chinese patients with depressive episode: A double-blind randomized comparison with imipramine. Chung Hua I Hsueh Tsa Chih. 1996;57(6):418-23. [pmid: 8803304].
210 Chouinard G. Bupropion and amitriptyline in the treatment of depressed patients. J Clin Psychiatry. 1983;44(5 Pt 2):121-9. [pmid: 6406440].
211 Chouinard G, Saxena BM, Nair NP, Kutcher SP, Bakish D, Bradwejn J, Kennedy SH, Sharma V, Remick RA, Kukha-Mohamad SA, et al. Brofaromine in depression: A Canadian multicenter placebo trial and a review of standard drug comparative studies. Clin Neuropharmacol. 1993;16(Suppl 2):S51-S54. [pmid: 8313397].
212 Chouinard G, Saxena BM, Nair NP, Kutcher SP, Bakish D, Bradwejn J, Kennedy SH, Sharma V, Remick RA, Kukha-Mohamad SA, et al. A Canadian multicentre placebo-controlled study of a fixed dose of brofaromine, a reversible selective MAO-A inhibitor, in the treatment of major depression. J Affect Disord. 1994;32(2):105-14. [pmid: 7829762].
213 Christiansen PE, Behnke K, Black CH, Ohrstrom JK, Bork-Rasmussen H, Nilsson J. Paroxetine and amitriptyline in the treatment of depression in general practice. Acta Psychiatr Scand. 1996;93(3):158-63. [pmid: 8739658].
214 Claghorn JL. The safety and efficacy of paroxetine compared with placebo in a double-blind trial of depressed outpatients. J Clin Psychiatry. 1992;53(Suppl):33-5. [pmid: 1531821].
215 Claghorn JL, Earl CQ, Walczak DD, Stoner KA, Wong LF, Kanter D, Houser VP. Fluvoxamine maleate in the treatment of depression: A single-center, double-blind, placebo-controlled comparison with imipramine in outpatients. J Clin Psychopharmacol. 1996;16(2):113-20. [pmid: 8690826].
216 Claghorn JL, Lesem MD. A double-blind placebo-controlled study of Org 3770 in depressed outpatients. J Affect Disord. 1995;34(3):165-71. [pmid: 7560544].
217 Clerc G, Ruimy P, Verdeau-Palles J. A double-blind comparison of venlafaxine and fluoxetine in patients hospitalized for major depression and melancholia. The Venlafaxine French Inpatient Study Group. Int Clin Psychopharmacol. 1994;9(3):139-43. [pmid: 7814822].
218 Clerc G, Pagot R, Bouchard JM, Oules J, Guibert M, Assicot M, Guillard A, Cottin M, Dachary JM, Bezaury JP, et al. Therapeutic contribution of milnacipran and clomipramine during a 3-month treatment: Results of a comparative study. Psychiatr Psychobiol. 1990;5(2):137-43.
219 Cohn CK, Robinson DS, Roberts DL, Schwiderski UE, O'Brien K, Ieni JR. Responders to antidepressant drug treatment: A study comparing nefazodone, imipramine, and placebo in patients with major depression. J Clin Psychiatry. 1996;57(Suppl 2):15-8.
220 Cohn CK, Shrivastava R, Mendels J, Cohn JB, Fabre LF, Claghorn JL, Dessain EC, Itil TM, Lautin A. Double-blind, multicenter comparison of sertraline and amitriptyline in elderly depressed patients. J Clin Psychiatry. 1990;51(Suppl B):28-33.
221 Cohn JB, Crowder JE, Wilcox CS, Ryan PJ. A placebo- and imipramine- controlled study of paroxetine. Psychopharmacol Bull. 1990;26(2):185-9. [pmid: 2146697].
222 Cohn JB, Wilcox CS. A comparison of fluoxetine, imipramine, and placebo in patients with major depressive disorder. J Clin Psychiatry. 1985;46(3 Pt 2):26-31.
223 Corne SJ, Hall JR. A double-blind comparative study of fluoxetine and dothiepin in the treatment of depression in general practice. Int Clin Psychopharmacol. 1989;4(3):245-54. [pmid: 2677126].
224 Cornelius JR, Salloum IM, Ehler JG, Jarrett PJ, Cornelius MD, Perel JM, Thase ME, Black A. Fluoxetine in depressed alcoholics. A double-blind, placebo-controlled trial. Arch Gen Psychiatry. 1997;54(8):700-5. [pmid: 9283504].
225 Cunningham LA, Borison RL, Carman JS, Chouinard G, Crowder JE, Diamond BI, Fischer DE, Hearst E. A comparison of venlafaxine, trazodone, and placebo in major depression. J Clin Psychopharmacol. 1994;14(2):99-106. [pmid: 8195464].
226 D'Amico MF, Roberts DL, Robinson DS, Schwiderski UE, Copp J. Placebo-controlled dose-ranging trial designs in phase II development of nefazodone. Psychopharmacol Bull. 1990;26(1):147-50. [pmid: 2196622].
227 Dahl LE, Lundin L, le Fevre Honore P, Dencker SJ. Antidepressant effect of femoxetine and desipramine and relationship to the concentration of amine metabolites in cerebrospinal fluid. A double-blind evaluation. Acta Psychiatr Scand. 1982;66(1):9-17. [pmid: 6181653].
228 Dalery J, Rochat C, Peyron E, Bernard G. [Comparative study of the efficacy and acceptability of amineptine and fluoxetine in patients with major depression]. [French]. Encephale. 1992;18(3):257-62. [pmid: 1299597].
229 Dam M, Tonin P, De Boni A, Pizzolato G, Casson S, Ermani M, Freo U, Piron L, Battistin L. Effects of fluoxetine and maprotiline on functional recovery in poststroke hemiplegic patients undergoing rehabilitation therapy. Stroke. 1996;27(7):1211-4. [pmid: 8685930].
230 Danish University Antidepressant Group. Moclobemide: A reversible MAO-A-inhibitor showing weaker antidepressant effect than clomipramine in a controlled multicenter study. J Affect Disord. 1993;28(2):105-16. [pmid: 8354766].
231 Danish University Antidepressant Group. Paroxetine: A selective serotonin reuptake inhibitor showing better tolerance, but weaker antidepressant effect than clomipramine in a controlled multicenter study. J Affect Disord. 1990;18(4):289-99. [pmid: 2140382].
232 de Jonghe F, Ravelli DP, Tuynman-Qua H. A randomized, double-blind study of fluoxetine and maprotiline in the treatment of major depression. Pharmacopsychiatry. 1991;24(2):62-7. [pmid: 1852793].
233 de Jonghe F, Swinkels J, Tuynman-Qua H. Randomized double-blind study of fluvoxamine and maprotiline in treatment of depression. Pharmacopsychiatry. 1991;24(1):21-7. [pmid: 1901418].
234 De Vanna M, Kummer J, Agnoli A, Gentili P, Lorizio A, Anand R. Moclobemide compared with second-generation antidepressants in elderly people. Acta Psychiatr Scand Suppl. 1990;360:64-6. [pmid: 2248077].
235 De Wilde J, Mertens C, Overo KF, Petersen HE. Citalopram versus mianserin. A controlled, double-blind trial in depressed patients. Acta Psychiatr Scand. 1985;72(1):89-96. [pmid: 3898725].
236 De Wilde J, Spiers R, Mertens C, Bartholome F, Schotte G, Leyman S. A double-blind, comparative, multicentre study comparing paroxetine with fluoxetine in depressed patients. Acta Psychiatr Scand. 1993;87(2):141-5. [pmid: 8447241].
237 Debus JR, Rush AJ, Himmel C, Tyler D, Polatin P, Weissenburger J. Fluoxetine versus trazodone in the treatment of outpatients with major depression. J Clin Psychiatry. 1988;49(11):422-6. [pmid: 3053668].
238 Del Zompo M, Bernardi F, Burrai C, Bocchetta A. A double-blind study of minaprine versus amitriptyline in major depression. Neuropsychobiology. 1990;24(2):79-83. [pmid: 2134115].
239 Dierick M, Ravizza L, Realini R, Martin A. A double-blind comparison of venlafaxine and fluoxetine for treatment of major depression in outpatients. Prog Neuropsychopharmacol Biol Psychiatry. 1996;20(1):57-71. [pmid: 8861177].
240 Ditzler K, Gessner B, Schatton WF, Willems M. Clinical trial on neuropas versus placebo in patients with mild to moderate depressive symptoms: A placebo-controlled, randomised double-blind study. Complementary Ther Med. 1994;2:5-13.
241 Doogan DP, Caillard V. Sertraline in the prevention of depression. Br J Psychiatry. 1992;160:217-22. [pmid: 1540762].
242 Doogan DP, Langdon CJ. A double-blind, placebo-controlled comparison of sertraline and dothiepin in the treatment of major depression in general practice. Int Clin Psychopharmacol. 1994;9(2):95-100. [pmid: 8057000].
243 Dorman T. Sleep and paroxetine: A comparison with mianserin in elderly depressed patients. Int Clin Psychopharmacol. 1992;6(Suppl 4):53-8. [pmid: 1431012].
244 Dowling B, Webb MG, Halpin CM, Sangiwa MG. Fluoxetine: A comparative study with dothiepin. Ir J Psychiatry. 1990;11(1):3-7.
245 Duarte A, Mikkelsen H, Delini-Stula A. Moclobemide versus fluoxetine for double depression: A randomized double-blind study. J Psychiatr Res. 1996;30(6):453-8. [pmid: 9023788].
246 Dubini A, Bosc M, Polin V. Do noradrenaline and serotonin differentially affect social motivation and behaviour?. Eur Neuropsychopharmacol. 1997;7(Suppl 1):S49-S55. [pmid: 9169310].
247 Dufresne RL, Becker RE, Blitzer R, Wagner RL, Lal H. Safety and efficacy of bupropion, a novel antidepressant. Drug Dev Res. 1985;6(1):39-46.
248 Dunlop SR, Dornseif BE, Wernicke JF, Potvin JH. Pattern analysis shows beneficial effect of fluoxetine treatment in mild depression. Psychopharmacol Bull. 1990;26(2):173-80. [pmid: 2236453].
249 Dunner DL, Cohn JB, Walshe T 3d, Cohn CK, Feighner JP, Fieve RR, Halikas JP, Hartford JT, Hearst ED, Settle EC Jr, et al. Two combined, multicenter double-blind studies of paroxetine and doxepin in geriatric patients with major depression. J Clin Psychiatry. 1992;53(Suppl):57-60. [pmid: 1531827].
250 Dunner DL, Schmaling KB, Hendrickson H, Becker J, Lehman A, Bea C. Cognitive therapy versus fluoxetine in the treatment of dysthymic disorder. Depression. 1996;4(1):34-41. [pmid: 9160652].
251 Dunningham W, Aguiar WM, Pinto MD. A double-blind Brazilian study of efficacy and safety of moclobemide versus imipramine in the treatment of patients with geriatric depression. Arq Bras Med. 1994;6:402-5.
252 Edwards JG, Dinan TG, Waller DG, Greentree SG. Double-blind comparative study of the antidepressant, unwanted and cardiac effects of minaprine and amitriptyline. Br J Clin Pharmacol. 1996;42(4):491-8. [pmid: 8904622].
253 Edwards JG, Goldie A. Placebo-controlled trial of paroxetine in depressive illness. Hum Psychopharmacol. 1993;8(3):203-9.
254 Evans M, Hammond M, Wilson K, Lye M, Copeland J. Placebo-controlled treatment trial of depression in elderly physically ill patients. Int J Geriatr Psychiatry. 1997;12(8):817-24. [pmid: 9283926].
255 Fabre LF. A 6-week, double-blind trial of paroxetine, imipramine, and placebo in depressed outpatients. J Clin Psychiatry. 1992;53(Suppl):40-3. [pmid: 1531823].
256 Fabre LF, Abuzzahab FS, Amin M, Claghorn JL, Mendels J, Petrie WM, Dube S, Small JG. Sertraline safety and efficacy in major depression: A double-blind fixed-dose comparison with placebo. Biol Psychiatry. 1995;38(9):592-602. [pmid: 8573661].
257 Fabre LF, Putman HP 3d. A fixed-dose clinical trial of fluoxetine in outpatients with major depression. J Clin Psychiatry. 1987;48(10):406-8. [pmid: 3312176].
258 Fabre L, Birkhimer LJ, Zaborny BA, Wong LF, Kapik BM. Fluvoxamine versus imipramine and placebo: A double-blind comparison in depressed patients. Int Clin Psychopharmacol. 1996;11(2):119-27. [pmid: 8803649].
259 Fairweather DB, Kerr JS, Harrison DA, Moon CA, et al. A double blind comparison of the effects of fluoxetine and amitriptyline on cognitive function in elderly depressed patients. Hum Psychopharmacol Clin Exp. 1993;8(1):41-7.
260 Falk WE, Rosenbaum JF, Otto MW, Zusky PM, Weilburg JB, Nixon RA. Fluoxetine versus trazodone in depressed geriatric patients. J Geriatr Psychiatry Neurol. 1989;2(4):208-14. [pmid: 2699556].
261 Fava M, Rappe SM, Pava JA, Nierenberg AA, Alpert JE, Rosenbaum JF. Relapse in patients on long-term fluoxetine treatment: Response to increased fluoxetine dose. J Clin Psychiatry. 1995;56(2):52-5. [pmid: 7852252].
262 Fawcett J, Zajecka JM, Kravitz HM, Edwards J, et al. Fluoxetine versus amitriptyline in adult outpatients with major depression. Curr Ther Res. 1989;45(5):821-32.
263 Feiger AD. A double-blind comparison of gepirone extended release, imipramine, and placebo in the treatment of outpatient major depression. Psychopharmacol Bull. 1996;32(4):659-65. [pmid: 8993088].
264 Feiger AD, Kiev A, Shrivastava RK, Wisselink PG, Wilcox CS. Nefazodone versus sertraline in outpatients with major depression: Focus on efficacy, tolerability, and effects on sexual function and satisfaction. J Clin Psychiatry. 1996;57(Suppl 2):53-62.
265 Feighner JP, Boyer WF. Paroxetine in the treatment of depression: A comparison with imipramine and placebo. Acta Psychiatr Scand Suppl. 1989;350:125-9. [pmid: 2530763].
266 Feighner JP, Boyer WF, Meredith CH, Hendrickson GG. A placebo-controlled inpatient comparison of fluvoxamine maleate and imipramine in major depression. Int Clin Psychopharmacol. 1989;4(3):239-44. [pmid: 2507630].
267 Feighner JP, Cohn JB. Double-blind comparative trials of fluoxetine and doxepin in geriatric patients with major depressive disorder. J Clin Psychiatry. 1985;46(3 Pt 2):20-5.
268 Feighner JP, Gardner EA, Johnston JA, Batey SR, Khayrallah MA, Ascher JA, Lineberry CG. Double-blind comparison of bupropion and fluoxetine in depressed outpatients. J Clin Psychiatry. 1991;52(8):329-35. [pmid: 1907963].
269 Feighner JP, Hendrickson G, Miller L, Stern W. Double-blind comparison of doxepin versus bupropion in outpatients with a major depressive disorder. J Clin Psychopharmacol. 1986;6(1):27-32. [pmid: 3081600].
270 Feighner JP, Pambakian R, Fowler RC, Boyer WF, D'Amico MF. A comparison of nefazodone, imipramine, and placebo in patients with moderate to severe depression. Psychopharmacol Bull. 1989;25(2):219-21. [pmid: 2690165].
271 Fernandez Labriola R, Caetano Esquivel G, Alvarez M, Servidio M. [Toloxatone and depression]. [Spanish]. Acta Psiquiatr Psicol Am Lat. 1991;37(4):291-8. [pmid: 1843597].
272 Ferreri M. Fluoxetine versus amineptine in the treatment of outpatients with major depressive disorders. Int Clin Psychopharmacol. 1989;4(Suppl 1):97-101. [pmid: 2644344].
273 Fieve RR, Goodnick PJ, Peselow E, Schlegel A. Fluoxetine response: Endpoint vs pattern analysis. Int Clin Psychopharmacol. 1986;1(4):320-3. [pmid: 3549877].
274 Fontaine R, Ontiveros A, Elie R, Kensler TT, Roberts DL, Kaplita S, Ecker JA, Faludi G. A double-blind comparison of nefazodone, imipramine, and placebo in major depression. J Clin Psychiatry. 1994;55(6):234-41. [pmid: 8071277].
275 Fournier JP, Lane RM, Chouinard G, Watson DB, Amin M, Remick RA, Thorpe LU. A double-blind comparison of sertraline and imipramine in outpatients with major depression: Acute (8 weeks) and continuation (16 weeks) treatment. Hum Psychopharmacol. 1997;12(3):203-15.
276 Franchini L, Gasperini M, Perez J, Smeraldi E, Zanardi R. A double-blind study of long-term treatment with sertraline or fluvoxamine for prevention of highly recurrent unipolar depression. J Clin Psychiatry. 1997;58(3):104-7. [pmid: 9108811].
277 Franchini L, Gasperini M, Smeraldi E. A 24-month follow-up study of unipolar subjects: A comparison between lithium and fluvoxamine. J Affect Disord. 1994;32(4):225-31. [pmid: 7897085].
278 Gagiano CA. A double blind comparison of paroxetine and fluoxetine in patients with major depression. Br J Clin Res. 1993;4:145-52.
279 Gagiano CA, Muller PG, Fourie J, Le Roux JF. The therapeutic efficacy of paroxetine: (a) an open study in patients with major depression not responding to antidepressants; (b) a double-blind comparison with amitriptyline in depressed outpatients. Acta Psychiatr Scand Suppl. 1989;350:130-1. [pmid: 2530765].
280 Gasperini M, Gatti F, Bellini L, Anniverno R, Smeraldi E. Perspectives in clinical psychopharmacology of amitriptyline and fluvoxamine. A double-blind study in depressed inpatients. Neuropsychobiology. 1992;26(4):186-92. [pmid: 1299793].
281 Geerts S, Bruynooghe F, De Cuyper H, Demeulemeester F, Haazen L. Moclobemide versus fluoxetine for major depressive episodes. Clin Neuropharmacol. 1994;17(Suppl 1):S50-S57. [pmid: 7954484].
282 Geisler A, Mygind S, Knudsen OR, Sloth-Nielsen M. Ritanserin and flupenthixol in dysthymic disorder: A controlled double blind study in general practice. Nord J Psychiatry. 1992;46(4):237-43.
283 Geretsegger C, Stuppaeck CH, Mair M, Platz T, Fartacek R, Heim M. Multicenter double blind study of paroxetine and amitriptyline in elderly depressed inpatients. Psychopharmacology (Berl). 1995;119(3):277-81. [pmcid: 161672]. [pmid: 7675961].
284 Gillin JC, Rapaport M, Erman MK, Winokur A, Albala BJ. A comparison of nefazodone and fluoxetine on mood and on objective, subjective, and clinician-rated measures of sleep in depressed patients: A double-blind, 8-week clinical trial. J Clin Psychiatry. 1997;58(5):185-92. [pmid: 9184611].
285 Ginestet D. Fluoxetine in endogenous depression and melancholia versus clomipramine. Int Clin Psychopharmacol. 1989;4(Suppl 1):37-40. [pmid: 2644338].
286 Guelfi JD, Payan C, Fermanian J, Pedarriosse AM, Manfredi R. Moclobemide versus clomipramine in endogenous depression. A double-blind randomised clinical trial. Br J Psychiatry. 1992;160:519-24. [pmid: 1571752].
287 Guillibert E, Pelicier Y, Archambault JC, Chabannes JP, Clerc G, Desvilles M, Guibert M, Pagot R, Poisat JL, Thobie Y. A double-blind, multicentre study of paroxetine versus clomipramine in depressed elderly patients. Acta Psychiatr Scand Suppl. 1989;350:132-4. [pmid: 2530766].
288 Guy W, Wilson WH, Ban TA, King DL, Manov G, Fjetland OK. A double-blind clinical trial of fluvoxamine and imipramine in patients with primary depression. Psychopharmacol Bull. 1984;20(1):73-8. [pmid: 6425916].
289 Haffmans PM, Timmerman L, Hoogduin CA. Efficacy and tolerability of citalopram in comparison with fluvoxamine in depressed outpatients: A double-blind, multicentre study. The LUCIFER Group. Int Clin Psychopharmacol. 1996;11(3):157-64.
290 Haider A, Miller DR, Christenson JL, Cushing AG, Station RD. Clinical effect of converting antidepressant therapy from fluoxetine to sertraline. Am J Health Syst Pharm. 1995;52(12):1317-9. [pmid: 7656119].
291 Halikas JA. Org 3770 (mirtazapine) versus trazodone: A placebo controlled trial in depressed elderly patients. Hum Psychopharmacol. 1995;10(Suppl 2):S125-S133.
292 Harrer G, Schmidt U, Kuhn U. "Alternative" Depressionbehandlung mit einem Hypericum-extrakt. Terapiewoche Neurologie/Psychiatrie. 1991;5:710-6.
293 Harris B, Szulecka TK, Anstee JA. Fluvoxamine versus amitriptyline in depressed hospital out-patients: A multicentre, double-blind, comparative trial. Br J Clin Res. 1991;2:89-99.
294 Heiligenstein JH, Tollefson GD, Faries DE. A double-blind trial of fluoxetine, 20 mg, and placebo in out-patients with DSM-III-R major depression and melancholia. Int Clin Psychopharmacol. 1993;8(4):247-51. [pmid: 8277143].
295 Hellerstein DJ, Yanowitch P, Rosenthal J, Samstag LW, Maurer M, Kasch K, Burrows L, Poster M, Cantillon M, Winston A. A randomized double-blind study of fluoxetine versus placebo in the treatment of dysthymia. Am J Psychiatry. 1993;150(8):1169-75. [pmid: 8328559].
296 Hoencamp E, Haffmans PM, Dijken WA, Hoogduin CA, Nolen WA, van Dyck R. Brofaromine versus lithium addition to maprotiline. A double-blind study in maprotiline refractory depressed outpatients. J Affect Disord. 1994;30(3):219-27. [pmid: 8006248].
297 Hoffmann J, Kuhl ED. [Therapy of depressive states with hypericin]. [German]. ZFA (Stuttgart). 1979;55(12):776-82. [pmcid: 17350]. [pmid: 375608].
298 Hoyberg OJ, Maragakis B, Mullin J, Norum D, Stordall E, Ekdahl P, Ose E, Moksnes KM, Sennef C. A double-blind multicentre comparison of mirtazapine and amitriptyline in elderly depressed patients. Acta Psychiatr Scand. 1996;93(3):184-90. [pmid: 8739664].
299 Hutchinson DR, Tong S, Moon CA, Vince M, Clarke A. Paroxetine in the treatment of elderly depressed patients in general practice: A double-blind comparison with amitriptyline. Int Clin Psychopharmacol. 1992;6(Suppl 4):43-51. [pmid: 1431010].
300 Jakovljevic M, Vujic D, Aleksandrovsky Y, Faltus F, Szelenberger W. Central-east European study of fluoxetine (Portal, Lek) and maprotiline (Ladiomil, Pliva) in major depressive episode. Psychiatria Danubina. 1996;8(Suppl 1):1-5.
301 Jenkins SW, Robinson DS, Fabre LF Jr, Andary JJ, Messina ME, Reich LA. Gepirone in the treatment of major depression. J Clin Psychopharmacol. 1990;0(3 Suppl):77S-85S.
302 Johnson D. Neurophysiological actions of hypericum in a double-blind study with test subjects. NerVenheilkunde. 1991;10(7 A):15-6.
303 Judd FK, Moore K, Norman TR, Burrows GD, Gupta RK, Parker G. A multicentre double blind trial of fluoxetine versus amitriptyline in the treatment of depressive illness. Aust N Z J Psychiatry. 1993;27(1):49-55. [pmid: 8481170].
304 Kamijima K, Koyama T, Mita T, Yamauchi T, Asai M, Toru M, Tamura A, Ushijima S, Hasegawa K, Murasaki M, et al. Clinical evaluation of sertraline hydrochloride, a selective serotonin reuptake inhibitor in the treatment of depression and depressive state: A double-blind, group comparison study of sertraline by hydrochloride vs amitriptyline hydrochloride. Jpn J Neuropsychopharmacol. 1997;19(6):529-48.
305 Katona CL, Abou-Saleh MT, Harrison DA, Nairac BA, Edwards DR, Lock T, Burns RA, Robertson MM. Placebo-controlled trial of lithium augmentation of fluoxetine and lofepramine. Br J Psychiatry. 1995;166(1):80-6. [pmid: 7894881].
306 Katona CL, Hunter BN, Bray J. A double-blind comparison of the efficacy and safety of paroxetine and imipramine in the treatment of depression with dementia. Int J Geriatr Psychiatry. 1998;3(2):100-8.
307 Keegan D, Bowen RC, Blackshaw S, Saleh S, Dayal N, Remillard F, Shrikhande S, Cebrian Perez S, Boulton A. A comparison of fluoxetine and amitriptyline in the treatment of major depression. Int Clin Psychopharmacol. 1991;6(2):117-24. [pmid: 1960381].
308 Keller MB, Harrison W, Fawcett JA, Gelenberg A, Hirschfeld RM, Klein D, Kocsis JH, McCullough JP, Rush AJ, Schatzberg A, et al. Treatment of chronic depression with sertraline or imipramine: Preliminary blinded response rates and high rates of under-treatment in the community. Psychopharmacol Bull. 1995;1(2):205-12.
309 Kerkhofs M, Rielaert C, de Maertelaer V, Linkowski P, Czarka M, Mendlewicz J. Fluoxetine in major depression: Efficacy, safety and effects on sleep polygraphic variables. Int Clin Psychopharmacol. 1990;5(4):253-60. [pmid: 2081896].
310 Khan A, Fabre LF, Rudolph R. Venlafaxine in depressed outpatients. Psychopharmacol Bull. 1991;27(2):141-4. [pmid: 1924660].
311 Kiev A. A double-blind, placebo-controlled study of paroxetine in depressed outpatients. J Clin Psychiatry. 1992;53(Suppl):27-9. [pmid: 1531818].
312 Kiev A, Feiger A. A double-blind comparison of fluvoxamine and paroxetine in the treatment of depressed outpatients. J Clin Psychiatry. 1997;58(4):146-52. [pmid: 9164424].
313 Kivela SL, Lehtomaki E. Sulpiride and placebo in depressed elderly outpatients: A double-blind study. Int J Geriatr Psychiatry. 1987;2(4):255-60.
314 Kniebel R, Burchard JM. Antidepressive therapy in practice. Z Allgemeinmedizin. 1988;64(23):689-96.
315 Ko HC, Lu RB, Shiah IS, Hwang CC. Plasma free 3-methoxy-4-hydroxyphenylglycol predicts response to fluoxetine. Biol Psychiatry. 1997;41(7):774-81. [pmid: 9084896].
316 Koczkas C, Holm P, Karlsson A, Nagy A, Ose E, Petursson H, Ulveras L, Wenedikter O. Moclobemide and clomipramine in endogenous depression. A randomized clinical trial. Acta Psychiatr Scand. 1989;9(6):523-9.
317 Konig CD. Hypericum perforatum L. (gemeines Johanniskraut) als Therapeutikum bei depressiven Verstimmungszustanden -- eine alternative zu synthetischen arzneimitteln. Unpublished.
318 Kragh-Sorensen P, Muller B, Andersen JV, Buch D, Stage KB. Moclobemide versus clomipramine in depressed patients in general practice. A randomized, double-blind, parallel, multicenter study. J Clin Psychopharmacol. 1995;15(4 Suppl 2):24S-30S.
319 Kwon JS, Youn T, Jung HY. Right hemisphere abnormalities in major depression: Quantitative electroencephalographic findings before and after treatment. J Affect Disord. 1996;40(3):169-73. [pmid: 8897116].
320 La Pia S, Giorgio D, Ciriello R, Sannino A. Evaluation of the efficacy, tolerability, and therapeutic profile of fluoxetine versus mianserin in the treatment of depressive disorders in the elderly. Curr Ther Res. 1992;52(6):847-58.
321 Laghrissi-Thode F, Pollock BG, Miller MC, Mulsant BH, Altieri L, Finkel MS. Double-blind comparison of paroxetine and nortriptyline on the postural stability of late-life depressed patients. Psychopharmacol Bull. 1995;31(4):659-63. [pmid: 8851637].
322 Lapierre YD, Joffe R, McKenna K, Bland R, Kennedy S, Ingram P, Reesal R, Rickhi BG, Beauclair L, Chouinard G, Annable L. Moclobemide versus fluoxetine in the treatment of major depressive disorder in adults. J Psychiatry Neurosci. 1997;22(2):118-26. [pmcid: 257795]. [pmid: 9074306].
323 Larsen JK, Gjerris A, Holm P, Andersen J, Bille A, Christensen EM, Hoyer E, Jensen H, Mejlhede A, Langagergaard A, et al. Moclobemide in depression: A randomized, multicentre trial against isocarboxazide and clomipramine emphasizing atypical depression. Acta Psychiatr Scand. 1991;84(6):564-70. [pmid: 1792931].
324 Larsen JK, Holm P, Mikkelsen PL. Moclobemide and clomipramine in the treatment of depression. A randomized clinical trial. Acta Psychiatr Scand. 1984;70(3):254-60. [pmid: 6388247].
325 Larsen JK, Holm P, Hoyer E, Mejlhede A, Mikkelsen PL, Olesen A, Schaumburg E. Moclobemide and clomipramine in reactive depression. A placebo-controlled randomized clinical trial. Acta Psychiatr Scand. 1989;79(6):530-6. [pmid: 2669441].
326 Laursen AL, Mikkelsen PL, Rasmussen S, le Fevre Honore P. Paroxetine in the treatment of depression -- a randomized comparison with amitriptyline. Acta Psychiatr Scand. 1985;71(3):249-55. [pmid: 3157296].
327 Laws D, Ashford JJ, Anstee JA. A multicentre double-blind comparative trial of fluvoxamine versus lorazepam in mixed anxiety and depression treated in general-practice. Acta Psychiatr Scand. 1990;81(2):185-9. [pmid: 2109498].
328 Lecrubier Y, Bourin M, Moon CA, Schifano F, Blanchard C, Danjou P, Hackett D. Efficacy of venlafaxine in depressive illness in general practice. Acta Psychiatr Scand. 1997;95(6):485-93. [pmid: 9242843].
329 Lecrubier Y, Boyer P, Turjanski S, Rein W. Amisulpride versus imipramine and placebo in dysthymia and major depression. Amisulpride Study Group. J Affect Disord. 1997;43(2):95-103.
330 Lecrubier Y, Pedarriosse AM, Payan C, Schmid-Burgk W, Stabl M. Moclobemide versus clomipramine in nonmelancholic, nonpsychotic major depression. Acta Psychiatr Scand. 1995;92(4):260-5. [pmid: 8848950].
331 Levine S, Deo R, Mahadevan K. A comparative trial of a new antidepressant, fluoxetine. Int Clin Psychopharmacol. 1989;4(Suppl 1):41-5. [pmid: 2644339].
332 Lineberry CG, Johnston JA, Raymond RN, Samara B, Feighner JP, Harto NE, Granacher RP Jr, Weisler RH, Carman JS, Boyer WF. A fixed-dose (300 mg) efficacy study of bupropion and placebo in depressed outpatients. J Clin Psychiatry. 1990;51(5):194-9. [pmid: 2110559].
333 Lingjaerde O, Jorgensen J, Storen R, Thomle S, Wendt Raeder L, Ruud LE, Schetelig E, Sveaas HK, Leivestad O. A double-blind comparison of moclobemide and doxepin in depressed general practice patients. Acta Psychiatr Scand. 1995;92(2):125-31. [pmid: 7572258].
334 Link C, Dunbar G. An overview of studies comparing the efficacy, safety, and tolerability of paroxetine and clomipramine. Nord J Psychiatry. 1992;46(Suppl 27):17-22.
335 Lonnqvist J, Sintonen H, Syvalahti E, Appelberg B, Koskinen T, Mannikko T, Mehtonen OP, Naarala M, Sihvo S, Auvinen J, et al. Antidepressant efficacy and quality of life in depression: A double-blind study with moclobemide and fluoxetine. Acta Psychiatr Scand. 1994;89(6):363-9. [pmid: 8085464].
336 Lopez-Ibor J, Guelfi JD, Pletan Y, Tournoux A, Prost JF. Milnacipran and selective serotonin reuptake inhibitors in major depression. Int Clin Psychopharmacol. 1996;11(Suppl 4):41-6.
337 Lydiard RB, Laird LK, Morton WA Jr, Steele TE, Kellner C, Laraia MT, Ballenger JC. Fluvoxamine, imipramine, and placebo in the treatment of depressed outpatients: Effects on depression. Psychopharmacol Bull. 1989;25(1):68-70. [pmid: 2505304].
338 Macher JP, Mirabaud C. A double-blind comparison of moclobemide and amineptine in the treatment of depressed out-patients. Psychopharmacology (Berl). 1992;106(Suppl):S116-S117. [pmcid: 161672]. [pmid: 1546123].
339 Mahapatra SN, Hackett D. A randomised, double-blind, parallel-group comparison of venlafaxine and dothiepin in geriatric patients with major depression. Int J Clin Pract. 1997;51(4):209-13. [pmid: 9287259].
340 Mandoki MW, Tapia MR, Tapia MA, Sumner GS, Parker JL. Venlafaxine in the treatment of children and adolescents with major depression. Psychopharmacol Bull. 1997;33(1):149-54. [pmid: 9133767].
341 March JS, Kobak KA, Jefferson JW, Mazza J, Greist JH. A double-blind, placebo-controlled trial of fluvoxamine versus imipramine in outpatients with major depression. J Clin Psychiatry. 1990;51(5):200-2. [pmid: 2110560].
342 Marttila M, Jaaskelainen J, Jarvi R, Romanov M, Miettinen E, Sorri P, Ahlfors U, Zivkov M. A double-blind study comparing the efficacy and tolerability of mirtazapine and doxepin in patients with major depression. Eur Neuropsychopharmacol. 1995;5(4):441-6. [pmid: 8998395].
343 Masco HL, Kiev A, Holloman LC, Batey SR, Johnston JA, Lineberry CG. Safety and efficacy of bupropion and nortriptyline in outpatients with depression. Curr Ther Res Clin Exp. 1994;55(7):851-63.
344 Masco HL, Sheetz MS, et al. Double-blind comparison of fluoxetine and amitriptyline in the treatment of major depressive illness. Adv Ther. 1985;2(6):275-84.
345 Mauri MC, Ferrara A, Fabiano L, Ricci C, Invernizzi G. A double blind study on fluvoxamine vs. placebo in depressed HIV positive patients: Short-term and perspective results. Integr Psychiatry. 1994;10(4):199-201.
346 McGrath PJ, Stewart JW, Quitkin FM, Wager S, Jenkins SW, Archibald DG, Stringfellow JC, Robinson DS. Gepirone treatment of atypical depression: Preliminary evidence of serotonergic involvement. J Clin Psychopharmacol. 1994;14(5):347-52. [pmid: 7806692].
347 Meignan-Debray S, Forette B, Roger M. Double-blind trial of medifoxamine (Cledial registered) versus placebo in elderly patients with depressive disorders. Psychol Med. 1990;22(9):883-92.
348 Mendels J, Johnston R, Mattes J, Riesenberg R. Efficacy and safety of b.i.d. doses of venlafaxine in a dose-response study. Psychopharmacol Bull. 1993;29(2):169-74. [pmid: 8290661].
349 Mendels J, Reimherr F, Marcus RN, Roberts DL, Francis RJ, Anton SF. A double-blind, placebo-controlled trial of two dose ranges of nefazodone in the treatment of depressed outpatients. J Clin Psychiatry. 1995;56(Suppl 6):30-6.
350 Mertens C, Pintens H. A double-blind, multicentre study of paroxetine and mianserin in depression. Acta Psychiatr Scand Suppl. 1989;350.
351 Moller HJ, Berzewski H, Eckmann F, Gonzalves N, Kissling W, Knorr W, Ressler P, Rudolf GA, Steinmeyer EM, Magyar I, et al. Double-blind multicenter study of paroxetine and amitriptyline in depressed inpatients. Pharmacopsychiatry. 1993;26(3):75-8. [pmid: 8415897].
352 Moller HJ, Volz HP. Brofaromine in elderly major depressed patients -- a comparative trial versus imipramine. Eur Neuropsychopharmacol. 1993;3(4):501-10. [pmid: 8111223].
353 Moller HJ, Volz HP. Brofaromine in major depressed patients: A controlled clinical trial versus imipramine and open follow-up of up to one year. J Affect Disord. 1992;26(3):163-72. [pmid: 1460166].
354 Montgomery DB, Roberts A, Green M, Bullock T, Baldwin D, Montgomery SA. Lack of efficacy of fluoxetine in recurrent brief depression and suicidal attempts. Eur Arch Psychiatry Clin Neurosci. 1994;244(4):211-5. [pmid: 7888419].
355 Montgomery SA, Baldwin DS, Priest RG, Steinert J, Patel A, Herrington RN, Livingston HM. Minaprine and dose response in depression. An investigation of two fixed doses of minaprine compared with imipramine. Pharmacopsychiatry. 1991;24(5):168-74. [pmid: 1775522].
356 Montgomery SA, Dunbar G. Paroxetine is better than placebo in relapse prevention and the prophylaxis of recurrent depression. Int Clin Psychopharmacol. 1993;8(3):189-95. [pmid: 8263317].
357 Montgomery SA, Rasmussen JG, Lyby K, Connor P, Tanghoj P. Dose response relationship of citalopram 20 mg, citalopram 40 mg and placebo in the treatment of moderate and severe depression. Int Clin Psychopharmacol. 1992;6(Suppl 5):65-70.
358 Montgomery SA, Rasmussen JG, Tanghoj P. A 24-week study of 20 mg citalopram, 40 mg citalopram, and placebo in the prevention of relapse of major depression. Int Clin Psychopharmacol. 1993;8(3):181-8. [pmid: 8263316].
359 Moon CA, Jago W, Wood K, Doogan DP. A double-blind comparison of sertraline and clomipramine in the treatment of major depressive disorder and associated anxiety in general practice. J Psychopharmacol (Oxf). 1994;8(3):171-6.
360 Moon CA, Jesinger DK. The effects of psychomotor performance of fluvoxamine versus mianserin in depressed patients in general practice. Br J Clin Pract. 1991;45(4):259-62. [pmid: 1810359].
361 Moon CA, Vince M. Treatment of major depression in general practice: A double-blind comparison of paroxetine and lofepramine. Br J Clin Pract. 1996;50(5):240-4. [pmid: 8794599].
362 Muijen M, Roy D, Silverstone T, Mehmet A, Christie M. A comparative clinical trial of fluoxetine, mianserin and placebo in depressed outpatients. Acta Psychiatr Scand. 1988;78(3):384-90. [pmid: 3057817].
363 Mullin JM, Pandita-Gunawardena VR, Whitehead AM. A double-blind comparison of fluvoxamine and dothiepin in the treatment of major affective disorder. Br J Clin Pract. 1988;42(2):51-5. [pmid: 3140864].
364 Murasaki M, Kamijima K, Yamashita I, Mita T, Yamauchi T, Asai M, Toru M, Tamura A, Ushijima S, Nakajima T, et al. Clinical evaluation of sertraline hydrochloride, a selective serotonin reuptake inhibitor for depression and depressive state. A double-blind study compared with imipramine hydrochloride. Jpn J Neuropsychopharmacol. 1997;19(6):505-27.
365 Nair NP, Amin M, Holm P, Katona C, Klitgaard N, Ng Ying Kin NM, Kragh-Sorensen P, Kuhn H, Leek CA, Stage KB. Moclobemide and nortriptyline in elderly depressed patients. A randomized, multicentre trial against placebo. J Affect Disord. 1995;33(1):1-9. [pmid: 7714303].
366 Nappi G, Sandrini G, Granella F, Ruiz L, Cerutti G, Facchinetti F, Blandini F, Manzoni GC. A new 5-HT2 antagonist (ritanserin) in the treatment of chronic headache with depression. A double-blind study vs amitriptyline. Headache. 1990;30(7):439-44. [pmid: 2119355].
367 Nemeroff CB, Ninan PT, Ballenger J, Lydiard RB, Feighner JP, Patterson WM, Greist JH. Double-blind multicenter comparison of fluvoxamine versus sertraline in the treatment of depressed outpatients. Depression. 1995;3:163-9.
368 Newburn GM, Fraser AR, Menkes DB, Mullen PE. A double blind trial of moclobemide versus amitriptyline in the treatment of depressive disorders. Aust N Z J Psychiatry. 1990;24(4):475-9. [pmid: 2073222].
369 Nielsen BM, Behnke K, Arup P, Christiansen PE, Geisler A, Ipsen E, Maach-Moller B, Ohrberg SC. A comparison of fluoxetine and imipramine in the treatment of outpatients with major depressive disorder. Acta Psychiatr Scand. 1993;87(4):269-72. [pmid: 8488748].
370 Noguera R, Altuna R, Alvarez E, Ayuso JL, Casais L, Udina C. Fluoxetine vs. clomipramine in depressed patients: A controlled multicentre trial. J Affect Disord. 1991;22(3):119-24. [pmid: 1918655].
371 Nyth AL, Gottfries CG, Lyby K, Smedegaard-Andersen L, Gylding-Sabroe J, Kristensen M, Refsum HE, Ofsti E, Eriksson S, Syversen S. A controlled multicenter clinical study of citalopram and placebo in elderly depressed patients with and without concomitant dementia. Acta Psychiatr Scand. 1992;86(2):138-45. [pmid: 1529737].
372 Ohrberg S, Christiansen PE, Severin B, Calberg H, Nilakantan B, Borup A, Sogaard J, Larsen SB, Loldrup D, Bahr B, et al. Paroxetine and imipramine in the treatment of depressive patients in psychiatric practice. Acta Psychiatr Scand. 1992;86(6):437-44. [pmid: 1471536].
373 Olie JP, Gunn KP, Katz E. A double-blind placebo-controlled multicentre study of sertraline in the acute and continuation treatment of major depression. Eur Psychiatry. 1997;12(1):34-41. [pmid: 19698503].
374 Orsel Donbak S, Turkcapar MH, Ozturk Kilic EZ, Demirergi N, Akdemir A, Sirin A, Ozbay MH. Moclobemide and sertraline in the treatment of depressive disorders: A comparative study. Acta Psychiatr Belg. 1995;95(3):139-51. [pmid: 8525856].
375 Osterheider M, Schmidtke A, Beckmann H. Behandlung depressiver Syndrome mit Hypericum (Johanniskraut) -- Eine placebokontrollierte Doppelblindstudie. Fortschr Neurol Psychiatr. 1992;60:210-1.
376 Othmer E, Othmer SC, Stern WC, Van Wyck Fleet J. Long-term efficacy and safety of bupropion. J Clin Psychiatry. 1983;44(5 Pt 2):153-6.
377 Pancheri P, Delle Chiaie R, Donnini M, Seripa S, Gambino C, Vicario E, Trillo L. Effects of moclobemide on depressive symptoms and cognitive performance in a geriatric population: A controlled comparative study versus imipramine. Clin Neuropharmacol. 1994;17(Suppl 1):S58-S73. [pmid: 7954485].
378 Pande AC, Birkett M, Fechner-Bates S, Haskett RF, Greden JF. Fluoxetine versus phenelzine in atypical depression. Biol Psychiatry. 1996;40(10):1017-20. [pmid: 8915561].
379 Parnetti L, Sommacal S, Morselli LA, Senin U. Multicentre controlled randomised double-blind placebo study of minaprine in elderly patients suffering from prolonged depressive reaction. Drug Invest. 1993;6(4):181-8.
380 Patris M, Bouchard JM, Bougerol T, Charbonnier JF, Chevalier JF, Clerc G, Cyran C, Van Amerongen P, Lemming O, Hopfner Petersen HE. Citalopram versus fluoxetine: A double-blind, controlled, multicentre, phase III trial in patients with unipolar major depression treated in general practice. Int Clin Psychopharmacol. 1996;11(2):129-36. [pmid: 8803650].
381 Paykel ES, Van Woerkom AE, Walters DE, White W, et al. Fengabine in depression: A placebo controlled study of a GABA agonist. Hum Psychopharmacol Clin Exp. 1991;6(2):147-54.
382 Perez A, Ashford JJ. A double-blind, randomized comparison of fluvoxamine with mianserin in depressive illness. Curr Med Res Opin. 1990;12(4):234-41. [pmid: 2127561].
383 Perez V, Gilaberte I, Faries D, Alvarez E, Artigas F. Randomised, double-blind, placebo-controlled trial of pindolol in combination with fluoxetine antidepressant treatment. Lancet. 1997;349(9065):1594-7. [pmid: 9174562].
384 Perry PJ, Garvey MJ, Kelly MW, Cook BL, Dunner FJ, Winokur G. A comparative trial of fluoxetine versus trazodone in outpatients with major depression. J Clin Psychiatry. 1989;50(8):290-4. [pmid: 2668259].
385 Peselow ED, Stanley M, Filippi AM, Barouche F, Goodnick P, Fieve RR. The predictive value of the dexamethasone suppression test. A placebo-controlled study. Br J Psychiatry. 1989;155:667-72. [pmid: 2532946].
386 Phanjoo AL, Wonnacott S, Hodgson A. Double-blind comparative multicentre study of fluvoxamine and mianserin in the treatment of major depressive episode in elderly people. Acta Psychiatr Scand. 1991;83(6):476-9. [pmid: 1909083].
387 Philipp M, Kohnen R, Benkert O. A comparison study of moclobemide and doxepin in major depression with special reference to effects on sexual dysfunction. Int Clin Psychopharmacol. 1993;7(3-4):149-53. [pmid: 8468436].
388 Preskorn SH. Antidepressant response and plasma concentrations of bupropion. J Clin Psychiatry. 1983;44(5 Pt 2):137-9. [pmid: 6406443].
389 Preskorn SH, Silkey B, Beber J, Dorey C. Antidepressant response and plasma concentrations of fluoxetine. Ann Clin Psychiatry. 1991;3(2):147-51.
390 Rahman MK, Akhtar MJ, Savla NC, Sharma RR, Kellett JM, Ashford JJ. A double-blind, randomised comparison of fluvoxamine with dothiepin in the treatment of depression in elderly patients. Br J Clin Pract. 1991;45(4):255-8. [pmid: 1810358].
391 Ramaekers JG, Ansseau M, Muntjewerff ND, Sweens JP, O'Hanlon JF. Considering the P450 cytochrome system as determining combined effects of antidepressants and benzodiazepines on actual driving performance of depressed outpatients. Int Clin Psychopharmacol. 1997;12(3):159-69. [pmid: 9248873].
392 Rampello L, Nicoletti G, Raffaele R. Dopaminergic hypothesis for retarded depression: A symptom profile for predicting therapeutical responses. Acta Psychiatr Scand. 1991;84(6):552-4. [pmid: 1792929].
393 Rapaport M, Coccaro E, Sheline Y, Perse T, Holland P, Fabre L, Bradford D. A comparison of fluvoxamine and fluoxetine in the treatment of major depression. J Clin Psychopharmacol. 1996;16(5):373-8. [pmid: 8889909].
394 Ravindran AV, Judge R, Hunter BN, Bray J, Morton NH. A double-blind, multicenter study in primary care comparing paroxetine and clomipramine in patients with depression and associated anxiety. Paroxetine Study Group. J Clin Psychiatry. 1997;58(3):112-8.
395 Ravindran AV, Teehan MD, Bakish D, Yatham L, O'Reilly R, Fernando ML, Manchanda R, Charbonneau Y, Buttars J. The impact of sertraline, desipramine, and placebo on psychomotor functioning in depression. Hum Psychopharmacol. 1995;10(4):273-81.
396 Reebye PN, Yiptong C, Samsoon J, Schulsinger F, Fabricius J. A controlled double-blind study of femoxetine and amitriptyline in patients with endogenous depression. Pharmacopsychiatria. 1982;15(5):164-9. [pmid: 6757983].
397 Reh C, Laux P, Schenk N. [Hypericum extract: An effective alternative in the treatment of depressions]. [German]. Therapiewoche. 1992;42(25):1576-81.
398 Reimherr FW, Chouinard G, Cohn CK, Cole JO, Itil TM, Lapierre YD, Masco HL, Mendels J. Antidepressant efficacy of sertraline: A double-blind, placebo- and amitriptyline-controlled, multicenter comparison study in outpatients with major depression. J Clin Psychiatry. 1990;51(Suppl B):18-27.
399 Remick RA, Claman J, Reesal R, Gibson RE, et al. Comparison of fluoxetine and desipramine in depressed outpatients. Curr Ther Res. 1993;53(5):457-65.
400 Remick RA, Keller FD, Gibson RE, Carter D. A comparison between fluoxetine and doxepin in depressed patients. Curr Ther Res Clin Exp. 1989;46(5):842-8.
401 Remick RA, Reesal R, Oakander M, Allen J, Claman J, Ramirez CE, Perry K, Keller FD. Comparison of fluvoxamine and amitriptyline in depressed outpatients. Curr Ther Res. 1994;55(3):243-50.
402 Reynaert C, Parent M, Mirel J, Janne P, Haazen L. Moclobemide versus fluoxetine for a major depressive episode. Psychopharmacology (Berl). 1995;118(2):183-7. [pmcid: 161672]. [pmid: 7617806].
403 Richou H, Ruimy P, Charbaut J. A multicentre, double-blind, clomipramine-controlled efficacy and safety study of Org 3770. Hum Psychopharmacol. 1995;10:263-71.
404 Rickels K, Amsterdam J, Clary C, Fox I, Schweizer E, Weise C. A placebo-controlled, double-blind, clinical trial of paroxetine in depressed outpatients. Acta Psychiatr Scand Suppl. 1989;350:117-23. [pmid: 2530761].
405 Rickels K, Robinson DS, Schweizer E, Marcus RN, Roberts DL. Nefazodone: Aspects of efficacy. J Clin Psychiatry. 1995;56(Suppl 6):43-6. [pmid: 7649973].
406 Rickels K, Schweizer E, Clary C, Fox I, Weise C. Nefazodone and imipramine in major depression: A placebo-controlled trial. Br J Psychiatry. 1994;164(6):802-5. [pmid: 7952987].
407 Robert P, Montgomery SA. Citalopram in doses of 20-60 mg is effective in depression relapse prevention: A placebo-controlled 6 month study. Int Clin Psychopharmacol. 1995;10(Suppl 1):29-35.
408 Robertson MM, Abou Saleh MT, Harrison DA, Nairac BL A double-blind controlled comparison of fluoxetine and lofepramine in major depressive illness J Psychopharmacol (Oxf) 1994 8(2) 98 103Robertson 1994
409 Robinson JM, Hodgson A, Whitehead AM. Fluvoxamine vs lofepramine: a double-blind, parallel group study in the treatment of hospital outpatients with depressive illness. Duphar Labs Report No: H114918/M. Unpublished 1989.
410 Roose SP, Laghrissi-Thode F, Kennedy JS, Nelson JC, Bigger JT Jr, Pollock BG, .Gaffney A, Narayan M, Finkel MS. Comparison of paroxetine and nortriptyline in depressed patients with ischemic heart disease. JAMA. 1998;279(4):287-91. [pmid: 9450712].
411 Ropert R. Fluoxetine versus clomipramine in major depressive disorders. Int Clin Psychopharmacol. 1989;4(Suppl 1):89-95. [pmid: 2644343].
412 Rosenberg C, Damsbo N, Fuglum E, Jacobsen LV, Horsgard S Citalopram and imipramine in the treatment of depressive patients in general practice. A Nordic multicentre clinical study Int Clin Psychopharmacol 1994 9(Suppl 1) 41 8Rosenberg 1994
413 Roth D, Mattes J, Sheehan KH, Sheehan DV. A double-blind comparison of fluvoxamine, desipramine and placebo in outpatients with depression. Prog Neuropsychopharmacol Biol Psychiatry. 1990;14(6):929-39. [pmid: 2126144].
414 Roth M, Mountjoy CQ, Amrein R Moclobemide in elderly patients with cognitive decline and depression: An international double-blind, placebo-controlled trial Br J Psychiatry 1996 168(2) 149 57Roth 1996 8837903
415 Salzmann E, Robin JL. Multicentric double-blind study comparing efficacy and safety of minaprine and imipramine in dysthymic disorders. Neuropsychobiology. 1995;31(2):68-75. [pmid: 7760988].
416 Schmidt U, Harrer G, Kuhn U, BergerDeinert W, Luther D. Interaction of hypericum extract with alcohol placebo controlled study with 32 volunteers. Nervenheilkunde. 1993;12(6 A):314-9.
417 Schmidt U, Sommer H. [Extract of St. John's wort in the treatment of depression -- attention and reaction remain unimpaired]. [German]. Fortschr Med. 1993;111(19):37-40. [pmid: 8444393].
418 Schmidt U, Sommer H. [St. John's wort extract in the ambulatory therapy of depression. Attention and reaction ability are preserved]. [German]. Fortschr Med. 1993;111(19):339-42. [pmid: 8370566].
419 Schnyder U, Koller-Leiser A. A double-blind, multicentre study of paroxetine and maprotiline in major depression. Can J Psychiatry. 1996;41(4):239-44. [pmid: 8726790].
420 Schone W, Ludwig M A double-blind study of paroxetine compared with fluoxetine in geriatric patients with major depression J Clin Psychopharmacol 1993 13(6 Suppl 2) 34S 39SSchone 1993 8106654
421 Schweizer E, Feighner JP, Mandos LA, Rickels K Comparison of venlafaxine and imipramine in the acute treatment of major depression in outpatients J Clin Psychiatry 1994 55(3) 104 8Schweizer 1994 8071246
422 Schweizer E, Weise C, Clary C, Fox I, Rickels K. Placebo-controlled trial of venlafaxine for the treatment of major depression. J Clin Psychopharmacol. 1991;11(4):233-6. [pmid: 1918421].
423 Shaw DM, Thomas DR, Briscoe MH, Watkins SE, Crimmins R, Harris B, Lovett J, Raj M, Lloyd AT, Osborne C, et al. A comparison of the antidepressant action of citalopram and amitriptyline. Br J Psychiatry. 1986;149:515-7. [pmid: 3545354].
424 Shrivastava RK, Cohn C, Crowder J, Davidson J, Dunner D, Feighner JP, Kiev A, Patrick R. Long-term safety and clinical acceptability of venlafaxine and imipramine in outpatients with major depression. J Clin Psychopharmacol. 1994;14(5):322-9. [pmid: 7806687].
425 Shrivastava RK, Shrivastava SH, Overweg N, Blumhardt CL. A double-blind comparison of paroxetine, imipramine, and placebo in major depression. J Clin Psychiatry. 1992;53(Suppl):48-51. [pmid: 1531825].
426 Simeon JG, Dinicola VF, Ferguson HB, Copping W. Adolescent depression: A placebo-controlled fluoxetine treatment study and follow-up. Prog Neuropsychopharmacol Biol Psychiatry. 1990;14(5):791-5. [pmid: 2293257].
427 Simon GE, VonKorff M, Heiligenstein JH, Revicki DA, Grothaus L, Katon W, Wagner EH. Initial antidepressant choice in primary care: Effectiveness and cost of fluoxetine vs tricyclic antidepressants. JAMA. 1996;275(24):1897-902. [pmid: 8648870].
428 Skausig OB, Nielsen OA, Morsing I, Petersen JS, et al Paroxetine and imipramine treatment of depressed patients in a controlled, multicentre study with plasma amino acid measurements Nord J Psychiatry 1992 46(Suppl 27) 23 6Skausig 1992
429 Skrumsager BK, Jeppesen K. Femoxetine and amitriptyline in general practice: A randomized double-blind group comparison. Pharmacopsychiatry. 1986;19(5):368-77. [pmid: 3774871].
430 Smeraldi E Amisulpride versus fluoxetine in patients with dysthymia or major depression in partial remission: A double-blind, comparative study J Affect Disord 1998 48(1) 47 56Smeraldi 1998 9495601
431 Smith WT, Glaudin V. A placebo-controlled trial of paroxetine in the treatment of major depression. J Clin Psychiatry. 1992;53(Suppl):36-9.
432 Smith WT, Glaudin V, Panagides J, Gilvary E. Mirtazapine vs. amitriptyline vs. placebo in the treatment of major depressive disorder. Psychopharmacol Bull. 1990;26(2):191-6. [pmid: 2236455].
433 South Wales Antidepressant Drug Trial Group. A double-blind multi-centre trial of fluoxetine and dothiepin in major depressive illness. Int Clin Psychopharmacol. 1988;3(1):75-81. [pmid: 3282004].
434 Sramek JJ, Kashkin K, Jasinsky O, Kardatzke D, Kennedy S, Cutler NR. Placebo-controlled study of a BT-200 versus fluoxetine in the treatment of major depressive disorder. Depression. 1995;3(4):199-203.
435 Stark P, Hardison CD A review of multicenter controlled studies of fluoxetine vs. imipramine and placebo in outpatients with major depressive disorder J Clin Psychiatry 1985 46(3 Pt. 2) 53 8Stark 1985 3882682
436 Steger W. Depressive Verstimmungen. Z Allg Med. 1985;61:914-8.
437 Steinmeyer EM, Vorbach EU, Arnoldt KH. Efficacy and safety of moclobemide compared with maprotiline in treatment of major depressive disorder. A double-blind multicenter study with parallel groups. Pharmacopsychiatry. 1993;26(6):246-53. [pmid: 8127929].
438 Stuppaeck CH, Geretsegger C, Whitworth AB, Schubert H, Platz T, Konig P, Hinterhuber H, Fleischhacker WW. A multicenter double-blind trial of paroxetine versus amitriptyline in depressed inpatients. J Clin Psychopharmacol. 1994;14(4):241-6. [pmid: 7962679].
439 Suleman MI, Sebit MB, Acuda SW, Siziya S. Fluoxetine and moclobemide versus amitriptyline in major depression: A single blind randomized clinical trial in Zimbabwe. Cent Afr J Med. 1997;43(2):38-40.
440 Suominen J, Tamminen T, Elosuo R, Manniche PM. Efficacy and tolerance of femoxetine and imipramine in the treatment of depressive states. A randomized, double-blind study. Pharmacopsychiatry. 1988;21(5):238-44. [pmid: 3067246].
441 Szegedi A, Wetzel H, Angersbach D, Dunbar GC, Schwarze H, Philipp M, Benkert O A double-blind study comparing paroxetine and maprotiline in depressed outpatients Pharmacopsychiatry 1997 30(3) 97 105Szegedi 1997 9211571
442 Tamminen T, Salminen JK, Skrumsager BK. [A double blind controlled trial of the selective serotonin uptake inhibitor femoxetine and amitriptyline in depression]. [Danish]. Nord Psykiatr Tidsskr. 1982;36(6):335-9.
443 Taragano FE, Lyketsos CG, Mangone CA, Allegri RF, Comesana-Diaz E. A double-blind, randomized, fixed-dose trial of fluoxetine vs. amitriptyline in the treatment of major depression complicating Alzheimer's disease. Psychosomatics. 1997;38(3):246-52. [pmid: 9136253].
444 Targ EF, Karasic DH, Diefenbach PN, Anderson DA, Bystritsky A, Fawzy FI. Structured group therapy and fluoxetine to treat depression in HIV-positive persons. Psychosomatics. 1994;35(2):132-7. [pmid: 8171171].
445 Thase ME, Fava M, Halbreich U, Kocsis JH, Koran L, Davidson J, Rosenbaum J, Harrison W A placebo-controlled, randomized clinical trial comparing sertraline and imipramine for the treatment of dysthymia Arch Gen Psychiatry 1996 53(9) 777 84Thase 1996 8792754
446 Tignol J. A double-blind, randomized, fluoxetine-controlled, multicenter study of paroxetine in the treatment of depression. J Clin Psychopharmacol. 1993;13(6 Suppl 2):18S-22S. [pmid: 8106650].
447 Tollefson GD, Bosomworth JC, Heiligenstein JH, Potvin JH, Holman S A double-blind, placebo-controlled clinical trial of fluoxetine in geriatric patients with major depression. The Fluoxetine Collaborative Study Group Int Psychogeriatr 1995 7(1) 89 104Tollefson 1995 7579025
448 Tollefson GD, Greist JH, Jefferson JW, Heiligenstein JH, Sayler ME, Tollefson SL, Koback K Is baseline agitation a relative contraindication for a selective serotonin reuptake inhibitor: A comparative trial of fluoxetine versus imipramine J Clin Psychopharmacol 1994 14(6) 385 91Tollefson 1994 7884018
449 Tome MB, Isaac MT, Harte R, Holland C Paroxetine and pindolol: A randomized trial of serotonergic autoreceptor blockade in the reduction of antidepressant latency Int Clin Psychopharmacol 1997 12(2) 81 9Tome 1997 9219043
450 Tylee A, Beaumont G, Bowden MW, Reynolds A. A double-blind, randomized, 12-week comparison study of the safety and efficacy of venlafaxine and fluoxetine in moderate to severe major depression in general practice. Prim Care Psychiatr. 1997;3(1):51-8.
451 Ucha Udabe R, Marquez CA, Traballi CA, Portes N. Double-blind comparison of moclobemide, imipramine and placebo in depressive patients. Acta Psychiatr Scand Suppl. 1990;360:54-6. [pmid: 2123367].
452 UK Moclobemide Study Group. A multicentre comparative trial of moclobemide, imipramine and placebo in major depressive disorder. Int Clin Psychopharmacol. 1994;9(2):109-13. [pmid: 8056992].
453 Valducci M, Valducci A, Paoletti C, Colonna CV. A double blind, placebo controlled clinical trial of evaluate efficacy and safety of fluoxetine in the treatment of major depression. G Ital Ric Clin Ter. 1992;13(3):59-64.
454 Van Moffaert M, Bartholome F, Cosyns P, De Nayer AR, Mertens C. A controlled comparison of sertraline and fluoxetine in acute and continuation treatment of major depression. Hum Psychopharmacol. 1995;10(5):393-405.
455 Van Moffaert M, De Wilde J, Vereecken A, Dierick M, Evrard JL, Wilmotte J, Mendlewicz J. Mirtazapine is more effective than trazodone: A double-blind controlled study in hospitalized patients with major depression. Int Clin Psychopharmacol. 1995;10(1):3-9. [pmid: 7622801].
456 Van Moffaert M, Pregaldien JL, Von Frenckell R, Gammans R. A double-blind comparison of nefazodone and imipramine in the treatment of depressed patients. New Trends Exp Clin Psychiatry. 1994;10(2):85-97.
457 Van Moffaert M, Vogels C, Beckers G, Vereecken A. Moclobemide versus amitriptyline in the treatment of depression: Two double blind multicenter studies in Belgium. New Trends Exp Clin Psychiatry. 1989;5(3):167-77.
458 Vanelle JM, Attar-Levy D, Poirier MF, Bouhassira M, Blin P, Olie JP. Controlled efficacy study of fluoxetine in dysthymia. Br J Psychiatry. 1997;170:345-50. [pmid: 9246253].
459 Vartiainen H, Leinonen E. Double-blind study of mirtazapine and placebo in hospitalized patients with major depression. Eur Neuropsychopharmacol. 1994;4(2):145-50. [pmid: 7919944].
460 Vaz-Serra A, Figueira ML, Firmino H, Albuquerque AJ, Jara JM, Pestana LC. Multicenter double-blind study of moclobemide and maprotiline. Clin Neuropharmacol. 1994;17(Suppl 1):S38-S49. [pmid: 7954483].
461 Vercoulen JH, Swanink CM, Zitman FG, Vreden SG, Hoofs MP, Fennis JF, Galama JM, van der Meer JW, Bleijenberg G. Randomised, double-blind, placebo-controlled study of fluoxetine in chronic fatigue syndrome. Lancet. 1996;347(9005):858-61. [pmid: 8622391].
462 Versiani M, Amrein R, Stabl M. Moclobemide and imipramine in chronic depression (dysthymia): An international double-blind, placebo-controlled trial. International Collaborative Study Group. Int Clin Psychopharmacol. 1997;12(4):183-93. [pmid: 9347378].
463 Versiani M, Nardi AE, Mundim FD, Alves A, Schmid-Burgk W Moclobemide, imipramine and placebo in the treatment of major depression Acta Psychiatr Scand Suppl 1990 360 57 8Versiani 1990 2248073
464 Volz HP, Gleiter CH, Moller HJ. Brofaromine versus imipramine in in-patients with major depression -- a controlled trial. J Affect Disord. 1997;44(2-3):91-9. [pmid: 9241569].
465 Vorbach EU, Arnoldt KH, Hubner WD. Efficacy and tolerability of St. Johns' Wort extract L1 160 versus imipramine in patients with severe depressive episodes according to ICD-10. Pharmacopsychiatry. 1997;30(Suppl 2):81-5. [pmid: 9342765].
466 Vorbach EU, Hubner WD, Arnoldt KH. Effectiveness and tolerance of the hypericum extract L1 160 in comparison with imipramine: Randomized double-blind study with 135 outpatients. J Geriatr Psychiatry Neurol. 1994;7(Suppl 1):S19-S23. [pmid: 7857502].
467 Walczak DD, Apter JT, Halikas JA, Borison RL, Carman JS, Post GL, Patrick R, Cohn JB, Cunningham LA, Rittberg B, Preskorn SH, Kang JS, Wilcox CS. The oral dose-effect relationship for fluvoxamine: A fixed-dose comparison against placebo in depressed outpatients. Ann Clin Psychiatry. 1996;8(3):139-51. [pmid: 8899132].
468 Weisler RH, Johnston JA, Lineberry CG, Samara B, Branconnier RJ, Billow AA. Comparison of bupropion and trazodone for the treatment of major depression. J Clin Psychopharmacol. 1994;14(3):170-9. [pmid: 8027413].
469 Wernicke JF, Dunlop SR, Dornseif BE, Bosomworth JC, Humbert M Low-dose fluoxetine therapy for depression Psychopharmacol Bull 1988 24(1) 183 8Wernicke 1988 3290940
470 Wheatley D. L1 160, an extract of St. John's wort, versus amitriptyline in mildly to moderately depressed outpatients -- a controlled 6-week clinical trial. Pharmacopsychiatry. 1997;30(Suppl 2):77-80. [pmid: 9342764].
471 Wheatley D. Minaprine: An anticholinergic-free antidepressant? Results of a controlled trial of mianserin. Br J Psychiatry. 1989;155:106-7. [pmid: 2690999].
472 Wheatley D. Minaprine in depression. A controlled trial with amitriptyline. Br J Psychiatry. 1992;161:113-5. [pmid: 1638306].
473 Wilcox CS, Cohn JB, Ferguson JM, Dale JL, Fabre LF A double-blind multicenter trial of a low-dose range and high-dose range of gepirone-extended release compared to placebo in the treatment of depressed outpatients Psychopharmacol Bull 1995 31(3)Wilcox 1995
474 Williams R, Edwards RA, Newburn GM, Mullen R, Menkes DB, Segkar C. A double-blind comparison of moclobemide and fluoxetine in the treatment of depressive disorders. Int Clin Psychopharmacol. 1993;7(3-4):155-8. [pmid: 8468437].
475 Witte B, Harrer G, Kaptan T, Podzuweit H, Schmidt U. [Treatment of depressive symptoms with a high concentration hypericum preparation. A multicenter, placebo-controlled double-blind study]. [German]. Fortschr Med. 1995;113(28):404-8. [pmid: 7498868].
476 Young JP, Coleman A, Lader MH. A controlled comparison of fluoxetine and amitriptyline in depressed out-patients. Br J Psychiatry. 1987;151:337-40. [pmid: 3322468].
477 Zapletalek M, Faltus F, Svestka J, Molean J, Binz U, Wendt G Der selektive und reversible MAO-Hemmer brofaromin im vergleich zu tranylcypromin Munch Med Wschr 1990 132 18 20Zapletalek 1990
478 Zivkov M, de Jongh GD. Org 3770 versus amitriptyline: A 6-week, randomised, double-blind multicentre trial in hospitalised depressed patients. Hum Psychopharmacol. 1995;10:173-80.
479 Zung WW. Review of placebo-controlled trials with bupropion. J Clin Psychiatry. 1983;44(5 Pt 2):104-14. [pmid: 6406436].
480 Dickersin K, Min Y. NIH clinical trials and publication bias. Online J Curr Clin Trials [serial online] Doc No. 53; 1993.
481 Schulz KF, Chalmers I, Hayes RJ, Altman DJ. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-12. [pmid: 7823387].
482 Schulz KF, Chalmers I, Hayes RJ, Altman DJ. Failure to conceal treatment allocation schedules in trials influenced estimates of treatment effects. Controlled Clin Trials 1994; 15:63s.
483 Gotzsche PC. Methodology and overt and hidden bias in reports of 196 double-blind trials of nonsteroidal antiinflammatory drugs in rheumatoid arthritis. Controlled Clin Trials. 1989;10(1):31-56. [pmid: 2702836].
484 Hollon SD, Shelton RC, Loosen PT. Cognitive therapy and pharmacotherapy for depression. J Consult Clin Psychol. 1991;59(1):88-99. [pmid: 2002147].
485 Pablos-Méndez A, Barr RG, Shea S. Run-in periods in randomized trials: Implications for the application of results in clinical practice. JAMA. 1998;279(3):222-5. [pmid: 9438743].
486 Trivedi MH, Rush J. Does a placebo run-in or a placebo treatment cell affect the efficacy of antidepressant medications?. Neuropsychopharmacology. 1994;11(1):33-43. [pmid: 7945742].
487 Schulberg HC, Coulehan JL, Block MR, Lave J, Rodriguez E, Scott CP, Madonia MJ, Imber S, Perel J. Clinical trials of primary care treatments for major depression: Issues in design, recruitment and treatment. Int J Psychiatry Med. 1993;23(1):29-42. [pmid: 8514463].
488 Thase ME, Trivedi MH, Rush AJ. MAOIs in the contemporary treatment of depression. Neurosychopharmacology. 1995;12(3):185-219.
489 Hedges LV, Olkin I. Statistical methods for meta-analysis. Orlando (FL): Academic Press; 1985.
490 Rosenthal. R. Meta-analytic procedures for social research. Rev. ed. Thousand Oaks (CA): Sage Publications; 1991.
491 Follmann D, Elliott P, Suh I, Cutler J. Variance imputation for overviews of clinical trials with continuous response. J Clin Epidemiol. 1992;45:769-73. [pmid: 1619456].
492 Berkey CS, Hoaglin DC, Mosteller F, Colditz GA. A random-effects regression model for meta-analysis. Stat Med. 1995;14:395-411. [pmid: 7746979].
493 Sharp S. sbe23: Meta-regression. Stata Tech Bull. 1998;42:16-22.
494 Berger JO. Statistical decision theory and Bayesian analysis. 2nd ed. New York: Springer-Verlag; 1985.
495 Carlin JB. Meta-analysis for 2x2 tables: A Bayesian approach. Stat Med. 1992;11:141-58. [pmid: 1349763].
496 Sharp S, Sterne J. sbe16: Meta-analysis. Stata Tech Bull. 1997;38:9-14.
497 Galbraith R. A note on graphical presentation of estimated odds ratios from several clinical trials. Stat Med. 1988;7(8):889-94. [pmid: 3413368].
498 Egger M, Davey Smith G, Schneider M, Minder CE. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315:629-34. [pmid: 9310563].
499 Tobias A. Assessing heterogeneity in meta-analysis: The Galbraith plot. Stata Tech Bull. 1997;41:15-7.
500 Steichen TJ. Tests for publication bias in meta-analysis. Stata Tech Bull. 1997;41:9-15.
501 Morris CN. Parametric empirical Bayes inference; theory and applications. J Am Stat Assoc. 1983;78:515-29.
502 Zeger SL. Models for longitudinal data: A generalized estimating equation approach. Biometrics. 1988;44:1049-60. [pmid: 3233245].
503 Benkert O, Szegedi A, Wetzel H, Staab HJ, Meister W, Philipp M. Dose escalation vs. continued doses of paroxetine and maprotiline: A prospective study in depressed out-patients with inadequate treatment response. Acta Psychiatr Scand. 1997;95(4):288-96. [pmid: 9150822].
504 Davis BA, Boulton AA, Yu PH, Durden DA, Bowen RC, Keegan DL, Blackshaw S, D'Arcy C, Remillard AJ, Dayal N, et al. Deuterium-labelled p-tyramine challenge test and phenolsulfotransferase activity in depressed patients -- failure to replicate decreased p-tyramine conjugation in depression. Prog Neuropsychopharmacol Biol Psychiatry. 1991;15(2):241-7. [pmid: 1871324].
505 Dunbar GC, Cohn JB, Fabre LF, Feighner JP, Fieve RR, Mendels J, Shrivastava RK. A comparison of paroxetine, imipramine and placebo in depressed out-patients. Br J Psychiatry. 1991;159:394-8. [pmid: 1835664].
506 Dobson KS. A meta-analysis of the efficacy of cognitive therapy for depression. J Consult Clin Psychol. 1989;57:414-19. [pmid: 2738214].
507 Robinson LA, Berman JS, Neimeyer RA. Psychotherapy for the treatment of depression: A comprehensive review of controlled outcome research. Psychcol Bull. 1990;108:30-49.
508 Reinecke MA, Ryan NE, DuBois DL. Cognitive-behavioral therapy of depression and depressive symptoms during adolescence: A review and meta-analysis. J Am Acad Child Adolesc Psychiatry. 1998;37(1):26-34. [pmid: 9444896].
509 Schone W, Ludwig M. [Paroxetine in the treatment of depression in geriatric patients -- a double-blind comparative study with fluoxetine]. [German]. Fortschr Neurol Psychiatr. 1994;62(Suppl 1):16-8. [pmid: 7959520].
510 Mittmann N, Herrmann N, Einarson TR, Busto UE, Lanctôt KL, Liu BA, Shulman KI, Silver IL, Naranjo CA, Shear NH. The efficacy, safety and tolerability of antidepressants in late life depression: A meta-analysis. J Affect Disord. 1997;46(3):191-217. [pmid: 9547117].
511 Austin MP, Souza FG, Goodwin GM. Lithium augmentation in antidepressant-resistant patients. A quantitative analysis. Br J Psychiatry. 1991;159:510-4. [pmid: 1836411].
512 Rudolph RL, Derivan AT. The safety and tolerability of venlafaxine hydrochloride: analysis of the clinical trials database [review]. J Clin Psychopharmacol. 1996;16(3 Suppl 2):54S-59S. [pmid: 8784648].
513 Figueira Bruno CA. [Serotonin syndrome: Literature review, diagnostic criteria and presentation of clinical cases]. [Portuguese]. Informacao Psiquiatrica. 1996;15(4):120-4.
514 Feighner JP, Boyer WF, Tyler DL, Neborsky RJ. Adverse consequences of fluoxetine-MAOI combination therapy. J Clin Psychiatry. 1990;51(6):222-5. [pmid: 2347858].
515 Scott HD, Rosenbaum SE, Waters WJ, Colt AM, Andrews LG, Juergen JP, Faich GA. Rhode Island physicians' recognition and reporting of adverse drug reactions. R I Med J. 1987;70(7):311-6. [pmid: 3476980].
516 Moride Y, Haramburu F, Requejo AA, Begaud B. Under-reporting of adverse drug reactions in general practice. Br J Clin Pharmacol. 1997;43(2):177-81. [pmid: 9131950].
517 Haramburu F, Begaud B, Pere JC. Comparison of 500 spontaneous and 500 published reports of adverse drug reactions. Eur J Clin Pharmacol. 1990;39(3):287-8. [pmid: 2257868].
518 Liu BA, Mittmann N, Knowles SR, Shear NH. Hyponatremia and the syndrome of inappropriate secretion of antidiuretic hormone associated with the use of selective serotonin reuptake inhibitors: A review of spontaneous reports. Can Assoc Med J. 1996;155(5):519-27.
519 Begaud B, Moride Y, Tubert-Bitter P, Chaslerie A, Haramburu F. False-positives in spontaneous reporting: Should we worry about them?. Br J Clin Pharmacol. 1994;38:401-4. [pmid: 7893579].
520 Woelk H, Burkard G, Grunwald J. Benefits and risks of the hypericum extract LI 160: Drug monitoring study with 3,250 patients. J Geriatr Psychiatry Neurol. 1994;7(Suppl 1):S34-S38. [pmid: 7857506].
521 Wagner W, Vause EW. Fluvoxamine: A review of global drug-drug interaction data [review]. Clin Pharmacokinet. 1995;29(Suppl 1):26-31. [pmid: 8846620].
522 Konig F, Hafele M, Hauger B, Loble M, Wossner S, Wolfersdorf M. [Bradycardia after beginning therapy with metoprolol and paroxetine]. [German]. Psychiatr Prax. 1996;23(5):244-5. [pmid: 8992519].
523 McAnally LE, Threlkeld KR, Dreyling CA. Case report of a syncopal episode associated with fluoxetine. Ann Pharmacother. 1992;26(9):1090-1. [pmid: 1421672].
524 Walley T, Pirmohamed M, Proudlove C, Maxwell D. Interaction of metoprolol and fluoxetine [letter]. Lancet. 1993;341(8850):967-8.
525 Ellison JM, Milofsky JE, Ely E. Fluoxetine-induced bradycardia and syncope in two patients. J Clin Psychiatry. 1990;51(9):385-6. [pmid: 2211552].
526 Feder R. Bradycardia and syncope induced by fluoxetine [letter]. J Clin Psychiatry. 1991;52(3).
527 Buff DD, Brenner R, Kirtane SS, Gilboa R. Dysrhythmia associated with fluoxetine treatment in an elderly patient with cardiac disease. J Clin Psychiatry. 1991;52(4):174-6. [pmid: 2016253].
528 Gardner SF, Rutherford WF, Munger MA, Panacek EA. Drug-induced supraventricular tachycardia: A case report of fluoxetine. Ann Emerg Med. 1991;20(2):194-7. [pmid: 1996805].
529 Appleby M, Mbewu A, Clarke B. Fluoxetine and ventricular torsade -- is there a link [letter]?. Int J Cardiol. 1995;49(2):178-80. [pmid: 7628890].
530 Roberge RJ, Martin TG. Mixed fluoxetine/loxapine overdose and atrial flutter. Ann Emerg Medicine. 1994;23(3):586-90.
531 Peano CL. Seizures, ventricular tachycardia, and rhabdomyolysis as a result of ingestion of venlafaxine and lamotrigine. Ann Emerg Med. 1997;30(5):704-8. [pmid: 9360588].
532 Cherin P, Colvez A, Deville de Periere G, Sereni D. Risk of syncope in the elderly and consumption of drugs: A case-control study. J Clin Epidemiol. 1997;50(3):313-20. [pmid: 9120531].
533 Tandan T, Giuffre M, Sheldon R. Exacerbations of neurally mediated syncope associated with sertraline [letter]. Lancet. 1997;349(9059):1145-6. [pmid: 9113018].
534 Spier SA, Frontera MA. Unexpected deaths in depressed medical inpatients treated with fluoxetine. J Clin Psychiatry. 1991;52(9):377-82. [pmid: 1894590].
535 Liu B, Anderson G, Mittmann N, To T, Axcell T, Shear N. Use of selective serotonin-reuptake inhibitors of tricyclic antidepressants and risk of hip fractures in elderly people. Lancet. 1998;351(9112):1303-7. [pmid: 9643791].
536 Boyer WF, Blumhardt CL. The safety profile of paroxetine [review]. J Clin Psychiatry. 1992;53(Suppl):61-6.
537 Beasley CM Jr, Masica DN, Heiligenstein JH, Wheadon DE, Zerbe RL. Possible monoamine oxidase inhibitor-serotonin uptake inhibitor interaction: Fluoxetine clinical data and preclinical findings. J Clin Psychopharmacol. 1993;13(5):312-20. [pmid: 8227489].
538 Ruiz F. Fluoxetine and the serotonin syndrome. Ann Emerg Med. 1994;24(5):983-5. [pmid: 7978579].
539 Kolecki P. Venlafaxine induced serotonin syndrome occurring after abstinence from phenelzine for more than two weeks [letter]. J Toxicol Clin Toxicol. 1997;35(2):211-2. [pmid: 9120894].
540 Brazelton T, Blanc PD, Olson KR. Toxic effects of nefazodone [letter]. Ann Emerg Med. 1997;30(4):550-1. [pmid: 9326873].
541 Bastani JB, Troester MM, Bastani AJ. Serotonin syndrome and fluvoxamine: A case study. Neb Med J. 1996;81(4):107-9.
542 Loza B. [A case of serotonin syndrome]. [Polish]. Psychiatr Pol. 1995;29(4):529-38. [pmid: 7568525].
543 Muly EC, McDonald W, Steffens D, Book S. Serotonin syndrome produced by a combination of fluoxetine and lithium [letter]. Am J Psychiatry. 1993;150(10).
544 Mekler G, Woggon B. A case of serotonin syndrome caused by venlafaxine and lithium. Pharmacopsychiatry. 1997;30(6):272-3. [pmid: 9442552].
545 Ohman R, Spigset O. Serotonin syndrome induced by fluvoxamine-lithium interaction [letter]. Pharmacopsychiatry. 1993;26(6):263-4. [pmid: 8127934].
546 Sobanski T, Bagli M, Laux G, Rao ML. Serotonin syndrome after lithium add-on medication to paroxetine. Pharmacopsychiatry. 1997;30(3):106-7. [pmid: 9211572].
547 Karle J, Bjorndal F. [Serotonergic syndrome -- in combination therapy with lithium and fluoxetine]. [Danish]. Ugeskr Laeger. 1995;157(9):1204-5. [pmid: 7701669].
548 Alderman CP, Lee PC. Comment: Serotonin syndrome associated with combined sertraline-amitriptyline treatment [letter]. Ann Pharmacother. 1996;30(12):1499-500.
549 Weiner AL, Tilden FF Jr, McKay CA Jr. Serotonin syndrome: Case report and review of the literature. Conn Med. 1997;61(11):717-21. [pmid: 9419960].
550 Reeves RR, Bullen JA. Serotonin syndrome produced by paroxetine and low-dose trazodone [letter]. Psychosomatics. 1995;36(2):159-60. [pmid: 7724720].
551 George TP, Godleski LS. Possible serotonin syndrome with trazodone addition to fluoxetine [letter]. Biol Psychiatry. 1996;39(5):384-5. [pmid: 8704074].
552 Baetz M, Malcolm D. Serotonin syndrome from fluvoxamine and buspirone [letter]. Can J Psychiatry. 1995;40(7):428-9. [pmid: 8548727].
553 Steiner W, Fontaine R. Toxic reaction following the combined administration of fluoxetine and L-tryptophan: Five case reports. Biol Psychiatry. 1986;21(11):1067-71. [pmid: 3488767].
554 Joffe RT, Sokolov ST. Co-administration of fluoxetine and sumatriptan: The Canadian experience. Acta Psychiatr Scand. 1997;95(6):551-2. [pmid: 9242852].
555 Egberts AC, ter Borgh J, Brodie-Meijer CC. Serotonin syndrome attributed to tramadol addition to paroxetine therapy. Int Clin Psychopharmacol. 1997;12(3):181-2. [pmid: 9248876].
556 Mason BJ, Blackburn KH. Possible serotonin syndrome associated with tramadol and sertraline coadministration. Ann Pharmacother. 1997;31(2):175-7. [pmid: 9034418].
557 Jahr JS, Pisto JD, Gitlin MC, O'Neill PT. The serotonin syndrome in a patient receiving sertraline after an ankle block. Anesth Analg. 1994;79(1):189-91. [pmid: 8010436].
558 Richard IH, Kurlan R. A survey of antidepressant drug use in Parkinson's disease. Parkinson Study Group. Neurology. 1997;49(4):1168-70.
559 Skop BP, Finkelstein JA, Mareth TR, Magoon MR, Brown TM. The serotonin syndrome associated with paroxetine, an over-the-counter cold remedy, and vascular disease. Am J Emerg Med. 1994;12(6):642-4. [pmid: 7945606].
560 Dent LA., Orrock MW. Warfarin-fluoxetine and diazepam-fluoxetine interaction. Pharmacotherapy. 1997;17(1):170-2. [pmid: 9017779].
561 Abad-Santos F, Carcas AJ, F-Capitan C, Frias J. Retroperitoneal haematoma in a patient treated with acenocoumarol, phenytoin and paroxetine. Clin Lab Haematol. 1995;17(2):195-7. [pmid: 8536426].
562 Claire RJ, Servis ME, Cram DL Jr. Potential interaction between warfarin sodium and fluoxetine [letter]. Am J Psychiatry. 1991;148(11).
563 Van Wijk B, Porsius AJ, Stricker BH. [Fluvoxamine or fluoxetine interaction with cumarine derivatives]. [Dutch]. Pharmaceutisch Weekblad. 1993;128(47):1417-9.
564 Woolfrey S, Gammack NS, Dewar MS, Brown PJ. Fluoxetine-warfarin interaction. BMJ. 1993;307(6898). [pmcid: 406324].
565 Christensen RC, Byerly MJ. Mandibular dystonia associated with the combination of sertraline and metoclopramide [letter]. J Clin Psychiatry. 1996;57(12).
566 Leo RJ. Movement disorders associated with the serotonin selective reuptake inhibitors [review]. J Clin Psychiatry. 1996;57(10):449-54. [pmid: 8909330].
567 Lewis CF, DeQuardo JR, Tandon R. Dystonia associated with trazodone and sertraline [letter]. J Clin Psychopharmacol. 1997;17(1):64-5. [pmid: 9004068].
568 Brown ES. Extrapyramidal side effects with low-dose risperidone [letter]. Can J Psychiatry. 1997;42(3):325-6. [pmid: 9114955].
569 Downs JM, Downs AD, Rosenthal TL, Deal N, Akiskal HS. Increased plasma tricyclic antidepressant concentrations in two patients concurrently treated with fluoxetine. J Clin Psychiatry. 1989;50(6):226-7. [pmid: 2785987].
570 Hambrecht M. [Toxic tricyclic drug plasma level caused by fluoxetine]. [German]. Psychiatr Prax. 1995;22(6):252-3. [pmid: 8570758].
571 Preskorn SH, Baker B. Fatality associated with combined fluoxetine-amitriptyline therapy [letter]. JAMA. 1997;277(21).
572 Ashton AK, Wolin RE. Nefazodone-induced carbamazepine toxicity. Am J Psychiatry. 1996;153(5).
573 Salama AA, Shafey M. A case of severe lithium toxicity induced by combined fluoxetine and lithium carbonate [letter]. Am J Psychiatry. 1989;146(2).
574 Alderman CP, Hundertmark JD, Soetratma TW. Interaction of serotonin re-uptake inhibitors with perhexiline. Aust N Z J Psychiatry. 1997;31(4):601-3. [pmid: 9272272].
575 Palumbo P, Campostrini R, Cantini A. [Intoxication with phenytoin induced by the selective serotonin-reuptake inhibitors in patients with epilepsy]. [Italian]. Bollettino -- Lega Italiana Contro L'Epilessia. 1996;(95-96):181-2.
576 Woods DJ, Coulter DM, Pillans P. Interaction of phenytoin and fluoxetine [letter]. N Z Med J. 1994;107(970).
577 Haselberger MB, Freedman LS, Tolbert S. Elevated serum phenytoin concentrations associated with coadministration of sertraline. J Clin Psychopharmacol. 1997;17(2):107-9. [pmid: 10950473].
578 Sperber AD. Toxic interaction between fluvoxamine and sustained release theophylline in an 11-year-old boy. Drug Saf. 1991;6(6):460-2. [pmid: 1793525].
579 van den Brekel AM, Harrington L. Toxic effects of theophylline caused by fluvoxamine. CMAJ. 1994;151(9):1289-90. [pmcid: 140416]. [pmid: 7954177].
580 Armstrong SC, Schweitzer SM. Delirium associated with paroxetine and benztropine combination [letter]. Am J Psychiatry. 1997;154(4):581-2. [pmid: 9090356].
581 Pollak PT, Sketris IS, MacKenzie SL, Hewlett TJ. Delirium probably induced by clarithromycin in a patient receiving fluoxetine. Ann Pharmacother. 1995;29(5):486-8. [pmid: 7655131].
582 Ames D, Wirshing WC, Szuba MP. Organic mental disorders associated with bupropion in three patients. J Clin Psychiatry. 1992;53(2):53-5. [pmid: 1541606].
583 Horton RC, Bonser RS. Interaction between cyclosporin and fluoxetine. BMJ. 1995;311(7002). [pmcid: 338093].
584 Black PN. Probable interaction between fluoxetine and itraconazole [letter]. Ann Pharmacother. 1995;29(10):1048-9. [pmid: 8845547].
585 McGlohn SE, Bostwick JM. Sertraline with methylphenidate in an ICU patient [letter]. Psychosomatics. 1995;36(6):584-5. [pmid: 7501791].
586 Jacobson RH, Wang P, Glueck CJ. Myositis and rhabdomyolysis associated with concurrent use of simvastatin and nefazodone [letter]. JAMA. 1997;277(4):296-7. [pmid: 9002485].
587 Katz SE. Possible paroxetine-zolpidem interaction [letter]. Am J Psychiatry. 1995;152(11).
588 Cassady SL, Thaker GK. Addition of fluoxetine to clozapine [letter]. Am J Psychiatry. 1992;149(9).
589 Pach J. [Pharmacotoxic psychosis and extrapyramidal motor syndrome. A case with acute adverse effect of fluoxetine and flupenthixol]. [German]. Nervenarzt. 1992;63(9):575-6. [pmid: 1407229].
590 Grinshpoon A, Berg Y, Mozes T, Mester R, Weizman A. Seizures induced by combined levomepromazine-fluvoxamine treatment. Int Clin Psychopharmacol. 1993;8(1):61-2. [pmid: 8473723].
591 Stein MH. Tardive dyskinesia in a patient taking haloperidol and fluoxetine [letter]. Am J Psychiatry. 1991;148(5).
592 Malek-Ahmadi P, Allen SA. Paroxetine-molindone interaction [letter]. J Clin Psychiatry. 1995;56(2):82-3. [pmid: 7852260].
593 Azaz-Livshits TL, Danenberg HD. Tachycardia, orthostatic hypotension and profound weakness due to concomitant use of fluoxetine and nifedipine. Pharmacopsychiatry. 1997;30(6):274-5. [pmid: 9442553].
594 Ahmed I, Dagincourt PG, Miller LG, Shader RI. Possible interaction between fluoxetine and pimozide causing sinus bradycardia. Can J Psychiatry. 1993;38(1):62-3. [pmid: 8448725].
595 Friedman EH. Re: Bradycardia and somnolence after adding fluoxetine to pimozide regimen [letter]. Can J Psychiatry. 1994;39(10).
596 Horrigan JP, Barnhill LJ. Paroxetine-pimozide drug interaction [letter]. J Am Acad Child Adolesc Psychiatry. 1994;33(7):1060-1. [pmid: 7961347].
597 Hansen Grant S, Silk KR, Guthrie S. Fluoxetine-pimozide interaction [letter]. Am J Psychiatry. 1993;150(11):1751-2.
598 Christensen RC. Adverse interaction of paroxetine and cyproheptadine [letter]. J Clin Psychiatry. 1995;56(9):433-4. [pmid: 7665546].
599 Marchiando RJ, Cook MD, Jue SG. Probable terfenadine-fluoxetine-associated cardiac toxicity [letter]. Ann Pharmacother. 1995;29(9):937-8.
600 Hastier P, Paolini O, Demarquay JF, Caroli-Bosc FX, Chichmanian RM, Saint-Paul MC, Delmont J. [Fulminant hepatitis induced by paracetamol at a therapeutic dose favoured by the ingestion of enzyme inducers in a patient with liver cirrhosis [letter]]. [French]. Gastroenterol Clin Biol. 1995;19(4):446-7. [pmid: 7672533].
601 Popli AP, Tanquary J, Lamparella V, Masand PS. Bupropion and anticonvulsant drug interactions. Ann Clin Psychiatry. 1995;7(2):99-101. [pmid: 8556101].
602 Shad MU, Preskorn SH. A possible bupropion and imipramine interaction [letter]. J Clin Psychopharmacol. 1997;17(2):118-9. [pmid: 10950476].
603 Young SJ. Panic associated with combining fluoxetine and bupropion [letter]. J Clin Psychiatry. 1996;57(4):177-8. [pmid: 8601558].
604 Wernicke JF. The side effect profile and safety of fluoxetine [review]. J Clin Psychiatry. 1985;46(3 Pt 2):59-67. [pmid: 3156126].
605 Coulter DM, Pillans PI. Fluoxetine and extrapyramidal side effects. Am J Psychiatry. 1995;152(1):122-5. [pmid: 7802102].
606 Baldassano CF, Truman CJ, Nierenberg A, Ghaemi SN, Sachs GS. Akathisia: A review and case report following paroxetine treatment [review]. Compr Psychiatry. 1996;37(2):122-4. [pmid: 8654061].
607 Gormley N, Watters L, Lawlor BA. Extrapyramidal side-effects in elderly patients exposed to selective serotonin reuptake inhibitors. Hum Psychopharmacol. 1997;12(2):139-43.
608 Caley CF, Friedman JH. Does fluoxetine exacerbate Parkinson's disease?. . J Clin Psychiatry. 1992;53(8):278-82. [pmid: 1500404].
609 Strouse TB, Salehmoghaddam S, Spar JE. Acute delirium and parkinsonism in a bupropion-treated liver transplant recipient [letter]. J Clin Psychiatry. 1993;54(12):489-90. [pmid: 8276742].
610 Goldstein DJ, Wilson MG. Adverse event frequencies generate hypotheses of efficacy and safety. Clin Pharmacol Ther. 1993;54(3):245-51. [pmid: 8375120].
611 Wagner W, Houser V, Wong LF. The safety profile of fluvoxamine in elderly patients. Hum Psychopharmacol. 1996;11(4):267-72.
612 Pai VB, Kelly MW. Bruising associated with the use of fluoxetine. Ann Pharmacother. 1996;30(7-8):786-8. [pmid: 8826562].
613 Humphries JE, Wheby MS, VandenBerg SR. Fluoxetine and the bleeding time. Arch Pathol Lab Med. 1990;114(7):727-8. [pmid: 2363631].
614 Tielens JA. Vitamin C for paroxetine- and fluvoxamine-associated bleeding [letter]. Am J Psychiatry. 1997;154(6):883-4. [pmid: 9167526].
615 Wilmshurst PT, Kumar AV. Subhyaloid haemorrhage with fluoxetine [letter]. Eye. 1996;10(1).
616 Leung M, Shore R. Fluvoxamine-associated bleeding [letter]. Can J Psychiatry. 1996;41(9):604-5. [pmid: 8946088].
617 Dursun SM, Mathew VM, Reveley MA. Toxic serotonin syndrome after fluoxetine plus carbamazepine [letter]. Lancet. 1993;342(8868):442-3.
618 Fogelson DL. Nefazodone- and/or sodium tetradecyl sulfate-associated leukopenia, fever, and shaking chills in a patient with premenstrual dysphoric disorder [letter]. J Clin Psychopharmacol. 1997;17(3):222-3. [pmid: 9169968].
619 Trescoli-Serrano C, Smith NK. Sertraline-induced agranulocytosis [letter]. Post Med J. 1996;72(849).
620 Vilinsky FD, Lubin A. Severe neutropenia associated with fluoxetine hydrochloride [letter]. Ann Intern Med. 1997;127(7):573-4. [pmid: 9313029].
621 Pantel J, Schroder J, Eysenbach K, Mundt C. Two cases of deep vein thrombosis associated with a combined paroxetine and zotepine therapy. Pharmacopsychiatry. 1997;30(3):109-11. [pmid: 9211574].
622 Pillans PI, Coulter DM,. Fluoxetine and hyponatraemia -- a potential hazard in the elderly [review]. N Z Med J. 1994;107(973):85-6. [pmid: 8202292].
623 Siegler EL, Tamres D, Berlin JA, Allen-Taylor L, Strom BL. Risk factors for the development of hyponatremia in psychiatric inpatients. Arch Intern Med. 1995;155(9):953-7. [pmid: 7726704].
624 Naranjo CA, Busto U, Sellers EM, Sandor P, Ruiz I, Roberts EA, Janecek E, Domecq C, Greenblatt DJ. A method for estimating the probability of adverse drug reactions. Clin Pharmacol Ther. 1981;30(2):239-45. [pmid: 7249508].
625 Liskin B, Walsh BT, Roose SP, Jackson W. Imipramine-induced inappropriate ADH secretion. J Clin Psychopharmacol. 1984;4(3):146-7. [pmid: 6429213].
626 Tollefson GD, Birkett M, Koran L, Genduso L. Continuation treatment of OCD: Double-blind and open-label experience with fluoxetine. J Clin Psychiatry. 1994;55(Suppl):69-76. [pmid: 7961535].
627 Gales BJ, Gales MA. Erythema multiforme and angioedema with indapamide and sertraline [letter]. Am J Hosp Pharm. 1994;51(1):118-9. [pmid: 8135249].
628 Kim SW, Pentel PR. Flu-like symptoms associated with fluoxetine overdose: A case report. J Toxicol Clin Toxicol. 1989;27(6):389-93. [pmid: 2628588].
629 Bodokh I, Lacour JP, Rosenthal E, Chichmanian RM, Perrin C, Vitetta A, Ortonne JP. [Lyell syndrome or toxic epidermal necrolysis and Stevens-Johnson syndrome after treatment with fluoxetine [letter]]. [French]. Therapie. 1992;47(5).
630 Beer K, Albertini J, Medenica M, Busbey S. Fluoxetine-induced hypersensitivity [letter]. Arch Dermatol. 1994;130(6):803-4. [pmid: 8002659].
631 Miller LG, Bowman RC, Mann D, Tripathy A. A case of fluoxetine-induced serum sickness. Am J Psychiatry. 1989;146(12):1616-7. [pmid: 2589557].
632 Wolkenstein P, Revuz J, Diehl JL, Langeron O, Roupie E, Machet L. Toxic epidermal necrolysis after fluvoxamine [letter]. Lancet. 1993;342(8866):304-5.
633 Johnston JA, Lineberry CG, Ascher JA, Davidson J, Khayrallah MA, Feighner JP, Stark P. A 102-center prospective study of seizure in association with bupropion. J Clin Psychiatry. 1991;52(11):450-6. [pmid: 1744061].
634 Kulin NA, Pastuszak A, Sage SR, Schick-Boschetto B, Spivey G, Feldkamp M, Ormond K, Matsui D, Stein-Schechman AK, Cook L, Brochu J, Rieder M, et al. Pregnancy outcome following maternal use of the new selective serotonin reuptake inhibitors: A prospective controlled multicenter study. JAMA. 1998;279(8):609-10. [pmid: 9486756].
635 Chambers CD, Johnson KA, Dick LM, Felix RJ, Jones KL. Birth outcomes in pregnant women taking fluoxetine. N Engl J Med. 1996;335(14):1010-5. [pmid: 8793924].
636 Edwards JG, Inman WH, Wilton L, Pearce GL, Kubota K. Drug safety monitoring of 12,692 patients treated with fluoxetine. Hum Psychopharmacol. 1997;12(2):127-37.
637 Goldstein DJ. Effects of third trimester fluoxetine exposure on the newborn. J Clin Psychopharmacol. 1995;15(6):417-20. [pmid: 8748430].
638 Peet M. Induction of mania with selective serotonin re-uptake inhibitors and tricyclic antidepressants. Br J Psychiatry. 1994;164(4):549-50. [pmid: 8038948].
639 Tollefson GD, Rampey AH Jr, Beasley CM Jr, Enas GG, Potvin JH. Absence of a relationship between adverse events and suicidality during pharmacotherapy for depression. J Clin Psychopharmacol. 1994;14(3):163-9. [pmid: 8027412].
640 Heiligenstein JH, Beasley CM Jr, Potvin JH. Fluoxetine not associated with increased aggression in controlled clinical trials. Int Clin Psychopharmacol. 1993;8(4):277-80. [pmid: 8277148].
641 Jick H, Ulcickas M, Dean A. Comparison of frequencies of suicidal tendencies among patients receiving fluoxetine, lofepramine, mianserin, or trazodone. Pharmacotherapy. 1992;12(6):451-4. [pmid: 1492009].
642 Edwards JG, Inman WH, Wilton L, Pearce GL. Prescription-event monitoring of 10,401 patients treated with fluvoxamine. Br J Psychiatry. 1994;164(3):387-95. [pmid: 7993416].
643 Spina E, Cuzzola P, de Domenico P, Rao G, Ancione M, Xerra AM, Costa G, Gitto C, Francomano A, Messina G, et al. [Drug surveillance in psychiatry: Preliminary study of the recording of unwanted side effects of tricyclic antidepressants and selective serotonin reuptake inhibitors]. [Italian]. Riv Psichiatria. 1995;30(4):161-6.
644 Achamallah NS. Visual hallucinations after combining fluoxetine and dextromethorphan [letter]. Am J Psychiatry. 1992;149(10).
645 Barrett J, Meehan O, Fahy T. SSRI and sympathomimetic interaction [letter]. Br J Psychiatry. 1996;168(2).
646 Zubieta JK, Demitrack MA. Possible bupropion precipitation of mania and a mixed affective state [letter]. J Clin Psychopharmacol. 1991;11(5):327-8. [pmid: 1765576].
647 Wagner W, Zaborny BA, Gray TE. Fluvoxamine. A review of its safety profile in world-wide studies [review]. Int Clin Psychopharmacol. 1994;9(4):223-7.
648 Spiller HA, Ramoska EA, Krenzelok EP, Sheen SR, Borys DJ, Villalobos D, Muir S, Jones-Easom L. Bupropion overdose: A 3-year multi-center retrospective analysis. Am J Emerg Med. 1994;12(1):43-5. [pmid: 8285970].
649 Grady TA, Pigott TA, L'Heureux F, Murphy DL. Seizure associated with fluoxetine and adjuvant buspirone therapy [letter]. J Clin Psychopharmacol. 1992;12(1):70-1. [pmid: 1552045].
650 Loo H, Piau A, Galinowski A, Olie JP. [Epileptogenic action of fluvoxamine. Apropos of a case]. [French]. Encephale. 1987;13(4):231-2. [pmid: 3117516].
651 Prasher VP. Seizures associated with fluoxetine therapy [review]. Seizure. 1993;2(4):315-7. [pmid: 8162401].
652 Vollmer Haase J, Folkerts H. [Secondarily generalised seizures during therapy with paroxetine]. [German]. Aktuel Neurol. 1997;24(4):167-9.
653 Van Wyck Fleet J, Manberg PJ, Miller LL, Harto-Truax N, Sato T, Fleck RJ, Stern WC, Cato AE. Overview of clinically significant adverse reactions to bupropion. J Clin Psychiatry. 1983;44(5 Pt 2):191-6.
654 Cato AE, Cook L, Starbuck R, Heatherington D. Methodologic approach to adverse events applied to bupropion clinical trials. J Clin Psychiatry. 1983;44(5 Pt 2):187-90. [pmid: 6406455].
655 Davidson J. Seizures and bupropion: A review [review]. J Clin Psychiatry. 1989;50(7):256-61. [pmid: 2500425].
656 Sheehan DV, Welch JB, Fishman SM. A case of bupropion-induced seizure. J Nerv Ment Dis. 1986;174(8):496-8. [pmid: 3090199].
657 Fink M. Toxic serotonin syndrome or neuroleptic malignant syndrome?. Pharmacopsychiatry. 1996;29(4):159-61. [pmid: 8858716].
658 Sternbach H. The serotonin syndrome [review]. Am J Psychiatry. 1991;148(6):705-13. [pmid: 2035713].
659 Richard IH, Kurlan R, Tanner C, Factor S, Hubble J, Suchowersky O, Waters C. Serotonin syndrome and the combined use of deprenyl and an antidepressant in Parkinson's disease. Parkinson Study Group. Neurology. 1997;48(4):1070-7.
660 Ebert D. [Therapy with selective serotonin reuptake inhibitors (SSRI.) Indications, uses and risks [review]]. [German]. Fortschr Med. 1996;114(18-19):243-7. [pmid: 8766793].
661 Kolecki P. Isolated venlafaxine-induced serotonin syndrome. J Emerg Med. 1997;15(4):491-3. [pmid: 9279702].
662 Pao M, Tipnis T. Serotonin syndrome after sertraline overdose in a 5-year-old girl [letter]. Arch Pediatr Adolesc Med. 1997;151(10):1064-7.
663 Halman M, Goldbloom DS. Fluoxetine and neuroleptic malignant syndrome. Biol Psychiatry. 1990;28(6):518-21. [pmid: 2223920].
664 Heinemann F, Assion HJ, Hermes G, Ehrlich M. [Paroxetine-induced neuroleptic malignant syndrome]. [German]. Nervenarzt. 1997;68(8):664-6. [pmid: 9380213].
665 Heinemann F, Assion HJ, Laux G. [Neuroleptic malignant syndrome from treatment with antidepressives]. [German]. Fortschr Neurol Psychiatr. 1997;65(5):208-13. [pmid: 9235312].
666 von Halling Laier MG, Gram LF. [Serotonin syndrome and malignant neuroleptic syndrome. A review based on the material from the National Board of Adverse Drug Reactions]. [Danish]. Ugeskr Laeger. 1996;158(48):6933-7. [pmid: 8984761].
667 Young C. A case of neuroleptic malignant syndrome and serotonin disturbance [letter]. J Clin Psychopharmacol. 1997;17(1):65-6. [pmid: 9004069].
668 Struebing VL. Differential diagnosis of malignant hyperthermia: A case report. AANA J. 1995;63(5):455-60. [pmid: 7502646].
669 Epstein Y, Albukrek D, Kalmovitc B, Moran DS, Shapiro Y. Heat intolerance induced by antidepressants. Ann N Y Acad Sci. 1997;813:553-8. [pmid: 9100934].
670 Warshaw MG, Keller MB. The relationship between fluoxetine use and suicidal behavior in 654 subjects with anxiety disorders. J Clin Psychiatry. 1996;57(4):158-66. [pmid: 8601551].
671 Jick SS, Dean AD, Jick H. Antidepressants and suicide. BMJ. 1995;310(6974):215-8. [pmcid: 381222]. [pmid: 7677826].
672 Beasley CM Jr, Dornseif BE, Bosomworth JC, Sayler ME, Rampey AH Jr, Heiligenstein JH, Thompson VL, Murphy DJ, Masica DN. Fluoxetine and suicide: A meta-analysis of controlled trials of treatment for depression. BMJ. 1991;303(6804):685-92. [pmcid: 37315]. [pmid: 1833012].
673 Beasley CM Jr, Dornseif BE, Bosomworth JC, Sayler ME, et al. Fluoxetine and suicide: A meta-analysis of controlled trials of treatment for depression. Int Clin Psychopharmacol. 1992;6(Suppl 6):35-57.
674 Wagner W, Plekkenpol B, Gray TE, Vlaskamp H, Essers H. Review of fluvoxamine safety database [review]. Drugs. 1992;43(Suppl 2):48-53. [pmid: 1378374].
675 Lopez Ibor JJ Jr. Reduced suicidality with paroxetine. Eur Psychiatry. 1993;8(Suppl 1):17s-19s.
676 Rothschild AJ, Locke CA. Reexposure to fluoxetine after serious suicide attempts by three patients: The role of akathisia. J Clin Psychiatry. 1991;52(12):491-3. [pmid: 1752848].
677 Tueth MJ. Akathisia causing suicide attempts in patients taking fluoxetine (Prozac) [news]. J Emerg Med. 1993;11(3):336-7. [pmid: 8340595].
678 Lancon C, Bernard D, Bougerol T. [Fluoxetine, akathisia and suicide [review]]. [French]. Encephale. 1997;23(3):218-23. [pmid: 9333553].
679 Hamilton MS, Opler LA. Akathisia, suicidality, and fluoxetine [review]. J Clin Psychiatry. 1992;53(11):401-6. [pmid: 1364815].
680 Henry JA, Alexander CA, Sener EK. Relative mortality from overdose of antidepressants. BMJ. 1995;310(6974):221-4. [pmcid: 381222]. [pmid: 7866123].
681 Druid H, Holmgren P. [A case report. Fatal case of acute fluoxetine poisoning]. [Swedish]. Lakartidningen. 1996;93(46):4149-50. [pmid: 8984269].
682 Harris CR, Gualtieri J, Stark G. Fatal bupropion overdose. J Toxicol Clin Toxicol. 1997;35(3):321-4. [pmid: 9140330].
683 Oslin DW, Duffy K. The rise of serum aminotransferases in a patient treated with bupropion [letter]. J Clin Psychopharmacol. 1993;13(5):364-5. [pmid: 8227497].
684 Hubbard R, Venn A, Smith C, Cooper M, Johnston I, Britton J. Exposure to commonly prescribed drugs and the etiology of cryptogenic fibrosing alveolitis: A case-control study. Am J Respir Crit Care Med. 1998;157(3 Pt 1):743-7. [pmid: 9517585].
685 Vandezande LM, Lamblin C, Wallaert B. [Interstitial lung disease linked to fluoxetine]. [French]. Rev Mal Respir. 1997;14(4):327-9. [pmid: 9411618].
686 Gonzalez-Rothi RJ, Zander DS, Ros PR. Fluoxetine hydrochloride (Prozac)-induced pulmonary disease. Chest. 1995;107(6):1763-5. [pmid: 7781383].
687 de Kerviler E, Tredaniel J, Revlon G, Groussard O, Zalcman G, Ortoli JM, Espie M, Hirsch A, Frija J. Fluoxetin-induced pulmonary granulomatosis. Eur Respir J. 1996;9(3):615-7. [pmid: 8730028].
688 Bass SP, Colebatch HJ. Fluoxetine-induced lung damage [letter]. Med J Aust. 1992;56(5):364-5.
689 Eke T, Bates AK. Acute angle closure glaucoma associated with paroxetine. BMJ. 1997;314(7091). [pmcid: 167160].
690 Kirwan JF, Subak-Sharpe I, Teimory M. Bilateral acute angle closure glaucoma after administration of paroxetine [letter]. Br J Ophthalmol. 1997;81(3).
691 Lewis CF, DeQuardo JR, DuBose C, Tandon R. Acute angle-closure glaucoma and paroxetine [letter]. J Clin Psychiatry. 1997;58(3):123-4.
692 Deeg MA, Lipkin EW. Hypoglycemia associated with the use of fluoxetine. West J Med. 1996;164(3).
693 Fernandez Lopez MI, Sanchez Esteban J, Jimenez Bello J, Meseguer Zaragoza A. [Suggestive episodes of hypoglycemia related to fluoxetine [letter]]. [Spanish]. Aten Primaria. 1996;18(10).
694 Warnock JK, Biggs F. Nefazodone-induced hypoglycemia in a diabetic patient with major depression [letter]. Am J Psychiatry. 1997;154(2):288-9. [pmid: 9016286].
695 Bertholon F, Krajewski E, El Allali A. [Explosive results: Paroxetine and priapism]. [French]. Ann Med Psychol. 1996;154(2):145-6.
696 Javed MA. Priapism associated with fluoxetine therapy: A case report. J Pak Med Assoc. 1996;46(2):45-6. [pmid: 8683851].
697 Mendelson WB, Franko T. Priapism with sertraline and lithium [letter]. J Clin Psychopharmacol. 1994;14(6):434-5. [pmid: 7884031].
698 Crowson AN, Magro CM. Antidepressant therapy: A possible cause of atypical cutaneous lymphoid hyperplasia. Arch Dermatol. 1995;131(8):925-9. [pmid: 7632065].
699 Rudnick A, Modai I, Zelikovski A. Fluoxetine-induced Raynaud's phenomenon. Biol Psychiatry. 1997;41(12):1218-21. [pmid: 9171912].
700 Kasantikul D. Reversible delirium after discontinuation of fluoxetine. J Med Assoc Thai. 1995;78(1):53-4. [pmid: 7622979].
701 Amsden GW, Georgian F. Orthostatic hypotension induced by sertraline withdrawal. Pharmacotherapy. 1996;16(4):684-6. [pmid: 8840377].
702 Propst A, Hayton BC, Wisebord S. Mania after withdrawal from sertraline. Can J Clin Pharmacol. 1997;4(3):115-7.
703 Bloch M, Stager SV, Braun AR, Rubinow DR. Severe psychiatric symptoms associated with paroxetine withdrawal [letter]. Lancet. 1995;346(8966).
704 Donovan S. The use of the General Practice Research Database (GPRD) to examine potential links between antidepressant medication and the incidence of suicide. Drug Inf J. 1996;30(3):785-92.
705 Wheadon DE., Rampey AH Jr, Thompson VL, Potvin JH, Masica DN, Beasley CM Jr. Lack of association between fluoxetine and suicidality in bulimia nervosa. J Clin Psychiatry. 1992;53(7):235-41. [pmid: 1639742].
706 Brunel P, Vial T, Roche I, Bertolotti E, Evreux JC. [Follow-up of 151 pregnant women exposed to antidepressant treatment (MAOI excluded) during organogenesis]. [French]. Therapie. 1994;49(2):117-22. [pmid: 7817334].
707 Nulman I, Rovet J, Stewart DE, Wolpin J, Gardner HA, Theis JG, Kulin N, Koren G. Neurodevelopment of children exposed in utero to antidepressant drugs. N Engl J Med. 1997;336(4):258-62. [pmid: 8995088].
708 Pastuszak A, Schick-Boschetto B, Zuber C, Feldkamp M, Pinelli M, Sihn S, Donnenfeld A, McCormack M, Leen-Mitchell M, Woodland C, et al. Pregnancy outcome following first-trimester exposure to fluoxetine (Prozac). JAMA. 1993;269(17):2246-8. [pmid: 8474204].
709 Goldstein DJ, Corbin LA, Sundell KL. Effects of first-trimester fluoxetine exposure on the newborn. Obstet Gynecol. 1997;89(5 Pt 1):713-8. [pmid: 9166307].
710 Rasmussen JG. The potential role of antidepressants in the precipitation of mania [abstract]. In: New Research Program and Abstract of the 144th annual meeting of the American Pyschiatric Association. Washington (DC): American Psychiatric Association; 1991.
711 Heiligenstein JH, Coccaro EF, Potvin JH, Beasley CM Jr, Dornseif BE, Masica DN. Fluoxetine not associated with increased violence or aggression in controlled clinical trials. Ann Clin Psychiatry. 1992;4(4):285-95.
712 Johnston JA, Lineberry CG, Frieden CS. Prevalence of psychosis, delusions, and hallucinations in clinical trials with bupropion [letter]. Am J Psychiatry. 1986;143(9):1192-3. [pmid: 3092682].
713 Waters CH. Fluoxetine and selegiline -- lack of significant interaction. Can J Neurol Sci. 1994;21(3):259-61. [pmid: 8000982].
714 Mendelson WB. The use of sedative/hypnotic medication and its correlation with falling down in the hospital. Sleep. 1996;19(9):698-701. [pmid: 9122555].
715 Thase ME. Efficacy and tolerability of once-daily venlafaxine extended release (XR) in outpatients with major depression. The Venlafaxine XR 209 Study Group. J Clin Psychiatry. 1997;58(9):393-8.
716 Cunningham LA. Once-daily venlafaxine extended release (XR) and venlafaxine immediate release (IR) in outpatients with major depression. Venlafaxine XR 208 Study Group. Ann Clin Psychiatry. 1997;9(3):157-64. [pmid: 9339881].
717 Lydiard RB, Stahl SM, Hertzman M, Harrison WM. A double-blind, placebo-controlled study comparing the effects of sertraline versus amitriptyline in the treatment of depression. J Clin Psychiatry. 1997;58(11):484-91. [pmid: 9413414].
718 Khan A, Upton GV, Rudolph RL, Entsuah R, Leventer SM. The use of venlafaxine in the treatment of major depression and major depression associated with anxiety: A dose-response study. Venlafaxine Investigator Study Group. J Clin Psychopharmacol. 1998;18(1):19-25. [pmid: 9472838].
719 Feighner J, Targum SD, Bennett ME, Roberts DL, Kensler TT, D'Amico MF, Hardy SA. A double-blind, placebo-controlled trial of nefazodone in the treatment of patients hospitalized for major depression. J Clin Psychiatry. 1998;59(5):246-53. [pmid: 9632036].
720 Leinonen E, Lepola U, Koponen H, Mehtonen OP, Rimon R. Long-term efficacy and safety of milnacipran compared to clomipramine in patients with major depression. Acta Psychiatr Scand. 1997;96(6):497-504. [pmid: 9421348].
721 Steen A, Den Boer JA. A double-blind six months comparative study of milnacipran and clomipramine in major depressive disorder. Int Clin Psychopharmacol. 1997;12(5):269-81. [pmid: 9466161].
722 Kavoussi RJ, Segraves RT, Hughes AR, Ascher JA, Johnston JA. Double-blind comparison of bupropion sustained release and sertraline in depressed outpatients. J Clin Psychiatry. 1997;58(12):532-7. [pmid: 9448656].
723 Wheatley DP, van Moffaert M, Timmerman L, Kremer CM. Mirtazapine: Efficacy and tolerability in comparison with fluoxetine in patients with moderate to severe major depressive disorder. Mirtazapine-Fluoxetine Study Group. J Clin Psychiatry. 1998;59(6):306-12. [pmid: 9671343].
724 Bouchard JM, Strub N, Nil R. Citalopram and viloxazine in the treatment of depression by means of slow drop infusion. A double-blind comparative trial. J Affect Disord. 1997;46(1):51-8. [pmid: 9387086].
725 Dam J, Ryde L, Svejso J, Lauge N, Lauritsen B, Bech P. Morning fluoxetine plus evening mianserin versus morning fluoxetine plus evening placebo in the acute treatment of major depression. Pharmacopsychiatry. 1998;31(2):48-54. [pmid: 9562208].
726 Emslie GJ, Rush AJ, Weinberg WA, Kowatch RA, Hughes CW, Carmody T, Rintelmann J. A double-blind, randomized, placebo-controlled trial of fluoxetine in children and adolescents with depression. Arch Gen Psychiatry. 1997;54:1031-7. [pmid: 9366660].
727 Tignol J, Pujol-Domenech J, Chartres JP, Leger JM, Pletan Y, Tonelli I, Tournoux A, Pezous N. Double-blind study of the efficacy and safety of milnacipran and imipramine in elderly patients with major depressive episode. Acta Psychiatr Scand. 1998;97(2):157-65. [pmid: 9517912].
728 Wagner GJ, Maguen S, Rabkin JG. Ethnic differences in response to fluoxetine in a controlled trial with depressed HIV-positive patients. Psychiatr Serv. 1998;49(2):239-40. [pmid: 9575014].
729 Elliott AJ, Uldall KK, Bergam K, Russo J, Claypoole K, Roy-Byrne PP. Randomized, placebo-controlled trial of paroxetine versus imipramine in depressed HIV-positive outpatients. Am J Psychiatry. 1998;155(3):367-72. [pmid: 9501747].
730 Zisook S, Peterkin J, Goggin KJ, Sledge P, Atkinson JH, Grant I. Treatment of major depression in HIV-seropositive men. HIV Neurobehavioral Research Center Group. J Clin Psychiatry. 1998;59(5):217-24. [pmid: 9632030].
731 Ekselius L, von Knorring L, Eberhard G. A double-blind multicenter trial comparing sertraline and citalopram in patients with major depression treated in general practice. Int Clin Psychopharmacol. 1997;12(6):323-31. [pmid: 9547134].