# Future Research

Future research priorities were identified using two approaches. First, available evidence for the 24 specific questions addressed by the report was reviewed. When available evidence was seriously flawed or insufficient to adequately answer the question, it was identified as an important gap in evidence and a research priority. These gaps are discussed below. Second, the technical panel identified additional promising areas of research, not directly addressed by the evidence report. These areas were prioritized using a modified Delphi process and are listed at the end of this section.

## Need for Improved and More Standard Trial Reporting

This evidence report highlights the need to improve the quality and homogeneity of trial reporting. Better reporting may aid interpretation and application of research findings and facilitate future literature syntheses. Two types of information were often in short supply: design characteristics that help the clinician assess the validity of trial results, and details about the intervention that may help providers replicate results in their own practice or health care system. Other important information that was usually provided, but reported in multiple ways, included primary outcomes and adverse events.

## Design Characteristics Known to Affect Validity

Trials consistently reported blinding, and most trials were double blind. However, actual methods of randomization and concealment of assignment usually were not reported. Since lack of adequate allocation concealment can be associated with bias, explicit descriptions of the randomization and concealment process should be part of standard reporting.

## Intervention Details about Patients and Providers and Their Therapeutic Relationship

Many studies did not report the ethnic background, educational level, socioeconomic status, or recruitment setting for the study population. These data, plus participant's age and gender, could help readers apply evidence by understanding the patient population to whom the data apply best. To replicate the treatment results, it is critical to understand the details of implementing the intervention. Almost all studies reported dosing targets for antidepressant medications, but few described the treating clinician, the duration and content of visits, or the types of therapeutic relationships that existed between participants and deliverers of the intervention. Planned and unplanned cointerventions, such as additional psychotropic medications or psychosocial interventions, were rarely described in sufficient detail to determine their potential effects.

## Heterogeneity in Assessing and Reporting Primary Outcomes and Adverse Effects

Almost all trials reported changes in depressive symptoms with antidepressant therapy as well as adverse effects associated with therapy. However, methods for assessing and reporting these outcomes varied substantially, making synthesis and interpretation across trials difficult. Based on data from these trials, it would be difficult for clinicians to make informed antidepressant choices regarding many potential adverse effects. Future researchers evaluating antidepressant therapies should aim for more standard and complete assessment of both depressive symptom outcomes and adverse effects.

## Gaps in Research Findings on Major Depression

The short-term efficacy of newer antidepressants is well established for major depression. However, available evidence could not answer many important clinical questions. Most studies were short term, focused exclusively on relief of depressive symptoms, and were conducted under rigorously controlled conditions necessary to evaluate efficacy. There is an important lack of longer term trials that could provide data on persistency of both beneficial and adverse effects. There is a major lack of information concerning functional status and health-related quality-of-life outcomes. There is a need for "effectiveness" studies to evaluate the relative benefits of treatments under usual clinical conditions. When coupled with cost data, such trials would provide critical information for health policymakers. Finally, continuation phase treatment clearly lowers relapse rates in patients with recurrent major depression. Data are needed regarding the efficacy of long-term treatment for less recurrent or severe depression.

## Gaps in Findings Regarding Psychosocial Treatment Alternatives and Herbal Remedies

The relative role and efficacy of newer antidepressants compared with psychosocial treatments is not clear. Many patients prefer psychosocial treatments such as psychotherapy; better data are needed for informed decisionmaking. Although hypericum (St. John's wort) appears efficacious, there were relatively few trials and evidence of positive publication bias among those reported. Large, well-conducted studies are needed to evaluate its efficacy compared with that of placebo and relative efficacy compared with that of other antidepressants. At least one such study is currently under way in the United States. No studies for the herbal remedies valeriana and kava kava were identified. If ineffective, these nonprescription products have the potential for harm by delaying effective treatment.

## Little Information about Depression That Resists Pharmacotherapy

Despite the clear efficacy of newer antidepressants, substantial numbers of patients do not respond adequately to initial treatment. Few studies evaluated treatment strategies to improve initial response rates or treatments for patients who fail an initial course of treatment. Combination therapy with psychosocial treatments, other psychotropic medications, or augmenting agents (e.g., lithium, thyroid preparations) has been inadequately evaluated.

## Gaps in Reporting on Other Common Forms of Depression

This literature synthesis showed a large body of data supporting the efficacy of newer antidepressants for major depression. In contrast, only 15 studies evaluated the efficacy of antidepressants for patients with dysthymia, subsyndromal depression, or mixed-anxiety depression. These forms of depression are collectively at least as prevalent as major depression and cause substantial morbidity. Given the high prevalence, negative effects on function, but milder symptomatology, large high-quality treatment trials are needed.

## Few Trials Report on Special Patient Populations

Few trials were found in special populations of high clinical relevance. The paucity of trials in children and adolescents is a particularly important gap in evidence. Suicide is one of the most common causes of death in late adolescence and is frequently related to depression. There is an urgent need for treatment trials in these groups. Because adverse-effects and drug-drug interactions may impair already compromised function, treatment in individuals with coexisting medical illness may be more difficult. Coexisting psychiatric illness may make treatment more refractory to treatment. Emerging data about strong treatment preferences in different ethnic groups could potentially affect treatment response. Pregnant and postpartum women have typically been excluded from treatment trials. The efficacy and safety of newer pharmacotherapies in these populations are not established.

## Other Priorities for Future Research

The technical panel noted the following as additional promising areas of research that were not addressed by the evidence report. Studies addressing issues potentially related to compliance, such as management of adverse events and achievement of therapeutic alliance and family support, were considered important. Both prevention and treatment of depression in patients with postmyocardial infarction were identified as warranting more evaluation. Studies that evaluate effectiveness of therapies in the prevention of the first episode of depression were considered important. Finally, evaluations of the relative desirability and acceptability of different alternative treatments for patients were recommended.