# Conclusions

## Major Depression

More than 80 studies prove newer antidepressant drugs are more efficacious than placebo for treating adults with major depression. Response rates were 50 percent for active treatment compared with 32 percent for placebo. Newer antidepressants are as efficacious as first and second generation tricyclic antidepressants. The number of studies comparing different classes of newer antidepressants is relatively small, but they show no difference in overall efficacy. For patients who have recovered from major depression, continued treatment with a newer antidepressant for at least 6 months decreases the risk of relapse by 70 percent. The large protective effect is best established for patients recruited from mental health settings or who have recurrent depression.

Data are insufficient to determine whether the combination of newer antidepressants with psychosocial therapies is more effective than antidepressants alone. Data also are insufficient to determine whether augmenting agents, such as pindolol and lithium, in combination with a newer antidepressant quicken or improve response rates in patients with resistant depression. Whether particular antidepressant agents are more effective than others is not clear for patients with resistant or refractory depression.

## Other Depressive Disorders

Two selective serotonin reuptake inhibitors (fluoxetine, sertraline) and amisulpride are proved efficacious for treating adults with dysthymia. Response rates for active treatment were 59 percent compared with 37 percent for placebo. There is no evidence suggesting that particular agents are more effective than others, including first generation tricyclic antidepressants. There is insufficient evidence to establish whether newer antidepressants are effective for subsyndromal (minor) depression or mixed anxiety depression.

## Herbal Remedies

Hypericum (St. John's wort) appears to be more effective than placebo for the short-term treatment of mild to moderately severe depressive disorders. Adverse effects occur significantly less frequently with hypericum compared with first generation tricyclic antidepressants. These findings are tempered by the relatively small number of trials and evidence of publication bias favoring positive trials. It is not clear whether hypericum is more or less effective than standard antidepressive agents.

## Newer Antidepressants Compared with Psychosocial Therapies

Data are too limited to determine whether newer antidepressants are more or less effective than psychosocial therapies. There are no trials comparing newer agents with educational or supportive counseling, and only one small trial compares psychotherapy directly with a newer agent in adults.

## Newer Antidepressants in Children, Older Adults, and Other Special Populations

Data are insufficient to guide management of depression in children and adolescents. Multiple antidepressants are proved better than placebo in treating major depression in older adults. Antidepressants appear equally effective. Few studies evaluate newer antidepressants in patients with depression and concomitant psychiatric and medical illness such as alcoholism, cancer, chronic fatigue syndrome, dementia, diabetes, HIV disease, ischemic heart disease, renal failure, or stroke. Results conflict and are insufficient to reliably determine the efficacy of newer agents compared with placebo or older agents.

## Treatment in Primary Care and Postpartum Settings

Newer antidepressants are better than placebo in treating depressive disorders in adults in primary care settings. Response rates were 60 percent for active treatment compared with 35 percent for placebo. There is no evidence that particular agents are more effective than others. As only one study with a high dropout rate evaluated newer pharmacotherapy in women with depression after childbirth, data are insufficient to determine the efficacy of newer antidepressants in the postpartum setting.

## Treatment Adherence and Adverse Effects

In general, participants discontinued treatment at similar rates for newer and older antidepressants due to lack of effect, adverse effects, or other reasons. However, fewer patients taking selective serotonin reuptake inhibitors or reversible inhibitors of monoamine oxidase A discontinued treatment because of adverse effects compared with first generation tricyclic antidepressants (rate differences 4 percent and 5 percent, respectively).

Compared with first generation tricyclic antidepressants, selective serotonin reuptake inhibitors resulted in significantly higher rates of diarrhea (rate difference 10 percent), nausea (RD 10 percent), insomnia (RD 7 percent), and headache (RD 3 percent). Tricyclic antidepressants resulted in significantly higher rates of dry mouth (RD 30 percent), constipation (RD 12 percent), dizziness (RD 11 percent), blurred vision (RD 4 percent), and tremors (RD 4 percent). Some adverse effects, such as sexual dysfunction, were reported too infrequently for reliable interpretation. Nine uncommon (<1 percent) but serious adverse effects were definitely associated with the selective serotonin reuptake inhibitors: bradycardia, bleeding, granulocytopenia, seizures, hyponatremia, hepatotoxicity, serotonin syndrome, extrapyramidal effects, and mania in unipolar depression. Bupropion was associated with seizures. Hypericum (St. John's wort) was not associated with serious adverse effects.

## Summary Implications

This evidence report clearly shows that newer antidepressants are effective treatments for major depression and dysthymia. They are efficacious in treating depressive disorders in mental health as well as primary care settings. Newer antidepressants have similar efficacy and total dropout rates compared with those of older antidepressants. Because of similar efficacy, both newer and older antidepressants should be considered when treatment decisions are made. When selecting antidepressants, clinicians should consider costs, the small but statistically significant differences in dropouts due to adverse effects, lack of information concerning relative benefits to alternative therapies (e.g., psychosocial and herbal), and individual patient's preferences and tolerance for particular adverse effects. Health policy planners should consider these factors and advocate for cost-effectiveness studies to better guide the allocation of health care dollars.

For patients with certain forms of depression, such as subsyndromal and mixed anxiety depression, and for special populations, such as children and adolescents, the data on newer pharmacotherapies are insufficient to guide treatment decisions. Clinicians who choose to generalize efficacy data from adult patients with major depression to such patients should do so with care.