# Results

## Description of Trials Evaluating Newer Pharmacotherapies for Depression

Over 300 randomized controlled trials have evaluated the efficacy of newer pharmacotherapies and herbal remedies for depression. Most trials focused on participants with major depression (Table 13). Relatively few studied patients with dysthymia, and only three each addressed subsyndromal and mixed anxiety depression. The largest number of comparisons (n=206) have been between newer and older antidepressants; approximately 100 studies compared the efficacy of newer antidepressants with that of placebo.

Table 13. Overview of comparisons by diagnostic category^a^

| Major Depression | Dysthymia | Subsyndromal Depression | Mixed Anxiety Depression | Heterogeneous Groups
Newer vs. placebo | 95 | 5 | 1 | 0 | 13
Newer vs. older | 161 | 6 | 2 | 3 | 34
Newer vs. newer | 34 | 1 | 0 | 0 | 2
Total | 290 | 12 | 3 | 3 | 49

a Done by comparison not by number of trials (i.e., trials may have more than two arms).

The setting from which patients are recruited affects types of patients entering studies and may affect outcomes. For example, patients recruited from inpatient mental health settings may have more severe depression or coexisting psychiatric illness, and efficacy of antidepressant treatment may depend, in part, on such factors. A large number of studies included in this evidence report did not describe or described poorly recruitment settings (Table 14). Of the 315 trials, 202 did not specify whether recruitment occurred in the mental health or primary care setting. Of those giving descriptions, 77 were based in mental health specialty practices, 27 were exclusively in primary care settings, and 9 came from mixed settings. Most studies reported whether recruitment involved in- or outpatient settings and most (n=160) were based in outpatient practices.

Table 14. Overview of Study Settings

| Mental Health | Primary Care | Mixed (mental health and primary care settings) | Mental Health and Primary Care Settings Unclear | Total
Outpatient | 44 | 15 | 6 | 95 | 160
Inpatient | 10 | 1 | 0 | 23 | 34
Mixed | 15 | 0 | 3 | 27 | 45
| | | (outpatient and Inpatient)
Outpatient/ inpatient unclear | 8 | 11 | 0 | 57 | 76
Total | 77 | 27 | 9 | 202 | 315

An understanding of the types of patients included in trials is necessary to best apply trial results. The majority of trials in this evidence report were conducted in middle-age adults. Twenty-seven studies enrolled substantial numbers of older adults (Table 15). Only two enrolled children or adolescents, and one was done in the postpartum setting. Ten studies evaluated the efficacy of antidepressants in patients with depression and a concomitant illness such as alcoholism or dementia. (Of note, one additional trial in children and adolescents, one in elders, three in depressed HIV patients, and one in the primary care setting were identified in recent ongoing electronic searches up to August 1998.) Most studies gave no data on participants' ethnic backgrounds and socioeconomic status.

Table 15. Number of Studies in Special Populations or Settings

Children or adolescents | 2
Older adults | 27
Specific concomitant illnesses | 10
Primary care setting | 27
Postpartum setting | 1

Tables 16, 17, and 18 display the types of comparisons between antidepressant drug classes and numbers of participants involved in such comparisons. SSRIs are the most widely tested, with 60 comparisons with placebo, 123 with older antidepressants, and 36 with a second SSRI or other newer agent. In contrast, the second (RIMA) and third (SNRI) most extensively evaluated classes have, together, 23 comparisons with placebo, 47 comparisons with older agents, and 15 comparisons with other newer antidepressants.

Table 16. Types of comparisons with placebo

Placebo Comparisons | Number of studies | Number of Participants
SSRI | 60 | 11,189
SNRI | 11 | 1,568
NRI | 2 | 332
RIMA | 12 | 1,072
5-HT_2_ | 8 | 987
5-HT_1A_ | 4 | 458
Gaba | 1 | 49
DopAnt | 3 | 608
DopRI | 3 | 411
Misc | 2 | 170
Herbal | 8 | 611

Table 17. Types of newer versus older agent comparisons

| First Generation TCA | Second Generation TCA | Other^a^ | Total
SSRI | 90 | 11 | 22 | 123
SNRI | 12 | 0 | 3 | 15
NRI | 1 | 0 | 1 | 2
RIMA | 26 | 1 | 5 | 32
5-HT_2_ | 9 | 0 | 0 | 9
5-HT_1A_ | 1 | 0 | 0 | 1
Gaba | 0 | 0 | 0 | 0
DopAnt | 2 | 1 | 0 | 3
DopRI | 6 | 1 | 0 | 7
Misc | 6 | 1 | 1 | 8
Herbal | 5 | 1 | 0 | 6

a Other category includes tetracyclic, triazolopyridine, and MAOI agents.

Table 18. Types of newer versus newer agent comparisons

| SSRI | SNRI | NRI | RIMA | Other | Total
SSRI | 16 | 5 | 1 | 9 | 5 | 36
SNRI | 5 | 0 | 0 | 0 | 0 | 5
NRI | 1 | 0 | 0 | 1 | 0 | 2
RIMA | 9 | 0 | 1 | 0 | 0 | 10
Other^a^ | 5 | 0 | 0 | 0 | 0 | 5

a Other category includes 5-HT_2, _5-HT_1A, _Gaba, DopAnt, DopRI, Misc, and herbal remedies

## Quantitative Results of Effects of Design and Methodologic Characteristics on Response Rates

Two subgroup analyses related to design and methodologic characteristics were conducted using the major depression trials. Analyses were done separately for each drug class comparison (e.g., SSRI versus placebo, SSRI versus TCA1, etc.). The first set of subgroup analyses compared effect sizes of major depression trials (differences in response rates) with the following dropout rates: <20 percent versus >20 percent, <30 percent versus >30 percent, and <40 percent versus >40 percent. These analyses showed no statistically significant effects of dropout rates on response to treatment. The second set of subgroup analyses compared effect sizes between trials with placebo run-in designs categorized into three groups: studies without a run-in phase, studies using a run-in to exclude placebo responders, and studies using a run-in phase without stating if it was used to exclude placebo responders. There were no statistically significant differences in effect sizes based on the run-in design.

Meta-regression analyses were performed to evaluate the potential independent effects of multiple factors on response rates. These were done separately for trials restricted to patients with major depression and for trials regardless of depression diagnosis. They also were done separately for studies comparing a newer antidepressant with placebo and studies comparing a newer antidepressant with a tricyclic antidepressant. Factors included in the analyses were mean age of participants, percent of female participants, class of newer antidepressant medication, proportion of dropouts, severity of depression as measured by a standardized mean score on the Hamilton Depression Rating Scale, and recruitment setting as reflected by outpatient versus other and mental health versus other. Newer drug classes with very small numbers of studies were excluded from the analyses as were special studies addressing combination therapy or long-term maintenance therapy.

First, each of the factors was examined individually for an association with response rates. For drug class comparisons, SSRIs were used as the reference group. Therefore, the analysis tests whether other newer classes of antidepressants led to a significantly higher response rate. For setting, we compared studies known to have recruited subjects from mental health settings versus other (e.g., primary care or unknown) and those that recruited from outpatient settings versus other (e.g., inpatient or unknown). Therefore, this analysis evaluates whether response rates were higher for mental health settings, outpatient settings, or a combination of the two (interaction term).

Results of the bivariate analyses are summarized in Table 19. Trials comparing newer agents with placebo that were conducted in outpatient versus other settings were associated with greater response rates both for major depression trials and for trials regardless of diagnosis. Placebo-controlled trials of major depression that had high dropout rates were also associated with greater response rates.

Table 19. Separate random-effects meta-regression results for each factor (reg. coef. SE)

Trials of Major Depression | | | Trials for all Types of Depression
Factor | Placebo Comparison | Tricyclic Comparison | Placebo Comparison | Tricyclic Comparison
Mean age | -0.002 (0.006) | -0.000 (0.003) | -0.003 (0.005) | 0.000 (0.002)
Percent female | -0.104 (0.080) | 0.001 (0.072) | 0.132 (0.089) | 0.018 (0.055)
Newer agent class:
SNRI | 0.001 (0.119) | -0.022 (0.064) | 0.035 (0.105) | 0.030 (0.052)
RIMA | 0.034 (0.129) | -0.057 (0.059) | 0.145 (0.110) | -0.045 (0.040)
Dropouts | 0.175 (0.074)^a^ | 0.004 (0.038) | 0.034 (0.037) | -0.028 (0.027)
Severity | 0.003 (0.039) | 0.026 (0.020) | 0.009 (0.032) | 0.017 (0.009)
Setting:
Mental health Outpatient Interaction term | -0.193 (0.218) 0.190 (0.094)^a^ 0.093 (0.253) | -0.072 (0.069) -0.020 (0.059) 0.127 (0.105) | 0.201 (0.151) 0.280 (0.088)^b^ -0.260 (0.181) | -0.040 (0.063) 0.006 (0.045) 0.071 (0.081)

a p<0.05 ^b^p<0.001

Next, we used random-effects meta-regression to simultaneously evaluate the relative contribution of factors to variation in response rates. For major depression trials only, higher numbers of dropouts were associated with greater reported response rates, suggesting that in such studies, high dropout rates may result in systematic overestimates of drug efficacy. Compared with the subgroup analyses that showed no effect of dropouts, this analysis had greater power to detect a significant difference. This analysis also differs from the subgroup analysis by simultaneously controlling for multiple factors that may affect response rates. In both regression analyses of newer versus older antidepressants (e.g., major depression trials, trials for all types of depression), no factors were related to response rates. These results are consistent with the subgroup analyses and bivariate analyses.

## Presentation of Results for Each of the 24 Formulated Questions

Results for each of the formulated questions in this evidence report are presented in a standard format. The "bottom line" answer to each question is presented based on a qualitative judgment that considered the quantity, quality, and consistency of available evidence. In general, we stated evidence about efficacy as conclusive when there were large (i.e., more than 10) numbers of randomized double-blind trials with reasonable numbers of patients (i.e., more than 100) with consistent results.

Brief comments framing the context of each question are made. A description of the quantity and quality of the pertinent evidence that was found follow the context comments. (Detailed information on individual studies is contained in evidence tables in Appendix 3.) A synthesis of the findings is then presented, accompanied by a graphical display of response rate results from individual pertinent trials.

Graphs are presented as standard forest plots with point estimates and surrounding 95 percent confidence intervals. Point estimates on graphs are risk ratios that compare response rates. In general, point estimates falling on the right side of the center axis line represent trials where newer agents showed greater response rates than placebo or older agents. Conversely, point estimates falling on the left side of the center axis line show trials with greater response rates among older agents or placebo. Classes of agents that are compared and citation numbers identify individual trials. Abbreviations that are used for classes of agents are shown below.

- 5-HT2-- 5-HT_2_ receptor antagonist
- 5-HT1A-- 5-HT_1A_ receptor agonist
- DopAnt-- Dopamine antagonist
- DopRI-- Dopamine reuptake inhibitor
- Gaba-- Gabamimetic
- Herbal-- Herbal remedy
- Dibenz-- Dibenzoxazepine
- MAOI-- Monoamine oxidase inhibitor
- Misc-- Miscellaneous
- NRI-- Norepinephrine reuptake inhibitor
- RIMA-- Reversible inhibitor of monoamine oxidase A
- SSRI-- Selective serotonin reuptake inhibitor
- SNRI-- Serotonin norepinephrine reuptake inhibitor
- TCA-- Tricyclic (TCA1--first generation)
- Tetra-- Tetracyclic
- Triazo-- Triazolopyridine

In some instances, quantitative summaries of data are presented. These summaries were derived using the meta-analytic techniques described in the data analysis section. Detailed results of meta-analyses are presented in Appendix 4.

For each question, a brief section describing gaps in current evidence follows the synthesis of findings. Finally, additional relevant evidence derived from other recent systematic reviews and ongoing MEDLINE and PubMed electronic searches through August 1998 are noted.

## Question 1. Are newer antidepressant agents more effective than placebo or older antidepressant agents for treating adult patients with major depression?

Over 80 studies prove that multiple newer antidepressant drugs are more efficacious than placebo for treating adults with major depression. Newer antidepressants are equally efficacious compared with first and second generation tricyclic antidepressants. The number of studies comparing different classes of newer antidepressants is relatively small, but they show no difference in efficacy. Overall dropouts did not differ significantly between active treatments.

### Context

The efficacy of antidepressants for major depression has been firmly established. However, different costs make the relative efficacy of newer antidepressants highly relevant. In addition, the efficacy of some newer agents has not been systematically reviewed.

### The Evidence from Placebo-Controlled Trials (Tables 20, 21, 22, 23)

Eighty-one trials of at least 6 weeks' duration, involving over 10,000 adult patients with major depression, compared newer antidepressants with placebo. Trials were conducted in 15 countries; the majority in the United States (n=54). All studies were sponsored by pharmaceutical companies (n=55 of 55 with identified funding). Participants were recruited from a variety of settings including outpatient (n=48), mixed in- and outpatient (n=7), inpatient (n=3), and not described (n=23). Only four studies specified recruitment that included primary care settings.

Table 20. Participants in 81 placebo-controlled trials for major depression

Number | Female | Average Age
10,306 | 59% | 43

Table 21. Settings

Outpatient | Mixed In- and Outpatient | Primary Care | Unknown
48 | 7 | 4 | 23

Table 22. Diagnostic systems used in the trials

DSM-IIIR major depression | 27
DSM-III major depression | 45
RDC major depression | 4
Other major depression | 5

Table 23. Designs of the 81 trials

Double blind | 6-8 weeks | Dropouts <20%
81 | 77 | 7

On average, the severity of depression was moderate to moderately severe as measured by a standard symptom rating scale (mean=24, standardized to the 17-item Hamilton Depression Rating Scale). Fewer than 1 percent of patients had depression with psychotic features.

The quality of the studies of SSRIs, among newer antidepressants, are the best (n=43 comparisons). SNRIs (n=12), RIMAs (n=10), 5-HT_2_ (n=9), 5-HT_1A_ (n=3), and DopRI (n=3) antidepressants have been evaluated in more than one study. There are single studies of fengabine (GABA) and reboxetine (NRI). Of these, 47 studies reported usable response rates. No studies compared DopAnt with placebo. Almost all trials were short duration, focusing on acute phase treatment. Duration was 6 to 8 weeks in 79 studies and 9 to 12 weeks in 2. Dropout rates were less than 20 percent (n=7), 20 to 30 percent (n=14), >30 percent (n=42), and not given for 18. All trials appeared double blind.

### The Findings of Placebo-Controlled Trials (Figure 7)

Response rates were analyzed using a modified intention-to-treat (MIT) approach, which gives a conservative estimate of response. Risk ratios were computed using both the MIT approach and an endpoint analysis (based on the number of patients evaluated at a predefined endpoint). The latter results are reported only when they differ from the MIT approach by at least 10 percent. Fifty-one percent of the participants randomized to active treatment experienced at least a 50 percent improvement in depressive symptoms as assessed by a depressive symptom rating scale or were much to very much improved on the Clinical Global Rating Scale. In contrast, only 32 percent responded significantly to placebo. As a group, newer antidepressants were significantly more efficacious than placebo (risk ratio [RR] 1.6, 95 percent CI 1.5 to 1.7). Studies reporting mean changes in symptom scores rather than response rates showed similar results. There was evidence of positive publication bias for two of the newest classes of antidepressants (SNRI and 5-HT_2_)_._

Figure 7. Placebo vs. Newer Antidepressants

Two classes of newer antidepressants have not been adequately evaluated against placebo. In one small study, fengabine (GABA) showed no effect.^ 381 ^ In the single study comparing an NRI (reboxetine) with placebo, reboxetine improved self-reported psychosocial functioning more than placebo, but effects on depressive symptoms were not reported.^ 196 ^ The effective classes are described below.

### Findings of Placebo-Controlled Trials by Drug Class

#### Selective serotonin reuptake inhibitors

Forty-three trials compared SSRIs with placebo. Of these, 25 reported usable response rates for 4 SSRI antidepressants (sertraline [5], paroxetine [5], fluvoxamine [6], and fluoxetine [9]). As a group, SSRIs were significantly more effective than placebo (RR 1.6, 95 percent CI 1.4 to 1.7). The magnitude of benefit appeared similar for the four antidepressants. These findings were confirmed by the studies reporting mean changes in depressive symptoms.

#### Serotonin norepinephrine reuptake inhibitors versus placebo

Twelve studies compared SNRI with placebo. In seven trials reporting response rates, venlafaxine (n=3) and mirtazapine (n=4) were proved more efficacious than placebo (RR 1.6, 95 percent CI 1.3 to 2.0). Trials reporting mean changes in depressive symptoms had similar consistent findings.

#### Reversible inhibitors of monoamine oxidase A versus placebo

Ten studies compared a RIMA with placebo; 6 reported response rates. Response rates were significantly better for moclobemide (n=5) and brofaromine (n=1) than those for placebo (RR 1.6, 95 percent CI 1.2 to 2.1). Continuous data, involving 4 of the 10 studies, showed a positive but statistically nonsignificant effect. Response rates varied significantly across studies. One study comparing 400 mg of moclobemide with placebo found lower than average benefit in patients with major depression and coexisting dementia.^ 414 ^ A second study, with an unusually high placebo response rate, showed no benefit for moclobemide or imipramine (TCA1).^ 452 ^

#### 5-HT_2_ receptor antagonists versus placebo

Nine studies compared nefazodone with placebo. In the four studies reporting response rates, nefazodone showed a response superior to that of placebo (modified intention-to-treat analysis -- RR 1.7, 95 percent CI 1.3 to 2.0; endpoint analysis -- RR 2.0, 95 percent CI 1.4 to 2.8). Studies reporting mean changes in depressive symptoms confirm these findings.

#### 5-HT_1A_ receptor agonists versus placebo

Three trials showed consistent results for gepirone, the only drug studied in this class. Gepirone was significantly better than placebo in relieving depressive symptoms.

#### Dopamine reuptake inhibitors versus placebo

Three studies examined the effects of bupropion; one reported response rates. Compared with placebo, bupropion led to significantly better responses. Two studies reporting mean changes in depressive symptoms showed no significant differences between bupropion and placebo.

### Evidence from Ongoing Searches

Five, short-term, placebo-controlled trials, involving 965 subjects were identified in searches from January 1998 through August 1998 (venlafaxine n=3; sertraline n=1; nefazodone n=1).^179,^ ^715, 716, 717, 718^ Results of these most recent trials are consistent with past trials; newer antidepressants show consistently positive effects compared with placebo.

### The Evidence from Newer Compared with Older Antidepressant Trials (Tables 24, 25, 26, 27)

In 150 studies, involving over 16,000 participants, there have been 154 comparisons between newer and older antidepressants. Studies were conducted predominantly in Europe (n=76) and the United States (n=49). Eighty-four studies with an identified funding source were sponsored by industry; 2 were sponsored by governmental agencies. When the study setting was described, the outpatient setting was most common (n=77), followed by mixed in- and outpatient settings (n=28) and inpatient settings (n=20). For 17 studies, recruitment included primary care settings.

Table 24. Participants in 150 trials comparing newer with older antidepressants for major depression

Number | Female | Average Age
16,290 | 66% | 48

Table 25. Settings

Outpatient | Mixed In- and Outpatient | Primary Care | Unknown
77 | 28 | 17 | 22

Table 26. Diagnostic systems used in the trials

DSM-IV major depression | 4
DSM-IIIR major depression | 48
DSM-III major depression | 78
RDC major depression | 10
Other major depression | 10

Table 27. Designs of the 150 trials

Double Blind | 6-8 Weeks | Dropouts <20%
143 | 146 | 33

Newer antidepressants were compared with first generation tricyclic antidepressants (n=122), second generation tricyclic drugs (n=8), trazodone (a triazolopyridine; n=8), tetracyclic antidepressants (n=14), or monoamine oxidase inhibitors (n=2). Among newer agents, SSRIs are the most extensively tested with 97 comparisons to older agents. Other classes compared with older agents are SNRIs (n=14), RIMAs (n=26), NRI (n=2), minaprine (Misc; n=3), 5-HT_2_ (n=6), 5-HT_1A_ (n=1), and DopRI (n=5). There were no comparisons to older agents identified for the two classes currently available only outside the United States -- GABA and DopAnt).

Trial duration was 6 to 8 weeks for 146 comparisons, 9 to 12 weeks for 5, and less than 12 weeks for 3. All but seven studies were double blind. Dropout rates were less than 20 percent (n=33), 20 to 30 percent (n=39), more than 30 percent (n=61), and not given for 21.

### The Findings from Newer Compared with Older Antidepressant Trials (Figures 8, 9, 10, 11)

Fifty-four percent of the participants randomized to a newer antidepressant experienced at least a 50 percent improvement in depressive symptoms as assessed by a rating scale (e.g., Hamilton Depression Rating Scale) or by "much to very much improvement" on the Clinical Global Rating Scale. An identical proportion (54 percent) responded significantly to an older antidepressant. As a group, newer antidepressants were equally efficacious compared with older antidepressants (RR 1.0, 95 percent CI 0.97 to 1.06). Studies reporting mean changes in symptom scores rather than response rates had similar findings. There was evidence of positive publication bias in the reporting of RIMA versus TCA1, but not for other comparisons of newer versus older agents. Specific drug classes are reviewed below.

Figure 8. Older Drug vs. SSRI

Figure 9. Older Drug vs. SNRI

Figure 10. Older Drug vs. RIMA

Figure 11. Older Drug vs. NRI, Misc, 5-HT2

### The Findings from Newer Compared with Older Antidepressant Trials by Drug Class

#### Selective serotonin reuptake inhibitors

In 55 studies reporting response rates, SSRIs were compared with TCA1 (n=38), TCA2 (n=5), the triazolopyridine trazodone (n=4), tetracyclic antidepressants (n=7), and MAOI (n=1). SSRIs were equally effective compared with TCA1 (RR 1.0, 95 percent CI 0.9 to 1.1), TCA2 (RR 1.1, 95 percent CI 0.9 to 1.3), Tetra (RR 1.1, 95 percent CI 0.9 to 1.3), Triazo or trazodone (RR 1.1, 95 percent CI 0.7 to 1.6), and MAOI antidepressants (RR 0.9, 95 percent CI 0.7 to 1.3).

There was significant variability in response rates for SSRI compared with TCA1 (test for heterogeneity, p=0.05). The heterogeneity appeared due to two studies showing a greater than average effect for SSRI. There were no clear differences in drug doses, diagnostic methods, or patient characteristics to explain the variability in outcomes. The summary risk ratio was not significantly affected when these two studies were excluded from the analysis. Studies examining mean differences in depressive symptoms showed the same results.

#### Serotonin norepinephrine reuptake inhibitors versus older agents

Eight studies giving usable response rates compared mirtazapine (n=4) or venlafaxine (n=4) with a TCA1. Results were consistent across studies, showing that the SNRI antidepressants were equally effective compared with TCA1 (RR 1.0, 95 percent CI 0.9 to 1.1). Studies reporting mean changes in depressive symptoms confirm these results. Three studies comparing an SNRI with trazodone (triazolopyridine) showed a modestly greater effect for the SNRI (RR 1.2, 95 percent CI 1.0 to 1.4). Average doses of trazodone ranged from a relatively low 220 mg to moderately high doses exceeding 350 mg per day.

#### Reversible inhibitors of monoamine oxidase A versus older agents

Twelve studies compared moclobemide with older agents and reported response rates: TCA1(n=10), TCA2 (n=1), and tetracyclic (n=1). Compared with TCA1, moclobemide was equally effective (RR1.0, 95 percent CI 0.9 to 1.1). Response rates varied significantly across these 10 studies with 1 showing better than average effects for moclobemide and 1 worse than average effects. These studies did not differ substantially in doses of antidepressants or in participant characteristics. There were no significant differences in response rates for the two small studies comparing moclobemide with nortriptyline (TCA2) and maprotiline (tetracyclic). These results were confirmed in studies reporting mean changes in depressive symptoms.

#### Norepinephrine reuptake inhibitors versus older agents

A single study, involving 256 patients recruited from in- and outpatient psychiatric settings, compared reboxetine with imipramine (TCA1). Response rates were significantly higher for reboxetine (67 percent versus 54 percent). However, there were no significant differences when the mean change in depressive symptoms was used as the outcome of interest. There were no reports identified for other NRI antidepressants or for reboxetine compared with other older agents.

#### Miscellaneous antidepressants versus older agents

Minaprine was compared with a TCA1 (n=2) and mianserin (tetracyclic). In each study, minaprine was equally effective compared with the older antidepressant.

#### 5-HT_2_ receptor antagonists versus older agents

Five studies compared nefazodone with a TCA1. Nefazodone did not differ significantly from older agents (RR 0.9, 95 percent CI 0.7 to 1.3), but response rates varied significantly across studies. In the study showing a significantly lower response rate,^ 173 ^ the target dose for nefazodone (100 to 400 mg) was lower than the usually recommended dose (300 to 600 mg/d).

#### 5-HT_1A_ receptor antagonists versus older agents

One study, reporting mean changes in depression symptomatology, compared gepirone with a first generation TCA. No significant differences between the two agents were seen.

#### Dopamine reuptake inhibitor versus older agents

Of five studies, bupropion has been compared with a TCA1 (n=3), nortriptyline (TCA2), and trazodone (Triazo). Bupropion was equally effective compared with tricyclic antidepressants and more effective in the single study compared with trazodone. However, the endpoint analysis did not show a statistically significant greater effect for bupropion compared with trazodone.

### Evidence From Ongoing Searches

Three additional trials, involving over 370 subjects, were identified in searches from January 1998 through August 1998 that compared milnacipran (SNRI, n=2) or sertraline (SSRI, n=1) with a TCA1.^717,^ ^720,^ ^ 721 ^ These trials are consistent with past trials in showing no major differences in efficacy between newer and older agents. The trial comparing sertraline and amitriptyline showed positive effects for both drugs across a broad array of health-related quality-of-life domains compared with placebo.

### The Evidence From Comparisons Between Newer Antidepressants (Tables 28, 29, 30, 31)

Newer antidepressants have been compared head to head in 32 studies, involving over 4,000 participants. Studies were conducted predominantly in Europe (n=19) and North America (n=8). All studies with an identified sponsor were funded by pharmaceutical companies. Participants were recruited from inpatient settings (n=16), mixed in- and outpatient settings (n=7), and outpatient settings (n=2); in seven studies, the setting was not specified. No study reported recruitment from primary care settings.

Table 28. Participants in 32 trials comparing newer classes of antidepressants for major depression

Number | Female | Average Age
4,077 | 63% | 45

Table 29. Settings

Inpatient | Mixed In- and Outpatient | Primary Care | Unknown
16 | 7 | 0 | 7

Table 30. Diagnostic systems used in the trials

DSM-IV major depression | 1
DSM-IIIR major depression | 27
DSM-III major depression | 4

Table 31. Designs of the trials

Double Blind | 6-8 Weeks | Dropouts <20%
30 | 29 | 12

Comparisons were between an SSRI and another newer agent (n=17), between two SSRI antidepressants (n=14), and between a RIMA and NRI antidepressant (n=1). Twenty-nine studies were 6 to 8 weeks in duration, 1 was 9 to 12 weeks, and 2 were longer than 12 weeks. Of the 32 studies, 30 were double blind. Dropout rates were lower than 20 percent (n=12), 20 to 30 percent (n=11), greater than 30 percent (n=5), and not given (n=4).

### The Findings From Comparisons Between Newer Antidepressants (Figure 12)

Fifty-three percent of the participants experienced at least a 50 percent improvement in depressive symptoms as assessed by a rating scale such as the Hamilton Depression Rating Scale or were much to very much improved on the Clinical Global Rating Scale. As a group, SSRI antidepressants were equally efficacious compared with other newer antidepressants. There was no evidence of publication bias for these comparisons. Ten studies reporting response rates compared two SSRI antidepressants, of which eight involved a comparison with fluoxetine. There was a trend for fluoxetine to be slightly less effective (RR 0.9, 95 percent CI 0.8 to 1.0) than the comparator SSRI (citalopram, sertraline, paroxetine). Analysis of the mean changes in depressive symptoms showed no significant difference for fluoxetine compared with other SSRIs.

Figure 12. Fluoxetine and Other Newer Drugs vs. SSRI

### Evidence from Ongoing Searches

Three trials identified from January through August 1998, involving 446 subjects, compared an SSRI with an SNRI, NRI, or DopRI.^722, 723, 724^ Mirtazapine, administered at levels outside the approved U.S. dosing range (mean=56 mg/d), was more efficacious than fluoxetine; otherwise, treatments were equally efficacious.

### Longer Duration Trials

Since the minimum duration of treatment for major depression is 6 months, longer duration studies may offer insights into long-term efficacy and delayed adverse effects. Only four trials, involving 764 participants, were designed to continue initial treatment for at least 24 weeks. Each study involved a different newer antidepressant (SSRI, 5-HT_2_, DopRI, DopAnt) compared with a TCA1. There was a single comparison to placebo. One study did not report outcomes.^ 376 ^

Response rates were similar for newer antidepressants (54 percent) and TCA1 (52 percent). These rates are nearly identical to 6-week trials. The most striking finding from these studies was the high overall dropout rate (>50 percent). Dropouts due to adverse effects were 24 percent for newer agents and 25 percent for TCA1. These rates are more than double those seen in shorter duration studies.

### Dropout Rates in All Major Depression Trials

Analysis of dropout rates offers direct evidence about the tolerability of antidepressant medications and indirect data about efficacy. For SSRI, the most commonly used class of newer antidepressants, overall dropouts did not differ significantly from TCA1 (risk difference 0.02, 95 percent CI 0.05 to 0.02), TCA2 (risk difference -0.09, 95 percent CI -0.20 to 0.01), or Tetra antidepressants (risk difference -02, 95 percent CI -0.10 to 0.09). Dropout rates due to adverse effects were lower for SSRI compared with TCA1 (risk difference -0.04, 95 percent CI -0.07 to -0.01) and showed a trend towards a lower dropout rate compared with TCA2 (risk difference -0.07, 95 percent CI -0.08 to 0.01) and tetracyclic antidepressants (risk difference -0.04, 95 percent CI -0.08 to 0.0). Additional details about dropout rates are given in another section.

### Gaps in Evidence

Significant gaps in evidence on treating major depression with newer antidepressants are as follows: Few studies examined long-term treatment efficacy and adverse effects, few studies reported effects of antidepressants on physical function or quality-of-life outcomes, and few studies were designed to test the effectiveness of antidepressants under usual clinical conditions without the specialized treatment and followup inherent in a randomized trial.

### Other Relevant Evidence

Several literature syntheses have addressed the efficacy of antidepressant drug therapy for major depression. These reviews differed in scope from the present evidence report in that they were limited to older agents or SSRIs compared with other agents. All prior reviews have found antidepressants to be more efficacious than placebo and have found similar efficacy between antidepressants.^7,^ ^28, 29, 30^ Estimates of dropout rates have ranged from no differences to clinically small (<4 percent), but statistically significant differences were found in favor of SSRI.^28, 29, 30^

## Question 2. Are newer antidepressant agents more effective than placebo or older antidepressant agents for treating adult patients with dysthymia?

Newer antidepressant drugs are more efficacious than placebo for treating adults with dysthymia. Response rates were 59 percent for active medication compared with 37 percent for placebo. Two selective serotonin reuptake inhibitors (fluoxetine, sertraline) and a dopamine antagonist are efficacious; there is no evidence suggesting that particular agents are more effective than others, including first generation tricyclic antidepressants.

### Context

Chronic, mild depressive disorder (dysthymia) is found in approximately 3 percent of community populations and causes significant impairment. Because the symptoms are less intense but more chronic (more than 2 years), dysthymia may respond differently to treatment than major depression.

### The Evidence (Tables 32, 33, 34, 35)

Nine trials of at least 6 weeks' duration involving 1,420 adult patients with dysthymia compared newer antidepressants with placebo (n=5), first generation tricyclics (n=5), an antipsychotic (n=1), or another newer antidepressant (n=1).^182,^ ^202,^ ^282,^ ^295,^ ^366,^ ^415,^ ^430,^ ^445,^ ^ 458 ^ Six of the nine trials were conducted in Europe, and pharmaceutical companies sponsored the four with an acknowledged funding source. All studies were conducted in outpatients. Settings were mental health specialty clinics (n=6), primary care clinics (n=1), and not described (n=2).

Table 32. Participants in nine trials for dysthymia

Number | Female | Average Age
1,420 | 67% | 45

Table 33. Settings

Mental Health | Primary Care | Mixed | Unknown
6 | 1 | 0 | 2

Table 34. Depressive disorders studied in the trials

DSM-IIIR dysthymia | 6
DSM-III dysthymia | 3

Table 35. Designs of the trials

Double Blind | 6-8 Weeks | Dropouts <20%
9 | 4 | 4

Selective serotonin reuptake inhibitors (n=3), a dopamine antagonist (n=1), and a 5-HT_2_ receptor antagonist (n=1) were compared with placebo. Sertraline (SSRI, n=1), ritanserin (5HT_2_, n=2), amisulpride (DopAnt, n=1), and minaprine (Misc, n=1), were compared with first generation tricyclic antidepressants. A single small trial compared ritanserin with an antipsychotic.

All trials examined acute phase treatment; duration was 6 to 8 weeks in four studies and 12 weeks in five studies. Dropout rates were lower than 20 percent (n=4) and 20 to 30 percent (n=5). All trials were double blind.

### The Findings (Figure 13)

Response rates were analyzed using a modified intent-to-treat approach, which gives a conservative estimate of response. Fifty-nine percent of the participants randomized to active treatment experienced at least a 50 percent improvement in depressive symptoms on a rating scale such as the Hamilton Depression Rating Scale or much to very much improved on the Clinical Global Rating Scale. Response rates for participants given placebo or first generation tricyclic antidepressants were 37 percent and 59 percent, respectively. Newer antidepressants were significantly more efficacious than placebo (RR 1.7, 95 percent CI 1.3 to 2.3) but similar to first generation tricyclic antidepressants (RR 1.0, 95 percent CI 0.9 to 1.2). There was no evidence of publication bias for these comparisons.

Figure 13. Dysthymia

*Response rates not given for (182, 366, 282)

In a single study comparing two newer agents, the efficacy of amisulpride (DopAnt) was similar to that of fluoxetine (SSRI). A small study in patients with chronic tension or mixed tension/migraine headaches and dysthymia (n=38) compared ritanserin (5HT_2_) with amitriptyline (TCA).^ 366 ^ Both groups showed similar but modest improvements in pain ratings and depressive symptomatology. Another study that only reported mean changes in depressive symptomatology showed similar responses for patients treated with ritanserin (5HT_2_) or imipramine (TCA); both drugs were superior to placebo.^ 182 ^

Overall dropout rates for newer antidepressants, first generation tricyclics, and placebo were 15 percent, 17 percent, and 19 percent, respectively. Four percent of participants given newer antidepressants dropped out because of side effects compared with 9 percent given tricyclics (risk difference -0.05, 95 percent CI -0.10 to -0.001) and 2 percent for placebo (risk difference 0.02, 95 percent CI -0.01 to 0.04).

### Gaps In Evidence

Relative to major depression, there are few trials examining newer pharmacotherapies for dysthymia. No trials report the effect of treatment on social functioning, work performance, or ability to carry out daily activities. The longest trials are only 12 weeks, leaving significant gaps in knowledge about long-term efficacy. Although response rates are similar to those seen for major depression, a large proportion do not respond to initial treatment. Studies are needed to examine treatments designed to enhance the initial response rate and treatments for refractory patients.

### Other Relevant Evidence

A Cochrane Collaboration review, with broader inclusion criteria (e.g., major depression with concurrent dysthymia included), examined 15 placebo-controlled trials. Results were concordant with the current review showing similar efficacy for multiple agents compared with placebo.^ 61 ^ A Cochrane Collaboration protocol titled, "A comparison of active drugs for the treatment of dysthymia," is in progress.^ 60 ^

## Question 3. Are newer antidepressant agents more effective than placebo or older antidepressant agents for treating adult persons with mixed anxiety depression?

There is insufficient evidence to establish whether newer antidepressants are more effective in treating mixed anxiety depression than placebo, older antidepressants, or anxiolytic agents. In the largest of three trials, paroxetine (SSRI) and clomipramine (TCA1) were compared. Response rates with either agent were as high or higher than rates seen in the treatment of major depression, which preliminarily suggests that these agents may be effective for treatment of mixed anxiety depression.

### Context

Depression and anxiety are common coexisting conditions; the most effective treatment for persons suffering from both conditions has not been established.

### The Evidence (Tables 36, 37, 38)

Three trials studied 1,237 adults with mixed anxiety depression.^327,^ ^359,^ ^ 394 ^ All participants had depression and significant anxiety as assessed by an anxiety symptom scale. The trials were conducted in primary care settings and were sponsored by industry. Patients with alcohol abuse or "serious" concomitant medical illness were excluded.

Table 36. Participants in three mixed anxiety depression trials

Number | Female | Average Age
1,237 | 72% | 40

Table 37. Settings

Mental Health | Primary Care
0 | 3

Table 38. Designs of the trials

Double Blind | 6-8 Weeks | Dropouts <20%
3 | 2 | 2

One large international trial of 12 weeks' duration (n=1,019) compared paroxetine (SSRI) at 20 to 40 mg/d with clomipramine (TCA) at 75 to 150 mg/d. One much smaller European trial (n=112) compared fluvoxamine (SSRI) at 300 mg/d with lorazepam (anxiolytic) at 6 mg/d. The other small European trial (n=106) compared sertraline (SSRI) at 50 to 150 mg/d and clomipramine (TCA) at 50 to 150 mg/d. Dropout rates were 24 percent for the large trial and 13 percent for each of the smaller trials.

### The Findings (Figure 14)

In the largest trial, 85 percent of patients given paroxetine and 83 percent of patients given clomipramine experienced at least a 50 percent improvement in symptoms as measured by the Montgomery-Âsberg Depression Scale. In one small trial, 80 percent and 82 percent of patients receiving fluvoxamine and lorazepam, respectively, were much or very much improved on the Clinical Global Impression Scale. In the other small trial, 58 percent of patients given sertraline and 61 percent of patients given clomipramine improved as measured by the Hamilton Depression Rating Scale, and 58 percent and 57 percent (sertraline and clomipramine, respectively) improved as measured by the Hamilton Anxiety Rating Scale. None of the comparisons within the three trials was significantly different.

Figure 14. Mixed Anxiety Depression

Dropout rates due to adverse effects were significantly greater with clomipramine (17 to 18 percent) compared with paroxetine (11 percent) and sertraline (4 percent). Administration of fluvoxamine (5 percent) and lorazepam (4 percent) resulted in similar dropout rates.

### Gaps In Evidence

There are inadequate data to guide drug management for patients with mixed anxiety depression. Specifically, there are no placebo-controlled trials and there is a dearth of trials of any type in persons with mixed anxiety depression.

### Other Relevant Evidence

No other recent relevant systematic review was found.

## Question 4. Are newer antidepressant agents more effective than placebo or older antidepressant agents for treating adult patients with subsyndromal depressive disorders?

Data are insufficient to determine whether newer antidepressant drugs are efficacious for adults with subsyndromal depressive disorders.

### Context

The efficacy of antidepressant drug therapy has been established for major depression. Less severe forms of depression, sometimes called "minor," "subthreshold," or "subsyndromal" depression, cause impairment and are common in primary care settings. The efficacy of antidepressant drug therapy for these disorders has been unclear.

### The Evidence (Tables 39, 40, 41, 42)

Three trials evaluating newer agents have involved 392 adult patients with subsyndromal depression.^379,^ ^457,^ ^ 441 ^ All were conducted in Europe and were sponsored by pharmaceutical companies. All studies were conducted in outpatients. Recruitment settings were mental health specialty (n=1), mixed primary care and mental health (n=1), and not described (n=1).

Table 39. Participants in the three trials

Number | Female | Average Age
392 | 68 percent | 53

Table 40. Settings

Mental Health | Primary Care | Mixed | Unknown
1 | 0 | 1 | 1

Table 41. Depressive disorders studied in the trials

DSM-III: subsyndromal or neurotic depression | 1
ICD-9: prolonged depressive reaction | 1
Research Diagnostic Criteria: subsyndromal | 1

Table 42. Designs of the trials

Double Blind | 6-8 Weeks | Dropouts <20%
2 | 2 | 1

Only one study, in older patients (mean age=71), was placebo controlled. Two studies compared newer agents (paroxetine [SSRI] and moclobemide [RIMA]) with older agents. Depressive illnesses were defined as DSM-III subsyndromal or neurotic depression (n=1); International Classification of Disease, 9^th^ ed. (ICD-9) prolonged depressive reaction to a stressor (n=1); and Research Diagnostic Criteria (RDC) for minor depression (n=1). Although these diagnoses are not exactly equivalent, they all describe patients with depressed mood or anhedonia and fewer than the five symptoms required for major depressive disorder. The three trials examined acute phase treatment; duration was 6 weeks in two studies and 13 weeks in the other. Dropout rates were lower than 20 percent (n=1), 20-30 percent (n=1), and >30 percent (n=1).

### The Findings (Figure 15)

The single placebo-controlled trial was conducted in older adults (age 60 to 85) with a "prolonged depressive reaction." It showed "improvement" for 60 percent of patients randomized to minaprine 200 mg/d compared with 39 percent of patients given placebo as measured by a Clinical Global Assessment. Compared with placebo, minaprine improved social functioning. There were no dropouts due to adverse effects.

Figure 15. Subsyndromal Depression

*Response rates not given for (379, 457)

The largest trial involved 544 patients with major (n=298) or subsyndromal (n=245) depression. Among those with subsyndromal depression, a 50 percent reduction in Hamilton Rating Depression scores was obtained in 77 percent of patients on paroxetine (20 to 40 mg/d) compared with 69 percent of patients on maprotiline (100 to 150 mg/d). (RR 1.1, 95 percent CI 0.95 to 1.25). For the entire sample, dropout rates due to adverse effects were similar for the two drugs (13 percent and 14 percent).

A small trial (n=17) compared moclobemide (RIMA) with amitriptyline (TCA) administered at a low dose (75 mg/d). Overall clinical response rates were very good or good in seven of eight patients on moclobemide and four of nine patients on amitriptyline. Dropout rates were high (25 percent and 44 percent) for the two drugs, respectively. This study was too small to detect clinically significant differences between treatment groups, and the dose of amitriptyline may have been inadequate.

### Gaps in Evidence

There are inadequate data to guide management for patients with subsyndromal depression. Data are insufficient to determine if therapy with newer antidepressant drugs is better than placebo for acute phase treatment. There are no trials comparing newer antidepressant drug therapy with any type of psychosocial therapy, a reasonable and attractive alternative for some patients with milder forms of depression. The data are inadequate to guide drug selection for clinicians who choose antidepressant drug therapy for patients with subsyndromal depression. Finally, no studies have examined the effects of treatment on patients' ability to perform their normal daily activities.

### Other Relevant Evidence

None was found.

## Question 5. Are newer antidepressant agents more effective than older antidepressant agents or placebo in the treatment of recurrent depression?

Multiple newer antidepressant agents are more effective than placebo and as efficacious as older antidepressants in patients with previous depressive episodes. Data are insufficient to determine whether lower response rates are seen in patients with recurrent depression compared with patients experiencing their first episode of depression.

### Context

Approximately 50 percent of patients who suffer from an initial depressive episode are likely to suffer a recurrence of their symptoms. Whether newer antidepressants are effective in treating such patients is unclear.

### The Evidence (Tables 43, 44, 45)

Most of the 315 trials addressed in this evidence report included patients with histories of depression. For example, 75 percent of the trials had study populations that included more than 50 percent of participants with histories of depression. Thus, much of the data reviewed in the section addressing major depression are derived from patients with one or more prior depressive episodes. Only eight studies specifically stated that they were studying recurrent depression.^225,^ ^238,^ ^276,^ ^298,^ ^425,^ ^468,^ ^504,^ ^ 505 ^ (Three additional studies that address long-term maintenance treatment in patients with recurrent depression are discussed in another section.) These are the only trials reviewed here, though it is clear many of the patients in the other trials had recurrent depression. The eight trials involved 1,624 patients. Most patients had recurrent major depression. Five of the studies were conducted in North America and two in Europe.

Table 43. Participants in the eight trials

Number | Female | Average Age
1,624 | 50% | 43

Table 44. Depressive disorders studied in the trials

Major depression | 8

Table 45. Designs of the trials

Double Blind | 6-8 Weeks | Dropouts <20%
8 | 8 | 1

The trials included four comparisons of newer agents with placebo, five of newer agents with first generation tricyclic agents (TCAs), and one comparison each of bupropion (DopRi) and venlafaxine (SNRI) with trazodone (Triazo). Dropout rates ranged from 12 percent to 55 percent, with only one trial having a dropout rate lower than 20 percent. Study duration was 6 weeks for all studies.

### The Findings (Figure 16)

Of patients with recurrent depression given a newer antidepressant, 47 percent had at least a 50 percent improvement in symptoms as measured by a depressive symptom rating scale. Only 28 percent responded significantly to placebo. For the three relevant trials reporting response rates, newer antidepressants were significantly more efficacious than placebo (RR 1.5, 95 percent CI 1.2 to 1.9).

Figure 16. Recurrent Depression

Of patients with recurrent depression given an older antidepressant, 45 percent responded. In the six relevant trials reporting response rates, newer antidepressants were equally efficacious as older agents.

### Gaps in Evidence

There are significant gaps in knowledge concerning the treatment of recurrent depression. More trials are needed to reliably determine whether response rates to antidepressants in such patients are lower than those seen in patients suffering their first episode of depression. Trials are also needed to determine whether particular patients such as those with multiple prior episodes of depression are more refractory to treatment than those with only one prior episode. Whether adverse effects of antidepressants are higher in persons with recurrent depression is also not well known.

### Other Relevant Evidence

None was found.

## Question 6. Are newer antidepressant agents more effective than older agents in the treatment of adult patients with refractory depression?

There are few trials evaluating benefits and risks of newer antidepressants for adults with major depression that has not responded to prior treatment. Evidence is insufficient to reliably determine response rates in such patients and whether particular antidepressant agents are more effective than others.

### Context

Approximately 50 percent of people suffering from major depression will have significant alleviation of symptoms with antidepressant therapy. Few guides help patients and clinicians select particular treatments when first attempts at therapy are not successful.

### The Evidence (Tables 46, 47, 48, 49)

Five European trials compared newer and older antidepressant agents in adults with refractory depression.^177,^ ^296,^ ^305,^ ^438,^ ^ 477 ^ Four were conducted in mental health settings; three were limited to inpatients.

These trials involved 396 patients with major depression who had persistent symptoms despite antidepressant therapy. Patients with alcohol abuse and serious medical conditions were not studied.

Table 46. Participants in the six trials

Number | Female | Average Age
396 | 66% | 44

Table 47. Depressive disorders studied in the trials

Major depression | 6

Table 48. Settings

Mental Health | Primary Care | Unclear
4 | 0 | 1

Table 49. Designs of the five trials

Double Blind | 6-8 Weeks | Dropouts <20%
5 | 4 | 1

Two trials compared paroxetine at 30 to 40 mg/d (SSRI) with either amitriptyline or imipramine at 150 mg/d (TCA). One compared brofaromine (RIMA) at 100 mg/d with tranylcypromine (MAOI) at 20 mg/d. The other two trials compared augmentation strategies of lithium with brofaromine or fluoxetine (SSRI) against lofepramine (TCA) or maprotiline (Tetra).

Four trials were 6 weeks in duration and one was 12 weeks. Dropout rates ranged from 19 percent to 49 percent.

### The Findings (Figure 17)

The two small trials that involved lithium showed no consistent benefits; they are described in a later section that addresses augmentation. Response rates for agents evaluated in the other three trials ranged from 66 percent to 80 percent. In these few trials with few participants, none of the comparisons varied significantly from agent to agent.

Figure 17. Refractory Depression

### Gaps in Evidence

There are large gaps in evidence concerning the treatment of refractory depression. There are very few trials. None is long enough to evaluate appropriate duration of therapy for patients with refractory depression. None has evaluated therapy with newer agents in the event of failed psychosocial therapy.

### Other Relevant Evidence

No other recent high-quality systematic reviews were found.

## Question 7. Are newer antidepressive agents more effective than psychosocial therapies for treating depressive disorders in adults?

There were no trials comparing newer agents with educational or supportive counseling. Only one small trial compared individual cognitive psychotherapy directly with a newer agent in adults. The gaps in the evidence do not permit an answer to this question.

### Context

Psychosocial therapies, including psychotherapy, group exercise, supportive counseling, and interventions to improve social supports, are preferred by some patients. Among these, psychotherapy is the best established alternative to pharmacotherapy for the treatment of nonpsychotic, nonbipolar depressive disorders in outpatients. To aid informed decisionmaking, we addressed the relative efficacy of psychosocial therapies compared with that of pharmacotherapy.

### The Evidence (Tables 50, 51, 52)

Only one small trial (n=31) has compared the efficacy of a newer agent, fluoxetine (SSRI) directly with a psychosocial therapy in adults.^ 250 ^ The trial was conducted in the United States, and the funding source was not identified. The psychosocial intervention involved individual cognitive therapy; the credentials and educational levels of the therapists were not clear. All subjects in the trial had dysthymia. The trial examined acute phase treatment, and the intervention lasted 16 weeks. There was a 29 percent dropout rate.

Table 50. Participants in one psychosocial trial

Number | Female | Average Age
31 | 46% | 36

Table 51. Depressive disorders studied in the trial

Dysthymia

Table 52. Design of the trial

Double Blind | Trial Length | Percent Dropouts
NA | 16 weeks | 29

### The Findings (Figure 18)

Both the cognitive therapy group and the fluoxetine group showed improvement over time. The number of patients was too small to detect clinically significant differences between treatment groups. Six of the 18 fluoxetine patients and 3 of the 13 cognitive therapy patients dropped out of treatment or were unavailable for end-of-treatment assessment.

Figure 18. Psychosocial Therapies vs. SSRI

### Gaps in Evidence

The paucity of studies comparing psychosocial interventions to newer pharmacotherapies represents a significant gap in the literature. A variety of psychosocial therapies such as general support and counseling have not been compared with newer pharmacotherapies. The only pertinent study had a small sample size and inadequate followup assessments. No trials of maintenance or relapse prevention are available. Data are insufficient to determine which patients will best respond to psychotherapy and which will respond to pharmacotherapy.

### Other Relevant Evidence

Prior systematic reviews and meta-analyses have shown that certain types of depressive-specific psychotherapies (e.g., cognitive or cognitive-behavioral therapy and interpersonal therapy) are as effective as pharmacotherapy for major depression.^6,^ ^8,^ ^ 21 ^ Trials addressed in these reviews have primarily involved older antidepressant agents. The relative effectiveness of the different varieties of psychotherapies is not entirely clear.^506,^ ^ 507 ^

## Question 8. Is hypericum (St. John's wort) more effective than placebo or standard antidepressant agents for treating adult patients with depressive disorders?

Hypericum (St John's wort) appears more effective than placebo for the short-term treatment of mild to moderately severe depressive disorders, but data are limited and subject to positive publication bias. Whether hypericum is as effective as standard antidepressant agents given in adequate doses is not established. Hypericum has fewer adverse effects than older first generation tricyclic antidepressant agents.

### Context

Extracts of the plant Hypericum perforatum L., popularly known as St. John's wort, have long been used in folk medicine and are licensed in Germany for the treatment of depression. The efficacy and tolerability of hypericum compared with standard antidepressants as well as placebo have been questioned.

### The Evidence (Tables 53, 54, 55)

Fourteen trials of at least 6 weeks' duration involving 1,417 adult participants compared hypericum with placebo (n=8) or first generation tricyclic antidepressants (n=6).^193,^ ^240,^ ^292,^ ^297,^ ^314,^ ^317,^ ^375,^ ^397,^ ^418,^ ^436,^ ^465,^ ^466,^ ^470,^ ^ 475 ^ None compared hypericum with newer agents. Most trials were conducted in Germany and were funded by industry. Multiple preparations, standardized based on content of hypericins (which may not be the only active ingredient), were studied. Doses of hypericum extract varied from 300 to 1800 mg/d. Three trials evaluated combinations of hypericum with other extracts such as valeriana. First generation tricyclic agents compared were amitriptyline (30 to 150 mg/d), desipramine (100 mg/d) and imipramine (75 mg/d).

Table 53. Participants in hypericum trials

Number | Female | Average Age
1,417 | 70% | 50

Table 54. Depressive disorders studied in the trials

Major depression | 6
Dysthymia or minor | 4
"Depressed mood" | 2
Heterogeneous | 2

Table 55. Designs of the trials

Double Blind | 6-8 Weeks | Dropouts <20%
14 | 14 | 14

Participants in the studies were recruited by psychiatrists, general practitioners, internists, and gynecologists. All were outpatients. They had multiple depressive disorders. All trials were described as double blind, though hypericum extracts have a characteristic taste and some degree of unblinding is possible. Dropout rates were low (approximately 10 percent).

### The Findings (Figure 19)

Sixty-two percent of the participants who were given single preparations of hypericum extracts experienced a 50 percent improvement in symptoms as measured by a depressive symptoms scale such as the Hamilton Depression Rating Scale. Response rates for participants given placebo and older tricyclic antidepressants at low doses were 38 percent and 61 percent, respectively. Hypericum extracts were significantly more effective than placebo (RR 1.9, 95 percent CI 1.2 to 2.8) but similar to older tricyclic agents given at low doses (RR 1.2, 95 percent CI 1.0 to 1.4). Publication bias analysis was positive, suggesting positive results of hypericum are systematically reported. Two trials of hypericum and valeriana that compared combination preparations with tricyclic agents found 68 percent and 50 percent response rates, respectively (RR 1.5, 95 percent CI 0.8 to 2.9).

Figure 19. St. Johns's Wort vs. Placebo and Tricyclics

Six percent of persons given hypericum preparations dropped out of the trials compared with 7 percent of those given older tricyclics at lower doses (risk difference -0.01, 95 percent CI -0.05 to 0.02). Proportions of patients reporting "any" side effect were 25 percent for hypericum preparations compared with 40 percent with tricyclic agents (risk difference -0.15, 95 percent CI -0.24 to 0.06).

### Gaps in Evidence

Evidence regarding the efficacy of hypericum is lacking in many areas. Neither the most appropriate preparation nor the most effective dose is known. There are not enough comparisons with older agents given at adequate doses, and there are no comparisons with newer antidepressant agents. There are no long-term maintenance or prevention of relapse data. Whether hypericum is effective for certain depressive disorders and not others is still unknown.

### Other Relevant Evidence

A recent Cochrane review, which will be continually updated, summarizes 27 short-term trials (including trials of less than 6 weeks' duration) of hypericum and is consistent with the above findings.^ 62 ^

## Question 9. Are aleriana and kava kava more effective than placebo or standard antidepressants for treating depressive disorders in adults?

No trial data assessing the efficacy of single preparations of valeriana or kava kava for treating depression were found.

## Question 10. Are newer antidepressant agents more effective than placebo or older antidepressants for treating depressive disorders in children and adolescents?

Only two studies were identified that studied newer agents in children and adolescents. The data are insufficient to guide management of depression in children and adolescents.

### Context

Although newer antidepressants are widely used in adults, their safety and efficacy in depression management for children and adolescents are unclear.

### The Evidence (Tables 56, 57, 58, 59)

Only two trials (n=80) evaluated the use of newer antidepressants in children and/or adolescents.^340,^ ^ 426 ^ One of the trials was conducted in the United States and the other was conducted in Canada. Funding sources were not identified in either study.

Table 56. Participants in two trials

Number | Female | Average Age
80 | 41% | 15

Table 57. Settings

Urban Psychiatric Clinic | Unknown
1 | 1

Table 58. Depressive disorders studied in two trials

Major Depression
2

Table 59. Designs of the two trials

Double Blind | 6-8 Weeks | Dropouts <20%
2 | 2 | 1

One trial compared fluoxetine (SSRI), at 20 to 60 mg, with placebo. The other trial compared a combination of venlafaxine (SNRI) and psychotherapy with a combination of placebo and psychotherapy. Venlafaxine was titrated to low doses of 12.5 mg 3 times per day (t.i.d.) for children and 25 mg t.i.d. for adolescents.

Patients in both trials had nonpsychotic major depression. Both trials examined acute phase treatment of 6 to 8 weeks' duration. Overall dropout rates were 18 percent and 25 percent, respectively. Few data on adverse effects were given.

#### The findings

Neither trial reported response rates. The first trial in 30 adolescents showed no significant difference between fluoxetine and placebo for depression symptoms or psychosocial functioning. The second trial involving 33 persons age 8 to 17 showed that both venlafaxine and psychotherapy improved depressive symptoms but there were no significant differences between groups in improvement.

### Gaps in Evidence

Gaps in the literature about efficacy of antidepressants in children and adolescents are substantial. There are no direct comparisons of newer agents alone with psychosocial therapy, older agents, or other newer agents. Only one trial compares a newer agent with placebo (see below for update on one additional trial). The two trials reviewed above are small and short. Adequate data about adverse events are lacking.

### Other Relevant Evidence

A recent systematic review summarized results of six randomized trials evaluating cognitive behavioral therapy in 231 adolescents with depression.^ 508 ^ Adolescents receiving cognitive behavioral therapy had fewer depressive symptoms than those assigned to control groups. Ongoing searches conducted through August 1998 identified one additional trial. This recent 8-week double-blind trial compared fluoxetine (20 mg/d) with placebo in 96 outpatients age 7 to 17 years.^ 726 ^ All had severe persistent nonpsychotic major depressive disorder. Overall discontinuation rates were greater among participants assigned to placebo than to fluoxetine (45 percent versus 29 percent). Discontinuation rates due to lack of efficacy with placebo were 40 percent compared with 16 percent with fluoxetine. At study exit, 56 percent of patients assigned to fluoxetine were much or very much improved on the CGI scale compared with 33 percent assigned to placebo (p=0.02).

## Question 11. Are newer antidepressant agents more effective than placebo or older antidepressant agents for treating older persons with depressive disorders?

Newer antidepressant drugs are better than placebo in treating major depression in older adults. There is no evidence suggesting that particular newer or older agents are significantly more effective than others. Newer agents are not associated with significantly fewer total dropouts or dropouts from adverse effects compared with older first generation tricyclic agents.

### Context

Frequent comorbid medical illness and concomitant treatment with other medications has led to the suspicion that antidepressant therapy is less effective in older persons than in middle-age persons.

### The Evidence (Tables 60, 61, 62)

There were 27 trials involving 3,929 persons over 60 years of age.^220,^ ^249,^ ^251,^ ^254,^ ^259,^ ^260,^ ^283,^ ^287,^ ^291,^ ^298,^ ^299,^ ^306,^ ^313,^ ^320,^ ^321,^ ^ 339, ^ ^352,^ ^365,^ ^371,^ ^377,^ ^379,^ ^386,^ ^390,^ ^414,^ ^443,^ ^447,^ ^ 509 ^ Nineteen were conducted in Europe or Scandinavia, 6 in the United States, and 2 in South America. Of 17 trials with an identified funding source, pharmaceutical companies funded all.

Table 60. Participants in 27 trials in older adults

Number | Female | Average Age
3,929 | 66% | 72

Table 61. Depressive disorders studied in the trials

Major depression | 22
Heterogeneous | 3
Unclassified | 1
Subsyndromal | 1

Table 62. Designs of the trials

Double Blind | 6-8 Weeks | Dropouts <20%
27 | 24 | 5

Ten comparisons of newer agents versus placebo were made. Most other comparisons were made with selective serotonin reuptake inhibitors (SSRI, n=10), reversible inhibitors of monoamine oxidase (RIMA, n=4), or serotonin norepinephrine reuptake inhibitors (SNRI, n=2) versus tricyclic antidepressants. All but two of the tricyclic comparisons were with first generation drugs such as amitriptyline, imipramine, and dothiepine. Newer antidepressants generally were given in the usual dose range, whereas 8 of the 17 comparison groups given tricyclic agents used low doses.

Most participants in the trials were outpatients with major depression. Two small trials (n=134) involved physically ill inpatients,^254,^ ^ 390 ^ and one included 46 frail elders receiving home nursing care.^ 313 ^ Persons with cognitive impairment were often excluded; however, three trials involving 961 patients specifically recruited patients with dementia.^306,^ ^414,^ ^ 443 ^

Few trials described the actual treatment environment or characteristics of providers who delivered treatment. Decisions regarding antidepressant management (initial dose, dosage changes, treatment discontinuation, or switches) generally followed set protocols. Adherence in terms of number of scheduled visits attended, pill counts, or numbers of prescriptions filled generally were not reported.

All trials studied acute phase treatment. Treatment duration was typically 6 to 8 weeks (n=24). Dropout rates were <20 percent (n=5), 20 to 30 percent (n=8), >30 percent (n=11), and unclear (n=3). Eleven trials reported cognitive status outcomes; none reported quality-of-life or physical function outcomes.

### The Findings (Figure 20)

Approximately 50 percent of the older participants who received newer antidepressants had at least a 50 percent improvement in symptoms as measured by a depressive symptoms rating scale. Response rates did not vary significantly from newer to newer agents except for sulpiride (DopAnt, also used as an antipsychotic drug), where one small study rendered a response rate of only 14 percent. The average response rate for older patients given placebo was 30 percent. Average response rates for older agents was 54 percent.

Figure 20. Older Persons

*Response rates not given for (414, 365, 259, 249, 306, 321, 298, 251)

Newer antidepressants excluding sulpiride were significantly more effective than placebo (RR 1.4, 95 percent CI 1.2 to 1.6). Newer antidepressants were similar in efficacy to tricyclic agents (RR 1.0, 95 percent CI 0.9 to 1.1). No specific classes of newer agents, including SSRI, RIMA, and NRI, were superior to tricyclic agents. Subgroup analyses showed that newer antidepressants were not superior to either tricyclics at low doses or first generation tricyclics only. There was no evidence of publication bias, and statistical tests for heterogeneity were not significant for above comparisons. Endpoint analyses showed identical results to the modified intent-to-treat analyses presented above.

Total dropout rates did not vary significantly between newer and older antidepressants. Dropout rates due to adverse effects were placebo 1 percent, SSRI 16 percent, TCA1 17 percent, NRI 11 percent, and RIMA 7 percent. One study had a 26 percent dropout rate in patients given nortriptyline (second generation tricyclic), which was titrated based on therapeutic drug levels. In general, dropouts due to adverse events did not vary significantly between newer agents and first generation tricyclics (risk difference -0.03, 95 percent CI -0.07 to 0.02).

The three trials conducted in cognitively impaired older adults compared moclobemide (RIMA) at 400 mg/d with placebo, fluoxetine (SSRI) at 10 mg/d with amitriptyline at 25 mg/d, and paroxetine (SSRI) at 20 to 40 mg/d with imipramine (TCA) at 50 to 100 mg/d. The large trial (n=726) found that moclobemide significantly improved depressive symptoms and cognitive status scores compared with placebo. The two small trials (total n=55) found no differences in depression or cognitive status between agents.

Three small trials in physically frail elders compared fluoxetine (SSRI) at 20mg/d with placebo, sulpiride (DopAnt) at 200 mg/d with placebo, and fluvoxamine (SSRI) at 150 mg/d with dothiepine (TCA) at 150 mg/d. None of these trials showed significant differences between groups.

### Gaps in Evidence

Significant gaps in the literature on treating depression in older adults are as follows: few trials in U.S. general practice and nursing home settings, few trials in non-major depression, no trials with physical function or quality-of-life outcomes, no trials comparing newer pharmacotherapies with psychosocial therapy, no trials of relapse prevention, and few trials in frail elders with significant comorbid illness.

### Other Relevant Evidence

A recent systematic review of 37 controlled studies found tricyclic agents were superior to placebo in treating depression in older ambulatory patients.^ 64 ^ Few trials of newer agents were included. Six small studies suggested behavioral therapy was more effective than usual care but not statistically significantly better than nonspecific interventions that provided similar attention to that received by behavioral treatment groups. Another recent meta-analysis addressing late-life depression found no differences in efficacy between selective serotonin reuptake inhibitors, reversible inhibitors of monoamine oxidase A, tricyclics, or other newer agents such as mianserin.^ 510 ^

Ongoing searches through August 1998 identified a recent double-blind trial comparing milnacipran (at 50 mg two times per day) with imipramine (at 50 mg two times per day) in 219 older persons with major depression. One-third of the participants dropped out of the 8-week trial that showed no significant differences in efficacy between the two agents.^ 727 ^

## Question 12. Are newer antidepressant agents more effective than placebo or older antidepressants for treating patients with comorbid medical (e.g., ischemic heart disease, cancer) or psychiatric (e.g., alcoholism) illness?

The available data for patients with depression and alcoholism, chronic fatigue syndrome, HIV, ischemic heart disease, renal failure, and stroke are insufficient to reliably determine the relative efficacy of newer agents compared with placebo or older agents. There are no trials evaluating efficacy of newer antidepressants in persons with concomitant major medical illnesses such as cancer and diabetes.

### Context

Patients with significant comorbid medical conditions often develop depression, but the efficacy of antidepressant pharmacotherapy is not well known in these populations. It is often thought that side effects and drug interactions may impair already compromised functioning in such patients.

### The Evidence (Tables 63, 64, 65, 66)

Ten trials involving 484 adults have evaluated newer antidepressants for treating depression in patients with specific comorbid medical and psychiatric illnesses.^171,^ ^172,^ ^190,^ ^198,^ ^224,^ ^229,^ ^345,^ ^410,^ ^444,^ ^ 461 ^ Four trials were conducted in the United States and six in European and Scandinavian countries. Of six trials that identified funding sources, five were funded by pharmaceutical companies. Six additional trials studied elders with physical illness or cognitive impairment^254,^ ^306,^ ^313,^ ^390,^ ^414,^ ^ 443 ^ They are described in the section addressing treatment in older patients.

Table 63. Participants in 10 trials

Number | Female | Average Age
484 | 40% | 51

Table 64. Special populations studied

Alcoholism | 2
Chronic fatigue syndrome | 2
HIV | 2
Ischemic heart disease | 1
Renal failure | 1
Stroke | 2

Table 65. Depressive disorders studied in 10 trials

Major depression | 3
Dysthymia | 1
Unclassified | 2
Atypical | 1
Adjustment disorder with depressed mood | 1
Heterogeneous | 2

Table 66. Designs of the 10 trials

Double Blind | 6-8 Weeks | Dropouts <20%
9 | 6 | 8

Newer agents evaluated have included selective serotonin reuptake inhibitors, reversible inhibitors of monoamine oxidase A, and serotonin norepinephrine reuptake inhibitors.

A variety of depressive disorders have been studied, including major depression, dysthymia, adjustment disorder with depressed mood, atypical disorder, and other unspecified types of depressions.

Two studies had a mixed patient group that included more than one disorder. There have been eight comparisons with placebo (one in combination with psychotherapy), four comparisons with older agents, and no direct comparisons of newer agents. A number of medical and psychiatric conditions were examined, including alcoholism, chronic fatigue syndrome, HIV, ischemic heart disease, renal failure, and stroke. There were no trials of at least 6 weeks' duration that addressed depressed patients with other major comorbid medical conditions such as diabetes or cancer.

Six trials examined acute phase treatment lasting 6 to 8 weeks, and four trials were 12 weeks. Total dropout rates for eight of the nine trials reporting this information were 20 percent or lower.

### The Findings

#### Alcoholism

Two small trials of 12 weeks' duration compared newer agents with placebo in patients with alcoholism and depression.^171,^ ^ 224 ^ The first involved 30 participants with dysthymia and longstanding alcohol dependence.^ 171 ^ Patients given viloxazine (NRI) at 400 mg/d had significantly greater improvements in Hamilton Depression Rating Scale scores than patients given placebo. Drinking behavior with viloxazine was improved but not statistically significantly different from that seen with placebo. The second trial involved 51 patients with major depression and alcohol dependence.^ 224 ^ All patients underwent detoxification and received the first two weeks of therapy in the hospital. Patients given fluoxetine (SSRI) at 20 to 40 mg/d had significantly greater improvements in depression symptoms and lesser amounts of alcohol consumption than those given placebo.

#### Chronic fatigue syndrome

An 8-week study with a 2-month followup compared fluoxetine (SSRI) at 20 mg/d with placebo in 44 patients with chronic fatigue syndrome and major depression. There were no differences in self-reported fatigue, depressive symptoms, or physical function between the two groups.^ 461 ^ A second trial compared sertraline (SSRI) at 50-150 mg/d with clomipramine (SSRI) at 50 to 150 mg/d in 40 patients with fatigue following a viral syndrome and atypical depression.^ 190 ^ No significant differences between groups for depression outcomes were found.

#### HIV

One small study compared fluvoxamine (at 100-150 mg three times per day) with placebo in 26 HIV-positive patients with adjustment disorder and depressed mood.^ 345 ^ At the end of 8 weeks, Hamilton Depression Rating Scale scores improved significantly (from 30.4 to 15.81) for the fluvoxamine group and did not change significantly (from 29.5 to 24.7) for the placebo group. A second study compared psychotherapy and fluoxetine (SSRI) at 20 mg/d with psychotherapy and placebo in 20 asymptomatic HIV-positive men with major depression or adjustment disorder with depressed mood.^ 444 ^ After 12 weeks, both groups experienced similar improvements; pretreatment Hamilton Depression Rating Scale scores of approximately 20 fell to posttreatment scores of approximately 7.

#### Ischemic heart disease (Figure 21)

A single trial compared paroxetine (SSRI) at 20 to 30 mg/d with nortriptyline (TCA) targeted to a therapeutic plasma level of 190 to 570 nmol/L.^ 410 ^ Eighty-one patients with major depression and ischemic heart disease (past myocardial infarction, positive treadmill or catheterization, or past coronary surgery) were followed for 6 weeks.^ 410 ^ A 50 percent or greater response rate as assessed by the Hamilton Depression Rating Scale was obtained in 25 of 41 (61 percent) patients given paroxetine and 22 of 40 (55 percent) patients given nortriptyline. Fewer patients dropped out with paroxetine (10 percent) than with nortriptyline (35 percent). Significantly more patients given nortriptyline than paroxetine dropped out because of adverse cardiac events (18 percent versus 1 percent).

Figure 21. Ischemic Heart Disease

#### Renal failure

One very small trial compared fluoxetine (SSRI) with placebo in 14 patients with major depression and end-stage renal disease on dialysis.^ 198 ^ At 8 weeks, there was no difference between groups in mean values of scores on several depression rating scales.

#### Stroke (Figure 22)

A small three-armed trial compared fluoxetine (SSRI) at 20 mg/d, maprotiline (Tetra) at 150 mg/d, and placebo in 52 severely disabled hemiplegic patients with unclassified depression.^ 229 ^ Treatment lasted 12 weeks. Findings were mixed. Patients receiving fluoxetine had better scores in activities of daily living after therapy than those receiving maprotiline. Both agents were associated with improvements in Hamilton Depression Rating Scale scores that were not significantly different from each other or from placebo.

Figure 22. Stroke

A 6-week trial compared citalopram (SSRI) at 10 to 40 mg/d and placebo in 66 patients with poststroke major or minor depression.^ 172 ^ A 50 percent or greater response rate as assessed by the Hamilton Depression Rating Scale was observed significantly more often in the patients receiving citalopram (59 percent) compared with placebo (28 percent). Dropout rates with citalopram were 21 percent and 6 percent with placebo.

### Gaps in Evidence

There are several major gaps relevant to the efficacy of newer antidepressants in treating persons with concomitant depression and medical illness. First, there are few relevant trials. Important common comorbid medical illnesses such as cancer and diabetes have not been studied. Most available trials are small and lack power to detect clinically important differences. Most trials are too short to assess sustainability of treatment benefits as comorbid illness continues or worsens. Few trials assess comprehensive outcomes including physical, mental and social function. Only one trial compares the efficacy of newer pharmacotherapies with that of a psychosocial therapy, which may be an attractive option in populations where side effects and drug interactions are a particular concern.

### Other Relevant Evidence

No recent systematic reviews evaluating the efficacy of newer antidepressants in patients with comorbid illness were found. Three recent trials in HIV-positive patients have been identified in ongoing searches conducted through August 1998. One 8-week trial has not reported outcomes according to groups who were randomized to either fluoxetine or placebo.^ 728 ^ A 12-week trial in 75 HIV-positive outpatients with major depression has compared paroxetine with imipramine and placebo. Fewer than 50 percent of the participants completed the trial, which found no significant differences in efficacy between paroxetine and imipramine, but there was a higher dropout rate from adverse effects with imipramine compared with paroxetine (48 percent versus 20 percent). A third recent 7-week trial compared fluoxetine plus group psychotherapy with group psychotherapy alone in 47 HIV-seropositive men with major depression. More participants assigned to fluoxetine plus psychotherapy versus psychotherapy alone had a 50 percent or greater response in depressive symptoms as measured by the Hamilton Depression Rating Scale.^ 730 ^

## Question 13. Does the efficacy of newer agents vary between men and women and between different ethnic groups?

There is insufficient evidence from the trials to evaluate systematic differences in antidepressant response rates between men and women and between different ethnic groups. Fewer than 10 percent of the trials reported any data about ethnicity. Most trials included more women than men and did not give response rates by gender. Meta-regression analyses using percent of women included in each trial did not identify this factor as a significant predictor of response rate (see previous section on Quantitative Results of Effects of Design and Methodologic Characteristics on Response Rates).

## Question 14. Are newer antidepressant agents more effective than placebo or older antidepressant agents for treating adult primary care patients with depressive disorders?

Newer antidepressant drugs are better than placebo in treating depressive disorders in adults in primary care settings. Multiple agents are proven effective; there is no evidence suggesting that particular agents are significantly more effective than others.

### Context

Most prior evidence addressing efficacy of antidepressant drug therapy has been derived from psychiatric settings. The efficacy of antidepressant therapy for the wide spectrum of patients seen in primary care has been unclear.

### The Evidence (Tables 67, 68, 69)

Twenty-seven trials evaluating newer agents involved 5,540 adult primary care patients. ^178,^ ^184,^ ^189,^ ^202,^ ^213,^ ^223,^ ^227,^ ^242,^ ^254,^ ^282,^ ^299,^ ^313,^ ^318,^ ^327,^ ^328,^ ^333,^ ^359,^ ^360,^ ^361,^ ^380,^ ^394,^ ^412,^ ^427,^ ^429,^ ^450,^ ^471,^ ^ 472 ^ Twenty-six trials were conducted in Europe and 1 in the United States. Of the 20 trials with an identified funding source, pharmaceutical companies sponsored all.

Table 67. Participants in 27 primary care trials

Number | Female | Average Age
5,540 | 71% | 45

Table 68. Depressive disorders studied in the trials

Major depression | 12
"Depression requiring treatment" | 4
Dysthymia | 2
Mixed anxiety depression | 3
"Depressive illness" | 4

Table 69. Designs of the trials

Double Blind | 6-8 Weeks | Dropouts <20%
24 | 22 | 12

All trials had recruitment and inclusion criteria that specified participants as patients of primary care providers or general practitioners. Few described the actual treatment environment or characteristics of providers that delivered treatment. Decisions regarding antidepressant management (initial dose, dosage changes, treatment discontinuation, or switches) generally followed set protocols except in the U.S. health maintenance organization trial where patients and their physicians made these decisions.^ 427 ^

Multiple newer agents including SSRIs, SNRIs, RIMAs, and DopAnts were evaluated. Most trials compared newer agents with first or second generation tricyclic agents. All but one trial used drug doses that were in usual dose ranges, though many were toward the lower range of standard doses.

Multiple depressive disorders were studied: major depression (n=12), "depression requiring treatment" as judged by the primary care provider (n=4), dysthymia (n=2), mixed anxiety depression (n=3), endogenous depression (1), and heterogeneous patient groups with depressive illness that included more than one disorder (n=4). Patients with alcohol abuse, cognitive impairment, and "serious" concomitant medical illnesses typically have been excluded. Exceptions were a large trial from a U.S. staff model health maintenance organization that did not exclude patients with concomitant medical illness and two small trials that specifically evaluated older frail patients with medical illness.^254,^ ^ 313 ^

All trials studied acute phase treatment. Treatment duration was typically 6 to 8 weeks (n=22), although three trials were 12 weeks and two were 20 to 24 weeks. Followup was generally conducted with outpatient visits, though the U.S. trial relied primarily on telephone followup assessments. Most trials did not clearly specify whether research assistants or primary care providers conducted followup assessments. Content of followup assessments appeared oriented primarily toward assessment of depressive symptoms using standardized rating scales. Whether general supportive measures and counseling occurred during followup visits was not specified.

Adherence to therapy generally was not measured except in the U.S. health maintenance organization trial. This trial reported numbers of patients completing telephone followups (91 percent) and percentages of patients who received at least 90 days of adequate treatment among those originally assigned to fluoxetine (61 percent), desipramine (49 percent), or imipramine (48 percent). Minimal "adequate treatment" doses were fluoxetine at 10 mg/d, desipramine 75 mg/d, and imipramine 74 mg/d.

Dropout rates in the trials were less than 20 percent (n=12), 20 to 30 percent (n=11), and more than 30 percent (n=3). Only four trials measured functional status or quality of life.

### The Findings (Figure 23)

Approximately 60 percent of the primary care participants who received newer antidepressants had at least a 50 percent improvement in symptoms as measured by a depressive symptoms rating scale (e.g., Hamilton Depression Rating Scale) or were much to very much improved as measured by a global assessment method (e.g., Clinical Global Impression Scale). Response rates did not vary significantly from newer agent to newer agent except for minaprine, where two studies showed lower response rates of approximately 34 percent. The average response rate for patients given placebo was 35 percent. The average response rate for patients given tricyclic agents was 60 percent. Newer antidepressant agents were significantly more effective than placebo (risk ratio 1.6, 95 percent CI 1.2 to 2.1) but similar to tricyclic agents (risk ratio 1.0, 95 percent CI 0.9 to 1.1) in efficacy. Risk ratios were virtually identical in modified intent-to-treat and endpoint analyses. Response rates appeared similar across depressive disorders.

Figure 23. Primary Care

*Response rates not given for (184, 227, 427, 282, 178)

Dropouts due to adverse effects occurred in 2 percent, 8 percent, and 13 percent of patients given placebo, newer agents, and tricyclic agents, respectively. Newer agents had significantly fewer dropouts from adverse effects than tricyclic agents (rate difference -0.04, 95 percent CI -0.07 to -0.00). There was some variability among newer agents with two venlafaxine (SNRI) studies showing higher (18 percent) dropout rates from adverse effects and one minaprine (Misc) study showing lower dropout rates of 2 percent.

In the 6-month U.S. health maintenance organization trial,^ 427 ^ patients assigned to fluoxetine (SSRI) reported fewer adverse events, were more likely to continue their original medication, and were more likely to reach "adequate" doses than those assigned to either desipramine (TCA2) or imipramine (TCA1). Depressive symptoms, quality of life, and total health care costs did not differ significantly between groups.

### Gaps in Evidence

Significant gaps in the literature on the primary care treatment of depression are as follows: few trials in U.S. general practice settings, few trials in patients without major depression, few trials with functional status or quality-of-life outcomes, no trials comparing newer pharmacotherapies with psychosocial therapies, no trials of relapse prevention, and few trials in patients with significant comorbid illness.

### Other Relevant Evidence

A recent evidence-based guideline also showed no major differences in efficacy between newer and older antidepressants in the primary care setting.^ 30 ^ Ongoing searches through August 1998 identified one additional trial. This double-blind multicenter trial in 400 patients with major depression compared sertaline (at 50 to 150 mg/d) with citalopram (at 20 to 60 mg/d). Approximately 75 percent of parTicipants completed the 24-week trial. No statistically significant differences in efficacy as measured by the Montgomery-Âsberg Depression Rating Scale scores were found.^ 731 ^

## Question 15. Are newer antidepressant agents more effective than placebo or older antidepressants in the postpartum setting?

Only one trial in the postpartum setting was identified. This question could not be answered definitively from existing data.

### Context

Depression occurring postpartum has been identified as a significant problem for both mothers and their babies. Because pregnant and lactating women have often been excluded from clinical trials, little is known about the safety and efficacy of antidepressant drugs in this population.

### The Evidence (Tables 70, 71, 72)

Only one trial in the postpartum setting was identified. ^ 176 ^ It was conducted in Great Britain. The funding source was not identified.

Table 70. Participants in one trial

Number | Female | Average Age
87 | 100% | 25

Table 71. Depressive disorders studied

Major or minor depression

Table 72. Designs of the two trials

Double Blind | Length | Percent Dropouts
Yes | 12 weeks | 26

Participating women were diagnosed with either major or minor depression 6 to 8 weeks after childbirth. It was not clear whether their depression had a postpartum onset. The women were randomized to one of four treatments: fluoxetine (SSRI) or placebo plus one or six sessions of cognitive behavioral therapy delivered by nonspecialists in mental health.

The trial examined acute phase treatment lasting 12 weeks. The participants had a 26 percent dropout rate.

### The Findings

Fluoxetine compared with placebo showed significant improvements in depressive symptoms as assessed by three different rating scales. Likewise, six sessions of counseling were superior to one in improving depressive symptoms. A synergistic interaction between fluoxetine and counseling was not apparent.

Thirty percent of the participants dropped out for unknown reasons (n=14), dislike of drug or adverse effects (n=9), or lack of improvement (n=3). The authors also noted that 101 of 188 recruited women with depression refused to participate in the trial because they were reluctant to take medication and they expected to improve without treatment.

### Gaps in Evidence

There are major gaps in knowledge about treatment of depression in the postpartum setting. They include no direct comparisons of newer agents with placebo, older agents, or psychosocial therapy. No trials involving pregnant women are available. The one trial conducted in the postpartum period did not report infant outcomes or general well-being and quality-of-life outcomes in mothers.

### Other Relevant Evidence

No other recent systematic reviews on the treatment of depression in the postpartum setting were found.

## Question 16. Are combinations of newer antidepressants with other antidepressants more efficacious than a single antidepressant for treating major depressive disorder in adults?

Data are insufficient to answer this question.

The ongoing search through August 1998 identified a single trial. This 6-week trial, involving 34 mostly hospitalized patients with major depression, compared the combination of fluoxetine at 20 mg/d (SSRI) plus mianserin (tetracyclic) at 30 mg/d with fluoxetine alone.^ 725 ^ The design was double blind; 12 subjects (34 percent) dropped out. The group assigned to combination therapy had significantly higher depression scores at baseline. The intention-to-treat analysis showed no statistically significant difference between the two treatment groups.

## Question 17. Are combinations of newer antidepressants with other antidepressants or anxiolytics more effective than a single antidepressant for specific disorders (e.g., mixed anxiety depression) and symptoms (e.g., insomnia)?

No trials addressing this question were found. There were also no trials that addressed the efficacy of combining either a tricyclic or an anxiolytic with a new agent specifically to counteract potential side effects of that agent.

## Question 18. Is the combination of newer antidepressant agents with psychosocial therapies better than newer antidepressants alone for treating or maintaining remission for depressive disorders in adults?

Although two studies were identified that used combinations of psychosocial therapies and newer antidepressants, they were compared with a combination of psychotherapy and placebo. Their results cannot be extrapolated to answer this question and leave many other questions unanswered.

### Context

Depressed patients often receive both antidepressants and psychosocial therapies in clinical practice. Although some feel that the two approaches are complementary and may be especially helpful for chronic cases of depression, others suggest that the two treatments may interfere with each other. For example, pharmacotherapy is seen by some as a superficial treatment that does not address the underlying cause of depression. Another concern is that early symptom relief by pharmacotherapy may lead to premature termination of psychotherapy. Others argue that psychotherapy counteracts the effect of pharmacotherapy by encouraging the patient to focus on upsetting issues. Pharmacotherapy may reduce symptoms more rapidly and psychotherapy may provide mood management skills that reduce likelihood of relapse or recurrence.

### The Evidence (Tables 73, 74, 75)

Only two trials involving 107 adults have evaluated combined treatments of newer antidepressants and psychosocial therapies to treat remission.^176,^ ^ 444 ^ One of the trials was conducted in the United States and the other in Great Britain. Only one trial identified a funding source (nonpharmaceutical).^ 444 ^

Table 73. Participants in two psychosocial trials

Number | Female | Average Age
107 | 81% | 27

Table 74. Depressive disorders studied in two trials

Heterogeneous | 2

Table 75. Designs of the two trials

Double Blind | 6-8 Weeks | Dropouts <20%
2 | 0 | 1

Both studies compared a combination of a psychosocial therapy and fluoxetine with combined psychosocial therapy and placebo. Neither study compared the combination treatment with a newer agent alone. The British trial involved 87 postpartum women with major or minor depressive disorder.^ 176 ^ Psychosocial therapy was individual counseling based on cognitive-behavioral therapy.^ 176 ^ Each session was structured to offer reassurance and advice. Therapists were general practitioners who were not mental health specialists. This trial had four arms and compared one versus six sessions of counseling.

The U.S. trial involved 20 HIV-positive men with either major depression or adjustment disorder with depressed mood.^ 444 ^ The psychosocial intervention involved a combination of elements from behavior therapy to problem-solving therapy. It was delivered as structured group therapy that emphasized active skills in coping. Sessions included relaxation training and problem-solving skills focused on specific HIV-related concerns. Therapists were psychiatric residents.

Both trials examined acute phase treatment lasting 12 weeks. Thirty percent of the postpartum women in the British trial dropped out; 10 percent of the HIV-positive men in the U.S. trial dropped out.

### The Findings

In the trial of 87 postpartum women, fluoxetine was significantly better than placebo in alleviating symptoms, and six sessions of counseling were significantly better than a single session. No significant interactions between drugs and counseling were seen. In the second trial of 20 HIV-positive men, fluoxetine plus psychotherapy was associated with similar improvements compared with psychotherapy alone.

### Gaps in Evidence

The lack of studies comparing combinations of newer agents and psychosocial therapy with monotherapy is problematic and leaves many questions unanswered. The two identified trials have methodologic problems and do not directly address whether combination therapy is superior to newer antidepressant therapy alone. One trial lacked adequate power to detect clinically significant differences between treatment groups and used relatively inexperienced therapists. Both trials were conducted in special populations that are not easily generalized to most patients with depression. No trials addressing combination therapy (newer pharmacotherapy plus psychosocial therapy) for maintenance or relapse prevention were found.

### Other Relevant Evidence

A few systematic reviews of the literature examining the efficacy of combined treatments suggest that combinations of psychotherapy and pharmacotherapy regimens are only slightly superior to either alone.^6,^ ^22,^ ^23,^ (See also the Cochrane Depression, Anxiety, and Neurosis Review Group's forthcoming systematic review of this literature.^ 41 ^ )

## Question 19. Are newer pharmacotherapies plus augmenting agents more effective than pharmacotherapy alone for treating adults with depressive disorders?

There is insufficient evidence to reliably establish whether augmenting agents significantly quicken response rates or improve response in adult patients with depression.

### Context

Augmenting agents such as pindolol and lithium are sometimes added to primary antidepressant medication. They are used for patients who fail to respond to initial treatment and to speed rate of response.

### The Evidence (Tables 76, 77, 78)

Five trials evaluating various augmentation strategies were found.^194,^ ^296,^ ^305,^ ^383,^ ^ 449 ^ They involved 347 patients. Four trials were conducted in Europe and one in the United States.

Table 76. Participants in the five augmentation trials

Number | Female | Average Age
347 | 71% | 45

Table 77. Depressive disorders studied in the trials

Major depression | 3
Resistant major depression | 2

Table 78. Designs of the trials

Double Blind | 6-8 Weeks | Dropouts <20%
5 | 5 | 2

Most participants in the trials had major depression. Almost all were recruited from outpatient mental health settings. Two trials specifically studied patients with resistant or refractory depression.^296,^ ^ 305 ^

Three trials compared the addition of pindolol with a serotonin reuptake inhibitor (SSRI) with the SSRI alone.^194,^ ^383,^ ^ 449 ^ One trial compared maprotiline (Tetra) plus lithium with brofaromine (RIMA) plus lithium.^ 653 ^ A four-arm trial compared the addition of lithium versus placebo in patients randomized to lofepramine (TCA) or fluoxetine (SSRI).^ 305 ^

All trials had treatment durations of 6 weeks. Dropout rates ranged from 19 percent to 35 percent.

### The Findings (Figure 24)

Pindolol plus an SSRI was associated with response rates of 43 percent to 75 percent compared with response rates of 55 percent to 65 percent with an SSRI alone. In this small set of trials, augmentation therapy was not significantly better than treatment with an SSRI alone. (risk ratio 1.0, 95 percent CI 0.7 to 1.4). Pindolol also was not consistently associated with more rapid time to response than SSRIs.

Figure 24. Augmenting Agents

No significant differences were found in the small trial of refractory depressed outpatients treated with brofaromine plus lithium versus maprotiline plus lithium. The small trial that added lithium for patients who had failed to respond to fluoxetine or lofepramine also showed no significant differences.

### Gaps in Evidence

Many more trials with augmenting agents are needed to determine whether recovery from a first episode of depression can be hastened and whether refractory or resistant depression can be treated successfully. The sustainability of any improvements will need to be established. Whether augmenting agents result in more adverse effects and greater numbers of dropouts than antidepressants agents alone also needs study.

### Other Relevant Evidence

An earlier meta-analysis of five small heterogeneous trials found that augmentation with lithium was superior to placebo.^ 511 ^ Most of the trials used older antidepressant agents and had significant methodologic problems; results were not consistent among the trials.

## Question 20. Are newer antidepressant agents more effective than placebo, older agents, or psychosocial therapies for maintaining remission in adults with depressive disorders?

For major depression, treatment with a newer agent maintains remission more effectively than placebo. The evidence is insufficient to determine if newer agents maintain remission more effectively than older agents or psychosocial therapies.

### Context

Because major depression has a high relapse rate, continued treatment is recommended beyond initial recovery. For treatments with established short-term efficacy, a critical test of overall efficacy is the ability to maintain remission long term.

### The Evidence: Randomized Discontinuation Trials (>Tables 79, 80, 81, 82)

The best information on long-term efficacy comes from trials that study patients who respond to initial treatment and who then are randomized to continued antidepressant treatment or placebo. If the antidepressant medication is effective long term, fewer patients on active treatment will relapse. Six studies using this design involving 910 adults with major depression compared citalopram (n=2), fluoxetine (n=2), paroxetine (n=1), or sertraline (n=1) with placebo.^206,^ ^241,^ ^261,^ ^356,^ ^358,^ ^ 407 ^ Of these, two studies did not report outcomes.^206,^ ^ 261 ^ Two additional studies involving 128 patients compared fluvoxamine with sertraline or lithium.^276,^ ^ 277 ^ All studies reporting outcomes were conducted in Europe, and the four with identified funding sources were sponsored by industry.

Table 79. Participants in eight maintenance trials

Number | Female | Average Age
1,038 | 75% | 49

Table 80. Settings

Mental Health | Primary Care | Mixed | Unknown
4 | 0 | 1 | 3

Table 81. Depressive disorders studied in the trials

DSM-IV major depression -- recurrent | 1
DSM-III-R major depression -- recurrent | 2
DSM-III-R major depression | 3
DSM-III major depression | 1
Unspecified major depression | 1

Table 82. Designs of the trials

Double Blind | Greater Than or Equal to 24 Weeks | Dropouts <20%
7 | 7 | 2

Patients were recruited from inpatient mental health settings (n=2), outpatient mental health (n=2), mixed mental health and primary care (n=1), and not described settings (n=3). In three studies, participants met criteria for recurrent major depression, placing them at higher risk for relapse.

All but one of the trials were double blind. Seven lasted at least 24 weeks with two lasting 2 years. Given the long-term followup, dropout rates were high. Dropout rates were lower than 20 percent (n=2), 20 to 30 percent (n=2), greater than 30 percent (n=1), and not given (n=3).

### The Findings: Randomized Discontinuation Trials

Ten percent of participants randomized to active treatment experienced a relapse within 24 weeks, defined by a greater than or equal to 50 percent increase in depressive symptoms on an interviewer-administered rating scale (e.g., Montgomery-Âsberg) or a clinical severity equal to 1 or 2 on the Clinical Global Rating Scale. Relapse rates for participants given placebo antidepressants were 35 percent. Newer antidepressants were significantly more effective in preventing relapse than placebo (risk ratio 0.3, 95 percent CI 0.2 to 0.5). For the two placebo-controlled studies with longer followup, the advantage of antidepressant drug versus placebo was maintained at 44 and 52 weeks.

In a study of patients who had maintained recovery for 4 months prior to randomization, two SSRIs, fluvoxamine at 200 to 300 mg/d and sertraline at 100 to 200 mg/d, showed equal effectiveness. No patient had relapsed at week 24; at 104 weeks 7/32 (22 percent) sertraline patients and 6/32 (19 percent) fluvoxamine patients had relapsed (risk ratio 0.86, 95 percent CI 0.5 to 1.4). In the single study comparing fluvoxamine at 200 mg/d with lithium at 600 to 900 mg/d, fluvoxamine was more effective at preventing relapse during the 2-year followup (13 percent versus 25 percent; risk ratio 0.5, 95 percent CI 0.3 to 0.9).

The optimal dose for continuation and maintenance phase treatments is important. Among the placebo-controlled trials, three of the four studies reporting outcomes continued treatment at or above the dose to which the patient had initially responded. The one study continuing treatment at a lower dose had a higher, though not significantly different, relapse rate.

### Gaps in Evidence

Efficacy for continuation phase treatment for up to 6 months has been shown for three SSRI antidepressants but not for other newer antidepressants. There is little information addressing the efficacy of newer pharmacotherapies for long-term maintenance phase treatment beyond 6 months. There are no studies comparing newer antidepressants with older agents or with psychosocial therapies.

### Other Relevant Evidence

None was identified.

## Question 21. What common adverse effects of newer antidepressant agents have been identified in randomized controlled trials and does their frequency vary significantly from one agent to another?

Because of missing data and heterogeneity in methods for assessing adverse events and feasibility, only comparisons between selective serotonin reuptake inhibitors and first generation tricyclic antidepressants were analyzed. Administration of tricyclics resulted in significantly higher rates of blurred vision, constipation, dizziness, dry mouth, and tremors. Selective serotonin reuptake inhibitors had significantly higher rates of diarrhea, headache, insomnia, and nausea. Data were inadequate to determine differences in sexual dysfunction.

### Context

Selections of particular antidepressant agents are often made based on anticipated tolerability and adverse effects.

### The Evidence

Adverse events were assessed and reported in multiple ways. Assessment methods included checklists, scales, spontaneous reporting, and chart review. Few trials differentiated emergent from preexisting symptoms. Trials presented results in different ways: total number of symptoms, numbers of patients experiencing specific symptoms, and only symptoms occurring over a specified frequency; all assessed symptoms regardless of frequency.

For feasibility reasons, we limited quantitative analysis of adverse events to 11 symptoms that were commonly reported. These commonly reported symptoms had been previously identified in another meta-analysis comparing SSRIs and TCAs.^ 28 ^ Only studies that gave the number of patients who reported these specific symptoms were included. Comparisons were limited to studies that were 12 weeks or shorter because there were few longer studies and longer studies had higher total dropout rates and less reliable reporting of adverse events. This meant that adverse events occurring late in therapy were not assessed. Quantitative comparisons were limited to examples where relevant data from 10 or more trials were available. As shown in Table 83, only selective serotonin reuptake inhibitors (SSRIs) versus first generation tricyclic antidepressants (TCA1) met this latter criteria.

Table 83. Trials reporting numbers of patients who experienced the common adverse events of interest

Drug Class Comparison | Numbers of Trials
RIMA vs. SSRI | 3
RIMA vs. 1^st^ TCA | 6
SNRI vs. 1^st^ TCA | 5
SSRI vs. SSRI | 5
SSRI vs. 1^st^ TCA | 31
SSRI vs. 2^nd^ TCA | 3
SSRI vs. Tetra | 4

Fewer than 10 percent of the trials explicitly reported suicide attempts and suicides. In all, 19 suicide attempts and 15 suicides were described in the 315 trials involving over 40,000 participants. Because of small numbers, these events were not compared between different classes. More information on suicide risk that was abstracted from literature other than randomized controlled trials is provided in the section addressing serious adverse events.

Though sexual dysfunction has been noted as an important side effect of antidepressant agents, such effects were reported in only 11 percent of the trials. The 34 trials assessed and reported sexual dysfunction in various ways including nonspecific sexual complaints, ejaculatory abnormality, decreased libido, male impotence, erectile dysfunction, and anorgasmia. Only six trials gave information by gender. Sexual dysfunction was reported with 14 different drugs across seven antidepressant classes. Moreover, data were insufficient to estimate incidence rates of types of sexual dysfunction and whether symptoms vary by agent.

### The Findings

Detailed results are given in Appendix 6; a summary is presented in Table 84 below. Blurred vision, constipation, dizziness, dry mouth, tremors, and urinary disturbance occurred significantly more often with first generation TCAs than with SSRIs. In particular, constipation and dry mouth were reported by 21 percent and 48 percent, respectively, of participants given first generation tricyclics. Diarrhea, headache, insomnia, and nausea occurred significantly more often with SSRIs than with first generation TCAs. Each of these symptoms was reported by approximately 10 percent of the participants given SSRIs, except for nausea that was reported by 19 percent of such participants. There were no significant differences in the rates of anxiety between SSRIs and first generation TCAs.

Table 84. Pooled rates and rate differences comparing SSRIs and first generation TCAs for common adverse events

Adverse Event | SSRI Rate | TCA Rate | Rate Diff.^a^ | 95% CI
Anxiety | 11% | 9% | 2% | -0.02 to 0.06
Blurred vision | 6% | 10% | -4% | -0.05 to -0.01
Constipation | 8% | 21% | -12% | -0.14 to -0.07
Diarrhea | 12% | 3% | 10% | 0.53 to 0.13
Dizziness | 8% | 19% | -11% | - 0.13 to -0.06
Dry mouth | 18% | 48% | -30% | - 0.33 to -0.23
Headache | 15% | 11% | 3% | 0.002 to 0.04
Insomnia | 13% | 6% | 7% | 0.32 to 0.08
Nausea | 19% | 9% | 10% | 0.06 to 0.11
Tremors | 7% | 11% | -4% | - 0.05 to -0.01
Urinary disturbance | 3% | 8% | -5% | - 0.08 to -0.01

a As the rate difference is a weighted pooled estimate, it is not exactly equivalent to the difference between the two pooled rates.

### Gaps in Evidence

Available randomized controlled trials provide a very limited view of adverse events associated with antidepressant use. Trials both assess and report adverse events in many inconsistent ways. Some adverse effects such as sexual dysfunction are uncommonly assessed. Trials are too short to assess long-term adverse effects. They are too small to assess uncommon but serious adverse effects.

### Other Relevant Evidence

A recent meta-analysis of 162 trials compared adverse events between SSRIs and TCAs.^ 28 ^ Findings were similar to those given above, except anxiety was more common with SSRIs than TCAs.

## Question 22. Do trials show varying adherence rates among newer antidepressant agents and between newer agents and older ones?

As fewer than 5 percent of studies reported adherence information, trial data are inadequate to show whether adherence rates vary between agents.

## Question 23. Do trials show varying rates between total dropouts, dropouts for adverse events, and dropouts for lack of efficacy?

There are no significant differences between newer and older antidepressants in overall discontinuation or dropout rates. First generation tricyclic antidepressants have significantly higher rates of dropouts due to adverse events than reversible inhibitors of monoamine oxidase A and selective serotonin reuptake inhibitors. Reversible inhibitors of monoamine oxidase A inhibitors have higher rates of dropouts due to lack of efficacy than first generation tricyclic agents.

### Context

Antidepressant treatment is not always successful. Patients sometimes discontinue or drop out of treatment because of side effects or because their depressive symptoms do not improve or even worsen. Data from short-term efficacy trials may help estimate such discontinuation rates but should be generalized cautiously to real practice settings.

### The Evidence

Eighty-seven percent of the trials reported data about numbers of trial participants who discontinued treatment or dropped out. Information was usually given for total numbers of dropouts as well as for numbers dropping out due to lack of efficacy and adverse effects. Other reasons for dropouts were usually not explained.

Comparisons were limited to studies that used standard drug dosages and that were 12 weeks or shorter. For precision and feasibility reasons, quantitative analyses were limited to drug class comparisons that had dropout data from 10 or more trials. Table 85 shows the four drug class comparisons that met these criteria.

Table 85. Numbers of trials meeting analysis restrictions that reported dropout information

| Numbers of Trials
Drug Class Comparison | Adverse Events | Lack of Efficacy | Total Dropouts
RIMA vs. TCA1 | 22 | 21 | 22
SSRI vs. TCA1 | 66 | 58 | 68
SSRI vs. TCA2 | 10 | - | 10
SSRI vs. Tetra | 13 | 11 | 15

### The Findings

Detailed analyses are given in Appendix 7; summaries of results are presented in Tables 86, 87, 88. Only two of the drug class comparisons had statistically significant different rates of dropouts due to adverse events. In 22 trials, 11 percent of patients given first generation tricyclic agents (TCA1) dropped out compared with 5 percent of those given reversible inhibitors of monoamine oxidase A (RIMA). In 66 trials, dropout rates due to adverse events were higher with first generation TCAs than selective serotonin reuptake inhibitors (16 percent versus 11 percent). Dropout comparisons were the same for trials regardless of length of followup (6 to 8 weeks versus 10 to 12 weeks).

Table 86. Dropout rates due to adverse events^a^

Class/Rate | Class/Rate | Diff. | CI
RIMA/5% | TCA1/11% | -5% | -0.07 to -0.03
SSRI/11% | TCA1/16% | -4% | -0.06 to -0.02
SSRI/7% | TCA2/13% | -6% | -0.12 to 0.01
SSRI/6% | Tetra/9% | -2% | -0.05 to 0.01

a Since the rate difference is a weighted pooled estimate, it is not exactly equivalent to the difference between the two pooled rates.

Table 87. Dropout rates due to lack of efficacy^a^

Class/Rate | Class/Rate | Diff. | CI
RIMA/10% | TCA1/6% | 3% | 0.01 to 0.04
SSRI/7% | TCA1/6% | 1% | 0.00 to 0.02
SSRI/5% | TCA2/4% | - | -
SSRI/4% | Tetra/4% | -0% | -0.03 to 0.02

a Since the rate difference is a weighted pooled estimate, it is not exactly quivalent to the difference between the two pooled rates.

Table 88. Total dropout rates and rate differences^a^

Class/Rate | Class/Rate | Diff. | CI
RIMA/26% | TCA1/27% | -1% | -0.05 to 0.02
SSRI/29% | TCA1/32% | -3% | -0.06 to 0.00
SSRI/16% | TCA2/24% | -7% | -0.16 to 0.02
SSRI/19% | Tetra/23% | -2% | -0.05 to 0.02

a Since the rate difference is a weighted pooled estimate, it is not exactly quivalent to the difference between the two pooled rates.

Only one of the drug class comparisons had statistically significant differences in dropout rates due to lack of efficacy. RIMAs had a 10 percent dropout rate due to lack of efficacy compared to with6 percent dropout rate for first generation tricyclics in 21 trials.

Total dropout rates ranged from 16 percent to 32 percent. There were no statistically significant differences in any of the four drug class comparisons in total dropout rates.

### Gaps in Evidence

Gaps in the evidence include the following: not enough trials to reliably estimate dropouts in most of the drug class comparisons, incomplete reporting regarding reasons for dropouts, and little information about dropouts in patients taking therapy for longer than 12 weeks.

### Other Relevant Evidence

Other meta-analyses have compared discontinuation rates of SSRIs with those of TCAs and related agents.^29,^ ^66,^ ^ 70 ^ The results have generally indicated that dropouts due to adverse effects are lower with SSRIs than with first generation tricyclics.

## Question 24. What uncommon but serious adverse effects of newer agents have been reported, and what is their frequency?

Nine uncommon (<1 percent) but serious adverse effects were definitely associated with the selective serotonin reuptake inhibitors. They were bradycardia, bleeding, granulocytopenia, seizures, hyponatremia, hepatotoxicity, serotonin syndrome, extrapyramidal effects, and mania in unipolar depression. Bupropion was associated with seizures. Hypericum (St. John's wort) was not associated with serious adverse effects.

### Context

There are at least three reasons that published rates of adverse effects of newer agents may underestimate the true rates that will be seen in practice. First, most of the data are from premarketing studies performed by pharmaceutical companies in carefully controlled research settings. When used in routine community practice settings, drugs may produce adverse effects more commonly. For example, no cases of serotonin syndrome occurred in 3,082 patients in premarketing trials of venlafaxine.^ 512 ^ However, several cases were reported after marketing.^ 513 ^ The reasons for this may be several, including the greater numbers of patients exposed, the more likely it is that uncommon side effects will become known. Also, community physicians may be treating patients with more complex illnesses who have greater risk of adverse effects. Alternatively, practitioners may use the drugs for more indications, or they may not withhold the drugs from certain high-risk subgroups, which may lead to higher overall rates of adverse effects. For instance, Feighner and coauthors reported that the serotonin syndrome occurred in 75 percent of patients already taking a monoamine oxidase inhibitor (MAOI) when started on fluoxetine;^ 514 ^ this combination of drugs is now considered contraindicated.

Second, adverse effects of newer drugs may be underreported, leading to underestimation of the true frequency. In the premarketing period, serious adverse effects must be reported to the FDA, and although the FDA may require that the adverse effect be added to the drug's labeling, the case and its details may never be published. In the postmarketing period, clinicians may not report every adverse effect they encounter. Studies have estimated that practitioners report to regulators approximately one serious adverse effect for every 100^ 515 ^ to 4,600^ 516 ^ that they see. An even smaller proportion of the less serious adverse events that clinicians find in practice are reported.^ 517 ^

Thirdly, many of the published reports of premarketing trials do not describe study methods and results in detail. This lack of detail hinders the assessment of methodologic strengths and avoidance of bias, which in turn limits confidence in estimates of adverse effects.

### Evidence about Uncommon but Serious Adverse Effects

This section addresses the following serious adverse effects: suicidality, complications of pregnancy, seizures, extrapyramidal effects, hyponatremia and the syndrome of inappropriate antidiuretic hormone secretion (SIADH), serotonin syndrome, immunologic and allergic effects, psychiatric and cognitive effects, cardiac dysrhythmias, drug interactions, hematologic effects, and a few additional isolated reports of even rarer effects. Results are presented only for agents approved by the Food and Drug Administration by January 1998 (several SSRIs, venlafaxine, bupropion) and hypericum (St. John's wort). There were 727 studies that were original reports of serious adverse effects; 63 were cohort studies or trials that quantified rates or rate differences. Detailed results of the 63 controlled studies are presented in Appendix 5.

The evidence of association between newer approved drugs and serious adverse effects is presented, starting with the more methodologically rigorous evidence from controlled studies and proceeding through case series and individual case reports. Reported associations cannot be automatically assumed to mean that the drug causes the adverse effect -- chance, coincidence, or confounding explanations are possible. When published case reports are examined carefully, 20 percent to 45 percent have been classified as showing "probable" causation and 50 percent to 75 percent as "possible"' causation.^ 518 ^ Alternative causes are well excluded in less than 20 percent of reports.^ 517 ^

In the absence of information from controlled studies, the number of cases reporting an association between a drug and an adverse effect may be of some use in judging causation. For instance, for rare conditions such as agranulocytosis, which occurs spontaneously at a rate of 6 per million people per year, even a single report of association with a new drug suggests that the association is unlikely to be due to chance alone. The more commonly a condition occurs spontaneously, the more case reports would be needed before chance association is unlikely. For instance, liver injury occurs spontaneously in about 24 per 100,000 people, so that at least 3 case reports of its occurring with a new drug would be needed before chance association would be unlikely.^ 519 ^ To help the reader use this perspective in making decisions about causation, numbers of cases that have been reported for particular putative adverse effects are given.

Of note, uncommon but serious adverse effects from SSRIs have been studied in detail, whereas only one pharmaceutically sponsored meta-analysis has studied venlafaxine and only one cohort of 3,250 patients has systematically sought adverse effects from St. John's wort.^ 520 ^ Although 1.5 percent of the cohort stopped taking St. John's wort because of adverse effects, none of the adverse effects was severe.

### The Findings Regarding Uncommon, but Serious, Adverse Events

Table 89 presents data on uncommon but serious adverse effects that have been definitively associated with newer antidepressants. Tables 90, 91, 92 present data on uncommon but serious adverse effects that have either not been associated with newer antidepressants or have been inadequately studied. The tables are followed by a more detailed narrative regarding findings for specific adverse effects.

Table 90. Equivocal uncommon but serious adverse effects

Adverse Effect | Drug(s) | Magnitude of Effect | Level of Evidence^a^
Spontaneous abortions | SSRIs | <6% | Trends in small controlled studies
Fetal malformations | SSRIs | <4% | Trends in small controlled studies
Fetal prematurity | SSRIs | <8% | Trend in one small controlled study
Mania in unipolar depression (as compared with tricyclic antidepressants) | SSRIs | <1% | Trends in meta-analyses
Hyponatremia/SIADH | Bupropion | Unknown | Case reports
Extrapyramidal effects | Bupropion | Unknown | Case report
Pulmonary fibrosis | SSRIs | Unknown | Case reports
Tardive dyskinesia | SSRIs | Unknown | Case reports
Parkinsonism | Bupropion | Unknown | Case report

a Trends in controlled studies were defined as increased rates compared with controls that were not statistically significant at the p<0.05 level.

Table 91. Uncommon but serious adverse effects not related to SSRIs

Adverse Effect | Drug(s) | Level of Evidence
Suicidal acts and ideation | SSRIs, bupropion | Controlled studies
Mania in bipolar depression | SSRIs | Controlled studies

Table 92. Uncommon but serious adverse effects insufficiently studied

Adverse Effect | Drug(s)
Fetal effects | Bupropion

Table 89. Definite uncommon but serious adverse effects of newer antidepressants

Adverse Effect | Drug(s) | Magnitude of effect | Level of Evidence
Seizures | SSRIs, Bupropion | <0.05 to 0.26% | Trends and dose response relationships in controlled studies
Hyponatremia/SIADH | SSRIs | <1% | One case control study, systematic review of case reports with resolution on withdrawal and rechallenge recurrence
Serotonin syndrome | SSRIs (combined with other serotoninergic or during overdose) | Case reports with resolution on withdrawal
Extrapyramidal effects: Dystonias Parkinsonism Akathisia | SSRIs | 0.4 to 13% depending on underlying risk factors. | Case reports with resolution on withdrawal
Mania in unipolar depression (as compared with placebo) | SSRIs | <1% | Significant meta- analyses
Bradycardia | SSRIs | Unknown | Case reports with one report of recurrence on rechallenge
Bleeding | SSRIs | <0.73% | Controlled study, case report with recurrence on rechallenge
Granulocytopenia | SSRIs | Unknown | Case report with positive withdrawal and rechallenge
Hepatotoxicity | SSRIs | Unknown | Case reports with resolution on withdrawal

### The Findings for Specific Adverse Effects

#### Cardiac dysrhythmias

Case reports suggest SSRIs and venlafaxine may rarely cause dysrhythmias. These may occur as drug interactions or with overdoses.

We found no controlled studies of the incidence of cardiac dysrhythmias with SSRIs, venlafaxine, bupropion, or St. John's wort. We located 12 reports of bradycardia occurring with SSRI therapy, sometimes due to interactions with antihypertensive drugs.^521, 522, 523,524^ Of these 12 cases, some occurred with syncope^523,^ ^525,^ ^ 526 ^ or atrial fibrillation,^ 527 ^ and one had a positive rechallenge test.^ 527 ^ SSRIs have also been associated with supraventricular dysrhythmias, including supraventricular tachycardia,^ 528 ^ and polymorphic ventricular tachycardia ("torsades de pointes").^ 529 ^ Also, after overdoses of SSRIs combined with other drugs, atrial flutter^ 530 ^ and ventricular tachycardia^ 531 ^ have occurred.

Fluoxetine therapy has been significantly associated with hospitalization in 11 of 588 cases of syncope,^ 532 ^ and although not proved, a cardiac dysrhythmia might have contributed to these cases. Alternatively, syncope from SSRIs might be neurally mediated.^ 533 ^ Sudden death has also been reported in three medically ill inpatients after fluoxetine therapy was initiated.^ 534 ^ Sertraline has been associated with falls by inpatients, and recently SSRIs have been associated with hip fractures in older persons;^ 535 ^ both of these associations might occur via the mechanism of cardiac dysrhythmia.

#### Drug-drug interactions

The most important drugs causing interactions from SSRIs and venlafaxine are with tricylic antidepressants, monoamine oxidase inhibitors, lithium, neuroleptics, anticonvulsants, and warfarin. Fewer drug interactions are known for bupropion.

The drug manufacturers have summarized the reports of drug-drug interactions for fluvoxamine^ 521 ^ and paroxetine.^ 536 ^ The most serious drug interactions are those that lead to the potentially fatal reactions, such as the serotonin syndrome (see below). This syndrome has occurred when SSRIs have been used with monoamine oxidase inhibitors.^518,^ ^ 537 ^ Because of permanent enzyme inhibition by monoamine oxidase inhibitors and the long half-life of fluoxetine, the serotonin syndrome has occurred, even when fluoxetine was started over 2 weeks after a monoamine oxidase inhibitor was stopped^538,^ ^ 539 ^ or when a monoamine oxidase inhibitor was used 4 weeks after fluoxetine was discontinued.^ 518 ^

Unfortunately, many of the reported adverse drug interactions are with combinations of agents that might be used in psychiatric patients. These combinations include the use of an SSRI with a second SSRI,^540,^ ^ 541 ^ lithium,^542, 543, 544, 545, 546, 547^ tricyclic antidepressant,^548,^ ^ 549 ^ trazodone,^550,^ ^ 551 ^ buspirone,^ 552 ^ or L-tryptophan.^521,^ ^ 553 ^ Additional reports include using an SSRI with sumatriptan,^ 554 ^ tramadol,^555,^ ^ 556 ^ and local anesthesia.^ 557 ^ Richard reported that serotonin syndrome occurred in 0.24 percent of patients with Parkinson's disease who were also treated with selegiline.^ 558 ^ Lastly, a case of serotonin syndrome has been reported to occur with paroxetine and nonprescription cold medicine (Nyquil®).^ 559 ^

Other potentially serious interactions have been reported. Fluoxetine and fluvoxamine have been associated with bleeding, including a fatal cerebral hemorrhage,^ 560 ^ when used with warfarin and related anticoagulants.^521,^ ^561, 562, 563, 564^ Extrapyramidal effects have been reported when an SSRI has been used with metoclopramide,^ 565 ^ cimetidine,^ 566 ^ trazodone,^ 567 ^ or risperidone.^ 568 ^

SSRI use can lead to toxic levels of drugs with competing metabolism. The most common interaction is with tricyclic antidepressants,^521,^ ^569,^ ^ 570 ^ which may be fatal.^ 571 ^ Similar interactions have occurred with carbamazipine,^521,^ ^ 572 ^ clozapine,^ 521 ^ diazepam,^ 560 ^ lithium,^ 573 ^ methadone,^ 521 ^ perhexiline,^ 574 ^ phenytoin,^575, 576, 577^ or theophylline.^521,^ ^578,^ ^ 579 ^

In addition to drug interactions already mentioned, others of varying severity include benztropine^ 580 ^ or clarithromycin,^ 581 ^ chloral hydrate,^ 582 ^ cyclosporin,^ 583 ^ itraconazole,^ 584 ^ lamotrigine,^ 531 ^ ethylphenidate,^ 585 ^ simvastatin,^ 586 ^ and zolpidem.^ 587 ^ Interactions have also occurred with various antipsychotics, such as clozapine,^ 588 ^ flupenthixol,^ 589 ^ levomepromazine,^ 590 ^ haloperidol,^ 591 ^ molindone,^ 592 ^ nifedipine,^ 593 ^ pimozide,^594,^ ^595,^ ^596,^ ^ 597 ^ and antihistamines such as cyproheptadine^ 598 ^ or terfenadine.^ 599 ^ Lastly, even acetominophen has been associated with fulminant hepatitis in a cirrhotic patient taking fluoxetine.^ 600 ^

Bupropion has been reported to interact with anticonvulsants^ 601 ^ and imipramine.^ 602 ^ Bupropion has been reported to case panic attacks when used with paroxetine.^ 603 ^

#### Extrapyramidal effects

Many extrapyramidal effects have been reported with newer antidepressants. Although the rates have not been compared with those of controls, rates appear higher in older patients, especially in older persons with preexisting parkinsonism. Irreversible tardive dyskinesia has been reported, but insufficient published details preclude stating whether this effect happens with SSRI monotherapy.

For this report, we grouped serious, drug-induced extrapyramidal effects into the dystonias, akathisia, parkinsonism, and tardive dyskinesia.^ 566 ^ We found no controlled studies comparing the rates of these events between patients on SSRIs and placebo. In a pharmaceutical clinical trials registry, when compared with those on tricyclic antidepressants, patients on fluoxetine showed a statistically insignificant trend toward less ataxia.^ 604 ^ In an uncontrolled study of patients in a postmarketing surveillance database, extrapyramidal effects occurred in 7 patients (an estimated 0.01 percent of more than 5,000 patients).^ 605 ^ In other uncontrolled studies, 4.5 percent of 67 patients using paroxetine had akathisia,^ 606 ^ and 6 percent of 67 older psychiatric inpatients developed mild parkinsonism on various SSRIs.^ 607 ^ Lastly, 13 percent of outpatients with preexisting Parkinson's had mild worsening when started on fluoxetine.^ 608 ^

Tardive dyskinesia, a potentially permanent extrapyramidal effect even after drug withdrawal, has also been reported with SSRI use. Leo found 76 cases of tardive dyskinesia on file with the manufacturer and 8 published case reports.^ 566 ^ Details are not available about the unpublished cases. Only three of the eight published cases resolved with discontinuation of the drug. It is unclear whether tardive dyskinesia has occurred with SSRI monotherapy.

There is one case report of parkinsonism in a patient receiving bupropion. This patient had liver failure that may have increased his blood levels of bupropion.^ 609 ^

#### Hematologic effects

SSRIs are rarely reported to affect coagulation, especially in interactions with anticoagulants. SSRIs are rarely associated with granulocytopenia.

The use of SSRIs has been associated with excess bleeding. In a controlled cohort study, patients taking fluoxetine had a 0.73 percent increased risk of bleeding compared with placebo.^ 610 ^ Uncontrolled cohort study estimated the increased risk of bleeding on SSRIs to be 0.04 percent^ 611 ^ to 0.7 percent.^ 610 ^ In addition, there are case reports of bruising,^612,^ ^ 613 ^ menorrhagia,^ 614 ^ and intraocular,^ 615 ^ retroperitoneal,^ 561 ^ or gastrointestinal bleeding.^611,^ ^ 616 ^ The increased bleeding is hypothesized to be an capillary fragility^ 614 ^ or blockade of 5-hydroxytryptamine uptake in the platelets^612,^ ^ 613 ^ or drug interaction when given with coumadin.^ 561 ^ A bleeding episode has been reported during SSRI monotherapy, and it recurred with rechallenge.^ 614 ^ There are rare case reports of granulocytopenia occurring with SSRIs granulocytopenia^521,^ ^617, 618, 619^ (with a positive rechallenge).^ 620 ^

The use of SSRIs has also been associated with unexplained thrombosis. Two patients developed deep vein thrombosis while on paroxetine.^ 621 ^ Since both of these patients were also taking zotepine, this association with SSRI use has not been proved causal.

We found no reports of hematologic effects of bupropion or of St. John's wort.

#### Hyponatremia and the syndrome of inappropriate antidiuretic hormone secretion

Hyponatremia is significantly associated with SSRI use and may occur in 0.12 percent of patients. It may be more common in older women. Hyponatremia has been reported in one patient taking bupropion.

The use of SSRIs has been associated with the development of hyponatremia, presumed due to SIADH. In the New Zealand Intensive Medicines Monitoring Program, seven cases of hyponatremia during fluoxetine use have been identified, all in older women.^ 622 ^ Given the size of the population covered in that program, those authors estimated the occurrence to be 0.12 percent of patients overall, although the cases only occurred in older women. In a case control study of psychiatric inpatients, Siegler et al. found the odds of fluoxetine use were 21.4 times (CI 5.3 to 86.8) that of control patients with normal sodium levels.^ 623 ^ Liu carefully reviewed 736 cases of hyponatremia from SIADH with SSRI use, gathered from published reports and multiple postmarketing surveillance databases (of note, only 30 of these cases were published).^ 513 ^ The majority (60 percent) were women, age 47 to 94. In all cases, hyponatremia resolved with discontinuation of the SSRI. Five of these cases underwent rechallenge with an SSRI; hyponatremia recurred in three. Lastly, Liu assessed causality in each report with the Naranjo scale,^ 624 ^ finding causality was definite in 10 percent, probable in 30 percent, and possible in 60 percent of cases. Although we found no controlled studies associating hyponatremia with bupropion use, we did find one case report.^ 625 ^

#### Immunologic and/or allergic effects

Various immunologic reactions rarely occur with SSRIs and bupropion. Based on data from large cohorts, these reactions occur in less than 0.1 percent of patients.

We located 12 reports of immunologically mediated events associated with SSRI use. Angioedema and tongue swelling have occurred with paroxetine.^ 626 ^ Angioedema with erythema multiforme has occurred when sertraline was given with indapamide.^ 627 ^ Another patient had flu-like symptoms, urticaria, and angioedema 2 days after a fluoxetine overdose.^ 628 ^ In addition, erythema multiforme has been reported with fluvoxamine use,^ 604 ^ and Stevens-Johnson syndrome has been reported with fluoxetine.^ 629 ^ Also, a case of erythema nodosum occurred in the meta-analysis of 4,126 patients treated with paroxetine.^ 536 ^ Other reports are of individual cases where SSRI use is associated with hypersensitivity reaction,^ 630 ^ serum sickness,^ 631 ^ and toxic epidermal necrolysis.^ 632 ^

One case of hypersensitivity (fever, rash, increased liver function tests) occurred in 3,279 patients treated with bupropion.^ 633 ^ One-half percent of patients taking St. John's wort have had allergic reactions attributed to this agent.^ 515 ^

#### Pregnancy and fetal complications

Whether increased rates of spontaneous abortions, prematurity, fetal malformations, and the need for special care nursery care occur from exposure to SSRIs during pregnancy is unclear. There is no information about pregnancy complications related to venlafaxine, bupropion, or hypericum.

We found eight studies examining the association between SSRIs and either adverse effects on pregnancy or adverse effects on fetal development. Of these, six were controlled studies. Three compared SSRIs versus agents known to be nonteratogens in regard to the association of first trimester exposure and spontaneous abortion.^634, 635, 636^ Two of these suggested a nonsignificant trend toward increased spontaneous abortions. The other reported a decreased risk of spontaneous abortion in pregnant women taking SSRIs; however, the control group consisted of women who had taken SSRIs prior to their last menstrual period.^ 636 ^ Since fluoxetine and its active metabolites have long half-lives, some of the control patients may have had significant blood levels. Pooling the results of the first two studies showed that SSRIs did not significantly increase the rate of spontaneous abortions (risk ratio 2.44 percent; 95 percent CI 1.16 to 6.05).

We located two controlled studies that examined the association between SSRIs and fetal malformations.^634,^ ^ 635 ^ Both studies reported insignificant associations. The pooled rate difference was 1.13 percent (95 percent CI 1.81 to 4.08).

In regard to prematurity, one controlled study reported an increase of 2.42 percent (95 percent CI 2.79 to 7.64) in women administered fluoxetine.^ 635 ^ The manufacturers of fluoxetine report a rate of 6.0 percent, which is 2.9 percent higher than their own report of the rate of prematurity in the general population.^ 637 ^ Chambers et al. reported a statistically significant increase in the need for special care nursery among infants exposed to fluoxetine during the third trimester.^ 635 ^

We found no controlled studies examining an association between bupropion use and abnormalities of fetal development.

#### Psychiatric and cognitive effects (other than suicide)

In unipolar depression, SSRIs tend to be associated with more mania than does placebo but similar to other antidepressants. In bipolar patients, SSRIs may protect against mania. Other psychiatric effects may occur more rarely.

In patients with exclusively or predominantly unipolar depression, two meta-analyses, which probably include some overlapping patients, both show a statistically significant increase in the emergence of mania as compared with placebo.^638,^ ^ 639 ^ As compared with tricyclic antidepressants in these patients, SSRIs show an insignificant trend of less than 0.2 percent more mania in two^638,^ ^ 639 ^ of three^ 536 ^ cohorts. These same two meta-analyses have associated SSRI with an increase in the emergence of mania, as compared with placebo, by 0.35 percent^ 639 ^ to 0.51 percent.^ 638 ^ In bipolar patients, again examining overlapping meta-analyses, SSRI use is consistently reported to cause less mania than did placebo or tricyclics. In the case of paroxetine, there was a statistically significant decrease in mania by 8.98 percent.^ 536 ^ Mania is reported in 0.5 percent of patients with unipolar depression treated with venlafaxine.^ 516 ^

Patients taking fluoxetine have not been found to have a statistically significant increase in violent or aggressive behaviors compared with patients on placebo, in three controlled studies.^639,^ ^640,^ ^ 641 ^ As compared with placebo, differences in the rate of aggression range from 0.50 to 0.34 percent.

Psychosis has developed in depressed patients taking SSRIs, occurring in 0.49 percent^ 639 ^ to 0.65 percent^ 604 ^ of patients. In one of these studies, this event rate was higher by 0.31 percent than the rate in placebo patients, but this difference did not reach statistical significance. Similarly, depressed patients taking SSRIs have occasionally developed acute confusion, occurring in 0.64 percent^ 642 ^ to 1.50 percent^ 643 ^ of patients. When compared with the rate in patients on tricyclic agents, this rate was slightly, but insignificantly, lower. We found no reports comparing SSRIs with placebo in regard to rates of acute confusion. Individual case reports have associated SSRI use with hallucinations when these drugs have been combined with dextromethorphan^ 644 ^ and amphetamine.^ 645 ^

We found fewer reports of adverse psychiatric or cognitive effects of bupropion use. In a controlled study, hallucinations occurred at similar rates in patients on bupropion compared with patients on placebo.^ 633 ^ In this study, three patients suffered psychosis and two developed mania. We found another report of a possible case of mania during bupropion therapy,^ 646 ^ as well as a report of three cases of hallucinations with bupropion therapy.^ 582 ^

#### Seizures

Seizures appear to occur with the newer antidepressants at a rate similar to that with tricyclic antidepressants.

Several cohort studies and reviews have examined the association between SSRI use and the occurrence of seizures.^516,^ ^536,^ ^611,^ ^638,^ ^ 647 ^ Unfortunately, all compare the rates of seizures in patients on SSRIs with the rates in patients on tricyclic antidepressants, which are known proconvulsants, rather than with placebo. Seizure rates on SSRIs have been found to range from 0.05 percent with fluvoxamine^ 647 ^ to 0.26 percent with venlafaxine.^ 516 ^ Case reports and case series describe seizures during overdoses with SSRIs,^ 648 ^ during cotreatment with buspirone^648,^ ^ 649 ^ or levomepromazine,^ 590 ^ and possibly during maintenance SSRI monotherapy.^650, 651, 652^ When bupropion use was compared with placebo in two controlled studies, patients experienced an increase in seizure rates of 0.44 to 0.87 percent,^653,^ ^ 654 ^ but these increases did not reach statistical significance. In an uncontrolled study, seizure rates were higher in those taking doses of bupropion above 450 mg/d.^ 655 ^ We found reports of five cases of seizures after bupropion overdose and one case of seizure in a patient on bupropion at 600 mg/d.^ 656 ^

#### Serotonin syndrome and other disorders of temperature regulation

Serotonin syndrome and possibly other disorders of thermal regulation occur with SSRIs.

The serotonin syndrome is a potentially fatal condition characterized by changes in cognition (confusion or hypomania), agitation, myoclonus, hyperreflexia, diaphoresis, shivering, tremor, incoordination, fever, and diarrhea. This syndrome may resemble malignant hyperthermia or the neuroleptic malignant syndrome,^ 657 ^ and it has been explained by presumed excessive serotonergic stimulation.^ 658 ^

In 3,082 patients in premarketing trials of venlafaxine, none developed serotonin syndrome.^ 516 ^ Outside of research settings, serotonin syndrome developed in 0.24 percent of patients with Parkinson's disease who were taking selegiline,^ 659 ^ 8 of 12 inpatients who were also taking a monoamine oxidase inhibitor,^ 518 ^ and none of 200 inpatients started on fluvoxamine (1.5 percent developed a partial syndrome).^ 660 ^

The serotonin syndrome has been reported when an SSRI is used along another serotonergic drug. It has also occurred after isolated SSRI overdose.^661,^ ^ 662 ^

Neuroleptic malignant syndrome,^663, 664, 665, 666, 667^ malignant hyperthermia,^666,^ ^ 668 ^ and heat stroke^ 669 ^ have all been reported with SSRIs. The relation of these disorders to serotonin syndrome is unclear.

#### Suicidal acts and ideation

Newer antidepressants are not associated with increased risk of suicide. In addition, newer antidepressants may be less lethal in overdosages than older agents.

Two cohort studies^670,^ ^ 671 ^ and seven reviews of trials ^604,^ ^610,^ ^639,^ ^672, 673, 674, 675^ have examined the risk of suicidal thoughts and acts while patients are on SSRIs compared with other agents or placebo. None of these studies has found a statistically significant increase in the risk of suicide. If anything, the trend is toward lower suicide risk, presumably because of treatment of the underlying depression. Only one case control found significantly increased fluoxetine use in cases of suicide; however, this trend became statistically insignificant after high-risk patients were excluded from analysis.^ 671 ^ These results suggest that clinicians are more likely to use fluoxetine than other antidepressants for high-risk patients.

We found reports describing patients taking SSRIs who developed such bothersome akathisia that they became suicidal. After discontinuation of the SSRI, the akathisia and suicidal thoughts resolved,^676, 677, 678^ but they recurred on one patients when the SSRI was reintroduced.^ 676 ^ Similarly, other extrapyramidal effects have been miserable enough for the dysphoria to reach the level of suicidal thought.^ 679 ^ These dramatic cases are few in number and probably represent the exceptions, not the rule.

One meta-analysis examined the suicide rates in controlled studies of bupropion versus placebo in a total of 1,153 patients.^ 653 ^ Those on bupropion tended to attempt suicide less often than those on tricyclics, but 0.44 percent more than those on placebo (neither difference was statistically significant).

When depressed patients attempt suicide via drug overdose, the SSRIs have been judged to be relatively less lethal than other antidepressants.^ 680 ^ However, overdoses with any of these agents can be fatal,^ 681 ^ as can overdoses with bupropion.^ 682 ^

#### Other adverse effects

Several other uncommon but serious effects have been reported with newer antidepressants, including hepatic and possibly pulmonary toxicity.

Three large studies have reported rates of hepatotoxicity with paroxetine and fluvoxamine.^536, 642, 674^ Rates of hepatotoxicity range from 0.01 percent^ 674 ^ to 0.04 percent.^ 642 ^ Bupropion use has also been associated in case reports with hepatotoxicity.^ 683 ^

In a case control study, idiopathic pulmonary disease was recently associated with use of antidepressants.^ 684 ^ There are several case reports of idiopathic lung disease resulting from an SSRI approved by the FDA.^536, 685, 686, 687, 688^ One case occurred in 4,126 patients treated with paroxetine.^ 536 ^ Further research is need to establish causality.

Several other adverse effects have been reported: acute glaucoma,^689, 690, 691^ hypoglycemia,^692, 693, 694^ male priapism,^594,^ ^695, 696, 697^ cutaneous pseudolymphomas,^ 698 ^ and Raynaud's syndrome.^ 699 ^ Upon withdrawal from SSRIs, some patients have developed symptoms that are occasionally severe, including delirium,^ 700 ^ postural hypotension,^ 701 ^ mania,^ 702 ^ and severe psychiatric symptoms.^ 703 ^ Bupropion use has been associated with priapism.^ 631 ^

### Gaps in Evidence

Substantial gaps in evidence concerning uncommon but serious adverse effects of newer antidepressants are likely because of inadequate reporting and surveillance measures and few controlled studies.

### Other Relevant Evidence

No other comprehensive rigorous systematic reviews evaluating uncommon but serious adverse effects of newer antidepressants were found.