# Introduction

Depressive disorders, including major depression and dysthymia, are serious, disabling illnesses. It is estimated that one in five individuals is affected by a mood disorder in his or her lifetime.^1,^ ^ 2 ^ Depressive episodes are associated with impairment in many areas of function: social, occupational, physical, and interpersonal. This impairment carries a high price tag. In the United States alone, the estimated monetary costs for depression exceeded $44 billion in 1990.^ 3 ^ The personal costs also are enormous, measured by mortality and suffering for individuals and their families. The World Health Organization estimates that major depression alone is the fourth most important cause worldwide of loss in disability-adjusted life years, a standard metric for measuring the impact of illness and will become the second most important cause by 2020.^4,^ ^ 5 ^

The benefits of treating depression disorders with antidepressants or specific psychotherapies were first established in the early 1970's. Early established therapies included tricyclic antidepressants such as amitriptyline and desipramine, monoamine oxidase inhibitors (MAOIs) including phenelzine and tranylcypromine, and cognitive behavioral therapy. In the 1980's, selective serotonin reuptake inhibitors (SSRIs), selective and reversible MAOIs, and other new antidepressants were developed.

In the late 1980s, the U.S. Department of Health and Human Services sponsored the development of standard treatment guidelines for major depression. The literature synthesis prepared for these guidelines showed that existing antidepressant medications were more effective than placebo, with an overall effectiveness of approximately 50 percent in patients with major depression.^6,^ ^ 7 ^ The guidelines advanced knowledge substantially, but there was insufficient evidence to address many clinically salient questions.^ 8 ^ For example, treatment for adolescents and for individuals with dysthymia and subsyndromal depression were not specifically addressed. Also, since publication of the guidelines, evidence has been accumulating. There has been a continued quest for new and more effective treatments. New classes of antidepressants and herbal treatments have contributed to explosive growth in the prescribing of antidepressants, increasing pharmacy costs for health plans, and wider but sometimes confusing choices for clinicians and patients.

The purpose of this evidence report is to provide a comprehensive evaluation of the efficacy of newer pharmacotherapies and herbal treatments for depressive disorders. Other issues relevant to the care of depressed individuals, such as the organization of care delivery systems and cost-effectiveness of specific agents, are beyond the scope of this evidence report. We anticipate the report will be valuable to clinicians and patients desiring evidence for informed choices about antidepressant drug and herbal therapies and to organizations developing clinical guidelines for the treatment of depression.

The following paragraphs review briefly the mood disorders addressed, the epidemiology of depressive disorders, the burden of depression, and the basis for treatment issues addressed by the report.

## Mood Disorders

All mood disorders are characterized by a syndrome that includes psychological (e.g., decreased concentration) and somatic symptoms (e.g., insomnia). Depressed mood or anhedonia is a prominent feature. Mood disorders are commonly classified into two major categories -- unipolar depressive disorders and bipolar disorders.^ 9 ^ The unipolar depressive disorders are the subject of this report. They consist of disorders characterized by depressive symptoms only, without a history of a manic, mixed, or hypomanic episode. The unipolar depressive disorders are divided into several groups such as major depressive disorder, dysthymic disorder, depression not otherwise specified (NOS), mixed anxiety-depressive disorder, and subsyndromal depression.^9, 10, 11, 12^

The literature encompassed by this report spans approximately two decades of research and an evolving nomenclature for depressive disorders. During this period, the definition of major depression has remained relatively constant, but descriptions and terms used for non-major depression have undergone important changes. Because of the variability in nosology, we have identified the diagnostic system when presenting results of treatment for particular types of depression. In addition, we have pointed out instances where differences in diagnostic terms may have contributed to inconsistent treatment results. The commonly used nomenclature for specific types of depression is defined in the glossary.

## Epidemiology

Major depressive disorder (MDD) is one of the most common and best described psychiatric disorders. It occurs in up to one in eight individuals during his or her lifetime and affects persons of all ages and races and throughout the socioeconomic range.^ 13 ^ The lifetime risk for MDD ranges from 10 to 25 percent for women and from 5 to 12 percent for men, with a point prevalence of 5 to 9 percent for women and 2 to 3 percent for men.^2,^ ^6,^ ^ 13 ^ Dysthymic disorder is somewhat less prevalent, with the lifetime risk ranging from 3 to 6 percent and a point prevalence of 1 to 4 percent. The prevalence of other depressive disorders such as depression NOS and mixed anxiety depression are less well described. In a large nationally representative survey of psychiatric disorders, 11 percent of individuals met criteria for depression NOS.^ 2 ^ According to data derived from a 1990 population base over a 12-month period, the total number of cases of depression in individuals 18 or older is increasing.^ 6 ^

Female gender, a prior episode of major depression, and a history of depressive illness in a first degree relative are the best established risk factors for a depressive illness.^ 6 ^ Depressive disorders also are more common in younger adults, rather than older adults. Recent data show an association between depression and chronic medical illnesses. There is no consistent relationship between prevalence of depressive disorders and race, education, income, or civil status. The prevalence of depressive disorders varies by setting with rates being lowest in community samples, intermediate in outpatient populations, and highest in inpatient settings.

## Burden of Depression

Depressive disorders are persistent, recurring illnesses that impose enormous personal suffering on individuals and their families. Depression is associated with increased mortality due to suicide and its interactions with other medical illness. The risk of suicide ranges from 43 to 224 per 100,000 person-years for those receiving treatment in primary care and in inpatient psychiatry settings, respectively.^ 14 ^ Over 60 percent of suicides are attributed to major depressive disorder.^ 6 ^ Detrimental effects on personal productivity, interpersonal relationships, and the ability to perform usual daily activities are pervasive. Studies examining the effects of depression on health-related quality of life demonstrate decrements that equal or exceed those of patients with chronic medical illnesses such as diabetes mellitus or ischemic heart disease.^15, 16, 17, 18^

In addition to personal costs, depression extracts a high economic toll on society as 1 of the 10 most costly illnesses in the United States. Estimated annual costs total about $44 billion (1990 dollars), with $12 billion per year going toward direct treatment costs and $31 billion per year lost in indirect costs.^ 3 ^ The indirect costs are attributed to premature death ($8 billion) and lost productivity in the workplace ($23 billion). This estimate encompasses costs for major depression, bipolar disorder, and dysthymia, with major depression accounting for over 85 percent of the cost. This estimate, however, does not represent the true cost to society because it does not measure the adverse effects of pain and suffering and other quality-of-life issues. Furthermore, these estimates are conservative; they fail to include other important costs such as additional out-of-pocket expenses incurred by families, excessive hospitalization for nonpsychiatric conditions due to depression, and unnecessary diagnostic tests for depressed patients who present with somatic symptoms. They also exclude costs associated with individuals who have symptoms which do not meet full diagnostic criteria for major depression.^14,^ ^ 19 ^

## Treatment of Depressive Disorders

An improved understanding of the natural history of major depression, including the high rates of recurrent illness and the efficacy of long-term treatment led the Agency for Health Care Policy and Research (AHCPR) guideline panel to recommend a three-phase treatment approach for major depression.^ 6 ^ In the acute treatment phase, complete symptom remission and psychosocial restoration are the goal. Upon return to normal mood, a 4- to 9-month continuation phase begins, where treatment is extended to prevent relapses. Prevention of new episodes is the goal of an extended, long-term maintenance therapy phase and is indicated for individuals at particularly high risk of recurrence.^ 20 ^

Three types of therapies have proved effective for depressive disorders: pharmacotherapy, psychotherapy, and electroconvulsive therapy (ECT).^6,^ ^21, 22, 23, 24, 25, 26^ This report, based on randomized controlled trials lasting at least 6 weeks, focuses on 29 newer antidepressant drugs and 3 herbal remedies. Six weeks was chosen as a minimal treatment duration to exclude studies with inadequate treatment durations and to allow a more extended period to detect dropouts resulting from adverse effects.^ 27 ^ Newer pharmacotherapies were of particular interest because of the large number of recently developed drugs and their relatively high cost. Herbal remedies were included because of the high degree of public and professional interest in these nonprescription treatments. Because older depressants were reviewed adequately in the AHCPR depression guidelines, these drugs are considered only when they are compared directly with a newer antidepressant. For interested readers, recent high-quality literature syntheses and evidence-based guidelines comparing older antidepressant drugs with placebo and the selective serotonin reuptake inhibitors are readily available.^6,^ ^28, 29, 30, 31^ Similarly, studies of psychosocial therapies were only considered when a comparison was made with 1 of the 32 selected antidepressants or herbal remedies. A comprehensive review of psychosocial therapies and electroconvulsive therapy was beyond the scope of this report.

To identify the most relevant issues, an expert multidisciplinary panel refined the focus of this report. The guiding principles were to address questions with the potential to develop new information not addressed in previous literature synthesis, relevance to clinicians' making treatment decisions, and relevance to policymakers' developing guidelines. The resulting list of questions (given in the next section) was long and broad-based. It was anticipated that data would be sparse or even absent for some questions but that important gaps in evidence would be highlighted.

Questions address the efficacy of newer pharmacotherapies for the most prevalent forms of depression and for individuals with recurrent or refractory depression. Additional questions involve the relative efficacy of newer agents compared with psychosocial therapies and the efficacy of herbal remedies. The major outcomes of interest for these questions were symptomatic response rates, health-related quality of life, and functional status. The report also focuses on specific patient populations (e.g., children and adolescents) and specific settings (e.g., primary care). Issues involving combination treatments with other psychotropics, psychosocial therapies, and augmenting agents are addressed. The important question of long-term efficacy is examined through relapse prevention studies. Finally, the report addresses a group of questions related to adherence, common adverse effects, and uncommon but serious adverse effects.