# Appendix 7: Analyses of Dropout

Contents

- 7.1 RIMA vs. TCA (first generation)
- 7.1.1 Dropouts - side effects
- 7.1.2 Dropouts - lack of efficacy
- 7.1.3 Dropouts - total
- 7.2 SSRI vs. TCA (first generation)
- 7.2.1 Dropouts - side effects
- 7.2.2 Dropouts - lack of efficacy
- 7.2.3 Dropouts - total
- 7.3 SSRI vs. TCA (second generation)
- 7.3.1 Dropouts - side effects
- 7.3.2 Dropouts - lack of efficacy
- 7.3.3 Dropouts - total
- 7.4 SSRI vs. Tetracyclics
- 7.4.1 Dropouts - side effects
- 7.4.2 Dropouts - lack of efficacy
- 7.4.3 Dropouts - total
- 7.5 SSRI vs. SSRI
- 7.5.1 Dropouts - lack of efficacy
- 7.6 SSRI vs. RIMA
- 7.6.1 Dropouts - lack of efficacy
- 7.6.2 Dropouts - total
- 7.7 SNRI vs. TCA (first generation)
- 7.7.1 Dropouts - side effects

## 7.1 RIMA vs. TCA (first generation)

Figure 7.1.1 RIMA vs. TCA1 Drop outs - Side Effects

Figure 7.1.2 Dropouts - Lack of Effiacy: RIMA vs TCA1

Figure 7.1.3 Dropouts - Total: RIMA vs TCA1

## 7.2 SSRI vs. TCA (first generation)

Figure 7.2.1 SSRI vs TCA1, Drop Outs - Side Effects

Figure 7.2.2 SSRI vs TCA1, Drop Outs - Lack of Efficacy

Figure 7.2.3 SSRI vs TCA1, Drop Outs - Total

## 7.3 SSRI vs. TCA (second generation)

Figure 7.3.1 SSRI vs TCA2, Drop Outs - Side Effects

Figure 7.3.2 Dropouts - Lack of Efficacy: SSRI vs TCA2

Figure 7.3.3 SSRI vs TCA2, Drop Outs - Total

## 7.4 SSRI vs. Tetracyclics

Figure 7.4.1 Dropouts - Side Effects: SSRI vs TETR

Figure 7.4.2 Dropouts - Lack of Efficacy: SSRI vs TETR

Figure 7.4.3 Dropouts - Total: SSRI vs TETR

## SSRI vs. SSRI

Figure 7.5.1 Dropouts - Lack of Efficacy: SSRI vs SSRI

## SSRI vs. RIMA

Figure 7.6.1 Dropouts - Lack of Efficacy: SSRI vs RIMA

Figure 7.6.2 Dropouts - Total: SSRI vs RIMA

## SNRI vs. TCA (first generation)

Figure 7.7.1 Dropouts - Side Effects: SNRI vs TCA1