# Appendix 6: Analyses of Common Adverse Effects

Table 1. Number of trials reporting common adverse events

Item / Step | Files
| RIMA vs TCA 1 | SNRI vs. TCA 1 | SSRI vs. RIMA | SSRI vs. SSRI | SSRI vs. TCA 1 | SSRI vs. TCA 2 | SSRI vs. Tetracyclic
1. # studies dry mouth | 7 | 9 | 4 | 4 | 49 | 4 | 8
2. # studies blurred vision | 5 | 3 | 1 | 0 | 25 | 2 | 3
3. # studies urinary | 3 | 1 | 0 | 0 | 13 | 2 | 2
4. # studies constipation | 7 | 8 | 0 | 3 | 42 | 5 | 3
5. # studies dizziness | 9 | 8 | 3 | 3 | 42 | 4 | 5
6. # studies insomnia | 6 | 4 | 5 | 5 | 30 | 3 | 5
7. # studies anxiety | 4 | 4 | 5 | 7 | 22 | 3 | 3
8. # studies headache | 8 | 7 | 4 | 9 | 44 | 4 | 6
9. # studies tremors | 8 | 5 | 1 | 4 | 35 | 1 | 3
10. # studies nausea | 9 | 6 | 5 | 11 | 45 | 4 | 12
11. # studies anorexia | 1 | 0 | 1 | 3 | 7 | 1 | 1
12. #studies diarrhea | 4 | 1 | 1 | 5 | 16 | 1 | 1

Figure 6.1 SSRI vs. TCA1, Dry Mouth

Figure 6.2 SSRI vs. TCA1, Urinary

Figure 6.3 SSRI vs. TCA1, Blurred Vision

Figure 6.4 SSRI vs. TCA1, Constipation

Figure 6.5 SSRI vs. TCA1, Dizziness

Figure 6.6 SSRI vs. TCA1, Insomnia

Figure 6.7 SSRI vs. TCA1, Anxiety

Figure 6.8 SSRI vs. TCA1, Tremors

Figure 6.9 SSRI vs. TCA1, Nausea