# Appendix 5: Evidence Table of Uncommon but Serious Adverse Effects

[Suicidal acts and suicidality]

[Suicidal acts and suicidality]

Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Results
Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Treatment rate % | Comparison rate % | Risk difference (%)
Fluoxetine | Suicide attempts | Beasley 1991* ^ 672 ^ | Meta-analysis | Premarketing RCTs of treatment for major depression. 1,765 patients received fluoxetine. | Placebo | 0.34 | 0.18 | 0.16%(-0.27 to 0.60)
Fluoxetine | Suicide attempts | Beasley 1991* ^ 672 ^ | Meta-analysis | Premarketing RCTs of treatment for major depression. 1,765 patients received fluoxetine. | Tricyclics | 0.34 | 0.41 | -0.07 (-0.61-0.47)
Fluoxetine | Suicide attempts | Beasley 1992* ^ 673 ^ | Meta-analysis | RCTs of obsessive-compulsive disorder. 266 patients received fluoxetine | Placebo | 0 | 0 | 0
Fluoxetine | Suicide attempts | Goldstein 1993* ^ 610 ^ | Meta-analysis | Investigation New Drug database of RCTs for weight loss. 2,661 patients received fluoxetine. | Placebo | 0.04 | 0 | 0.04 (-0.12 to 0.19)
Fluoxetine | Suicide attempts | Jick 1995^671^ | Cohort | Patients in the UK General Practice Research database between 1988-1993. 1,1860 patients received fluoxetine. | Other antidepressant | 0.09 | 0.07 | -0.03 (-0.03 to 0.08)
Fluoxetine | Suicide attempts | Jick 1995^ 671 ^ Donovan 1996704 | Nested case control | All patients in the UK General Practice Research database ..39 received fluoxetine. | Other antidepressant | Not applicable | Not applicable | 3.8 (1.7 to 8.6)(adjusted odds ratio)
Fluoxetine | Suicidal attempts | Jick 1995^ 671 ^ Donovan 1996^ 704 ^ | Nested case control | Patients without history of suicidal behavior who are in the UK General Practice Research database . 21 received fluoxetine. | Other antidepressant | Not applicable | Not applicable | 2.1 (0.6 to 7.9) (adjusted odds ratio)
Fluoxetine | Suicidal attempts | Warshaw 1996* ^ 670 ^ | Controlled cohort | Harvard/Brown Anxiety Disorders Research Program anxiety cohort. 191 patients received fluoxetine. | Other medication | 2.62 | 3.02 | -0.41 (-3.16 to 2.34)
Fluoxetine | Suicidal attempts | Wheadon 1992* ^ 705 ^ | Meta-analysis | Two studies in the U.S. Investigational New Drug database of treatment of bulimia nervosa. 554 patients received fluoxetine. | Placebo | 1.26 | 0.87 | 0.40 (-1.12 to 1.91)
Fluoxetine | Suicidal ideation | Beasley 1991* ^ 672 ^ | Meta-analysis | Premarketing RCTsof treatment formajor depression.1,201 patientsreceived fluoxetine. | Placebo | 1.2 | 2.6 | -1.47 (-3.19 to 0.25)
Fluoxetine | Suicidal ideation | Beasley 1991* ^ 672 ^ | Meta-analysis | Premarketing RCTsof treatment formajor depression.1,201 patientsreceived fluoxetine. | Tricyclics | 1.2 | 3.6 | -2.42 (-4.31 to 0.54)
Fluoxetine | Suicidal ideation | Beasley 1992* ^673^ | Meta-analysis | RCTs of obsessive-compulsive disorder. 266 patients received fluoxetine | Placebo | 19.16 | 29.55 | -10.39 (-21.05 to 0.27)

[Suicidal acts and suicidality - continued]

[Suicidal acts and suicidality - continued]

Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Results
Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Treatment rate % | Comparison rate % | Risk difference (%)
Fluoxetine | Suicidal attempts | Tollefson 1994* ^ 639 ^ (probably includes Beasley^ 673 ^) | Meta-analysis | Investigational New Drug Database of trials for depression. 1,322 patients received fluoxetine. | Placebo | 1.37 | 1.93 | -0.56 (-1.80 to 0.68)
Fluoxetine | Suicidal attempts | Tollefson 1994* ^ 639 ^ (probably includes Beasley^ 673 ^) | Meta-analysis | Investigational New Drug Database of trials for depression. 1,322 patients received fluoxetine. | Tricyclics | 1.37 | 2.46 | -1.09 (-2.32 to 0.14)
Fluvoxamine | Suicidal attempts | Wheadon 1992* ^ 604 ^ | Meta-analysis | Two studies in the U.S. Investigational New Drug database of treatment of bulimia nervosa. 554 patients received fluoxetine. | Placebo | 3.07 | 3.03 | 0.04 (-2.60-2.67)
Fluvoxamine | Suicidal attempts | Wagner 1992* ^ 674 ^ | Controlled cohort | Patients in marketing studies. 24,624 received fluvoxamine. | 25 patients on placebo | 0.41 | 0 | 0.41 (-4.87 to 5.69
Fluvoxamine | Suicidal attempts | Wagner 1992* ^ 674 ^ | Controlled cohort | Patients in marketing studies. 24,624 received fluvoxamine. | 723 patients on other antidepressant | 0.41 | 0.55 | 0.14 (0.69 to 0.40)
Fluvoxamine | Suicidal attempts | Wagner 1996* ^611^ | Uncontrolled cohort | Elderly patients from preceding study postmarketing studies. 4,843 received fluvoxamine | Not applicable | 0.14 (-1.26 to 1.55) | Not applicable
Fluvoxamine | Suicidal ideation | Wagner 1992* ^674^ | Controlled cohort | Patients in marketing studies. 24,624 received fluvoxamine. | 25 patients on placebo | 0.80 | 0 | 0.80 (-4.48 to 6.08)
Fluvoxamine | Suicidal ideation | | | | 723 patients on other antidepressant | 0.80 | 0.69 | 0.11 (-0.51 to 0.72)
Paroxetine | Suicide competion | Boyer1992* ^ 536 ^ | Meta-analysis | Premarketing RCTs of depression. 4,126 patients received paroxetine. | Other antidepressant | 0.15 | 0.17 | -0.02 (-0.24 to 0.20)
Paroxetine | Suicidal attempts | López-Ibor 1993^ 675 ^ | Meta-analysis | Worldwide database of controlled clinical trials. 2,963 patients treated with paroxetine | 554 patients who took placebo | 1.52 | 1.44 | 0.07 (-1.01 to 1.16)
Paroxetine | Suicidal attempts | López-Ibor 1993^ 675 ^ | Meta-analysis | Worldwide database of controlled clinical trials. 2,963 patients treated with paroxetine | 1,151 patients who took tricyclics | 1.52 | 1.30 | 0.22 ( -0.57 to 1.00)
Paroxetine | Suicidal ideation | López-Ibor 1993^ 675 ^ | Meta-analysis | Worldwide database of controlled clinical trials. 2,963 patients treated with paroxetine | 554 patients who took placebo | 0.44 | 0.36 | 0.08 (-0.48 to - 0.63)
Paroxetine | Suicidal ideation | López-Ibor 1993^ 675 ^ | Meta-analysis | Worldwide database of controlled clinical trials. 2,963 patients treated with paroxetine | 1,151 patients who took tricyclics | 0.44 | 0.43 | 0.00 (-0.44 to -0.45)
Bupropion | Suicide attempts | Van Wyck 1983* ^ 653 ^ | Meta-analysis | Premarketing trials for depression. 1,153 patients received bupropion. | Placebo | 1.26 | 0.56 | 0.69 (-0.62 to 2.01)
Bupropion | Suicide attempts | Van Wyck 1983* ^ 653 ^ | Meta-analysis | Premarketing trials for depression. 1,153 patients received bupropion. | Amitriptyline | 0.95 | 2.04 | -0.89 (-2.98 to 1.21)

[Fetal adverse effects]

[Fetal adverse effects]

Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Results
Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Treatment rate % | Comparison rate % | Risk difference (%)
Fluoxetine, Fluvoxamine, Paroxetine, Sertraline | Spontaneous abortions | Brunel 1994^ 706 ^ | Controlled cohort | Inquiries to the Pharmacovigilance and Poisons Center in Lyon, France. 114 outcomes of pregnancy known from 151 inquiries. 34 women were exposed to SSRIs during the first trimester. | Tricyclics | 1.15 | 2.04 | -10.46 (-19.30 to 1.62)
Fluoxetine, Fluvoxamine, Paroxetine, Sertraline | Major malformations | Brunel 1994^ 706 ^ | Controlled cohort | See preceding | Tricyclics | 0 | 4.12 | -4.12 (-9.14 to 5.68)
Fluvoxamine, Paroxetine, Sertraline | Spontaneous abortions | Kulin 1998^ 634 ^ Probably includes Nulman^ 707 ^ and Pastuszak ^ 708 ^ | Controlled cohort | Pregnant women in Motherisk Program. 267 women took active drug. | Pregnant women exposed to non-teratogenic agents | 11.24 | 7.87 | 3.37 (-1.61-8.35)
Fluvoxamine, Paroxetine, Sertraline | Major malformations | See preceding. | Controlled cohort | See preceding. | Pregnant women exposed to non-teratogenic agents | 3.37 | 3.37 | 0.00 (-3.06 to 3.06)
Fluoxetine | Spontaneous abortion | Chambers 1996^ 635 ^ | Controlled cohort | Pregnant women in the California Teratogen Information Service and Clinical Research Program. 56 women received fluoxetine in first trimester. | Pregnant women exposed to non-teratogenic agents | 10.09 | 8.66 | 1.43 (-3.79 to 6.65)
Fluoxetine | Spontaneous abortion | Kulin 1998^ 634 ^ Probably includes Nulman^ 707 ^ and Pastuszak^ 708 ^ | Controlled cohort | Pregnant women in Motherisk Program. 88 women took fluoxetine. | Pregnant women exposed to non-teratogenic agents | 13.64 | 0? (not clear) | 13.64 (6.24 to 21.04)
Fluoxetine | Spontaneous abortion | Kulin 1998^ 634 ^ Probably includes Nulman^ 707 ^ and Pastuszak^ 708 ^ | Controlled cohort | See preceeding. 74 patients received fluoxetine and were matched to tricyclic controls. | Pregnant women who took tricyclics | 13.64 | 9.30 | 4.33 (-4.41 to 13.08)
Fluoxetine | Spontaneous abortion | Edwards 1997^ 636 ^ | Controlled Cohort | Pregnant women in the Prescription event monitoring program of the Drug Safety Research Unit, Southampton, UK. 57 women received fluoxetine during early pregnancy. | Pregnant taking fluoxetine but stopped prior to LMP. | 10.53 | 18.60 (Unclear how recently control group stopped fluox-etine) | -8.08 (-22.18 to 6.02)

[Fetal adverse effects - continued]

[Fetal adverse effects - continued]

Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Results
Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Treatment rate % | Comparison rate % | Risk difference (%)
Fluoxetine | Spontaneous reporting | Goldstein 1997* ^ 709 ^ | Uncontrolled cohort | Patients reported to manufacturer because of first trimester exposures. 796 women. | Not applicable | 13.82 (10.34 to 17.29) | not applicable
Fluoxetine | Spontaneous reporting | Pastuszak, 1993^ 708 ^ Probably included in Kulin^ 634 ^ And Nulman^ 707 ^ | Controlled cohort | Pregnant women in Motherisk Program. 128 patients received fluoxetine and were matched with controls. | Pregnant women exposed to non-teratogenic agents. | 14.84 | 14.84 | 0.00 (.71 to 8.71)
Fluoxetine | Spontaneous reporting | Pastuszak, 1993^ 708 ^ Probably included in Kulin^ 634 ^ And Nulman^ 707 ^ | Controlled cohort | See preceding. 74 patients received fluoxetine and werevmatched to tricyclic controls. | Tricyclics | 13.51 | 12.16 | 1.35 (-9.42 to 12.13)
Fluoxetine | Stillbirths | Goldstein 1997* ^709^ | Uncontrolled cohort | Patients reported to manufacturer because of first trimester exposures. 796 women. | Not applicable | 0.38 (-3.10 to 3.85) | Not applicable
Fluoxetine | Major malformations | Chambers 1996^ 635 ^ | Controlled cohort | Pregnant women in the California Teratogen Information Service and Clinical Research Program. 90 women received fluoxetine in 2/3 trimesters. | Pregnant women exposed to non-teratogenic agents | 6.67 | 3.54 | 3.12 (-1.31 to 7.56)
Fluoxetine | Major malformations | Nulman 1997 ^ 707 ^ Probably included in Kulin^ 634 ^ | Controlled cohort | Pregnant women in Motherisk Program. | Pregnant women exposed to non-teratogenic agents | 2.27 | 2.38 | -0.11 (-4.62 to4.40)
Fluoxetine | Major malformations | Nulman 1997 ^ 707 ^ Probably included in Kulin^ 634 ^ | Controlled cohort | Pregnant women in Motherisk Program. | Pregnant women who took tricyclics | 2.27 | 2.33 | -0.05 (-4.11 to 4.00)
Fluoxetine | Major malformations | Pastuszak, 1993^ 708 ^ Probably included in Kulin^ 634 ^ | Controlled Cohort | Pregnant women in Motherisk Program. 128 patients received fluoxetine and were matched with controls. | Pregnant women exposed to non-teratogenic agents. | 1.56 | 1.56 | 0.00 (-3.04 to 3.04)
Fluoxetine | Major malformations | Pastuszak, 1993^ 708 ^ Probably included in Kulin^ 634 ^ | Controlled Cohort | See preceding. 74 patients received fluoxetine and were matched to tricyclic controls. | Tricyclics | 2.70 | 0 | 2.70 (-1.76 to 7.16)
Fluoxetine | Admitted to a special care nursery after exposure in last trimester. | Chambers 1996^ 635 ^ | Controlled cohort | Pregnant women in the California Teratogen Information Service and Clinical Research Program. 184 babies were exposed to fluoxetine. | Pregnant woment exposed to non-teratogenic agents | 20.11 | 8.85 | 11.27 (4.25-18.28)
Fluoxetine | Prematurity | Chambers 1996^ 635 ^ | Controlled cohort | See preceding. | Pregnant women exposed to non-teratogenic agents | 8.33 | 5.91 | 2.42 (-2.79 to 7.64)
Fluoxetine | Fetal neurodevelopment, IQ scores. | Nulman 1997^ 707 ^ | Cohort | Pregnant women Motherisk Program. 55 women received fluoxetine | Pregnant women exposed to non-teratogenic agents | | | No significant findings
Fluvoxamine | Spontaneous abortion | Edwards 1994^ 642 ^ | Uncontrolled cohort | Pregnant women in the 31 pregnant women reported to the Prescription Event Monitoring Program of the Drug Safety Research Unit, Southampton, UK. | Not applicable | 19.35

[Seizures]

[Seizures]

Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Results
Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Treatment rate % | Comparison rate % | Risk difference (%)
Paroxetine | Seizures | Boyer 1992* ^ 536 ^ | Meta-analysis | Premarketing RCTs of depression. 4,126 patients received paroxetine | Other antidepressant | 0.15 | 0.28 | 0.13 (-0.40 to 0.14)
Fluvoxamine | Seizures | Edwards 1994^ 642 ^ | Uncontrolled cohort | Prescription Event Monitoring Program of the British Drug safety Research Unit. Cohort of 10,401 outpatients taking fluvoxamine. | Not applicable | 0.18 Note: seizures more common in older patients.
Fluvoxamine | Seizures | Wagner 1994* ^ 647 ^ | Uncontrolled cohort | Patients in postmarketing studies. 34,587 received fluvoxamine | Not applicable | 0.05 | Not applicable
Fluvoxamine | Seizures | Wagner 1996* ^ 611 ^ | Uncontrolled cohort | 4,843 elderly patients in preceding study. | Not applicable | 0.17 (-1.24 to 1.57) | Not applicable
Venlafaxime | Seizures | Rudolph 1996* ^ 516 ^ | Meta-analysis | Premarketing trials for unipolar depression. 3,082 patients received venlafaxine. | Other antidepressant. Usually a tricyclic. | 0.26 | 0.38
Bupropion | Seizures | Johnston 1991* ^ 633 ^ | Uncontrolled cohort | Open trial by Burroughs-Wellcome. 1,616 patients on <450 mg/day of bupropion. | Not applicable | 0.40 (-1.31 to 2.11) | Not applicable
Bupropion | Seizures | Davidson 1989* ^ 655 ^ | Uncontrolled Meta-analysis | Uncontrolled studies by Burroughs-Wellcome. 3,395 patients on <450 mg/day of bupropion. | Not applicable | 0.44 (-1.24 to 2.12) | Not applicable
Bupropion | Seizures | Davidson 1989* ^ 655 ^ | Uncontrolled Meta-analysis | Uncontrolled studies by Burroughs-Wellcome. 4,262 patients on any dose of bupropion | Not applicable | 0.87 (-0.63 to 2.67 | Not applicable
Bupropion | Seizures | Van Wyck 1983* ^ 653 ^ | Meta-analysis | Premarketing RCTs. 1,153 patients received bupropion. | Placebo | 0.10 | 0 | 0.10 (-0.71 to 0.92)
Bupropion | Seizures | Van Wyck 1983* ^ 653 ^ | Meta-analysis | Premarketing RCTs. 1,153 patients received bupropion. | Amitriptyline | 0.10 | 0 | 0.10 (-0.64 to 0.85)
Bupropion | Seizures | Cato 1983* ^ 654 ^ | Meta-analysis | Premarketing RCTs. 220 patients received bupropion | Placebo | 0.6 | 0? | NA

[Psychiatric adverse effects]

[Psychiatric adverse effects]

Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Results
Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Treatment rate % | Comparison rate % | Risk difference (%)
Psychiatric adverse effects
Fluoxetine Fluvoxamine Paroxetine Sertraline | Mania | Peet, 1994^ 638 ^ | Meta-analysis | Patients with unipolar depression from an unknown number of trials. 10,246 patients received SSRI. | Tricyclic | 0.72 | 0.52 | .21 (-0.11 to 0.52)
Fluoxetine Fluvoxamine Paroxetine Sertraline | Mania | Peet, 1994^ 638 ^ | Meta-analysis | Patients with unipolar depression from an unknown number of trials. 10,246 patients received SSRI. | Placebo | 0.72 | 0.21 | 0.51 (0.29 to 0.73)
Fluoxetine Fluvoxamine Paroxetine Sertraline | Mania | Peet, 1994^ 638 ^ | Meta-analysis | Patients with bipolar depression from an unknown number of trials. 242 patients received SSRI. | Tricyclic | 3.72 | 11.20 | -7.48 (-13.50 to 1.46)
Fluoxetine Fluvoxamine Paroxetine Sertraline | Mania | Peet, 1994^ 638 ^ | Meta-analysis | Patients with bipolar depression from an unknown number of trials. 242 patients received SSRI. | Placebo | 3.72 | 4.17 | 0.45 (-6.58 to 5.69)

[Psychiatric adverse effects]

[Psychiatric adverse effects]

Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Results
Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Treatment rate % | Comparison rate % | Risk difference (%)
Fluoxetine | Mania | Tollefson 1994 * ^ 639 ^ | Meta-analysis * | Investigational New Drug Database of trials for depression. 1,322 patients received fluoxetine. | 569 patients taking placebo | 0.73 | 0.18 | 0.56 (0.05 to 1.06)
Fluoxetine | Mania | Tollefson 1994 * ^ 639 ^ | Meta-analysis * | Investigational New Drug Database of trials for depression. 1,322 patients received fluoxetine. | 731 patients taking tricyclics | 0.73 | 0.68 | 0.05 (-0.65 to 0.75)
Paroxetine | Mania | Rasmussen 1991 * ^ 710 ^ Boyer 1992 * ^ 536 ^ | Meta-analysis | Pharmaceutical database of unipolar depressions. Unknown number of patients. | Other antidepressant | 1.00 | 1.00 | 0.00 (-0.55 to 0.55)
Paroxetine | Mania | Rasmussen 1991 * ^ 710 ^ Boyer 1992 * ^ 536 ^ | Meta-analysis | See preceding. Bipolar patients | Other antidepressant | 2.00 | 11.00 | -8.98 (-10.48 to -7.47)
Venlafaxine | Mania | Rudolph 1996 * ^ 516 ^ | Meta-analysis | Premarketing trials for unipolar depression. 3,082 patients received venlafaxine. | Other antidepressant. Usually a tricyclic. | 0.5 | ?
Fluoxetine | Aggression | Heiligenstein 1992* ^ 711 ^ 1993* ^ 640 ^ | Meta-analysis | Premarketing double blind RCTs. 2,615 patients received fluoxetine. | Placebo | 0.15 | 0.65 | -0.50 (-0.95 to 0.05)
Fluoxetine | Aggression | Jick 1992^ 641 ^ | Controlled cohort | Boston Collaborative Drug Surveillance Program from 1/88 to 4/90. 1,468 patients received fluoxetine. | 6824 patient receiving other antidepressants | 0.07 | 0.07 | 0.01 (-0.15 to 0.14)
Fluoxetine | Violence | Tollefson 1994* ^ 639 ^ | Meta-analysis * | Investigational New Drug Database of trials for depression. 1,322 patients received fluoxetine. | 569 patients taking placebo | 0.34 | 0 | 0.34 (-0.01 to 0.70)
Fluoxetine | Violence | Tollefson 1994* ^ 639 ^ | Meta-analysis * | Investigational New Drug Database of trials for depression. 1,322 patients received fluoxetine. | 731 patients taking tricyclics | 0.34 | 0.14 | 0.21 (-0.16 to 0.57)
Fluoxetine | Psychosis | Tollefson 1994* ^ 639 ^ | Meta-analysis* | Investigational New Drug Database of trials for depression. 1,322 patients received fluoxetine. | 569 patients taking placebo | 0.49 | 0.18 | 0.31 (-0.14 to 0.77)
Fluoxetine | Psychosis | Tollefson 1994* ^ 639 ^ | Meta-analysis* | Investigational New Drug Database of trials for depression. 1,322 patients received fluoxetine. | 731 patients taking tricyclics | 0.49 | 0.10
Fluoxetine | Psychosis | Wernicke 1985* ^ 604 ^ | Meta-analysis of uncontrolled studies. | Lilly clinical trials program. 1,378 patients received fluoxetine. | Not applicable | 0.65 (-1.99 to 3.29)
Fluvoxamine | Hallucinations | Edwards 1994^ 642 ^ | Case series/ Uncontrolled cohort. | Adverse effects reported to the Prescription Event Monitoring Program of the Drug Safety Research Unit, Southampton, UK. 10,401 patients received fluvoxamine. | Not applicable | 0.22 (-0.74 to 1.18) | Not applicable
Bupropion | Mania | Johnston 1991 * ^ 633 ^ | Uncontrolled cohort | Open trial by Burroughs-Wellcome. 3,279 patients on <450 mg/day of bupropion. | Not applicable | 0.06 (-1.65 to 1.77)
Bupropion | Psychosis | Johnston 1991* ^ 633 ^ | Uncontrolled cohort | See preceding. | Not applicable | 0.09 | Not applicable
Bupropion | Hallucinations | Johnston 1986* ^ 712 ^ | Meta-analysis | Premarketing studies. 3,277 received bupropion. | Amitriptyline | 3.35 | 2.99 | 0.35 (-3.09 to 3.80)
Bupropion | Hallucinations | Johnston 1986* ^ 712 ^ | Meta-analysis | Premarketing studies. 3,277 received bupropion. | Placebo | 0.93 | 1.08 | -0.15 (-1.97 to 1.67)
Bupropion | Delusions | Johnston 1986* ^ 712 ^ | Meta-analysis | See preceding. | Amitriptyline | 0.42 | 0.60 | -0.18 (-1.61 to 1.25)
Bupropion | Delusions | Johnston 1986* ^ 712 ^ | Meta-analysis | See preceding. | Placebo | 1.24 | 1.08 | 0.16 (-1.76 to 2.08)

[Other adverse effects

[Other adverse effects

Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Results
Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Treatment rate % | Comparison rate % | Risk difference (%)
Other adverse effects
Fluoxetine Fluvoxamine Paroxetine Sertraline | Confusion | Spina 1995^643^ | Controlled cohort | 848 patients received a SSRI | Tricyclics. | 1.5 | 3.1 | -1.82 (-3.93 to 0.29)
Fluvoxamine | Confusion | Edwards 1994^642^ | Uncontrolled cohort. | Adverse effects reported to the Prescription event Monitoring Program of the Drug Safety Research Unit, Southampton, UK. 10,401 patientc received fluvoxamine. | Not applicable | 0.64 (-0.32 to 1.61)
Fluoxetine | Confusion | Wagner 1996* ^611^ | Uncontrolled cohort | Elderly patients in postmarketing studies. 4,843 received fluvoxamine | Not applicable | 0.04 (-1.37 to 1.45) | Not applicable
Fluoxetine | Serotonin syndrome | Feighner 1990^ 518 ^ | Uncontrolled cohort | 12 inpatients on fluoxetine who were started on a monoamine oxidase inhibitor | Not applicable | 75 | Not applicable
Fluoxetine | Serotonin syndrome | Feighner 1990^ 518 ^ | Uncontrolled cohort | 6 inpatients on fluoxetine who were started on a monoamine oxidase inhibitor at least 10 days after stopping fluoxetine. | Not applicable | 33 | Not applicable
Fluvoxamine | Serotonin syndrome | Ebert 1996^ 660 ^ | Uncontrolled cohort | 200 inpatients started on fluvoxamine. | Not applicable | 0 (1.5% developed partial syndrome) | Not applicable
Venlafaxine | Serotonin syndrome | Rudolph 1996* ^ 516 ^ | Meta-analysis | Premarketing trials for unipolar depression. 3,082 patients received venlafaxine. | | 0
SSRIs | Serotonin syndrome | Richard 1997^ 659 ^ | Case series/ Uncontrolled cohort | Outpatients in the Parkinson Study Group who had serotonin syndrome and were on selegiline. 4,568 patients received an SSRI | Patients not taking an SSRI. | 0.24 | Not applicable
Fluoxetine | Serotonin syndrome | Waters 1994^ 713 ^ | Uncontrolled cohort | 23 outpatients with Parkinson's Disease who were on selegiline. | Not applicable | 0 (-20.43 to 20.43) | Not applicable
Fluoxetine | Hyponatremia* (not always symptomatic) | Pillans 1994^ 622 ^ | Case series / Uncontrolled cohort | 7 cases of hyponatremia reported to the New Zealand Intensive Medicines Monitoring Programme. 5,628 patients were teated with fluoxetine. | Not applicable | 0.12 (-1.18 to 1.43) (Only occurred in elderly women)
Fluoxetine | Hyponatremia (Na<130mol/L) | Siegler 1995^ 623 ^ | Case control | Psychiatric inpatients. 19 received fluoxetine. | Patients not on fluoxetine. | Not applicable | Not applicable | Adjusted OR=21.4 (CI: 5.3 to 86.9)

[Other adverse effects - continued]

[Other adverse effects - continued]

Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Results
Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Treatment rate % | Comparison rate % | Risk difference (%)
Fluoxetine | Extrapyramidal Symptoms | Coulter 1995^ 605 ^ | Case series/ Uncontrolled cohort | Adverse effects reported to the New Zealand Intensive Medicines Monitoring Programme. 5,555 patients received fluoxetine in New Zealand. | Not applicable | 0.27 (-1.04 to 1.58) | Not applicable
Fluoxetine | Extrapyramidal Symptoms | Edwards 1997^ 636 ^ | Case series/ Uncontrolled cohort | Adverse effects reported to the Prescription Event Monitoring Program of the British Drug safety Research Unit. Cohort of 12,692 outpatients taking fluoxetine. | Not applicable | 0.19 (-0.68 to 1.10)
Fluoxetine Fluvoxamine Paroxetine Sertaline | Drug induced Parkinsonism | Gormley 1997^ 607 ^ | Uncontrolled cohort | 67 elderly inpatients started on an SSRI | Not applicable | 5.97 (6.00 to 17.94) | Not applicable
Fluoxetine | Mild worsening of Parkinson's disease | Caley 1992^ 608 ^ | Uncontrolled cohort | 23 outpatients with pre-existing Parkinson's Disease | Not applicable | 13.04 (-7.39 to 33.48) | Not applicable
Fluoxetine | Ataxia | Wernicke 1985* ^ 604 ^ | Meta-analysis | Pharmaceutical trials, 1,378 patients received fluoxetine. | Amitriptyline | 0.44 | 1.4 | -0.97 (-3.74 to 1.79)
Bupropion | Ataxia | Johnston 1991* ^ 633 ^ | Uncontrolled cohort | Open trial by Burroughs-Wellcome. 3,279 patients on <450 mg/day of bupropion. | Not applicable | 0.06 (-1.65 to 1.77)
Paroxetine | Akathisia | Baldassano 1996^ 606 ^ | Uncontrolled cohort. | 67 patients on paroxetine seen by four academic psychiatrists. | Not applicable. | 4.48 (-7.49 to 16.45) | Not applicable
Sertraline | Falls | Mendelson, 1996^ 714 ^ | Case control | Inpatients on psychotropic medicines who fell. 7 received sertaline. | Patients not on fluoxetine or sertraline | Not applicable | Not applicable | infinite (p=0.05, all patients on sertraline were among cases) Odds ratio
Fluoxetine | Falls | Mendelson, 1996^ 714 ^ | Case control | Inpatients on psychotropic medicines who fell. Six received fluoxetine. | Patients not on fluoxetine or sertraline | Not applicable | Not applicable | 4.5 (p=NS) Odds ratio
SSRIs | Hip fractures | Liu 1998^ 535 ^ | Case control | Residents of Ontario hospitalized for a hip fracture. 8,239 cases. | Not taking an SSRI | Not applicable | Not applicable | 2.4 (adjusted odds ratio)

[Other adverse effects - continued]

[Other adverse effects - continued]

Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Results
Drug | Adverse effect | Author, year *industry study | Study Design | Population, size of treatment group | Comparison Group | Treatment rate % | Comparison rate % | Risk difference (%)
Fluoxetine | Admission for syncope | Cherin, 1997^ 532 ^ | Case control | 630 patients at least 65 years old admitted for syncope. 1,807 outpatient controls who were at least 65 years old. | Patients not on fluoxetine. | Not applicable | Not applicable | Adjusted OR=2.6 (CI: 1.8 to 3.5)
Fluvoxamine | Syncope | Wagner 1992* ^ 674 ^ | Uncontrolled cohort | Marketing trials. 24,624 patients received fluoxetine. | Not applicable | 0.04 (-0.59 to 0.67) | Not applicable
Fluvoxamine | Syncope | Wagner 1996* ^ 611 ^ | Uncontrolled cohort | Elderly patients in postmarketing studies. 4,843 received fluvoxamine | Not applicable | 0.06 (-1.34 to 1.47) | Not applicable
Paroxetine | Pulmonary alveloitis | Boyer 1992^ 536 ^ | Meta-analysis | Premarketing RCTs of depression. 4,126 patients received paroxetine | Other anti-depressant | 0.02 (-.02 to 1.5)(single case) | 0?
Fluoxetine | Hepatitis | Wagner 1992* ^ 674 ^ | Uncotnrolled Meta-analysis | Marketing trials.24,624 patients received fluoxetine. | Not applicable | 0.01 (-0.61 to 0.64) | Not applicable
Paroxetine | Hepatitis | Boyer 1992* ^ 536 ^ | Meta-analysis | Premarketing RCTs of depression. 4,126 patients received paroxetine | Other anti-depressant | 0.02 (-.02 to 1.5)(single case) | Not applicable
Fluoxamine | Jaundice | Edwards 1994^ 642 ^ | Uncontrolled cohort | Prescription event monitoring Program of the British Drug safety Research Unit. Cohort of 10,401 outpatients taking fluvoxamine. | Not applicable | 0.04 (-0.92 to 1.00) | Not applicable
Bupropion | Hypersensitivity (fever, rash, hepatotoxicity) | Johnston 1991* ^ 633 ^ | Uncontrolled cohort | Open trial by Burroughs-Wellcome. 3,279 patients on <450 mg/day of bupropion. | Not applicable | 0.03 (-1.68 to 1.74) | Not applicable
Paroxetine | Erythema nodosum | Boyer 1992* ^ 536 ^ | Meta-analysis | Premarketing RCTs of depression. 4,126 patients received paroxetine | Other anti-depressant | 0.02 (-.02 to 1.5)(single case) | Not applicable
Fluoxetine | Bleeding* | Goldstein, 1993* ^ 610 ^ | Meta-analysis* | Four RCTs of treatment for obesity. | Placebo | 0.73 | 0 | 0.73 (0.18 to 1.29)
Fluvoxamine | Gastrointestinal bleeding | Wagner 1992* ^ 674 ^ | Uncontrolled cohort | Patients in marketing studies. 24,624 received fluvoxamine | Not applicable | 0.01 (-0.62 to 0.63) | Not applicable
Fluvoxamine | Bleeding syndrome | Wagner 1994* ^ 647 ^ | Uncontrolled cohort | Patients in postmarketing studies. 34,587 received fluvoxamine | Not applicable | 0 | Not applicable
Fluvoxamine | Bleeding | Wagner 1996* ^ 611 ^ | Uncontrolled cohort | 4,843 elderly patients in preceding study. | Not applicable | 0.04 (-1.37 to 1.45) | Not applicable
Fluvoxamine | Serious drug interactions | Wagner 1995*;^ 521 ^ | Case series/ Uncontrolled cohort | 32 patients reported to the manufacturer because of serious adverse effects from drug interactions. Pharmaceutical database of an estimated 8 million patients | Not applicable | 0.0004 | Not applicable
Fluvoxamine | Death | Henry 1995^ 680 ^ | Controlled cohort | General Medical Practices (England, Wales, Scotland) within National Health Service. Unknown size. | Amitripyline | 4.78 (deaths per million prescriptions) | 38.94 (deaths per million prescriptions)
Paroxetine | Death | Henry 1995^ 680 ^ | Controlled cohort | General Medical Practices (England, Wales, Scotland) within National Health Service. | Amitripyline | 2.60 (deaths per million prescriptions) | 38.94 (deaths per million prescriptions)
Sertraline | Death | Henry 1995^ 680 ^ | Controlled cohort | See preceding. | Amitripyline | 6.23 (deaths per million prescriptions) | 38.94 (deaths per million prescriptions)

Notes: The risk difference is calculated with "Meta-analyst" using the DerSimonian method with a random effect model. For uncontrolled cohort studies, confidence intervals are calculated with "Epistat" using the binomial distribution.