# Appendix 4: Efficacy Analysis Figures

Contents

- 4.1 Major Depression
- 4.1.1 SSRI vs. Placebo
- 4.1.2 SSRI vs. Placebo
- 4.1.3 RIMA vs. Placebo
- 4.1.4 5-HT2 vs. Placebo
- 4.1.5 5-HT1A vs. Placebo
- 4.1.6 SSRI vs. First Generation TCA
- 4.1.7 SSRI vs. Second Generation TCA
- 4.1.8 SSRI vs. Tetracyclic
- 4.1.9 SSRI vs. Triazolopyridine
- 4.1.10 SNRI vs. First Generation TCA
- 4.1.11 SNRI vs. Triazolopyridine
- 4.1.12 RIMA vs. First Generation TCA
- 4.1.13 5-HT2 vs. First Generation TCA
- 4.1.14 Fluoxetine vs. Other SSRI
- 4.1.15 SSRI vs. SSRI
- 4.1.16 SSRI vs. SNRI
- 4.1.17 SSRI vs. RIMA

## 4.1 Major Depression

### Figure 4.1.1 SSRI vs Placebo

[image]

### Figure 4.1.2 SNRI vs Placebo

[image]

### Figure 4.1.3 RIMA vs PLACEBO

[image]

### Figure 4.1.4 5-HT2 vs Placebo

[image]

### Figure 4.1.5 5-HT1A vs PLACEBO

[image]

### Figure 4.1.6 SSRI vs First Generation TCA

[image]

### Figure 4.1.7 SSRI vs SECOND GENERATION TCA

[image]

### Figure 4.1.8 SSRI vs TETRACYCLIC

[image]

### Figure 4.1.9 SSRI vs TRIAZOLOPYRIDINE

[image]

### Figure 4.1.10 SNRI vs FIRST GENERATION TCA

[image]

### Figure 4.1.11 SNRI vs TRIAZOLOPYRIDINE

[image]

### Figure 4.1.12 RIMA vs FIRST GENERATION TCA

[image]

### Figure 4.1.13 5-HT2 vs FISRT GENERATION TCA

[image]

### Figure 4.1.14 Fluoxetine vs OTHER SSRI

[image]

### Figure 4.1.15 SSRI vs SSRI

[image]

### Figure 4.1.16 SSRI vs SNRI

[image]

### Figure 4.1.17 SSRI vs RIMA

[image]