# Appendix 3: Evidence Table of Individual Trials

[Table of Individual Trials Aguglia-Ansseau ]Appendix 3:

[Table of Individual Trials Aguglia-Ansseau ]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
AGUGLIA^ 167 ^ | FLUOXETINE vs SERTRALINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD >=18 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: ITALY N: 108 Mean age: 58, Female: 75% | Total dropouts: 49/108 Outcomes reported: HAMD MADRS CGI
AHLBERG^ 168 ^ | FEMOXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: Newcastle HAMD>17 Diagnosis: Major Depression Setting: Mental Health Specialty Care Outpatient Clinic Country: SWEDEN DENMARK N: 42 Mean age: 45, Female: 67% | Total dropouts: 3/42 Outcomes reported: HAMD
ALBY^ 169 ^ | FLUOXETINE vs TIANEPTINE Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HARD >25 FARD >25 Diagnosis: Heterogeneous Setting: Outpatient Clinic Country: FRANCE N: 206 Mean age: 44, Female: 70% | Total dropouts: 91/206 Outcomes reported: HARD
ALLAIN^ 170 ^ | MOCLOBEMIDE vs VILOXAZINE vs MAPROTILINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR MADRS APROX 20-30. HAM ANXIETY <15 MMSE >23 Diagnosis: Major Depression Setting: Mental Health Specialty Care Outpatient Clinic Country: FRANCE N: 46 Mean age: 28, Female: 85% | Total dropouts: 9/46 Outcomes reported: MADRS
ALTAMURA^ 171 ^ | PLACEBO vs VILOXAZINE vs IMIRAMINE Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD >18 (21 ITEMS) Special population: Alcoholism Diagnosis: Dysthymia Setting: Outpatient Clinic Inpatient Country: ITALY N: 30 Mean age: 45, Female: 20% | Total dropouts: 3/30 Outcomes reported: HAMD
ANDERSEN^ 172 ^ | PLACEBO vs CITALOPRAM Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: BDI, HAMD (17 ITEMS)>=13-17 for less than Major Depression; 18-29 for Major Depression Special population: Stroke Diagnosis: Heterogeneous Setting: Outpatient Clinic Inpatient Country: DENMARK N: 66 Mean age: 67, Female: 61% | Total dropouts: 9/66 Outcomes reported: HAMD
ANSSEAU^ 173 ^ | NEFAZODONE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR MADRS >=27 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: BELGIUM N: 106 Mean age: 47, Female: 70% | Total dropouts: 38/106 Outcomes reported: HAMD MADRS CGI
ANSSEAU^ 174 ^ | FLUVOXAMINE vs PAROXETINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (21 ITEMS) >=18 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: BELGIUM N: 135 Mean age: 44, Female: 58% | Total dropouts: 39/135 Outcomes reported: HAMD CGI
ANSSEAU^ 175 ^ | FLUOXETINE vs MILNACIPRAN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR MADRS >25, CGI >4, RASKIN > COVI Diagnosis: Major Depression Setting: Not Stated/Unclear Country: BELGIUM N: 190 Mean age: 45, Female: 75% | Total dropouts: 41/190 Outcomes reported: HAMD MADRS CGI

[Table of Individual Trials Continued: Appleby-Bakish]Appendix 3:

[Table of Individual Trials Continued: Appleby-Bakish]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
APPLEBY^ 176 ^ | COGNITIVE BEHAVIOR MONTHLY vs COGNITIVE BEHAVIOR DAILY vs FLUOXETINE + PSYCHOTHERAPY MONTHLY vs FLUOXETINE + PSYCHOTHERAPY DAILY Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: EDINBURG POSTNATAL DEPRESSION SCALE, REVISED CLINICAL INTERVIEW SCHEDULE Special population: Psychotherapy Diagnosis: Postpartum depression Setting: Post-partum Country: UK N: 87 Mean age: 25, Female: 100% | Total dropouts: 26/87 Outcomes reported: HAMD
ARMINEN^ 177 ^ | PAROXETINE vs IMIPRAMINE Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR RDC HAMD (17 ITEMS)>=18 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: DENMARK N: 57 Mean age: NG, Female: 54% | Total dropouts: 28/57 Outcomes reported: HAMD MADRS
AYLWARD^ 178 ^ | SULPIRIDE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: HAMD >=25 (3 SUICIDAL) ICD-8 296.2 OR 300.4 Diagnosis: Heterogeneous Setting: Not Stated/Unclear Country: UK N: 50 Mean age: 46, Female: 60% | Total dropouts: 9/50 Outcomes reported: HAMD CGI
BAKER^ 179 ^ | FLUOXETINE vs DOXEPIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD>=18 Diagnosis: Major Depression Setting: Outpatient Clinic Country: CANADA N: 40 Mean age: 42, Female: 46% | Total dropouts: 9/40 Outcomes reported: HAMD
BAKISH^ 180 ^ | FLUOXETINE vs PAROXETINE Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >=18 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: CANADA N: NG Mean age: 39, Female: 62% | Total dropouts: NG/NG Outcomes reported: None
BAKISH^ 181 ^ | PLACEBO vs RITANSERTIN vs IMIPRAMINE Duration of treatment: 7 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS)>=13 Diagnosis: Dysthymia Setting: Outpatient Clinic Country: CANADA N: 50 Mean age: 38, Female: 48% | Total dropouts: 15/50 Outcomes reported: HAMD
BAKISH^ 180 ^ | PLACEBO vs MOCLOBEMIDE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (17 ITEMS)>=18 Diagnosis: Major Depression Setting: Mental Health Specialty Care Outpatient Clinic Country: CANADA N: 173 Mean age: 19-64, Female: 44% | Total dropouts: 66/173 Outcomes reported: HAMD

[Table of Individual Trials Continued: Baldwin-Bergmann]Appendix 3:

[Table of Individual Trials Continued: Baldwin-Bergmann]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
BALDWIN^ 183 ^ | NEFAZODONE vs PAROXETINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD >= 18 Diagnosis: Major Depression Setting: Mental Health Specialty Care Outpatient Clinic Country: UNTED KINGDOM IRELAND N: 206 Mean age: 38, Female: 55% | Total dropouts: 56/206 Outcomes reported: HAMD MADRS CGI
BARGE-SCHAAPVELD^ 184 ^ | FLUVOXAMINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: No Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >=18; CGI>=4 Diagnosis: Major Depression Setting: Primary Care Country: NETHERLANDS N: 23 Mean age: NG, Female: NG | Total dropouts: 2/23 Outcomes reported: None
BASCARA^ 185 ^ | PAROXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (21 ITEMS) >= 18 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: PHILIPPINES N: 50 Mean age: 34, Female: 52% | Total dropouts: 5/50 Outcomes reported: HAMD CGI
BATTEGAY^ 186 ^ | PAROXETINE vs AMITRIPTYLINE Duration of treatment: 7 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: HAMD (17 ITEMS) > 20 Diagnosis: Heterogeneous Setting: University Affiliated Outpatient Clinic Country: SWITZERLAND N: 21 Mean age: 39, Female: 57% | Total dropouts: 11/21 Outcomes reported: HAMD MADRS CGI
BEASLEY^ 187 ^ | FLUOXETINE vs TRAZODONE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (21 ITEMS)>=20 Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 126 Mean age: 40, Female: 67% | Total dropouts: 43/126 Outcomes reported: HAMD CGI
BEASLEY^ 188 ^ | FLUOXETINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (21 ITEMS) >= 20; RASKIN DEP >= 8 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: USA N: 118 Mean age: 43, Female: 81% | Total dropouts: 71/118 Outcomes reported: HAMD CGI
BEAUMONT^ 189 ^ | MOCLOBEMIDE vs DOTHIEPIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (17 ITEMS)>13 Diagnosis: Major Depression Setting: Primary Care Country: UK IRELAND N: 345 Mean age: 44, Female: 71% | Total dropouts: 80/345 Outcomes reported: HAMD CGI
BEHAN^ 190 ^ | SERTRALINE vs CLOMIPRAMINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR MADRS >22 Special population: Chronic Fatigue Diagnosis: Major Depression Setting: Not Stated/Unclear Country: UK N: 40 Mean age: NG, Female: NG | Total dropouts: 7/40 Outcomes reported: None
BENKERT^ 191 ^ | VENLAFAXINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR MADRS>=30 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: EUROPE N: 167 Mean age: 47, Female: 68% | Total dropouts: 52/167 Outcomes reported: HAMD MADRS
BENNIE^ 192 ^ | FLUOXETINE vs SERTRALINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >=18, RASKIN>COVI Diagnosis: Major Depression Setting: Not Stated/Unclear Country: UK N: 286 Mean age: 50, Female: 61% | Total dropouts: 47/286 Outcomes reported: HAMD CGI
BERGMANN^ 193 ^ | HYPERICUM EXTRACT vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes | Inclusion criteria: ICD-10 F 32.0, 32.1, 33.0-33.1 Diagnosis: Mild to Moderately Severe Depressive Syndrome Setting: Mental Health Specialty Care Outpatient Country: GERMANY N: 80 Mean age:55 , Female: 66% | Total dropouts: 4/80 Outcomes reported: HAMD

[Table of Individual Trials Continued: Berman-Botte]Appendix 3:

[Table of Individual Trials Continued: Berman-Botte]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
BERMAN^ 194 ^ | FLUOXETINE, PLACEBO vs FLUOXETINE, PINDOLOL Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIV Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Country: USA N: 43 Mean age: 42, Female: 44% | Total dropouts: 8/43 Outcomes reported: HAMD
BERSANI^ 195 ^ | SERTRALINE vs AMITRIPTYLINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR Diagnosis: Major Depression Setting: Not Stated/Unclear Country: ITALY N: 68 Mean age: 47, Female: 63% | Total dropouts: 7/68 Outcomes reported: HAMD CGI
BERZEWSKI^ 196 ^ | REBOXETINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (21 ITEMS)>=22 Diagnosis: Major Depression Setting: University Affiliated Private Clinic Outpatient Clinic Inpatient Country: GERMANY BELGIUM SOUTH AFRICA N: 256 Mean age: 44, Female: 65% | Total dropouts: 68/256 Outcomes reported: HAMD MADRS CGI
BESANCON^ 197 ^ | FLUOXETINE vs MIANSERIN Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII MADRS >25 Diagnosis: Heterogeneous Setting: Outpatient Clinic Country: FRANCE N: 75 Mean age: 43, Female: 66% | Total dropouts: 11/75 Outcomes reported: MADRS
BLUMENFIELD^ 198 ^ | PLACEBO vs FLUOXETINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: HAMD (17 ITEMS)>=16 Special populations: Renal Failure Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 14 Mean age: NG, Female: NG | Total dropouts: 1/14 Outcomes reported: HAMD MADRS
BOTTE^ 199 ^ | PLACEBO vs MOCLOBEMIDE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: ICD, 1975 (296.1, UNIPOLAR DEPRESSION; 300.4; NEUROTIC DEPRESSION) Diagnosis: Heterogeneous Setting: Not Stated/Unclear Country: BELGIUM N: 47 Mean age: 47, Female: 62% | Total dropouts: NG/47 Outcomes reported: HAMD

[Table of Individual Trials Continued: Bouchard-Brown]Appendix 3:

[Table of Individual Trials Continued: Bouchard-Brown]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
BOUCHARD^ 200 ^ | CITALOPRAM vs MAPROTILINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: MADRS>=15 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: DENMARK FRANCE N: 96 Mean age: 45, Female: 75% | Total dropouts: 30/96 Outcomes reported: MADRS CGI
BOWDEN^ 201 ^ | FLUOXETINE vs DESIPRAMINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (21 ITEMS) >=20 Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Inpatient Country: USA N: 58 Mean age: 38, Female: 59% | Total dropouts: 13/58 Outcomes reported: HAMD
BOYER^ 202 ^ | PLACEBO vs AMISULPRIDE AMINEPTINE Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR MADRS < 21 & >= 2 anergia, chronic fatigue, loss of interest, lack of pleasure, less active Diagnosis: Dysthymia Setting: Outpatient Clinic Country: FRANCE N: 323 Mean age: 48, Female: 75% | Total dropouts: 119/323 Outcomes reported: MADRS CGI
BREMNER^ 203 ^ | PLACEBO vs MIRTAZAPIEN vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS) >=18, ZUNG Diagnosis: Major Depression Setting: Private Clinic Outpatient Clinic Country: USA N: 150 Mean age: 39, Female: 68% | Total dropouts: 31/150 Outcomes reported: HAMD MADRS CGI
BROWN^ 204 ^ | PLACEBO vs FLUVOXAMINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD (21 ITEMS) >20 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 81 Mean age: NG, Female: 67% | Total dropouts: 14/81 Outcomes reported: HAMD

[Table of Individual Trials Continued: Buchsbaum-Chiu]Appendix 3:

[Table of Individual Trials Continued: Buchsbaum-Chiu]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
BUCHSBAUM^ 205 ^ | PLACEBO vs SERTRALINE Duration of treatment: 10 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (24 ITEMS)>=25 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: NG Mean age: 39, Female: 59% | Total dropouts: NG/NG Outcomes reported: HAMD
BURKE^ 206 ^ | PLACEBO vs FLUOXETINE 20 vs FLUOXETINE 60 Duration of treatment: 11 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DX SYSTEM NOT DESCRIBED; HAMD>=18 Diagnosis: Major Depression Setting: University Affiliated Outpatient Clinic Country: USA N: 30 Mean age: 40, Female: 70% | Total dropouts: 13/30 Outcomes reported: None
BYERLEY^ 207 ^ | PLACEBO vs FLUOXETINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (20 ITEMS) >=20 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 95 Mean age: 39, Female: 66% | Total dropouts: 35/95 Outcomes reported: HAMD CGI
CASSANO^ 208 ^ | PLACEBO vs FLUVOXAMINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII Feighner HAMD (17 ITEMS)>=15 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: EUROPE CANADA USA N: 481 Mean age: 42, Female: 62% | Total dropouts: 206/481 Outcomes reported: HAMD CGI
CHIU^ 209 ^ | PAROXETINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD SCORE >18 Diagnosis: Major Depression Setting: Mental Health Specialty Care Outpatient Clinic Inpatient Country: TAIWAN N: 40 Mean age: 45, Female: 63% | Total dropouts: 10/40 Outcomes reported: HAMD

[Table of Individual Trials Continued: Chouinard-Christiansen]Appendix 3:

[Table of Individual Trials Continued: Chouinard-Christiansen]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
CHOUINARD^ 210 ^ | BUPROPION vs AMITRIPTYLINE Duration of treatment: 13 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: Modified DSM III criteria, including duration >=4 weeks HAMD (21 ITEMS) > 18 Diagnosis: Heterogeneous Setting: Outpatient Clinic Country: CANADA N: 118 Mean age: 37, Female: 67% | Total dropouts: 24/118 Outcomes reported: HAMD CGI
CHOUINARD^ 210 ^ | BUPROPION vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: Modified DSM III criteria, including duration >=4 weeks, HAMD (21 ITEMS) >=18 Diagnosis: Heterogeneous Setting: Outpatient Clinic Inpatient Country: CANADA N: 92 Mean age: 41, Female: 52% | Total dropouts: 21/92 Outcomes reported: HAMD CGI
CHOUINARD^ 211 ^ | PLACEBO vs BROFAROMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >=18 AND >=3 ON ITEMS 1 (DEPRESSED MOOD) Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: CANADA N: NG Mean age: NG, Female: NG | Total dropouts: NG/NG Outcomes reported: None
CHOUINARD^ 212 ^ | PLACEBO vs BROFAROMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD>=18 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: CANADA N: 220 Mean age: 41, Female: 56% | Total dropouts: 95/220 Outcomes reported: HAMD CGI
CHRISTIANSEN^ 213 ^ | PAROXETINE vs AMITRIPTYLINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: HAMD >=15 (17 ITEMS) Diagnosis: Heterogeneous Setting: Not Stated/Unclear Country: DENMARK N: 144 Mean age: NG, Female: NG | Total dropouts: 31/144 Outcomes reported: HAMD CGI

[Table of Individual Trials Continued: Claghorn-Clerc]Appendix 3:

[Table of Individual Trials Continued: Claghorn-Clerc]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
CLAGHORN^ 214 ^ | PLACEBO vs PAROXETINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD (17 ITEMS) >=18, RDS>=8, CAS>RDS Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 72 Mean age: 35, Female: 40% | Total dropouts: 33/72 Outcomes reported: HAMD MADRS CGI
CLAGHORN^ 215 ^ | PLACEBO vs FLUVOXAMINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 150 Mean age: NG, Female: 65% | Total dropouts: 89/150 Outcomes reported: HAMD CGI
CLAGHORN^ 216 ^ | PLACEBO vs MIRTAZAPINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS)>=18 Diagnosis: Major Depression Setting: Private Clinic Outpatient Clinic Country: USA N: 90 Mean age: 39, Female: 49% | Total dropouts: 44/90 Outcomes reported: HAMD MADRS CGI
CLERC^ 217 ^ | FLUOXETINE vs VENLAFAXINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR MADRS>=25 Diagnosis: Major Depression Setting: Inpatient Country: BELGIUM FRANCE N: 68 Mean age: 51, Female: 68% | Total dropouts: 18/68 Outcomes reported: HAMD MADRS CGI
CLERC^ 218 ^ | MILNACIPRAN vs CLOMIPRAMINE Duration of treatment: weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII Newcastle MADRS >= 30, NEWCASTLE <=20 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: FRANCE N: 112 Mean age: 49, Female: 71% | Total dropouts: 30/112 Outcomes reported: HAMD MADRS

[Table of Individual Trials Continued: Cohn-Corne]Appendix 3:

[Table of Individual Trials Continued: Cohn-Corne]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
COHN^ 219 ^ | PLACEBO vs NEFAZODONE vs IMIPRAMINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD > 20 Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 119 Mean age: 39, Female: 72% | Total dropouts: 45/119 Outcomes reported: HAMD CGI
COHN^ 220 ^ | SERTRALINE vs AMITRIPTYLINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS) >= 18, RASKIN>COVI Special population: Elderly Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 241 Mean age: 70, Female: 49% | Total dropouts: 120/241 Outcomes reported: HAMD CGI
COHN^ 221 ^ | PLACEBO vs PAROXETINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS) >=18, RASKIN DEPRESSION SCALE>=8, RASKIN SCORE>COVI ANXIETY SCALE Diagnosis: Major Depression Setting: Private Clinic Outpatient Clinic Country: USA N: 120 Mean age: 42, Female: 59% | Total dropouts: 18/120 Outcomes reported: HAMD MADRS CGI
COHN^ 222 ^ | PLACEBO vs FLUOXETINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD>=20 Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 166 Mean age: 43, Female: 61% | Total dropouts: 95/166 Outcomes reported: HAMD CGI
CORNE^ 223 ^ | FLUOXETINE vs DOTHIEPIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: RDC HAMD>=17 Diagnosis: Major Depression Setting: Primary Care Country: UK N: 100 Mean age: 42, Female: 70% | Total dropouts: 21/100 Outcomes reported: HAMD CGI

[Table of Individual Trials Continued: Cornelius-Dalery]Appendix 3:

[Table of Individual Trials Continued: Cornelius-Dalery]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
CORNELIUS^ 224 ^ | PLACEBO vs FLUOXETINE Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR Special population: Alcoholism Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Inpatient Country: USA N: 51 Mean age: 35, Female: 49% | Total dropouts: 5/51 Outcomes reported: HAMD
CUNNINGHAM^ 225 ^ | PLACEBO vs VENLAFAXINE vs TRAZADONE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (21 ITEMS) >= 20 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 225 Mean age: NG, Female: NG | Total dropouts: 76/225 Outcomes reported: HAMD MADRS CGI
D'AMICO^ 226 ^ | PLACEBO vs NEFAZODONE 50, vs NEFAZODONE 100 vs NEFAZODONE 200 vs NEFAZODONE 300 Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII RDC Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: NG Mean age: NG, Female: NG | Total dropouts: NG/NG Outcomes reported: HAMD
DAHL^ 227 ^ | FEMOXETINE vs DESIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: Newcastle ENDOGENOUS TYPE AND HAMD>17, DEPRESSIVE DISORDER BY GLOBAL CLINICAL JUDGEMENT Diagnosis: Heterogeneous Setting: Not Stated/Unclear Country: SWEDEN N: 42 Mean age: 43, Female: 68% | Total dropouts: 7/42 Outcomes reported: HAMD
DALERY^ 228 ^ | FLUOXETINE vs AMINEPTINE Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR Diagnosis: Major Depression Setting: Outpatient Clinic Country: FRANCE N: 169 Mean age: 43, Female: 69% | Total dropouts: 28/169 Outcomes reported: MADRS CGI

[Table of Individual Trials Continued: Dam-De Jonghe]Appendix 3:

[Table of Individual Trials Continued: Dam-De Jonghe]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
DAM^ 229 ^ | PLACEBO vs FLUOXETINE vs MAPROTILINE Duration of treatment: 12 weeks Subjects blinded: Unclear Providers blinded: Unclear Excluded placebo responders: No | Inclusion criteria: NOT SPECIFIED Special population: Stroke Diagnosis: Heterogeneous Setting: Not Stated/Unclear Country: ITALY N: 52 Mean age: 68, Female: 57% | Total dropouts: 6/52 Outcomes reported: HAMD
DANISH UNIVERSITY ANTI-DEPRESSANT GROUP^ 230 ^ | MOCLOBEMIDE vs CLOMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: HAMD >= 18 AND/OR HAMD (5 ITEMS Subscale) >=9 Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Inpatient Country: DENMARK N: 115 Mean age: 51, Female: 66% | Total dropouts: 32/115 Outcomes reported: HAMD
DANISH UNIVERSITY ANTI-DEPRESSANT GROUP^ 231 ^ | PAROXETINE vs CLOMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD >= 18 AND/OR HAMD Subscale >= 9 Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Inpatient Country: DENMARK N: 120 Mean age: NG, Female: 66% | Total dropouts: 31/120 Outcomes reported: HAMD
DE JONGHE^ 232 ^ | FLUOXETINE vs MAPROTILINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS) >=18 Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Inpatient Country: NETHERLANDS N: 65 Mean age: 47, Female: 69% | Total dropouts: 8/65 Outcomes reported: HAMD CGI
DE JONGHE^ 233 ^ | FLUVOXAMINE vs MAPROTILINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS) >=12 Diagnosis: Heterogeneous Setting: Not Stated/Unclear Country: NETHERLANDS N: 48 Mean age: 40, Female: 60% | Total dropouts: 10/48 Outcomes reported: HAMD CGI

[Table of Individual Trials Continued: De Vanna-Dorman]Appendix 3:

[Table of Individual Trials Continued: De Vanna-Dorman]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
DE VANNA^ 234 ^ | MOCLOBEMIDE vs MAPROTILINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: HAMD (24 ITEMS) >=20, ICD 9. Diagnosis: Major Depression Setting: Inpatient Country: ITALY GERMANY SWITZERLAND N: 39 Mean age: NG, Female: NG | Total dropouts: NG/39 Outcomes reported: HAMD
DE WILDE^ 235 ^ | CITALOPRAM vs MIANSERIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: RDC CPRS SUBSCALE FOR DEPRESSION (10 ITEMS)>=25) Diagnosis: Heterogeneous Setting: Inpatient Country: BELGIUM N: 60 Mean age: 47, Female: 53% | Total dropouts: 2/60 Outcomes reported: CGI
DE WILDE^ 236 ^ | FLUOXETINE vs PAROXETINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (21 ITEMS) >18 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: BELGIUM N: 93 Mean age: 44, Female: 62% | Total dropouts: 15/93 Outcomes reported: HAMD MADRS CGI
DEBUS^ 237 ^ | FLUOXETINE vs TRAZODONE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (21 ITEMS) >20 Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 43 Mean age: 37, Female: 74% | Total dropouts: 18/43 Outcomes reported: HAMD
DEL ZOMPO^ 238 ^ | MINAPRINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS) >=16 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: ITALY N: 60 Mean age: 47, Female: 72% | Total dropouts: 13/60 Outcomes reported: HAMD CGI
DIERICK^ 239 ^ | FLUOXETINE vs VENLAFAXINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD >= 20 Diagnosis: Major Depression Setting: Mental Health Specialty Care Outpatient Clinic Country: ITALY SWITZERLAND FRANCE N: 314 Mean age: 43, Female: 65% | Total dropouts: 78/314 Outcomes reported: HAMD MADRS
DITZLER^ 240 ^ | HYPERICUM EXTRACT vs PLACEBO Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes | Inclusion criteria: DSM IIIR Diagnosis: Moderate to Severe Major Depression Setting: Mental Health Specialty Care Outpatient Country: GERMANY N: 60 Mean age: 44, Female: 70% | Total dropouts: NG/60 Outcomes reported: CGI
DOOGAN^ 241 ^ | PLACEBO vs SERTRALINE Duration of treatment: 44 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD>=17 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: UK AUSTRIA FRANCE SWITZERLAND GERMANY N: 300 Mean age: 51, Female: 69% | Total dropouts: 156/300 Outcomes reported: HAMD CGI
DOOGAN^ 242 ^ | PLACEBO vs SERTRALINE vs DOTHIEPIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR MADRS>=22 AND CGI SEVERITY >=4 Diagnosis: Major Depression Setting: Primary Care Country: UK N: 308 Mean age: 46, Female: 70% | Total dropouts: 39/308 Outcomes reported: MADRS CGI
DORMAN^ 243 ^ | PAROXETINE vs MIANSERIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD (17 ITEMS) >=17 Diagnosis: Major Depression Setting: Outpatient Clinic Country: UK N: 57 Mean age: NG, Female: NG | Total dropouts: 5/57 Outcomes reported: HAMD

[Table of Individual Trials Continued: Dowling-Dunlop]Appendix 3:

[Table of Individual Trials Continued: Dowling-Dunlop]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
DOWLING^ 244 ^ | FLUOXETINE vs DOTHIEPIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD>=17 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: IRELAND N: 60 Mean age: 44, Female: 77% | Total dropouts: 23/60 Outcomes reported: HAMD MADRS
DUARTE^ 245 ^ | FLUOXETINE vs MOCLOBEMIDE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR Diagnosis: Major Depression Setting: Outpatient Clinic Country: ARGENTINA N: 42 Mean age: 45, Female: 40% | Total dropouts: 0/42 Outcomes reported: HAMD CGI
DUBINI^ 246 ^ | PLACEBO vs FLUVOXAMINE vs REBOXETINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (21 ITEMS) >=22 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: ITALY FRANCE N: 302 Mean age: NG, Female: NG | Total dropouts: NG/302 Outcomes reported: HAMD MADRS CGI
DUFRESNE^ 247 ^ | BUPROPION 600 vs BUPROPION 750 vs AMINEPTINE Duration of treatment: 10 weeks Subjects blinded: Unclear Providers blinded: Unclear Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD >= 18 Diagnosis: Major Depression Setting: Inpatient Country: USA N: 3 Mean age: NG, Female: NG | Total dropouts: NG/3 Outcomes reported: HAMD CGI
DUNLOP^ 248 ^ | PLACEBO vs FLUOXETINE 20 vs FLUOXETINE 40 vs FLUOXETINE 60 Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD >=14, RASKIN > COVI Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 372 Mean age: NG, Female: NG | Total dropouts: 152/372 Outcomes reported: HAMD CGI

[Table of Individual Trials Continued: Dunner-Evans]Appendix 3:

[Table of Individual Trials Continued: Dunner-Evans]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
DUNNER^ 249 ^ | PAROXETINE vs DOXEPIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII Special population: Elderly Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 272 Mean age: 68, Female: 54% | Total dropouts: 85/272 Outcomes reported: HAMD MADRS CGI
DUNNER^ 250 ^ | FLUOXETINE vs COGNITIVE THERAPY Duration of treatment: 16 weeks Subjects blinded: No Providers blinded: No Excluded placebo responders: No | Inclusion criteria: DSMIIIR SCID Diagnosis: Dysthymia Setting: Mental Health Specialty Care Outpatient Clinic Country: USA N: 31 Mean age: 36, Female: 46% | Total dropouts: 9/31 Outcomes reported: HAMD
DUNNINGHAM^ 251 ^ | MOCLOBEMIDE vs IMIPRAMINE Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD>18 Special population: Elderly Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Country: BRAZIL N: 60 Mean age: 66, Female: 65% | Total dropouts: 22/60 Outcomes reported: None
EDWARDS^ 252 ^ | MINAPRINE 100 vs MINAPRINE 200 vs MINAPRINE 300 vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD <17 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: UK IRELAND N: 531 Mean age: 45, Female: 61% | Total dropouts: 133/531 Outcomes reported: HAMD MADRS
EDWARDS^ 253 ^ | PLACEBO vs PAROXETINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: FEIGHNER OR DSM III OR RDC Diagnosis: Major Depression Setting: Mental Health Specialty Care Outpatient Clinic Country: UK N: 41 Mean age: 44, Female: 56% | Total dropouts: 24/41 Outcomes reported: HAMD CGI
EVANS^ 254 ^ | PLACEBO vs FLUOXETINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: ELDRS >5; GMS-AGECAT case level of depression Special population: Elderly, Physically Ill Patients Diagnosis: Heterogeneous Setting: University Affiliated Outpatient Clinic Inpatient Not Stated/Unclear Country: UK N: 82 Mean age: 80, Female: 76% | Total dropouts: 40g/82 Outcomes reported: HAMD

[Table of Individual Trials Continued: Fabre-Fairweather]Appendix 3:

[Table of Individual Trials Continued: Fabre-Fairweather]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
FABRE^ 255 ^ | PLACEBO vs PAROXETINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS)>=18, RDS>=8, COVI ANXIETY SCALE<RDS SCORE Diagnosis: Major Depression Setting: Private Clinic Outpatient Clinic Country: USA N: 120 Mean age: 36, Female: 62% | Total dropouts: NG/120 Outcomes reported: HAMD MADRS CGI
FABRE^ 256 ^ | PLACEBO vs SERTRALINE 50 vs SERTRALINE 100 vs SERTRALINE 200 Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA CANADA N: 369 Mean age: 38, Female: 53% | Total dropouts: 178/369 Outcomes reported: HAMD CGI
FABRE^ 257 ^ | PLACEBO vs FLUOXITINE 20 vs FLUOXETINE 40 vs FLUOXETINE 60 Duration of treatment: 6 weeks Subjects blinded: yes Providers blinded: yes Excluded placebo responders: yes | Inclusion Criteria: DSMIII HAMD >20 Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 356 Mean Age: 40, Female: 57%
FABRE^ 258 ^ | PLACEBO vs FLUOXAMINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD>20, RASKIN>=8, COVI<RASKIN Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 150 Mean age: NG, Female: 76% | Total dropouts: 84/150 Outcomes reported: HAMD MADRS CGI
FAIRWEATHER^ 259 ^ | FLUOXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: NOT GIVEN Special population: Elderly Diagnosis: Heterogeneous Setting: Not Stated/Unclear Country: UK N: 66 Mean age: 70, Female: NG | Total dropouts: NG/66 Outcomes reported: MADRS

[Table of Individual Trials Continued: Falk-Feiger]Appendix 3:

[Table of Individual Trials Continued: Falk-Feiger]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
FALK^ 260 ^ | FLUOXETINE vs TRAZODONE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD > 20 Special population: Elderly Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 27 Mean age: 68, Female: 74% | Total dropouts: 14/27 Outcomes reported: HAMD CGI
FAVA^ 261 ^ | PLACEBO (50 wks) vs FLUOXETINE20 (50 wks) vs FLUOXETINE 20 (38 wks)--> PLACEBO (12 wks) vs FLUOXETINE 20 (14 wks)--> PLACEBO (36 wks) Duration of treatment: 50 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: FULL RECOVERY HAMD (17 ITEMS) <7 FROM DSM III R MAJOR DEPRESSION Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Country: USA N: 77 Mean age: NG, Female: NG | Total dropouts: NG/77 Outcomes reported: None
FAWCETT^ 262 ^ | FLUOXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (21 ITEMS) >=20 Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Country: USA N: 40 Mean age: 42, Female: 65% | Total dropouts: 19/40 Outcomes reported: HAMD CGI
FEIGER^ 263 ^ | NEFAZODONE vs SERTRALINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 160 Mean age: 44, Female: 51% | Total dropouts: 39/160 Outcomes reported: HAMD CGI
FEIGER^ 264 ^ | PLACEBO vs GEPIRONE vs IMIPRAMINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 123 Mean age: 39, Female: 55% | Total dropouts: 48/123 Outcomes reported: HAMD MADRS CGI

[Table of Individual Trials Continued: Feighner]Appendix 3:

[Table of Individual Trials Continued: Feighner]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
FEIGHNER^ 265 ^ | PLACEBO vs PAROXETINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS) >=18 Diagnosis: Major Depression Setting: Mental Health Specialty Care Outpatient Clinic Country: USA N: 726 Mean age: 40, Female: 51% | Total dropouts: 357/726 Outcomes reported: HAMD MADRS CGI
FEIGHNER^ 266 ^ | PLACEBO vs FLUVOXAMINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII Diagnosis: Major Depression Setting: Inpatient Country: USA N: 86 Mean age: 41, Female: 85% | Total dropouts: 26/86 Outcomes reported: HAMD
FEIGHNER^ 267 ^ | FLUOXETINE vs DOXEPIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD>=20, RASKIN>=8 Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 157 Mean age: NG, Female: 58% | Total dropouts: 85/157 Outcomes reported: HAMD CGI
FEIGHNER^ 268 ^ | BUPROPION vs FLUOXETINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (21 ITEMS) >= 20 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 123 Mean age: 42, Female: 62% | Total dropouts: 34/123 Outcomes reported: HAMD CGI
FEIGHNER^ 269 ^ | BUPROPION vs DOXEPIN Duration of treatment: 13 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: Feighner Diagnosis: Major Depression Setting: Mental Health Specialty Care Private Clinic Outpatient Clinic Country: USA N: 147 Mean age: 44, Female: 68% | Total dropouts: NG/147 Outcomes reported: HAMD CGI
FEIGHNER^ 270 ^ | PLACEBO vs NEFAZODONE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: RDC Endicott HAMD (17 ITEMS) >=18 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 45 Mean age: 45, Female: 49% | Total dropouts: 15/45 Outcomes reported: HAMD CGI

[Table of Individual Trials Continued: Fernandez-Labriola - Fournier]Appendix 3:

[Table of Individual Trials Continued: Fernandez-Labriola - Fournier]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
FERNANDEZ-LABRIOLA^ 271 ^ | PLACEBO vs TOLOXATONE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: HAMD >20 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: ARGENTINA URUGUAY N: 101 Mean age: 44, Female: 47% | Total dropouts: 24/101 Outcomes reported: HAMD
FERRERI^ 272 ^ | FLUOXETINE vs AMINEPTINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD (21 ITEMS) >=18<=25 Diagnosis: Major Depression Setting: Mental Health Specialty Care Private Clinic Outpatient Clinic Country: FRANCE N: 64 Mean age: 48, Female: 71% | Total dropouts: 11/64 Outcomes reported: HAMD MADRS
FIEVE^ 273 ^ | PLACEBO vs FLUOXETINE 5 vs FLUOXETINE 20 vs FLUOXETINE 40 Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (21 ITEMS) >=20 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 49 Mean age: NG, Female: 43% | Total dropouts: NG/49 Outcomes reported: HAMD CGI
FONTAINE^ 274 ^ | PLACEBO vs NEFAZODONE 250 vs NEFAZODONE 500 vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: RDC HAMD (17 ITEMS) >=22 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: CANADA N: 180 Mean age: 42, Female: 62% | Total dropouts: 64/180 Outcomes reported: HAMD CGI
FOURNIER^ 275 ^ | SERTRALINE vs IMIPRAMINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >=18, RASKIN> COVI Diagnosis: Major Depression Setting: Not Stated/Unclear Country: CANADA N: 104 Mean age: 41, Female: 58% | Total dropouts: 51/104 Outcomes reported: HAMD CGI

[Table of Individual Trials Continued: Franchini-Gasperini]Appendix 3:

[Table of Individual Trials Continued: Franchini-Gasperini]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
FRANCHINI^ 276 ^ | FLUVOXAMINE vs SERTRALINE Duration of treatment: 104 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIV Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Country: ITALY N: 64 Mean age: 48, Female: 77% | Total dropouts: 0/64 Outcomes reported: HAMD
FRANCHINI^ 277 ^ | FLUVOXAMINE vs LITHIUM Duration of treatment: 104 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR RECOVERED FROM MAJOR DEPRESSION, HAMD<=18,MADRS<=20 Diagnosis: Heterogeneous Setting: Outpatient Clinic Country: ITALY N: 64 Mean age: 50, Female: 84% | Total dropouts: 0/64 Outcomes reported: HAMD
GAGIANO^ 278 ^ | PAROXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: HAMD (21 ITEMS)>=18 Diagnosis: Heterogeneous Setting: Outpatient Clinic Country: SOUTH AFRICA N: 65 Mean age: NG, Female: 68 | Total dropouts: 25/65 Outcomes reported: None
GAGIANO^ 279 ^ | FLUOXETINE vs PAROXETINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (21 ITEMS) >18 Diagnosis: Major Depression Setting: Outpatient Clinic Country: SOUTH AFRICA N: 90 Mean age: 39, Female: 80% | Total dropouts: 18/90 Outcomes reported: HAMD MADRS CGI
GASPERINI^ 280 ^ | FLUVOXAMINE vs AMITRIPTYLINE Duration of treatment: 7 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR RDC Diagnosis: Major Depression Setting: Inpatients University Affiliated Country: ITALY N: 56 Mean age: 51, Female: 64% | Total dropouts: 3/56 Outcomes reported: HAMD MADRS

[Table of Individual Trials Continued: Geerts-Ginestet]Appendix 3:

[Table of Individual Trials Continued: Geerts-Ginestet]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
GEERTS^ 281 ^ | FLUOXETINE vs MOCLOBEMIDE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >=17 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: BELGIUM N: 49 Mean age: 42, Female: 53% | Total dropouts: 21/49 Outcomes reported: HAMD
GEISLER^ 282 ^ | RITANSERIN vs FLUPENTHIXOL Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD >= 15 Diagnosis: Dysthymia Setting: Primary Care Outpatient Clinic Country: DENMARK N: 67 Mean age: 48, Female: 73% | Total dropouts: 5/67 Outcomes reported: HAMD CGI
GERETSEGGER^ 283 ^ | PAROXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD (17 ITEMS) >18 Special population: Elderly Diagnosis: Major Depression Setting: Inpatient Country: EUROPE N: 91 Mean age: 71, Female: 86% | Total dropouts: 22/91 Outcomes reported: HAMD MADRS CGI
GILLIN^ 284 ^ | FLUOXETINE vs NEFAZODONE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >=17 Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 44 Mean age: 36, Female: 68% | Total dropouts: 8/44 Outcomes reported: HAMD
GINESTET^ 285 ^ | FLUOXETINE vs CLOMIPRAMINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII Major Depression with Melancholia Diagnosis: Major Depression Setting: Inpatient Country: FRANCE N: NG Mean age: 49, Female: 52% | Total dropouts: 19/NG Outcomes reported: HAMD MADRS

[Table of Individual Trials Continued: Guelfi-Haider]Appendix 3:

[Table of Individual Trials Continued: Guelfi-Haider]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
GUELFI^ 286 ^ | MOCLOBEMIDE vs CLOMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII ICD9-ENDOGENOUS DEPRESSION 296.1/296.3, MADRS>=25 Diagnosis: Major Depression Setting: Mental Health Specialty Care Outpatient Clinic Inpatient Country: FRANCE N: 129 Mean age: 47, Female: 69% | Total dropouts: 32/129 Outcomes reported: HAMD MADRS CGI
GUILLIBERT^ 287 ^ | PAROXETINE vs CLOMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (21 ITEMS) >20, NEWCASTLE SCALE>6 Special population: Elderly Diagnosis: Major Depression Setting: Not Stated/Unclear Country: FRANCE N: 79 Mean age: 68, Female: 70% | Total dropouts: 21/79 Outcomes reported: HAMD
GUY^ 288 ^ | FLUVOXAMINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: RDC HAMD (17 ITEMS) >=15 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: USA N: 36 Mean age: 38, Female: 75% | Total dropouts: NG/36 Outcomes reported: HAMD CGI
HAFFMANS^ 289 ^ | CITALOPRAM vs FLUVOXAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >=16 Special population: Elderly Diagnosis: Major Depression Setting: Mental Health Specialty Care Outpatient Clinic Country: NETHERLANDS N: 217 Mean age: 42, Female: 59% | Total dropouts: 50/217 Outcomes reported: HAMD CGI
HAIDER^ 290 ^ | FLUOXETINE CONTINUATION vs SERTRALINE 50MG/20 FLUOXETINE vs SERTRALINE 75MG/20 FLUOXETINE Duration of treatment: 6 weeks Subjects blinded: No Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Country: USA N: 70 Mean age: NG, Female: NG | Total dropouts: 25/70 Outcomes reported: HAMD + BDI Overall

[Table of Individual Trials Continued: Halikas-Hellerstein]Appendix 3:

[Table of Individual Trials Continued: Halikas-Hellerstein]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
HALIKAS^ 291 ^ | PLACEBO vs MIRTAZAPINE vs TRAZODONE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS) >=18 Special population: Elderly Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 150 Mean age: 62, Female: 54% | Total dropouts: 41/150 Outcomes reported: HAMD MADRS CGI
HARRER^ 292 ^ | HYPERICUM EXTRACT vs PLACEBO Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes | Inclusion criteria: ICD-9 300.4, 309.0 Diagnosis: Mild to Moderate Severe Neurotic Depression Setting: Outpatient Primary Care Country: GERMANY N: 120 Mean age: 49, Female: 59% | Total dropouts: 16/120 Outcomes reported: HAMD
HARRIS^ 293 ^ | FLUVOXAMINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII Diagnosis: Major Depression Setting: Outpatient Clinic Country: UK N: 69 Mean age: 43, Female: 72% | Total dropouts: 19/69 Outcomes reported: HAMD CGI
HEILIGENSTEIN^ 294 ^ | PLACEBO vs FLUOXETINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR RDC HAMD (17 ITEMS)>=15 (>=8) Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 89 Mean age: 40, Female: 71% | Total dropouts: 24/89 Outcomes reported: HAMD MADRS CGI
HELLERSTEIN^ 295 ^ | PLACEBO vs FLUOXETINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR SCID-P Diagnosis: Dysthymia Setting: Not Stated/Unclear Country: USA N: 35 Mean age: 36, Female: 51% | Total dropouts: 3/35 Outcomes reported: HAMD CGI

[Table of Individual Trials Continued: Hoencamp-Hutchinson]Appendix 3:

[Table of Individual Trials Continued: Hoencamp-Hutchinson]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
HOENCAMP^ 296 ^ | BROFAROMINE vs MAPROTILINE, LITHIUM Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR Diagnosis: Major Depression Setting: Mental Health Specialty Care Outpatient Clinic Country: NETHERLANDS N: 51 Mean age: 39, Female: 63% | Total dropouts: 10/51 Outcomes reported: HAMD CGI
HOFFMAN^ 297 ^ | HYPERICUM EXTRACT vs PLACEBO Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes | Inclusion criteria: Not given Diagnosis: Mild to Severe Depression Setting: Unclear Country: GERMANY N: 60 Mean age: 49, Female: 51% | Total dropouts: NG/60 Outcomes reported: Global Assessment
HOYBERG^ 298 ^ | MIRTAZAPINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (21 ITEMS) >=18 Diagnosis: Major Depression Setting: Mental Health Specialty Care Outpatient Clinic Inpatient Country: NORWAY UK N: 115 Mean age: 71, Female: 75% | Total dropouts: 24/115 Outcomes reported: HAMD MADRS CGI
HUTCHINSON^ 299 ^ | PAROXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD>=18 Special population: Elderly Diagnosis: Major Depression Setting: Primary Care Outpatient Clinic Country: UK N: 90 Mean age: 72, Female: 77% | Total dropouts: 23/90 Outcomes reported: HAMD CGI

[Table of Individual Trials Continued: Jakovljevic-Katona]Appendix 3:

[Table of Individual Trials Continued: Jakovljevic-Katona]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
JAKOVLJEVIC^ 300 ^ | FLUOXETINE vs MAPROTILINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIV HAMD (17 ITEMS) 18-26 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: CENTRAL AND EAST EUROPE N: 98 Mean age: 51, Female: 83% | Total dropouts: 12/98 Outcomes reported: HAMD CGI
JENKINS^ 301 ^ | PLACEBO vs GEPIRONE 45 vs GEPIRONE 90 Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: RDC HAMD (25 ITEMS) >= 20 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 130 Mean age: 41, Female: 47% | Total dropouts: 86/130 Outcomes reported: HAMD CGI
JUDD^ 303 ^ | FLUOXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >17 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: AUSTRALIA N: 58 Mean age: 42, Female: 66% | Total dropouts: 12/58 Outcomes reported: HAMD
KAMIJIMA^ 304 ^ | SERTRALINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIV HAMD (17 ITEMS) >=16, ICD-10 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: JAPAN N: 188 Mean age: 46, Female: 47% | Total dropouts: 93/188 Outcomes reported: HAMD
KATONA^ 305 ^ | FLUOXETINE+PLACEBO vs FLUOXETINE+LITHIUM vs LOFEPRAMINE + PLACEBO vs LOFEPRAMINE + LITHIUM Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR Newcastle HAMD>=17 Diagnosis: Major Depression Setting: nbsp;Mental Health Specialty Care University Affiliated Outpatient Clinic Inpatient Country: UK N: 62 Mean age: 40, Female: 55% | Total dropouts: 15/62 Outcomes reported: HAMD
KATONA^ 306 ^ | PAROXETINE vs IMIPRAMINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: RDC MADRS >20, MMSE 17-23 Special population: Elderly, Dementia Diagnosis: Heterogeneous Setting: Not Stated/Unclear Country: AUSTRALIA GERMANY AUSTRIA FRANCE ITALY SWITZERLAND N: 198 Mean age: 76, Female: 78% | Total dropouts: 51/198 Outcomes reported: MADRS CGI

[Table of Individual Trials Continued: Keegan-Khan]Appendix 3:

[Table of Individual Trials Continued: Keegan-Khan]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
KEEGAN^ 307 ^ | FLUOXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIDIS, HAMD>20, BDI>-20 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: CANADA N: 42 Mean age: 44, Female: 67% | Total dropouts: 5/42 Outcomes reported: HAMD
KELLER^ 308 ^ | SERTRALINE vs IMIPRAMINE Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD-24>=18 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 635 Mean age: 42, Female: 59% | Total dropouts: NG/635 Outcomes reported: None
KERKHOFS^ 309 ^ | FLUOXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: RDC Diagnosis: Major Depression Setting: Not Stated/Unclear Country: BELGIUM N: 34 Mean age: 46, Female: 65% | Total dropouts: 15/34 Outcomes reported: HAMD MADRS CGI
KHAN^ 310 ^ | PLACEBO vs VENLAFAXINE 75 vs VENLAFAXINE 225 vs VENLAFAXONE 375 Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (21 ITEMS) >=20 Diagnosis: Major Depression Setting: Mental Health Specialty Care Outpatient Clinic Country: USA N: 93 Mean age: 41, Female: 56% | Total dropouts: NG/93 Outcomes reported: HAMD MADRS CGI

[Table of Individual Trials Continued: Kiev-Kwon]Appendix 3:

[Table of Individual Trials Continued: Kiev-Kwon]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
KIEV^ 311 ^ | PLACEBO vs PAROXETINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD (17 ITEMS)>=18 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 81 Mean age: 38, Female: 45% | Total dropouts: 30/81 Outcomes reported: HAMD MADRS
KIEV^ 312 ^ | FLUVOXAMINE vs PAROXETINE Duration of treatment: 7 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD>=20 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 60 Mean age: 41, Female: 53% | Total dropouts: 20/60 Outcomes reported: HAMD CGI
KIVELA^ 313 ^ | PLACEBO vs SULPIRIDE Duration of treatment: 20 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII ZUNG (45) Special population: Elderly, physically frail Diagnosis: Heterogeneous Setting: Primary Care Outpatient Clinic Country: FINLAND N: 66 Mean age: 76, Female: 70% | Total dropouts: 20/66 Outcomes reported: HAMD
KNIEBEL^ 314 ^ | HYPERICUM EXTRACT PLUS VALERIAN EXTRACT vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded:Yes Providers blinded: Yes | Inclusion criteria: DSM III R ICD-9 309.0, 309.1, 300.4, 300.5 Diagnosis: Dysthymia Setting: Primary Care, Mental Health Specialty Care Country: GERMANY N: 162 Mean age: 49, Female: 66% | Total dropouts: 7/162 Outcomes reported: HAMD CGI
KO^ 315 ^ | FLUOXETINE vs MAPROTILINE Duration of treatment: 6 weeks Subjects blinded: Unclear Providers blinded: Unclear Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (17-ITEMS)>14 Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Community Clinic Outpatient Clinic Country: TAIWAN N: 123 Mean age: 39, Female: 68% | Total dropouts: 60/123 Outcomes reported: HAMD
KOCZKAS^ 316 ^ | MOCLOBEMIDE vs CLOMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII Newcastle HAMD (17 ITEMS) >= 15 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: SWEDEN DENMARK N: 62 Mean age: 49, Female: 68% | Total dropouts: 21/62 Outcomes reported: HAMD
KONIG^ 317 ^ | HYPERICUM EXTRACT vs PLACEBO Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes | Inclusion criteria: Not given Diagnosis: Psychoaffective Disorder with Depressed Mood Setting: Primary Care Outpatients Country: GERMANY N: 112 Mean age: 45, Female: 75% | Total dropouts: NG/112 Outcomes reported: Depression Status Inventory Bf-S von Zerssen
KRAGH-SORENSEN^ 318 ^ | MOCLOBEMIDE vs CLOMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR Newcastle HAMD>10 Diagnosis: Major Depression Setting: Primary Care Country: DENMARK N: 142 Mean age: 48, Female: 70% | Total dropouts: 41/142 Outcomes reported: HAMD
KWON^ 319 ^ | FLUOXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Unclear Providers blinded: Unclear Excluded placebo responders: No | Inclusion criteria: DSMIII Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Country: SOUTH KOREA N: NG Mean age: 44, Female: 65% | Total dropouts: NG/NG Outcomes reported: HAMD

[Table of Individual Trials Continued: La Pia-Lecrubier]Appendix 3:

[Table of Individual Trials Continued: La Pia-Lecrubier]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
LA PIA^ 320 ^ | FLUOXETINE vs MIANSERIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR Special population: Elderly Diagnosis: Heterogeneous Setting: Outpatient Clinic Inpatient Country: ITALY N: 40 Mean age: 72, Female: 60% | Total dropouts: 5/40 Outcomes reported: HAMD
LAGHRISSI-THODE^ 321 ^ | PAROXETINE vs NORTRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR Special population: Elderly Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 20 Mean age: 64, Female: 41% | Total dropouts: 0/20 Outcomes reported: None
LAPIERRE^ 322 ^ | FLUOXETINE vs MOCLOBEMIDE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >=18 Diagnosis: Major Depression Setting: Outpatient Clinic Country: CANADA N: 128 Mean age: 41, Female: 74% | Total dropouts: 20/128 Outcomes reported: HAMD MADRS CGI
LARSEN^ 323 ^ | MOCLOBEMIDE vs CLOMIPRAMINE vs ISOCARBOXAZIDE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD (17 ITEMS) >=15, or quantitative scale for atypical depression >=15 Diagnosis: Heterogeneous Setting: Outpatient Clinic Country: DENMARK N: 167 Mean age: 45, Female: 65% | Total dropouts: 48/167 Outcomes reported: HAMD CGI
LARSEN^ 324 ^ | MOCLOBEMIDE vs CLOMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII Newcastle HAMD (17 ITEMS) >= 15x2, ONE WEEK REPORT Diagnosis: Major Depression Setting: Not Stated/Unclear Country: DENMARK N: 38 Mean age: 57, Female: 68% | Total dropouts: 9/38 Outcomes reported: HAMD
LARSEN^ 325 ^ | PLACEBO vs MOCLOBEMIDE vs CLOMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD >=15 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: DENMARK SWEDEN N: 60 Mean age: 52, Female: 67% | Total dropouts: 14/60 Outcomes reported: HAMD
LAURSEN^ 326 ^ | PAROXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: manic-depressive on ICD-8; HAMD (17 ITEMS)>15 Diagnosis: Heterogeneous Setting: Outpatient Clinic Inpatient Country: DENMARK N: 44 Mean age: 62, Female: 70% | Total dropouts: 14/44 Outcomes reported: HAMD
LAWS^ 327 ^ | FLUVOXAMINE vs LORAZEPAM Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: MADRS>=21 & CLINICAL ANXIETY SCALE >=11 Diagnosis: Mixed Anxiety Depression Setting: Primary Care Country: UK N: 112 Mean age: 50, Female: 78% | Total dropouts: 15/112 Outcomes reported: MADRS CGI
LECRUBIER^ 328 ^ | PLACEBO vs VENLAFAXINE VS IMIPRAMINE Duration of treatment: weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: RDC MILD TO MODERATE INTENSITY SCORE OF 4-8 ON RASKIN THREE AREAS SCALE Diagnosis: Heterogeneous Setting: Primary Care University Affiliated Outpatient Clinic Country: UK FRANCE ITALY N: NG Mean age: 39, Female: 67% | Total dropouts: NG/NG Outcomes reported: MADRS CGI
LECRUBIER^ 329 ^ | PLACEBO vs AMISULPRIDE vs IMIPRAMINE Duration of treatment: 26 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR Diagnosis: Heterogeneous Setting: Mental Health Specialty Care Private Clinic Outpatient Clinic Country: FRANCE N: 219 Mean age: 43, Female: 55% | Total dropouts: 101/219 Outcomes reported: MADRS CGI
LECRUBIER^ 330 ^ | MOCLOBEMIDE vs CLOMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD (17 ITEMS) Diagnosis: Major Depression Setting: Mental Health Specialty Care Private Clinic Outpatient Clinic Country: FRANCE N: 191 Mean age: 44, Female: 61% | Total dropouts: 38/191 Outcomes reported: HAMD CGI

[Table of Individual Trials Continued: Levine-Lydiard]Appendix 3:

[Table of Individual Trials Continued: Levine-Lydiard]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
LEVINE^ 331 ^ | FLUOXETINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: RDC HAMD>=17 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: UK N: 60 Mean age: 44, Female: 71% | Total dropouts: 10/60 Outcomes reported: HAMD MADRS
LINEBERRY^ 332 ^ | PLACEBO vs BUPROPION Duration of treatment: weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (21 ITEMS >= 20) Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 219 Mean age: 41, Female: 65% | Total dropouts: 57/219 Outcomes reported: HAMD MADRS CGI
LINGjAERDE^ 333 ^ | MOCLOBEMIDE vs DOXEPIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: NO SPECIFIED DIAGNOSIS REQUIRED Special population: Severe medical illness Diagnosis: Heterogeneous Setting: Primary Care Outpatient Clinic Country: NORWAY N: 56 Mean age: 43, Female: 66% | Total dropouts: 7/56 Outcomes reported: MADRS CGI
LINK^ 334 ^ | PAROXETINE vs CLOMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: ICD-9, DANISH UNIVERSITIES ANTIDEPRESSANT GROUP; HAMD (17 ITEMS) >=18 Special population: Elderly Diagnosis: Heterogeneous Setting: Not Stated/Unclear Country: UK N: 116 Mean age: 49, Female: NG | Total dropouts: 53/116 Outcomes reported: HAMD
LINK^ 334 ^ | PAROXETINE vs CLOMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: NOT GIVEN Diagnosis: Heterogeneous Setting: Not Stated/Unclear Country: UK N: 85 Mean age: NG, Female: NG | Total dropouts: 23/85 Outcomes reported: HAMD
LONNQVIST^ 335 ^ | FLUOXETINE vs MOCLOBEMIDE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >= 16 Diagnosis: Major Depression Setting: Mental Health Specialty Care Outpatient Clinic Inpatient Country: FINLAND N: 209 Mean age: 47, Female: 65% | Total dropouts: 40/209 Outcomes reported: HAMD MADRS CGI
LOPEZ-IBOR^ 336 ^ | FLUOXETINE vs MILNACIPRAN Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR RDC MADRS >=25; CGI >=3; Raskin depression scale score > COVI anxiety scale Diagnosis: Major Depression Setting: Not Stated/Unclear Country: FRANCE SPAIN N: 193 Mean age: NG, Female: NG | Total dropouts: NG/193 Outcomes reported: HAMD MADRS
LOPEZ-IBOR^ 336 ^ | FLUVOXAMINE vs MILNACIPRAN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR MADRS >=25; CGI >=3; Raskin depression scale score > COVI anxiety scale Diagnosis: Major Depression Setting: Not Stated/Unclear Country: Unclear N: 113 Mean age: NG, Female: NG | Total dropouts: NG/113 Outcomes reported: HAMD MADRS
LYDIARD^ 337 ^ | PLACEBO vs FLUVOXAMINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS) >=22, CGI AT LEAST MODERATELY DEPRESSED Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 54 Mean age: 47, Female: 69% | Total dropouts: 9/54 Outcomes reported: HAMD

[Table of Individual Trials Continued: Macher-Moller]Appendix 3:

[Table of Individual Trials Continued: Macher-Moller]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
MACHER^ 338 ^ | MOCLOBEMIDE vs AMINEPTINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: HAMD (17 ITEMS) Diagnosis: Major Depression Setting: Mental Health Specialty Care Private Clinic Outpatient Clinic Country: FRANCE N: 184 Mean age: NG, Female: NG | Total dropouts: 71/184 Outcomes reported: HAMD CGI
MAHAPATRA^ 339 ^ | VENLAFAXINE vs DOTHIEPIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (21 ITEMS) >=18, MMSE >23 Special population: Elderly Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: UK NETHERLANDS N: 92 Mean age: 74, Female: 71% | Total dropouts: 16/92 Outcomes reported: HAMD MADRS CGI
MANDOKI^ 340 ^ | COGNITIVE BEHAVIOR vs VENLAFAXINE+PSYCHOTHERAPY Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIV Special population: Adolescent, Psychotherapy Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Country: USA N: 40 Mean age: 13, Female: 24% | Total dropouts: 7/40 Outcomes reported: HAMD
MARCH^ 341 ^ | PLACEBO vs FLUVOXAMINE vs IMIPRAMINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS) >=22, BPRS <= 2, CGI MODERATELY ILL Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 54 Mean age: 39, Female: 69% | Total dropouts: 14/54 Outcomes reported: HAMD MADRS
MARTTILA^ 342 ^ | MIRTAZAPINE vs DOXEPIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII RDC HAMD>=18 Diagnosis: Major Depression Setting: Mental Health Specialty Care Outpatient Clinic Inpatient Country: FINLAND NETHERLANDS N: 163 Mean age: 41, Female: 60% | Total dropouts: 27/163 Outcomes reported: HAMD MADRS
MASCO^ 343 ^ | BUPROPION vs NORTRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: HAMD (21 ITEMS) >= 20 Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 115 Mean age: 44, Female: 54% | Total dropouts: 37/115 Outcomes reported: HAMD CGI
MASCO^ 344 ^ | FLUOXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: HAMD>=20,RASKIN>=8 Diagnosis: Major Depression Setting: Mental Health Specialty Care Private Clinic Outpatient Clinic Country: USA N: 41 Mean age: 51, Female: 81% | Total dropouts: 6/41 Outcomes reported: HAMD CGI
MAURI^ 345 ^ | PLACEBO vs FLUVOXAMINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR Special population: HIV Positive Diagnosis: Minor Depression Setting: Not Stated/Unclear Country: ITALY N: 26 Mean age: 35, Female: 27% | Total dropouts: NG/26 Outcomes reported: HAMD
MCGRATH^ 346 ^ | PLACEBO vs GEPIRONE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: RDC COLUMBIA CRITERIA HAMD (21 ITEMS) >=10 Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 60 Mean age: 38, Female: 35% | Total dropouts: 21/60 Outcomes reported: HAMD MADRS CGI
MEIGNAN-DEBRAY^ 347 ^ | PLACEBO vs MEDIFOXAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII MADRS>=20 Special Population: Elderly Diagnosis: Major Depression Setting: Inpatient Country: FRANCE N: 101 Mean age: 82, Female: 90% | Total dropouts: 10/101 Outcomes reported: MADRS
MENDELS^ 348 ^ | PLACEBO vs VENLAFAXINE 25 vs VENLAFAXONE 75 vs VENLAFAXINE 200 Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD >=20 Diagnosis: Major Depression Setting: Private Clinic Outpatient Clinic Country: USA N: 312 Mean age: 39, Female: 67% | Total dropouts: 80/312 Outcomes reported: HAMD MADRS CGI
MENDELS^ 349 ^ | PLACEBO vs NEFAZODONE 300 vs NEFAZODONE 600 Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: RDC HAMD(17 ITEMS) >20 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 240 Mean age: 39, Female: 62% | Total dropouts: 59/240 Outcomes reported: HAMD CGI
MERTENS^ 350 ^ | PAROXETINE vs MIANSERIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD (21 ITEMS) >= 18 Diagnosis: Heterogeneous Setting: Mental Health Specialty Care Inpatient Country: BELGUIM N: 67 Mean age: 51, Female: 70% | Total dropouts: 6/67 Outcomes reported: HAMD
MOLLER^ 351 ^ | PAROXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD (21 ITEMS) >=18 Diagnosis: Major Depression Setting: Inpatient Country: EUROPE N: 223 Mean age: NG, Female: NG | Total dropouts: 86/223 Outcomes reported: HAMD CGI
MOLLER^ 352 ^ | BROFAROMINE vs IMIPRAMINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD (21 ITEMS) >= 16 Special population: Elderly Diagnosis: Major Depression Setting: Private Clinic Outpatient Clinic Country: GERMANY N: 195 Mean age: 68, Female: 75% | Total dropouts: 40/195 Outcomes reported: HAMD
MOLLER^ 353 ^ | BROFAROMINE vs IMIPRAMINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: RDC HAMD(21 ITEMS) >=18 Diagnosis: Major Depression Setting: Outpatient Clinic Country: GERMANY N: 224 Mean age: 47, Female: 59% | Total dropouts: 46/224 Outcomes reported: HAMD

[Table of Individual Trials Continued: Montgomery-Murasaki]Appendix 3:

[Table of Individual Trials Continued: Montgomery-Murasaki]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
MONTGOMERY^ 354 ^ | PLACEBO vs FLUOXETINE Duration of treatment: 24 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR Diagnosis: Heterogeneous Setting: Mental Health Specialty Care Country: UK N: 107 Mean age: NG, Female: NG | total dropouts: NG/107 Outcomes reported: DSM IIIR
MONTGOMERY^ 355 ^ | MINAPRINE 200 vs MINAPRINE 300 vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (21 ITEMS) >=17 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: UK N: 101 Mean age: 43, Female: 63% | Total dropouts: 31/101 Outcomes reported: HAMD MADRS
MONTGOMERY^ 356 ^ | PLACEBO vs PAROXETINE Duration of treatment: 52 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (21 ITEMS)>=18 & 2 PRIOR EPISODES IN PAST 4 YRS Diagnosis: Major Depression Setting: Mental Health Specialty Care Outpatient Clinic Country: UK N: 135 Mean age: 48, Female: 79% | Total dropouts: 57/135 Outcomes reported: HAMD
MONTGOMERY^ 357 ^ | PLACEBO vs CITALOPRAM 20 vs CITALOPRAM 40 Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR MADRS>=22 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: UK DENMARK N: 199 Mean age: 44, Female: 69% | Total dropouts: 44/199 Outcomes reported: None
MONTGOMERY^ 358 ^ | PLACEBO vs CITALOPRAM 20 vs CITALOPRAM 40 Duration of treatment: 24 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR Diagnosis: Major Depression Setting: Not Stated/Unclear Country: UK DENMARK N: 147 Mean age: NG, Female: NG | Total dropouts: 39/147 Outcomes reported: MADRS
MOON^ 359 ^ | SERTRALINE vs CLOMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD>=17 & HAMA>=16 Diagnosis: Mixed Anxiety Depression Setting: Primary Care Outpatient Clinic Country: UK N: 106 Mean age: 44, Female: 47% | Total dropouts: 14/106 Outcomes reported: HAMD CGI
MOON^ 360 ^ | FLUVOXAMINE vs MIANSERIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII MADRS>=24 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: UK N: 62 Mean age: 42, Female: 68% | Total dropouts: 13/62 Outcomes reported: MADRS CGI
MOON^ 361 ^ | LOFEPRAMINE vs PAROXETINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Unclear Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR Diagnosis: Major Depression Setting: Primary Care Country: UK N: 122 Mean age: NG, Female: 71% | Total dropouts: 17/122 Outcomes reported: MADRS CGI
MUIJEN^ 362 ^ | PLACEBO vs FLUOXETINE vs MIANSERIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: RDC HAMD (17 ITEMS)>=17 Diagnosis: Heterogeneous Setting: Outpatient Clinic Country: UK N: 81 Mean age: 35, Female: 67% | Total dropouts: 37/81 Outcomes reported: HAMD
MULLIN^ 363 ^ | FLUVOXAMINE vs DOTHIEPIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD (17 ITEMS) >=17 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: UK N: 73 Mean age: 47, Female: 71% | Total dropouts: 23/73 Outcomes reported: HAMD CGI
MURASAKI^ 364 ^ | SERTRALINE vs SERTRALINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >= 16 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: JAPAN N: 155 Mean age: 45, Female: 56% | Total dropouts: 118/155 Outcomes reported: HAMD

[Table of Individual Trials Continued: Nair-Othmer]Appendix 3:

[Table of Individual Trials Continued: Nair-Othmer]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
NAIR^ 365 ^ | PLACEBO vs MOCLOBEMIDE vs NORTRIPTYLINE Duration of treatment: 7 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD(17 ITEMS) >=18 Special population: Elderly Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: CANADA UK DENMARK N: 109 Mean age: 70, Female: 71% | Total dropouts: 54/109 Outcomes reported: HAMD CGI
NAPPI^ 366 ^ | RITANSERIN vs AMITRIPTYLINE Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD >18 Diagnosis: Dysthymia Setting: Mental Health Specialty Care University Affiliated Country: ITALY N: 38 Mean age: 38, Female: 79% | Total dropouts: 0/38 Outcomes reported: HAMD
NEMEROFF^ 367 ^ | FLUVOXAMINE vs SERTRALINE Duration of treatment: 7 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (21 ITEMS)>20, HAMD depressed mood >2, Raskin 8, COVI Anxiety Scale score < Raskin Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 97 Mean age: 40, Female: 61% | Total dropouts: 25/97 Outcomes reported: HAMD CGI
NEWBURN^ 368 ^ | MOCLOBEMIDE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD>17 Special population: Adolescent Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: NEW ZEALAND N: 49 Mean age: 37, Female: 69% | Total dropouts: 12/49 Outcomes reported: HAMD
NIELSEN^ 369 ^ | FLUOXETINE vs IMIPRAMINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII BECH-RAFAELSEN MELANCHOLIA SCALE, HAMD>18 Diagnosis: Major Depression Setting: Outpatient Clinic Country: DENMARK N: 59 Mean age: 45, Female: 75% | Total dropouts: 16/59 Outcomes reported: HAMD CGI
NOGUERA^ 370 ^ | FLUOXETINE vs CLOMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS) >=17;RASKIN>=8 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: SPAIN N: 120 Mean age: 46, Female: 73% | Total dropouts: 16/120 Outcomes reported: HAMD CGI
NYTH^ 371 ^ | PLACEBO vs CITALOPRAM Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD>14 Special population: Elderly Diagnosis: Heterogeneous Setting: Not Stated/Unclear Country: SWEDEN NORWAY DENMARK N: 149 Mean age: 77, Female: 69% | Total dropouts: 55/149 Outcomes reported: HAMD MADRS CGI
OHRBERG^ 372 ^ | PAROXETINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >=15 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: DENMARK N: 159 Mean age: 44, Female: 73% | Total dropouts: 40/159 Outcomes reported: HAMD
OLIE^ 373 ^ | PLACEBO vs SERTRALINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >=21 Diagnosis: Major Depression Setting: Outpatient Clinic Country: FRANCE UK N: 258 Mean age: 44, Female: 63% | Total dropouts: 72/258 Outcomes reported: HAMD MADRS CGI
ORSEL DONBAK^ 374 ^ | MOCLOBEMIDE vs SERTRALINE Duration of treatment: 13 weeks Subjects blinded: No Providers blinded: No Excluded placebo responders: No | Inclusion criteria: DSMIIIR Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: TURKEY N: 55 Mean age: 36, Female: 58% | Total dropouts: 19/55 Outcomes reported: HAMD
OSTERHEIDER^ 375 ^ | HYPERICUM EXTRACT vs PLACEBO Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes | Inclusion criteria: Not given Diagnosis: Moderately Sever to Severe Depression Setting: Unclear Country: NG N: 47 Mean age: 43, Female: 65% | Total dropouts: NG/47 Outcomes reported: HAMD CGI
OTHMER^ 376 ^ | BUPROPION vs AMITRIPTYLINE Duration of treatment: 52 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII Feighner DSMIII&FEIGHNER; MUST BE RESPONDER DURING ACUTE PHASE TREATMENT (HAMD DROP BY >=35) Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 60 Mean age: NG, Female: 60% | Total dropouts: NG/60 Outcomes reported: HAMD

[Table of Individual Trials Continued: Pancheri-Phanjoo]Appendix 3:

[Table of Individual Trials Continued: Pancheri-Phanjoo]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
PANCHERI^ 377 ^ | MOCLOBEMIDE vs IMIPRAMINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (21 ITEMS) >= 18 Special population: Elderly Diagnosis: Major Depression Setting: Outpatient Clinic Country: ITALY N: 30 Mean age: 78, Female: 63% | Total dropouts: 5/30 Outcomes reported: HAMD CGI
PANDE^ 378 ^ | FLUOXETINE vs PHENELZINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR COLUMBIA SCORE >10 Diagnosis: Major Depression Setting: University Affiliated Outpatient Clinic Country: USA N: 40 Mean age: 34, Female: 83% | Total dropouts: 2/40 Outcomes reported: HAMD CGI
PARNETTI^ 379 ^ | PLACEBO vs MINAPRINE Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: MMSE >=24, ICD9=309.1 Special population: Elderly Diagnosis: Minor Depression Setting: Not Stated/Unclear Country: ITALY N: 130 Mean age: 71, Female: 64% | Total dropouts: 7/130 Outcomes reported: CGI
PATRIS^ 380 ^ | CITALOPRAM vs FLUOXETINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR MADRS>=22 Diagnosis: Major Depression Setting: Primary Care Outpatient Clinic Country: FRANCE N: 357 Mean age: 43, Female: 77% | Total dropouts: 35/357 Outcomes reported: HAMD MADRS CGI
PAYKEL^ 381 ^ | PLACEBO vs FENGABINE Duration of treatment: weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD>15 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: UK N: 49 Mean age: 39, Female: 67% | Total dropouts: 17/49 Outcomes reported: HAMD
PEREZ^ 382 ^ | FLUVOXAMINE vs MIANSERIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII MADRS >30 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: UK N: 63 Mean age: 41, Female: 73% | Total dropouts: 16/63 Outcomes reported: MADRS CGI
PEREZ^ 383 ^ | FLUOXETINE + PLACEBO vs FLOUXETINE + PINDOLOL Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIV Diagnosis: Major Depression Setting: Mental Health Specialty Care Country: SPAIN N: 111 Mean age: 43, Female: 71% | Total dropouts: 22/111 Outcomes reported: HAMD MADRS CGI
PERRY^ 384 ^ | FLUOXETINE vs TRAZODONE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD>=20 Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 40 Mean age: 41, Female: 53% | Total dropouts: ng/40 Outcomes reported: HAMD CGI
PESELOW^ 385 ^ | PLACEBO vs PAROXETINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS) >= 18; RASKIN DEPRESSION SCALE > 9; RASKIN > COVI ANXIETY SCALE Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 702 Mean age: NG, Female: NG | Total dropouts: NG/702 Outcomes reported: HAMD CGI
PHANJOO^ 386 ^ | FLUVOXAMINE vs MIANSERIN Duration of treatment: 6 weeks Subjects blinded: Unclear Providers blinded: Unclear Excluded placebo responders: Yes | Inclusion criteria: DSMIII MADRS >30 Special population: Elderly Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: UK N: 50 Mean age: 77, Female: 68% | Total dropouts: 19/50 Outcomes reported: MADRS CGI

[Table of Individual Trials Continued: Philipp-Reebye]Appendix 3:

[Table of Individual Trials Continued: Philipp-Reebye]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
PHILIPP^ 387 ^ | MOCLOBEMIDE vs DOXEPIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: RDC HAMD (17 ITEMS)>=18 Diagnosis: Major Depression Setting: Mental Health Specialty Care Private Clinic Outpatient Clinic Country: GERMANY N: 237 Mean age: 42, Female: NG | Total dropouts: 68/237 Outcomes reported: HAMD CGI
PRESKORN^ 388 ^ | PLACEBO vs BUPROPION vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 61 Mean age: NG, Female: NG | Total dropouts: NG/61 Outcomes reported:None
PRESKORN^ 389 ^ | FLUOXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD >= 20 Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 61 Mean age: NG, Female: NG | Total dropouts: 27/61 Outcomes reported: HAMD CGI
RAHMAN^ 390 ^ | FLUVOXAMINE vs DOTHIEPIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII MADRS >=30 Special population: Elderly, physically ill Diagnosis: Major Depression Setting: Inpatient Country: UK N: 52 Mean age: 74, Female: 77% | Total dropouts: 16/52 Outcomes reported: MADRS CGI
RAMAEKERS^ 391 ^ | FLUOXETINE vs MOCLOBEMIDE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >=17 Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Country: BELGUIM N: 41 Mean age: 42, Female: 39% | Total dropouts: 4/41 Outcomes reported: HAMD MADRS
RAMPELLO^ 392 ^ | PLACEBO vs MINAPRINE vs AMINEPTINE vs CLOMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR Diagnosis: Heterogeneous Setting: Not Stated/Unclear Country: ITALY N: 40 Mean age: NG, Female: 60% | Total dropouts: 5/40 Outcomes reported: HAMD
RAPAPORT^ 393 ^ | FLUOXETINE vs FLUVOXAMINE Duration of treatment: 7 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (21 ITEMS) >= 20 Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 100 Mean age: 39, Female: 64% | Total dropouts: 15/100 Outcomes reported: HAMD CGI
RAVINDRAN^ 394 ^ | PAROXETINE vs CLOMIPRAMINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: "DEPRESSION WITH ANXIETY; MADRS>=20; CLINICAL ANXIETY SCALE >=11 Diagnosis: Major Depression and anxiety Setting: Primary Care Country: MANY EUROPEAN N: 1019 Mean age: 43, Female: 73% | Total dropouts: 262/1019 Outcomes reported: HAMD MADRS CGI
RAVINDRAN^ 395 ^ | PLACEBO vs SERTRALINE vs DESIPRAMINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >=15 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: CANADA N: 103 Mean age: 38, Female: 59% | Total dropouts: 45/103 Outcomes reported: HAMD MADRS CGI
REEBYE^ 396 ^ | FEMOXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: Newcastle HAMD >18 Diagnosis: Major Depression Setting: Mental Health Specialty Care Community Clinic Outpatient Clinic Inpatient Country: DENMARK N: 84 Mean age: NG, Female: NG | Total dropouts: 7/84 Outcomes reported: HAMD

[Table of Individual Trials Continued: Reh-Robert]Appendix 3:

[Table of Individual Trials Continued: Reh-Robert]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
REH ^ 397 ^ | HYPERICUM EXTRACT vs PLACEBO Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes | Inclusion criteria: ICD-9 300.4, 309.0 Diagnosis: Neurotic Depression Setting: Mental Health Specialty Care Outpatients Country: GERMANY N: 50 Mean age: 48, Female: 78% | Total dropouts: NG/50 Outcomes reported: HAMD CGI
REIMHERR^ 398 ^ | PLACEBO vs SERTRALINE vs AMITRIPTYLINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (24 ITEMS) >=18, RASKIN >COVI Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA CANADA N: 448 Mean age: 39, Female: 54% | Total dropouts: 180/448 Outcomes reported: HAMD CGI
REMICK^ 399 ^ | FLUOXETINE vs DESIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (21 ITEMS) >=20 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: CANADA N: 47 Mean age: 42, Female: 59% | Total dropouts: 7/47 Outcomes reported: HAMD CGI
REMICK^ 400 ^ | FLUOXETINE vs DOXEPIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD>20 Diagnosis: Major Depression Setting: Private Clinic Outpatient Clinic Country: CANADA N: 75 Mean age: 43, Female: 60% | Total dropouts: 23/75 Outcomes reported: HAMD CGI
REMICK^ 401 ^ | FLUVOXAMINE vs AMITRIPTYLINE Duration of treatment: 7 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >20 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: CANADA N: 33 Mean age: 41, Female: 61% | Total dropouts: 11/33 Outcomes reported: HAMD CGI
REYNNAERT^ 402 ^ | FLUOXETINE vs MOCLOBEMIDE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >=16 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: BELGIUM N: 101 Mean age: 46, Female: NG | Total dropouts: 19101 Outcomes reported: HAMD
RICHOU^ 403 ^ | MIRTAZAPINE vs CLOMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII RDC HAMD (21 ITEMS) >=18 Diagnosis: Major Depression Setting: Inpatient Country: FRANCE N: 174 Mean age: 51, Female: 71% | Total dropouts: 51/174 Outcomes reported: HAMD MADRS
RICKELS^ 404 ^ | PLACEBO vs PAROXETINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD(17 ITEMS) >=18, RASKIN DEP SCAL > COVI Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 111 Mean age: 45, Female: 64% | Total dropouts: 38/111 Outcomes reported: HAMD CGI
RICKELS^ 405 ^ | PLACEBO vs NEFAZODONE vs IMIPRAMINE Duration of treatment: 68 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >=20 Diagnosis: Heterogeneous Setting: Outpatient Country: USA N: 118 Mean age: NG, Female: NG | Total dropouts: NG/118 Outcomes reported: HAMD CGI
RICKELS^ 406 ^ | PLACEBO vs NEFAZODONE vs IMIPRAMINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR Diagnosis: Major Depression Setting: Primary Care Mental Health Specialty Care Outpatient Clinic Country: USA N: 283 Mean age: 43, Female: 63% | Total dropouts: 112/283 Outcomes reported: HAMD CGI
ROBERT^ 407 ^ | PLACEBO vs CITALOPRAM Duration of treatment: 24 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR MADRS>=25; RESPONDERS TO OPEN LABEL TX Diagnosis: Major Depression Setting: Not Stated/Unclear Country: FRANCE N: 226 Mean age: 48, Female: 72% | Total dropouts: NG/226 Outcomes reported: HAMD MADRS

[Table of Individual Trials Continued: Robertson-Schmidt]Appendix 3:

[Table of Individual Trials Continued: Robertson-Schmidt]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
ROBERTSON^ 408 ^ | FLUOXETINE vs LOFEPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD>=17 Diagnosis: Heterogeneous Setting: Mental Health Specialty Care University Affiliated Community Clinic Outpatient Clinic Inpatient Country: UK N: 183 Mean age: 39, Female: 65% | Total dropouts: 40/183 Outcomes reported: HAMD
ROBINSON^ 409 ^ | FLUVOXAMINE vs LOFEPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: not given Diagnosis: Heterogeneous Setting: Outpatient Clinic Country: UK N: 66 Mean age: 29, Female: 56% | Total dropouts: 16/66 Outcomes reported: HAMD CGI
ROOSE^ 410 ^ | PAROXETINE vs NORTRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIV HAMD (17 ITMES) >=16 Special population: Ischemic heart diesease Diagnosis: Major Depression Setting: University Affiliated Outpatient Clinic Country: USA N: 81 Mean age: 58, Female: 17% | Total dropouts: 18/81 Outcomes reported: HAMD
ROPERT^ 411 ^ | FLUOXETINE vs CLOMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD>=18, HAMD (21 ITEMS) <=25 Diagnosis: Major Depression Setting: Outpatient Clinic Country: FRANCE N: 143 Mean age: 44, Female: 65% | Total dropouts: 20/143 Outcomes reported: HAMD MADRS CGI
ROSENBERG^ 412 ^ | CITALOPRAM 30 vs CITALOPRAM 60 vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: HAMD>=14 AND "IN NEED OF ANTIDEPRESSANT TREATMENT" Minor Depression Diagnosis: Major Depression Setting: Primary Care Outpatient Clinic Country: DENMARK NORWAY SWEDEN FINLAND N: 472 Mean age: 47, Female: 69% | Total dropouts: 72/472 Outcomes reported: HAMD MADRS CGI
ROTH^ 413 ^ | PLACEBO vs FLUVOXAMINE vs DESIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS) >22 Diagnosis: Major Depression Setting: University Affiliated Outpatient Clinic Country: USA N: 90 Mean age: 42, Female: 65% | Total dropouts: 19/90 Outcomes reported: HAMD MADRS CGI
ROTH^ 414 ^ | PLACEBO vs MOCLOBEMIDE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII MMSE >11, <28. SCAGS >= 40, SCAG (4 ITEMS) >=8, GDS >5, HAMD (17 ITEMS)>=14 Special population: Elderly, cognitively impaired Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: INTERNATIONAL N: 726 Mean age: 74, Female: 77% | Total dropouts: NG/726 Outcomes reported: HAMD CGI
SALZMANN^ 415 ^ | MINAPRINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS)>=17 Diagnosis: Dysthymia Setting: Outpatient Clinic Country: GERMANY N: 67 Mean age: 55, Female: 81% | Total dropouts: 16/67 Outcomes reported: HAMD CGI
SCHMIDT ^ 416 ^ | HYPERICUM EXTRACT vs PLACEBO Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes | Inclusion criteria: ICD-9 300.4, 309.0 Diagnosis: Neurotic Depression Setting: Mental Health Care Specialty, Outpatients, Primary Care Country: GERMANY N: 65 Mean age: 44, Female: 76% | Total dropouts: NG/65 Outcomes reported: HAMD

[Table of Individual Trials Continued: Schnyder-Skausig]Appendix 3:

[Table of Individual Trials Continued: Schnyder-Skausig]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
SCHNYDER^ 419 ^ | PAROXETINE vs MAPROTILINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (21 ITEMS) >=18 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: SWITZERLAND N: 71 Mean age: 44, Female: 65% | Total dropouts: 14/71 Outcomes reported: HAMD MADRS CGI
SCHONE^ 420 ^ | FLUOXETINE vs PAROXETINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (21 ITEMS) >= 18 Special population: Elderly Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: EUROPE N: 106 Mean age: 76, Female: 87% | Total dropouts: 18/106 Outcomes reported: HAMD MADRS
SCHWEIZER^ 421 ^ | PLACEBO vs VENLAFAXINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (21 ITEMS) >=20 Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Country: USA N: 224 Mean age: 42, Female: 67% | Total dropouts: 80/224 Outcomes reported: HAMD MADRS CGI
SCHWEIZER^ 422 ^ | PLACEBO vs VENLAFAXINE 75 vs VENLAFAXONE 225 vs VENLAFAXINE 375 Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (21 ITEMS) >=20 Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Private Clinic Outpatient Clinic Country: USA N: 60 Mean age: 46, Female: 37% | Total dropouts: 27/60 Outcomes reported: HAMD MADRS CGI
SHAW^ 423 ^ | CITALOPRAM vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD (17 ITEMS)>= 18 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: UK N: 49 Mean age: NG, Female: NG | Total dropouts: 22/49 Outcomes reported: HAMD
SHRIVASTAVA^ 424 ^ | VENLAFAXINE vs IMIPRAMINE Duration of treatment: 52 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 381 Mean age: 42, Female: 54% | Total dropouts: 276/381 Outcomes reported: CGI
SHRIVASTAVA^ 425 ^ | PLACEBO vs PAROXETINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS) >18,RASKIN>8,COVI < RASKIN Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 120 Mean age: 34, Female: 39% | Total dropouts: 66/120 Outcomes reported: HAMD MADRS CGI
SIMEON^ 426 ^ | PLACEBO vs FLUOXETINE Duration of treatment: 7 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD > 20 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: CANADA N: 40 Mean age: 16, Female: 55% | Total dropouts: 10/40 Outcomes reported: None
SIMON^ 427 ^ | FLUOXETINE vs DESIPRAMINE vs IMIPRAMINE Duration of treatment: 24 weeks Subjects blinded: No Providers blinded: No Excluded placebo responders: No | Inclusion criteria: DSMIIIR PRIMARY CARE MD DECISION TO TREAT Diagnosis: Heterogeneous Setting: Primary Care Outpatient Clinic Country: USA N: 536 Mean age: 41, Female: 73% | Total dropouts: NG/536 Outcomes reported: HAMD
SKAUSIG^ 428 ^ | PAROXETINE vs IMIPRAMINE Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD >=18 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: DENMARK N: 31 Mean age: NG, Female: 65% | Total dropouts: =16/31 Outcomes reported: HAMD

[Table of Individual Trials Continued: Skrumsager-Szegedi]Appendix 3:

[Table of Individual Trials Continued: Skrumsager-Szegedi]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
SKRUMSAGER^ 429 ^ | FEMOXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DEPRESSIVE ILLNESS REQUIRING TX HAMD>=17 Diagnosis: Major Depression Setting: Primary Care Country: DENMARK N: 81 Mean age: 42, Female: 75% | Total dropouts: 26/81 Outcomes reported: HAMD
SMERALDI^ 430 ^ | AMISULPRIDE vs FLUOXETINE Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR MADRS 14-26 Diagnosis: Dysthymia Setting: Mental Health Specialty Care Outpatient Clinic Country: ITALY N: 281 Mean age: 50, Female: 69% | Total dropouts: 72/281 Outcomes reported: MADRS CGI
SMITH^ 431 ^ | PLACEBO vs PAROXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (17 ITEMS) >=18, RDS>=8;COVI<RDS Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 77 Mean age: 45, Female: 50% | Total dropouts: 36/77 Outcomes reported: HAMD
SMITH^ 432 ^ | PLACEBO vs MIRTAZAPINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD >=18 Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 150 Mean age: 43, Female: 57% | Total dropouts: 53/150 Outcomes reported: HAMD MADRS CGI
SOUTH WALES ANTI-DEPRESSANT DRUG TRIAL GROUP^ 433 ^ | FLUOXETINE vs DOTHIEPIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD (17 ITEMS) > 17 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: UK N: 59 Mean age: 47, Female: 83% | Total dropouts: 23/59 Outcomes reported: HAMD
SRAMEK^ 434 ^ | PLACEBO vs ABT 200 vs FLUOXETINE Duration of treatment: 9 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (24 ITEMS) >=21 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 216 Mean age: 34, Female: 60% | Total dropouts: 59/216 Outcomes reported: HAMD MADRS CGI
STARK^ 435 ^ | PLACEBO vs FLUOXETINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (21 ITEMS) >= 20, RASKIN >=8 Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 540 Mean age: NG, Female: NG | Total dropouts: 269/540 Outcomes reported: HAMD CGI
STEGER ^ 436 ^ | HYPERICUM EXTRACT PLUS VALERIAN EXTRACT vs DESIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes | Inclusion criteria: Not given Diagnosis: Single Mild or Moderate Severe Depression Setting: Primary Care Outpatients Country: GERMANY N: 100 Mean age: 66, Female: 70% | Total dropouts: 6/100 Outcomes reported: CGI
STEINMEYER^ 437 ^ | MAPROTILINE vs MOCLOBEMIDE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD (17 ITEMS)>=17 Diagnosis: Major Depression Setting: Outpatient Clinic Country: GERMANY N: 115 Mean age: 48, Female: 63% | Total dropouts: 29/115 Outcomes reported: HAMD
STUPPAECK^ 438 ^ | PAROXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD (21 ITEMS) >=18 Diagnosis: Major Depression Setting: Mental Health Specialty Care Private Clinic Inpatient Country: EUROPE N: 153 Mean age: 47, Female: 66% | Total dropouts: 61/153 Outcomes reported: HAMD MADRS CGI
SULEMAN^ 439 ^ | FLUOXETINE vs MOCLOBEMIDE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: No Excluded placebo responders: No | Inclusion criteria: DSMIV HAMD (17ITEMS) >= 17 Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Country: ZIMBABWE N: 45 Mean age: 33, Female: NG | Total dropouts: 0/45 Outcomes reported: HAMD CGI
SUOMINEN^ 440 ^ | FEMOXETINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: RDC Newcastle NEWCASTE II, HAMD (17 ITEMS) >= 18 Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Country: DENMARK FINLAND N: 52 Mean age: 49, Female: 67% | Total dropouts: 6/52 Outcomes reported: HAMD CGI
SZEGEDI^ 441 ^ | PAROXETINE vs MAPROTILINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: RDC HAMD (17 ITEMS) >=13 Diagnosis: Heterogeneous Setting: Mental Health Specialty Care Outpatient Clinic Country: GERMANY N: 544 Mean age: 44, Female: 75% | Total dropouts: 131/544 Outcomes reported: HAMD MADRS CGI

[Table of Individual Trials Continued: Tammien-UK Moclo Bemide Study Group]Appendix 3:

[Table of Individual Trials Continued: Tammien-UK Moclo Bemide Study Group]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
TAMMIEN^ 442 ^ | FEMOXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: Newcastle HAMD>18 Diagnosis: Heterogeneous Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Inpatient Country: DENMARK N: 45 Mean age: 41, Female: 44% | Total dropouts: 11/45 Outcomes reported: HAMD CGI
TARAGANO^ 443 ^ | FLUOXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII NINCD AND STROKE/ALZHEIMERS Special population: Elderly, Alzheimers Diagnosis: Major Depression Setting: Outpatient Clinic Country: ARGENTINA N: 37 Mean age: 72, Female: 78% | Total dropouts: 15/37 Outcomes reported: HAMD
TARG^ 444 ^ | BEHAVIOR+PROB SOLVING vs FLUOXETINE + PSYCHOTHERAPYS Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD>=16 Special population: HIV, Psychotherapy Diagnosis: Heterogeneous Setting: Outpatient Clinic Country: USA N: 20 Mean age: 33, Female: 0% | Total dropouts: 2/20 Outcomes reported: HAMD
THASE^ 445 ^ | PLACEBO vs SERTRALINE vs IMIPRAMINE Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (29 ITEMS)>=12; or CGI >2 Diagnosis: Dysthymia Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Country: USA N: 416 Mean age: 42, Female: 65% | Total dropouts: NG/416 Outcomes reported: HAMD MADRS CGI
TIGNOL^ 446 ^ | FLUOXETINE vs PAROXETINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII MADRS>24 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: FRANCE N: 178 Mean age: 44, Female: 69% | Total dropouts: 2/178 Outcomes reported: MADRS CGI
TOLLEFSON^ 447 ^ | PLACEBO vs FLUOXETINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD-28>=16 Special population: Elderly Diagnosis: Major Depression Setting: University Affiliated Private Clinic Outpatient Clinic Country: USA N: 671 Mean age: 68, Female: 55% | Total dropouts: 137/671 Outcomes reported: HAMD CGI
TOLLEFSON^ 448 ^ | FLUOXETINE vs IMIPRAMINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII RDC HAMD (17 ITEMS) >17 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 124 Mean age: 37, Female: 69% | Total dropouts: 47/124 Outcomes reported: HAMD CGI
TOME^ 449 ^ | PAROXETINE+PLACEBO vs PAROXETINE+PINDOLOL Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: ICD10 FOR "MILD, MODERATE OR SEVERE UNIPOLAR DEPRESSION" & >=18 ON MADRS Diagnosis: Major Depression Setting: Outpatient Clinic Not Stated/Unclear Country: UK N: 83 Mean age: 35, Female: 60% | Total dropouts: 22/83 Outcomes reported: MADRS
TYLEE^ 450 ^ | FLUOXETINE vs VENLAFAXINE Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIV MADRS>=19 Diagnosis: Heterogeneous Setting: Primary Care Outpatient Clinic Country: IRELAND UK N: 341 Mean age: 45, Female: 71% | Total dropouts: 93/341 Outcomes reported: HAMD MADRS CGI
UCHA UDABE^ 451 ^ | PLACEBO vs MOCLOBEMIDE vs IMIPRAMINE Duration of treatment: weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD>=17 Diagnosis: Major Depression Setting: Outpatient Clinic Country: ARGENTINA N: 72 Mean age: 43, Female: 61% | Total dropouts: NG/72 Outcomes reported: HAMD
UK MOCLO BEMIDE STUDY GROUP^ 452 ^ | PLACEBO vs MOCLOBEMIDE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (17 ITEMS)>=16 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: UK N: 249 Mean age: NG, Female: 55% | Total dropouts: 89/249 Outcomes reported: HAMD CGI

[Table of Individual Trials Continued: Valdlucci-Versiani]Appendix 3:

[Table of Individual Trials Continued: Valdlucci-Versiani]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
VALDUCCI^ 453 ^ | PLACEBO vs FLUOXETINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD >=18 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: ITALY N: 40 Mean age: 46, Female: 58% | Total dropouts: 0/40 Outcomes reported: HAMD
VAN MOFFAERT^ 454 ^ | FLUOXETINE vs SERTRALINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >=18 WITH CGI .=3 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: BELGIUM N: 165 Mean age: 47, Female: 66% | Total dropouts: 108/165 Outcomes reported: HAMD MADRS CGI
VAN MOFFAERT^ 455 ^ | MIRTAZAPINE vs TRAZODONE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII RDC HAMD (17 ITEMS) >= 18 Diagnosis: Major Depression Setting: Inpatient Country: BELGIUM N: 200 Mean age: 46, Female: 70% | Total dropouts: 49/200 Outcomes reported: HAMD MADRS
VAN MOFFAERT^ 456 ^ | NEFAZODONE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII MADRS >27; HAMD (17 ITEMS)> 20 on first 17 ITEMS Diagnosis: Major Depression Setting: Mental Health Specialty Care University Affiliated Outpatient Clinic Country: BELGIUM N: 85 Mean age: NG, Female: 66% | Total dropouts: 8/85 Outcomes reported: HAMD MADRS CGI
VAN MOFFAERT^ 457 ^ | MOCLOBEMIDE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII Diagnosis: Minor Depression Setting: Outpatient Clinic Country: BELGIUM N: 17 Mean age: NG, Female: NG | Total dropouts: 6/17 Outcomes reported: HAMD
VAN MOFFAERT^ 457 ^ | MOCLOBEMIDE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII Diagnosis: Major Depression Setting: Mental Health Specialty Care Inpatient Country: BELGUIM N: 27 Mean age: NG, Female: NG | Total dropouts: 9/27 Outcomes reported: HAMD
VANELLE^ 458 ^ | PLACEBO vs FLUOXETINE Duration of treatment: 12 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR Diagnosis: Dysthymia Setting: Not Stated/Unclear Country: FRANCE N: 140 Mean age: 43, Female: 76% | Total dropouts: 25/140 Outcomes reported: HAMD CGI
VARTIAINEN^ 459 ^ | PLACEBO vs MIRTAZAPINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII RDC HAMD (21 ITEMS) >=18 Diagnosis: Major Depression Setting: Inpatient Country: FINLAND N: 114 Mean age: 46, Female: 54% | Total dropouts: 46/114 Outcomes reported: HAMD MADRS
VAZ-SERRA^ 460 ^ | MOCLOBEMIDE vs MAPROTILINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII Diagnosis: Heterogeneous Setting: Not Stated/Unclear Country: PORTUGUAL N: 80 Mean age: 44, Female: 84% | Total dropouts: 5/80 Outcomes reported: HAMD
VERCOULEN^ 461 ^ | PLACEBO vs FLUOXETINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: BDI>16 Special population: Chronic fatigue Diagnosis: Major Depression Setting: Primary Care Mental Health Specialty Care University Affiliated Outpatient Clinic Country: NETHERLAND N: 48 Mean age: 39, Female: 82% | Total dropouts: 4/48 Outcomes reported: BDI
VERSIANI^ 462 ^ | PLACEBO vs MOCLOBEMIDE vs IMIPRAMINE Duration of treatment: 8 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR CGI >=MODERATE Diagnosis: Heterogeneous Setting: Mental Health Specialty Care Outpatient Clinic Country: BRAZIL SWITZERLAND N: 315 Mean age: 41, Female: 71% | Total dropouts: 43/315 Outcomes reported: HAMD CGI
VERSIANI^ 463 ^ | PLACEBO vs MOCLOBEMIDE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII HAMD (21 ITEMS) >=17 Diagnosis: Major Depression Setting: Outpatient Clinic Country: BRAZIL N: 490 Mean age: 42, Female: 76% | Total dropouts: 148/490 Outcomes reported: HAMD

[Table of Individual Trials Continued: Volz-Zung]Appendix 3:

[Table of Individual Trials Continued: Volz-Zung]Appendix 3

Study | Methods | Participants | Dropouts/Outcomes
VOLZ^ 464 ^ | BROFAROMINE vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD (21 ITEMS) >=18 Diagnosis: Heterogeneous Setting: Inpatient Country: EUROPE AND ARGENTINA N: 198 Mean age: 45, Female: 75% | Total dropouts: 61/198 Outcomes reported: HAMD
VORBACH^ 465 ^ | HYPERICUM EXTRACT vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes | Inclusion criteria: Not given Diagnosis: Major Depression Setting: Outpatients Country: GERMANY N: 135 Mean age: 53, Female: 47% | Total dropouts: 5/135 Outcomes reported: HAMD CGI
VORBACH^ 466 ^ | HYPERICUM EXTRACT vs IMIPRAMINE Duration of treatment: 6 weeks Subjects blinded:Yes Providers blinded:Yes | Inclusion criteria: Not given Diagnosis: Severe Major Depression Setting: Mental Health Specialty Care Outpatients Country: GERMANY N: 209 Mean age: 49, Female: 74% | Total dropouts: 23/209 Outcomes reported: HAMD CGI
WALCZAK^ 467 ^ | PLACEBO vs FLUVOXAMINE 25 vs FLUVOXAMINE 50 vs FLUVOXAMINE 100 vs FLUVOXAMINE 150 Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (21 ITEMS) >20 Diagnosis: Major Depression Setting: Not Stated/Unclear Country: USA N: 600 Mean age: NG, Female: NG | Total dropouts: 240/600 Outcomes reported: HAMD CGI
WEISLER^ 468 ^ | BUPROPION vs TRAZODONE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIIIR HAMD (21 ITEMS) , >=20 Diagnosis: Major Depression Setting: Private Clinic Outpatient Clinic Country: USA N: 124 Mean age: 41, Female: 59% | Total dropouts: 50/124 Outcomes reported: HAMD CGI
WERNICKE^ 469 ^ | PLACEBO vs FLUOXETINE 5 vs FLUOXETINE 20 vs FLUOXETINE 40 Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD>20, CGI MODERATE Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 363 Mean age: 39, Female: 61% | Total dropouts: 141/363 Outcomes reported: HAMD CGI
WHEATLEY^ 470 ^ | HYPERICUM EXTRACT vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes | Inclusion criteria: Not given Diagnosis: Major Depression Setting: Primary Care, Outpatients Country: UK N: 165 Mean age: 40, Female: 56% | Total dropouts: NG/165 Outcomes reported: HAMD MADRS CGI
WHEATLEY^ 471 ^ | MINAPRINE vs MINAPRINE vs MIANSERIN Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIII Diagnosis: Major Depression Setting: Primary Care Outpatient Clinic Country: UK N: 117 Mean age: NG, Female: NG | Total dropouts: 18/117 Outcomes reported: HAMD
WHEATLEY^ 472 ^ | MINAPRINE vs MINAPRINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR Diagnosis: Major Depression Setting: Primary Care Outpatient Clinic Country: UK N: 144 Mean age: 44, Female: NG | Total dropouts: 33/144 Outcomes reported: HAMD MADRS
WILCOX^ 473 ^ | PLACEBO vs GEPIRONE 50 vs GEPIRONE 100 Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: DSMIIIR HAMD (17 ITEMS) >=20 Diagnosis: Major Depression Setting: Private Clinic Outpatient Clinic Country: USA N: 145 Mean age: 43, Female: 54% | Total dropouts: 62/145 Outcomes reported: HAMD MADRS CGI
WILLIAMS^ 474 ^ | FLUOXETINE vs MOCLOBEMIDE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD >= 17 Diagnosis: Major Depression Setting: Outpatient Clinic Inpatient Country: NEW ZEALAND N: 122 Mean age: 48, Female: 67% | Total dropouts: 30/122 Outcomes reported: HAMD CGI
WITTE^ 475 ^ | HYPERICUM EXTRACT vs PLACEBO Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes | Inclusion criteria: ICD-10 F32.1 Diagnosis: Major Depression Setting: Primary Care, Outpatients Country: N: 97 Mean age: 43, Female: 66% | Total dropouts: NG/97 Outcomes reported: HAMD CGI
YOUNG^ 476 ^ | FLUOXETINE vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: No | Inclusion criteria: RDC HAMD>18 Diagnosis: Major Depression Setting: Mental Health Specialty Care Outpatient Clinic Country: UK N: 64 Mean age: 46, Female: 66% | Total dropouts: 14/64 Outcomes reported: BDI
ZAPLETALEK^ 477 ^ | BROFAROMINE vs TRANYLCYPROMINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII HAMD>=18 Diagnosis: Major Depression Setting: Mental Health Specialty Care Inpatient Country: EUROPE N: 73 Mean age: 44, Female: 58% | Total dropouts: NG/73 Outcomes reported: HAMD
ZIVKOV^ 478 ^ | ORG 3770 vs AMITRIPTYLINE Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: DSMIII RDC HAMD (21 ITEMS) >=20 Diagnosis: Major Depression Setting: Inpatient Country: NETHERLANDS N: 251 Mean age: 47, Female: 78% | Total dropouts: 56/251 Outcomes reported: HAMD
ZUNG^ 479 ^ | PLACEBO vs BUPROPION 450 vs BUPROPION 900 Duration of treatment: 6 weeks Subjects blinded: Yes Providers blinded: Yes Excluded placebo responders: Yes | Inclusion criteria: HAMD (21 ITEMS) > 15, DSMII (CRITERIA SIMILAR TO DSMIII FOR MAJOR DEPRESSION) Diagnosis: Major Depression Setting: Outpatient Clinic Country: USA N: 131 Mean age: 37, Female: 68% | Total dropouts: 12/131 Outcomes reported: HAMD CGI