# Evidence Tables

Evidence Table 1. Nebulized Epinephrine vs. Nebulized Saline Placebo

Study Characteristics | Stated Objective of Study | Inclusion/Exclusion Criteria | Demographic Characteristics and Comorbidities | Intervention | Outcome | | Quality
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Kristjansson et al., 1993^52^ | To examine the effect of nebulized racemic adrenaline in infants and toddlers with acute bronchiolitis | • < 18 mos | 34 eligible, 29 completed study | [underlined: Group A (n = 15)] | | | Fair
| | • No atopic eczema | | Nebulized racemic adrenaline (20 mg/μ)
[underlined: Setting:] | | • Symptom score of 4 or more (0 – 10 scale) | [underlined: Sex] | | | | [underlined: Significant differences at baseline]
Sweden, Norway, multi-center, inpatient | | • Diagnosis of bronchiolitis according to the criteria of Court:^19^ | Racemic adrenaline: 67% male (10/15) | 0.1 ml if < 5 kg | Primary outcome
| | - rapid respiration, dyspnea, wheezing, chest recession, cough, rales, ronchi very frequent (present in 50% or more of children in age group) | Placebo: 64% male (9/14) | 0.15 ml if 5 – 6.9 kg | • Mean symptom score at 0, 15, 30, 45, 60 mins after inhalation | • Clinical score significantly lower in adrenaline group at all time intervals (P < 0.05) | SaO_2_and TcPo_2_lower in racemic adrenaline group, difference significant for TcPo_2_only (P < 0.05)
[underlined: Followup:] | | | [underlined: Mean age at enrollment] | 0.2 ml if 7 – 9.9 kg
Acute | | | NR | 0.25 ml if >10 kg
[underlined: Study design] | | | [underlined: Mean gestational age] | Mixed in 3 ml 0.9% saline, nebulized with air flow of 8 L/min via spacer and close fitting facemask
RCT-P | | - visible chest distension, increased pulmonary translucency on chest radiograph, nasal discharge, red pharynx frequent (present in 25% – 50% of children in age group) | NR | | • Mean change in SaO_2_at 0, 15, 30, 45, 60 mins after inhalation | • SaO_2_ improvement in adrenaline group significant (P < 0.05) immediately post-treatment but not thereafter
| | | [underlined: Comorbidities] | [underlined: Group B (n = 14)] | | | [underlined: Other comments]
[underlined: Length of enrollment] | | | None | Nebulized placebo | | | • Adrenaline group had lower TcPo_2_but CIs have significant overlap
NR | | | | | Secondary outcomes | | • No statistical correction for multiple comparisons
[underlined: Masking] | | - Fever very frequent, high fever uncommon | | Identically appearing solution and schedule
Double-blind | | • Symptom score of 4 or more (0 – 10 scale) | | [underlined: Other treatment] | • Mean change in TcPo_2_(kPa) at 0, 15, 30, 45, 60 mins after inhalation | • Significantly different at all time internals (P < 0.05)
| | | | NR
| | [underlined: Exclusion criteria] | | | • Mean respiratory rate (breaths/min) at 0, 15, 30, 45, 60 mins after inhalation | • No significant differences at 1 hr
| | None listed | | | • Mean heart rate (beats/min) at 0, 15, 30, 45, 60 mins after inhalation | • No significant differences at 1 hr
| | | | | • Mean diastolic and systolic pressure (mm Hg) at 0, 15, 30, 45, 60 mins after inhalation | • No significant differences at 1 hr
| | | | | Subgroup analysis | • SaO_2_significantly elevated throughout one hr period post-treatment (P < 0.05)
| | | | | Severely affected infants with baseline SaO_2_< 93% (n = 11)
| | | | | Adverse events
| | | | | None other than circumoral paleness

Evidence Table 2. Subcutaneous Epinephrine vs. Saline Placebo

Study characteristics | Stated objective of study | Inclusion/exclusion criteria | Demographic Characteristics and Cormorbidities | Intervention | Outcome | | Quality
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Lowell et al., 1987^110^ | To evaluate the efficacy of subcutaneous epinephrine in improving respiratory distress in children under the age of 24 months with acute episodes of wheezing | • < 24 months of age | 45 eligible, 30 randomized, 12 entered in observational cohort | [underlined: Group A (n=16)] | | | Good
[underlined: Setting:] | | • Wheezing on physical exam (high pitched, continuous, musical, respiratory sound on 2 examinations at least 5 mins. apart) | [underlined: Sex] | Epinephrine | | | [underlined: Significant differences at baseline]
United States, ED | | [underlined: Exclusion criteria] | Epinephrine: 63 % male (10/16) | 0.1 ml/kg (1 mg/ml) × 2 15 mins. apart | Primary outcome | | None
[underlined: Followup:] | | • Prior bronchodilator therapy | Placebo: 71% male (10/14) | [underlined: Group B (n=14)] | • Absolute change in clinical score (respiratory assessment change score or RACS) | • P < 0.05 | [underlined: Other comments]
Acute | | • Chronic cardorespiratory problem (cystic fibrosis or congenital heart disease) | [underlined: Mean age at enrollment in mo. ± SD] | Placebo | - Graphical presentation, figures cannot be extracted | | Observational cohort included to account for selection bias, observational cohort more likely to be moderately or severely ill (58%) compared to experimental cohort (30%)
[underlined: Study design] | | • Heart rate = 200 beats/min. | Epinephrine: 8.9 ± 5.8 | Saline 0.01 ml/kg × 2 15 mins. apart | • Improvement, defined as RACS = 4 or RACS<4 (epinephrine vs. placebo) | • P = 0.0067
RCT-P | | • Respiratory rate = 100 breaths/min | Placebo: 9.9 ± 5.6 | [underlined: Other treatment] | - 56% vs. 7%
[underlined: Length of enrollment] | | • Lethargy judged to be in incipient respiratory failure | [underlined: Mean gestational age] | NR | Subgroup analysis
October 1982–May 1983 | | | NR | | • Age | • P values NR
[underlined: Masking] | | | [underlined: Comorbidities] | | - < 6 mo.
Double-blind | | | None | | - = 6 mo. to < 12 mo.
| | | | | - = 12 mo. to < 18 mo.
| | | | | - = 18 mo. to < 24 mo.
| | | | | Adverse events
| | | | | NR

Evidence Table 3. Nebulized Epinephrine vs. Nebulized Bronchodilators (Salbutamol or Albuterol)

Study Characteristics | Stated Objective of Study | Inclusion/Exclusion Criteria | Demographic Characteristics and Cormorbidities | Intervention | Outcomes | | Quality
[underlined: Author] | To compare the efficacy of multiple doses of epinephrine versus salbutamol in infants hospitalized with acute bronchiolitis | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Bertrand et al., 2001^53^ | | • < 1 yr of age | 33 enrolled, 30 completed study | [underlined: Group A (n = 14)] | | | Good
[underlined: Setting] | | • First wheezing episode | [underlined: Sex] | Salbutamol | Primary outcome | | [underlined: Significant differences at baseline]
Chile, inpatient | | • Acute onset of respiratory distress | Salbutamol: 50% male (7/14) | 0.5 ml (2.5 mg) plus 0.9% saline to total volume of 4 ml q 2 to 4 hrs | • Mean duration of hospitalization in days ± SE (salbutamol vs. epinephrine): | • No (P = 0.11) | None
[underlined: Followup] | | • X-ray of chest compatible with bronchiolitis | Epinephrine: 56% male (9/16) | [underlined: Group B (n = 53)] | - 5.2 ± 1.0 vs. 4.1 ± 1.1 | | [underlined: Other comments]
Short term | | [underlined: Exclusion criteria] | [underlined: Mean age at enrollment (mo.± SE)] | Epinephrine (1:1000) | • Change in clinical scores pre and post treatment (at baseline, 24 and 36 hrs) | • Significant only for epinephrine at baseline (P = 0.025) | • The scores of 3 enrolled patients who were transferred to receive mechanical ventilation were excluded from the final analysis
[underlined: Study design] | | • Prematurity | Salbutamol: 3.7 ± 0.6 | 0.5 ml (0.5 mg) plus 0.9% saline to total volume of 4 ml q 2 to 4 hrs | Secondary outcomes | | • Two of the significant outcomes (hospitalization on Days 4 and 5) may be influenced by the larger number of adverse events in salbutamol group
RCT non-placebo | | • Chronic lung or cardiac disease | Epinephrine: 3.9 ± 0.4 | Both salbutamol and epinephrine nebulized with continuous oxygen flow at 6 to 8 L/min via facemask | • Hospitalization on Day 4 (salbutamol vs. epinephrine) | • Yes (P = 0.03) | • Did not use intent to treat analysis
[underlined: Length of enrollment] | | • Lower respiratory tract infection within previous 3 mos | [underlined: Mean gestational age] | [underlined: Other treatment] | • Hospitalization on Day 5 (salbutamol vs. epinephrine) | • Yes (P = 0.025)
May to Sept 1994 | | • Bronchodilator or steroid therapy within the month | NR | NR | • Readmission within 2 wks | • No
[underlined: Masking] | | | [underlined: Comorbidities] | | • Mean length of O_2_ treatment in days | • No
Double-blind | | | None | | • Average % of O_2_ required to maintain O_2_ saturation > 94% | • No
| | | | | Subgroup analysis
| | | | | None
| | | | | Adverse events
| | | | | • Increase in heart rate on second day (mean heart rate ± SE),: | • P = 0.02
| | | | | - Salbutamol: 146 ± 4
| | | | | - Epinephrine: 153 ± 2.9
| | | | | • Development of atelectasis
| | | | | - Salbutamol: 3/14
| | | | | - Epinephrine: 0/16
| | | | | • Bacterial super - infection
| | | | | - Salbutamol: 2/14
| | | | | - Epinephrine: 0/13
[underlined: Author] | To compare the efficacy of epinephrine with that of salbutamol in outpatients with acute bronchiolitis | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant difference between groups] | [underlined: Quality]
Menon et al., 1995 ^22^ | | • 6 wks to 1 yr | 41 completed study | [underlined: Group A (n = 21)] | | | Good
[underlined: Setting] | | • O_2_ saturation ≤ 85% and ≥ 96% | [underlined: Sex] | Salbutamol | Primary Outcomes | | [underlined: Significant differences at baseline]
Canada, Emergency department | | • RDAI score ≥ 4 | NR | 0.3 ml of a 5 mg/ml solution (1.5 mg) combined with 2.7 ml of 0.9 % saline at 0 and 30 mins | • O_2_ saturation at 30, 60 and 90 mins (salbutamol vs. epinephrine) | • Yes, at 60 mins (P = 0.02) | None reported
[underlined: Followup] | | • First episode of wheezing | [underlined: Mean age (yrs ± SD)] | [underlined: Group B (n = 20)] | - 60 mins: 94% vs. 96% | | [underlined: Other comments]
• Acute | | • Clinical symptoms of viral respiratory infection (temperature ≥ 38°C or coryza) | Salbutamol: 0.4 ± 0.2 | Epinephrine | Secondary Outcomes | | None
• Short term | | [underlined: Exclusion criteria] | Epinephrine: 0.5 ± 0.2 | 3 ml of 1:1000 solution at 0 and 30 mins nebulized with continuous flow of O_2_ at 5 to 6 L/min | • Clinical scores at 30, 60 and 90 mins | • No (P values NR)
[underlined: Study Design] | | • Chronic cardiac or pulmonary disease | [underlined: Mean gestational age] | [underlined: Other interventions] | • Respiratory rate (breaths/min) at 30, 60, 90 mins | • No (P values NR)
RCT non-placebo | | • Diagnosis of asthma by a physician | NR | Higher concentration of O_2_ or extra doses of salbutamol as needed | • Heart rate (beats/min ± SD) at 30, 60 and 90 mins (salbutamol vs. epinephrine) | • Yes, at 90 mins ([underlined: P] = 0.003)
[underlined: Length of enrollment] | | • Any previous use of bronchodilators | [underlined: Comorbidities] | | - 90 mins: 165 ± 13 vs. 151 ± 16
Jan 1994 – March 1994 | | • Severe disease requiring resuscitation or heart rate < 200 beats/min | None | | • Hospitalization (salbutamol vs. epinephrine) | • Yes (P = 0.003)
[underlined: Masking] | | • Received glucocorticoids within the previous 24 hrs | | | - 81% (17/21) vs. 33% (7/20)
Double-blind | | | | | • Mean duration of admission | • No (P = 0.4)
| | | | | • Rate of discharge from ED in first 4 hrs | • Yes, faster for epinephrine group (P = 0.02 for survival analysis)
| | | | | • Return visits to hospital within 24 hrs of hospital discharge | • No (P = 0.94),
| | | | | Other analysis
| | | | | Effect of time, group, and interaction between time and group on outcomes based on repeated measures analysis
| | | | | Adverse events
| | | | | Higher incidence of pallor in epinephrine group at 30 and 60 mins, diminished by 90 mins | • P = 0.01 at 30 mins P = 0.06 at 60 mins P = 0.13 at 90 mins
[underlined: Author] | To determine whether early treatment with nebulized racemic epinephrine improves RDAI score in infants with acute bronchiolitis | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Reijonen et al., 1995^54^ | | • Hospitalized patients age 1 – 23 mons | 100 enrolled | [underlined: Group A (n = 24)] | | | Good
[underlined: Setting] | | • Clinical criteria of acute bronchiolitis: wheezing and respiratory distress in patient with acute URTI | [underlined: Sex] | REP | Primary outcomes | | [underlined: Significant differences at baseline]
Finland, Emergency room | | [underlined: Exclusion criteria] | REP^1^: 58% male (14/24) | Racemic epinephrine: 0.9 mg/kg in 2 ml saline | • Change in RDAI score | • No | None
[underlined: Followup] | | • Chronic cardiorespiratory disease (asthma, BPD, CHD) | AP: 59% male (16/27) | Placebo: 0.9% saline | - all groups showed improvement
Acute | | • Use of oral, nebulized or parenteral bronchodilator in preceding 6 hrs | PRE: 79% male (19/24) | [underlined: Group B (n = 27)] | • Respiratory rates at 0, 15, 30, 45, 60, 75, 90, mins | • No
[underlined: Study design] | | • Impending respiratory failure | PA: 84% male (21/25) | AP | • Sa O_2_at 0, 15, 30, 45, 60, 75, 90 mins | • No
RCT-P | | • If admitted at night (10 pm to 7 am) | [underlined: Mean age at enrollment (mo).± SD)] | Albuterol: 0.15 mg/kg in 2 ml saline solution | • O_2_treatment | • NR | [underlined: Other comments]
[underlined: Length of enrollment] | | | REP: 10.6 ± 5.6 | Placebo: 0.9% saline | • Heart rate at 0, 15, 30, 45, 60, 75, 90, mins | • No | • Percentage of childrn with history of atopy high
Jan 1992 to Nov 1993 | | | AP: 9.9 ± 5.5 | [underlined: Group C (n = 24)] | Subgroup analyses | | • All children admitted to ER care (and enrolled in subsequent study)^75^
[underlined: Masking] | | | PRE: 10.1 ± 5.7 | PRE | • Age | • No
Double-blind | | | PA: 10.3 ± 7.5 | Same as REP | - <1 yr
| | | [underlined: Mean gestational age] | [underlined: Group D (n = 24)] | - > 1 yr
| | | NR | PA | • Severity of disease | • No
| | | [underlined: Comorbidities] | Same as AP | - RDAI > 8
| | | • 13% with previous history of wheezing (no sig diffs among groups) | All groups received 2 nebs 30 mins apart via nebulizer with continuous oxygen flow of 5 L/min | - RDAI = 8
| | | • 31% with atopy (no sig diffs among groups) | [underlined: Other treatment] | Adverse events
| | | | • O_2_as needed | None observed
[underlined: Author] | To compare inhaled racemic epinephrine vs. salbutamol to test the efficacy of a combined a - and ß -receptor agonist in acute brochiolitis | [underlined: Inclusion criteria] | [underlined: Number] | • IM epinephrine for all patients 60 mins after first inhalation | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Sanchez et al., 1993^55^ | | • <1 yr of age | 32 enrolled, 24 completed study | [underlined: Interventions (n = 24)] | | | Fair
[underlined: Setting] | | • acute bronchiolitis | [underlined: Sex] | Infants sedated with oral chloral hydrate (80 mg/kg first dose) | Primary Outcomes | | [underlined: Significant differences at baseline]
Canada, Inpatient | | [underlined: Exclusion criteria] | 50% male (12/24) | After 1 hr, infants received either salbutamol (0.03 ml/kg in 2 ml in 0.9% saline) or racemic epinephrine (0.1 ml/kg in 2 ml in 0.9% saline) | • Respiratory rate (mean values before vs. after ± SD) | • Not significant before treatment (P value NR), significant after treatment (P < 0.001) | None reported
[underlined: Followup] | | • Previous bronchodilator treatment prior to admit | [underlined: Mean age at enrollment (mo ± SD)] | 2.5 hrs later, a second dose of chloral hydrate (40 mg/kg) followed in 30 mins by the drug not previously given | - Salbutamol 47.0 ± 1.5 vs. 40.8 ± 0.8 | | [underlined: Comments]
Acute | | • History of: | 4.6 ± 0.5 | [underlined: Other treatment] | - Racemic epinephrine 46.5 ± 1.4 vs. 35.5 ± 0.4 | | • Limited generalizability due to selection of infants with mild to moderate bronchiolitis, sedation of infants with chloral hydrate
[underlined: Study design] | | - wheezing | [underlined: Mean gestational age] | Supplemental oxygen as needed | • SaO_2_ (mean values before vs. after ± SD) | • Not significant before or after treatment (P value NR) | • Did not examine role of rebound after racemic epinephrine
RCT-C | | - chronic cardiorespiratory disease (asthma, CF, BPD, CHD) | Not reported | | - Salbutamol 91.5 ± 0.7 vs. 92.1 ± 0.7
[underlined: Length of enrollment] | | - parental history of asthma | [underlined: Comorbidities] | | - Racemic epinephrine 91.8 ± 0.8 vs. 93.0 ± 0.7
Dec 1991 to Apr 1992 | | | None | | Secondary Outcomes
[underlined: Masking] | | | | | [underlined: Pulmonary function tests:]
Double-blind | | | | | • V_T_ | • Not significant before or after treatment
| | | | | • Heart rate | • Not significant before or after treatment
| | | | | • Minute ventilation | • Not significant before treatment, significantly lower after epinephrine than after salbutamol
| | | | | • C_DYN_ - total | • Not significant before or after treatment
| | | | | • Resistance - inspiratory | • Not significant before treatment, significantly lower after epinephrine than after salbutamol
| | | | | • Resistance - expiratory | • Not significant before treatment, significantly lower after epinephrine than after salbutamol
| | | | | • Ti/Ttot | • Not significant before or after treatment
| | | | | Adverse events
| | | | | None observed

1 REP: Racemic epinephrine followed by placebo

AP: Nebulized albuterol followed by placebos

PRE: Placebo followed by nebulized racemic epinephrine

PA: Placebo followed by nebulized albuterol

Evidence Table 4. Nebulized Bronchodilators (Salbutamol or Albuterol) vs. Oral Bronchodilators, Nebulized Ipratropium Bromide, or Saline Placebo or No Treatment

Study Characteristics | Stated Objective of Study | Inclusion/Exclusion Criteria | Demographic Characteristics and Cormorbidities | Intervention | Outcome | | Quality
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Can et al., 1998^24^ | To evaluate the efficacy and safety of salbutamol in infants with acute bronchiolitis | Derived from study by Wohl et al. 1990,^109^ details not provided | 158 enrolled, 156 completed study | [underlined: Group A (n = 52)] | Primary Outcomes | | Fair
[underlined: Setting] | | [underlined: Exclusion criteria] | [underlined: Sex] | Nebulized salbutamol | • Mean RDS ± SD (salbutamol vs. saline vs. mist) | | [underlined: Significant differences at baseline]
Turkey, emergency department | | • < 24 mons | Salbutamol: 48% male | 0.15 mg/kg in 2 ml saline | - Initial: 11.0 ± 3.2 vs. 11.3 ± 3.6 vs. 10.8 ± 33 (33 quoted from text) | - No (P> 0.05) | • Group A had CXR findings consistent with acute bronchiolitis significantly more often (P< 0.05) than groups B and C
[underlined: Followup] | | • Prematurity and mechanical ventilation after birth | Saline: 76% male | [underlined: Group B (n = 52)] | - 30 mins.: 7.0 ± 3.1 vs. 9.7 ± 3.7 vs. 10.8 ± 3.6 | - P < 0.0001 for both salbutamol vs. saline and salbutamol vs. mist. Saline vs. mist not significant | [underlined: Other comments]
Acute | | • Chronic cardiopulmonary disease | Mist: 51% male | Nebulized saline | | | • Followup limited to 60 mins
[underlined: Study Design] | | • Previous bronchodilator and steroid administration during the admission | [underlined: Mean age at enrollment (mo ± SD)] | [underlined: Group C (n = 52)] | - 60 mins.: 5.2 ± 1.8 vs. 10.2 ± 3.5 vs. 9.6 ± 3.4 | - P < 0.0001 for both salbutamol vs. saline and salbutamol vs. mist. Saline vs. mist not significant | • “Mist” not defined
RCT-P | | • Symptoms > 1 wk | Salbutamol: 7.2 ± 4.2 | Mist in a tent | • Percent with RDS> 5 at 30 mins (salbutamol vs. saline vs. mist) | • P - value NR
[underlined: Length of enrollment] | | • Heart rate > 200 beats/min and/or respiratory rate > 80 breaths/min | Saline: 6.8 ± 2.1 | In all groups, second dose given at 30 mins if RDS > 5 | - 28% vs. 3% vs. 11%
Jan 1994 – Jan 1996 | | • Lethargy or stupor | Mist: 7.4 ± 5.3 | [underlined: Other treatment] | Secondary Outcomes
[underlined: Masking] | | • History of previous attack | [underlined: Mean gestational age] | Humidified O_2_ at 5 L/min given to all groups | • SaO_2_ changes | • Salbutamol lower, but not statistically significant
Double-blind | | • Respiratory Distress Score < 5 | NR | | • Heart rate | • No
| | | [underlined: Comorbidities] | | Subgroup analysis
| | | None | | • Age | • No
| | | | | - < 6 mo. vs. > 6 mo.
| | | | | Adverse events
| | | | | Frequency of tachycardia and hypoxia did not reach statistical significance, no details provided
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Cengizlier et al., 1997^58^ | To evaluate the efficacy of oral or MDI salbutamol using a coffee cup as a spacer device in bronchiolitis | • First episode of bronchiolitis | 31 completed study | [underlined: Group A (n = 11)] | Primary outcome | | Fair
[underlined: Setting] | | • 6 to 24 mons | [underlined: Sex] | Oral salbutamol | • Mean duration of hospitalization in days | • No (P> 0.05 for both oral salbutamol vs. control and inhaled salbutamol vs. control) | [underlined: Significant differences at baseline]
Turkey, Inpatient | | • Bronchiolitis diagnosed by ward pediatrician as expiratory wheezing of acute onset with signs of viral illness | Oral salbutamol: 55% male (6/11) | 0.1 mg/kg/dose QID | - oral salbutamol: 5 | | None: P values not provided, but groups do not appear to be significantly different
[underlined: Followup] | | [underlined: Exclusion criteria] | Inhaled salbutamol: 58% male (7/12) | [underlined: Group B (n = 12)] | - inhaled salbutamol: 6 | | [underlined: Other comments]
• Acute | | • Asthma | Control: 38% male (3/8) | Inhaled salbutamol | - control: 5 | | None
• Short term | | • Cystic fibrosis | [underlined: Mean age at enrollment in mo. ± SD] | 200 μg/dose every 3° using an inhaler with a coffee cup as a spacer device | • Mean change in clinical scores between admission and discharge ± SD | • No (P > 0.05 for both oral salbutamol vs. control and inhaled salbutamol vs. control)
[underlined: Study design] | | • Congenital heart disease | Oral salbutamol: 9.6 ± 6.4 | [underlined: Group C (n = 8)] | - oral salbutamol: 1.9 ± 0.4
RCT non-placebo | | | Inhaled salbutamol: 11.6 ± 1.2 | Control | - inhaled salbutamol: 2.0 ± 0.2
[underlined: Length of enrollment] | | | Control: 9.2 ± 3.6 | No therapy | - control: 1.8 ± 0.3
NR | | | [underlined: Mean gestational age] | [underlined: Other treatment] | Secondary outcomes
[underlined: Masking] | | | NR | Routine supportive care | • Increase in heart rate 1 hr after first dose of bronchodilator | • No
Cannot be determined | | | [underlined: Comorbidities] | | Subgroup analysis
| | | None | | None
| | | | | Adverse events
| | | | | NR
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Dobson et al., 1998^37^ | To determine whether albuterol enhances clinical and physiological recovery in hospitalized infants with moderately severe bronchiolitis | • < 24 months of age | 58 enrolled, 52 completed study | [underlined: Group A (n = 23)] | Primary Outcomes | | Good
[underlined: Setting] | | • First episode of wheezing during bronchiolitis season | [underlined: Sex] | Nebulized albuterol | • Improvement in % SaO_2_ on room air over time for albuterol vs. placebo (95% CI) | • No | [underlined: Significant differences at baseline]
United States, inpatient | | • Moderately severe bronchiolitis defined by the presence of one of the following | Albuterol: 61% male (14/23) | Dose: | - 0 – 24 hrs: 1.8% (0.1% – 3.6%) vs. 1.6% (0.2% – 3.0%) | | None
[underlined: Followup] | | - SaO_2_ < 94% | Placebo: 45% male (13/29) | 1.25 mg if <10 kg, | - 24 hrs to max SaO_2:_2.2% (1.3% – 3.1%) vs. 1.8% (0.9% – 2.8%) | | [underlined: Other comments]
Short term | | - moderate to severe accessory muscle use (= 2) or moderate to severe wheezing (= 2) | [underlined: Mean age at enrollment (mo.± SD)] | 2.5 mg if >10 mg | - Time 0 to max SaO_2_: 4.0% (2.6% – 5.4%) vs. 3.4% (2.4% – 4.5%) | | Had 90% power to detect change in SaO_2_of = 2%
[underlined: Study design] | | [underlined: Exclusion criteria] | Albuterol: 5.1 ± 3.7 | q. 2 hr x 24 hos | Secondary Outcomes
RCT-P | | • Underlying chronic cardiac or pulmonary disease | Placebo: 6.1 ± 5.4 | then q. 4 hr x 48 hrs | • Percent patients discharged from hospital at 24, 48, 72 hrs | • No
[underlined: Length of enrollment] | | • Significant concurrent illness (sepsis, meningitis, pneumonia, urinary tract infections, gastroenteritis) | [underlined: Mean gestational age ( wks. ± SD)] | [underlined: Group B (n = 29)] | • Length of hospital stay | • No
Dec 1995 – March 1996 | | • Current gestational age <38 wks | Albuterol: 39.2 ± 1.6 | Placebo | Subgroup analysis
[underlined: Masking] | | • History of wheezing requiring hospitalization or bronchodilator therapy before current illness | Placebo: 38.8 ± 2.4 | 3ml normal saline by nebulized aerosol following same dosing schedule | • Age | • No
Double-blind | | • Concurrent steroid treatment | [underlined: Comorbidities] | [underlined: Other treatment] | - <12 mons of age
| | • Severe bronchiolitis requiring intensive care (mechanical ventilation, documented apnea, heart rate > 200 beats/min, hypercarbia) | None reported | Routine supportive care as needed | Adverse events
| | | | | “Comparison of adverse events for albuterol vs. control groups approaches, but does not reach, statistical significance” (no details provided)
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Gadomski et al., 1994^60^ | • To determine the efficacy of albuterol in reducing respiratory distress in infants with bronchiolitis | • <18 mons | Number enrolled not stated, 128 randomized and 41 enrolled in study of recurrent wheezing, 169 completed study | [underlined: Group A (n = 32)] | Primary Outcomes | | Excellent
[underlined: Setting] | • To assess effectiveness of route of delivery (nebulization vs. oral) | • First episode of wheezing | [underlined: Sex] | Nebulized albuterol | • Clinical scores at baseline, 30 and 60 mins | • No | [underlined: Significant differences at baseline]
Egypt, outpatient and emergency room | • To determine the incidence of positive blood culture among first-time wheezing infants | • Recurrent wheezers/asthmatics recruited as open-label control subjects | Nebulized albuterol: 75% male | 0.15 mg/kg x 2 doses 30 mins. apart | • Respiratory rates at baseline, 30 and 60 mins | • No | Recurrent wheezers older, heavier, more likely to have received meds before visit
[underlined: Followup] | | [underlined: Exclusion criteria] | Nebulized saline: 72% male | [underlined: Group B (n = 32)] | • Heart rates at baseline, 30 and 60 mins | • No | [underlined: Other comments]
Acute | | • Chronic diseases of the cardiorespiratory system | Oral albuterol: 69% male | Nebulized saline | • Oxygen saturation at baseline, 30 and 60 mins | • No | Group E not randomized
[underlined: Study Design] | | • Heart rate > 200 beats/min | Oral saline: 75% male | 0.9% solution x 2 doses 30 mins apart | Secondary Outcomes
RCT-P, Group E not randomized | | • Cyanosis | Recurrent wheezers: 63% male | All doses delivered via nebulizer with pediatric face mask with room air at flow rate of 4 – 6 L/min | • Leukocyte counts | • No
| | • Apathy, lethargy, or an otherwise depressed sensorium suggestive of incipient respiratory failure or sepsis | [underlined: Median age at enrollment] | [underlined: Group C (n = 32)] | • Antimicrobial activity in urine | • No
[underlined: Length of enrollment] | | • Persistent vomiting | Nebulized albuterol: 4.0 mos | Oral albuterol | • Blood culture | • No
NR | | • Refused feedings | Nebulized saline: 5.0 mos | 0.15 mg/kg PO | • Chest x-rays | • No
[underlined: Masking] | | | Oral albuterol: 5.5 mos | [underlined: Group D (n = 32)] | Subgroup analysis
Double-blind | | | Oral saline: 4.0 mos | Oral rehydration solution (with similar color and odor as Group C) | Change in state (i.e., falling asleep, waking up) | • No
| | | Recurrent wheezers: 12.0 mos | [underlined: Group E (n = 41)] | Adverse events
| | | [underlined: Mean gestational age] | Recurrent wheezers treated with nebulized albuterol | NR
| | | NR | 0.15 mg/kg x 2 or 3 doses
| | | [underlined: Comorbidities] | [underlined: Other treatment]
| | | None reported | After 60 mins, open-label albuterol nebulization treatment given to infants whose clinical condition had worsened or not improved prior to breaking randomization code
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Gadomski et al., 1994^59^ | To examine the efficacy of albuterol (oral and nebulized) in the management of bronchiolitis | • 15 months of age | 93 randomized, 5 withdrawn, 13 in pilot study and did not complete protocol, 76 completed both assessments | [underlined: Group A (n = 22)] | Primary outcome | | Good
[underlined: Setting] | | • First episode of wheezing | [underlined: Sex] | Nebulized albuterol | • Respiratory rate at baseline, 30 and 60 mins | • No | [underlined: Significant differences at baseline]
United States, Emergency department and outpatient clinic | | • Clinical definition of bronchiolitis: | Nebulized albuterol: 45% male (10/22) | If = 7 kg, 1 mg/dose nebulized albuterol in 3 mL saline x 2 doses, 30 mins apart | • Change in respiratory rate between baseline and 30 mins and baseline and 60 mins | • No | None
[underlined: Followup] | | - acute infection of lower respiratory tract | Nebulized saline: 57% male (13/23) | If > 7 kg, 0.15 mg/kg/dose nebulized albuterol in 3 mL x 2, 30 mins apart | Secondary outcomes | | [underlined: Other comments]
Acute | | - fever | Oral albuterol: 58% male (11/19) | Nebulized with compressed air at 6 L/min with pediatric face mask | • Clinical score at baseline, 30 and 60 mins | • No | Oral placebo same color as active drug, but no attempt made to mask flavor of albuterol itself
[underlined: Study design] | | - rhinitis | Oral placebo: 63% male (15/24) | [underlined: Group B (n = 23)] | • Change in clinical score between baseline and 30 mins and baseline and 60 mins | • No
RCT-P | | - tachypnea | [underlined: Mean age at enrollment (mo)] | Nebulized saline | • Oxygen saturation at baseline, 30 and 60 mins | • No
[underlined: Length of enrollment] | | - expiratory wheezing | Nebulized albuterol: 5.6 | 3 mL saline x 2, 30 mins apart | • Change in oxygen saturation between baseline and 30 mins and baseline and 60 mins | • No
Feb 1990 – Dec 1992 | | - increased respiratory effort | Nebulized saline: 5.8 | [underlined: Group C (n = 19)] | • Heart rate at baseline, 30 and 60 mins | • Yes (heart rate significantly higher for oral albuterol group at 60 mins, P = 0.006)
| | [underlined: Exclusion criteria] | Oral albuterol: 4.8 | Oral albuterol | • Change in heart rate between baseline and 30 mins and baseline and 60 mins | • Yes (change in heart rate significantly higher for oral albuterol group at 60 mins, P = 0.008)
[underlined: Masking] | | • Previous use of bronchodilator | Oral placebo: 5.3 | If = 7 kg, 2.5 mL (1 mg) | • Need for additional treatment | • No
Double-blind | | • History of intubation and mechanical ventilation | [underlined: Mean gestational age] | If > 7 kg, 0.15 mg/kg/dose | • Number hospitalized | • No
| | • Chronic cardiorespiratory diseases (congenital heart disease, CF, BPD) | NR | [underlined: Group D (n = 24)] | Subgroup analysis
| | • Severely ill infants: | [underlined: Comorbidities] | Oral placebo | • Age | • No
| | - heart rate > 200 beats | None | Oral rehydration solution, same color as oral bronchodilator | - < 6 mo vs. = 6 mo.
| | - respiratory rate > 100 breaths/min | | [underlined: Other treatment] | • Change in state | • Yes (P= 0.01 for change in RR and change in clinical score)
| | - apathy/lethargy | | After 60 mins, open-label albuterol nebulization treatment given to infants whose clinical condition had worsened or not improved prior to breaking randomization code | [underlined: Adverse events]
| | - depressed sensorium suggestive of incipient respiratory failure or sepsis | | | • Increased heart rate among oral albuterol group
| | | | | • Facial flushing at 60 mins (3 nebulized albuterol subjects, 1 oral albuterol subject)
| | | | | • Hyperactivity (2 nebulized albuterol subjects, 1 oral albuterol subject)
| | | | | • Coughing (1 nebulized saline subject, 1 oral placebo subject)
| | | | | • Tremor at 60 mins (1 oral albuterol subject)
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Goh et al., 1997^61^ | To determine the efficacy of bronchodilators in the treatment of bronchiolitis | • < 2 yrs old | Between Aug 1992 and Jul 1993, 99 patients randomized, 89 completed study | [underlined: Group A (n = 29)] | Primary outcome | | Fair
[underlined: Setting] | | • Admitted for signs and symptoms of bronchiolitis | Between Nov 1993 and Apr 1994, 21 patients included | Nebulized normal saline | • Mean duration of hospitalization in days for all groups: | • No (P > 0.05) | [underlined: Significant differences at baseline]
Singapore, Inpatient | | [underlined: Exclusion criteria] | [underlined: Sex] | 2 ml | - 4 (no other details provided) | | None
[underlined: Followup] | | • Congenital heart disease | Placebo: 69% male (20/29) | [underlined: Group B (n = 30)] | Secondary outcomes | | [underlined: Other comments]
Acute | | • Immunocompromised patients | Salbutamol: 80% male (24/30) | Nebulized salbutamol | • Severity scores at baseline, Day 1, Day 2 and Day 3 | • No (P > 0.05) | Humidified oxygen group was enrolled 1 yr after the RCT portion of the study, not randomized
[underlined: Study design] | | • Recurring mechanical ventilation | Ipratropium bromide: 67% male (20/30) | 2.5 mg/mL | Subgroup analysis
Placebo, salbutamol and ipratropium bromide: RCT-P | | History of previous wheeze | Humidified oxygen 73% male (22/30) | If = 6 mo., 0.3 mL made up to 2 mL with normal saline | • Duration of hospitalization by age | • No (P> 0.05)
Humidified oxygen: | | | [underlined: Mean age at enrollment (mo ± SD)] | If > 6 mo., 0.6 mL made up to 2 mL with normal saline | • Age > 6 mo vs. age < 6 mo | • No (P> 0.05)
open label | | | Placebo: 7.4 ± 0.89 | [underlined: Group C (n = 30)] | - Hospitalization days
[underlined: Length of enrollment] | | | Salbutamol: 5.7 ± 0.77 | Nebulized ipratropium bromide | - Number of nebulizations
Placebo, salbutamol and ipratropium bromide: Aug 1992 to Jul 1993 | | | Ipratropium bromide: 5.2 ± 0.67 | 250 μg/mL made up to to 2 ml saline by age as above | Adverse events
Humidified oxygen: | | | Humidified oxygen: 5.9 ± 0.71 | All nebulizations over 10 to 15 mins by face mask driven by oxygen flow at flow rate of 6 to 8 L/min | NR
Nov 1993 to Apr 1994 | | | [underlined: Mean gestational age] | [underlined: Group D (n = 31)]
[underlined: Masking] | | | NR | Humidified oxygen
Attending physician blinded, not clear if caretakers were blinded | | | [underlined: Comorbidities] | [underlined: Other treatment]
| | | None | As indicated
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Hickey et al., 1994^57^ | To determine the efficacy of albuterol delivered via metered-dose inhaler with spacer for the treatment of wheezing infants | • 1–18 months | 47 eligible, 42 enrolled | [underlined: Group A (n=19)] | Primary outcome | • No sig. diffs. between groups, however Group A scores improved significantly from baseline by 2^nd^ treatment (P < 0.05), Group B scores improved significantly only by 4^th^ treatment (P < 0.05) | Good
[underlined: Setting:] | | • Wheezing | [underlined: Sex] | 2 treatments of albuterol followed by 2 treatments of placebo | • Improvement in wheezing scores | | [underlined: Significant differences at baseline]
United States, Emergency Department | | [underlined: Exclusion criteria] | Group 1: 74% male (14/19) | [underlined: Group B (n=23)] | - Graphical presentation, figures cannot be extracted | | None
[underlined: Followup:] | | • Cardiac or musculoskeletal disease | Group 2: 61% male (14/23) | 2 treatments of placebo followed by 2 treatments of albuterol | • Improvement in retraction scores | • No sig. diffs. between groups, however Group A scores did not improved significantly from baseline, Group B scores improved significantly by 4^th^ treatment (P < 0.05) | [underlined: Other comments]
Acute | | • History of treatment with supplemental oxygen | [underlined: Median age at enrollment in mo (range)] | 2 puffs per treatment, either 90 μg of albuterol per puff or only the oleic acide dispersant. | - Graphical presentation, figures cannot be extracted | | None
[underlined: Study design] | | • Bronchodilator use in the previous 24 hrs | Group 1: 6.2 (1.2–18.3) | 20 mins. interval between treatments, delivered via metered-dose inhaler and “home-made” spacer device crafted at the Children's Hospital of Pittsburgh | • Mean respiratory rate at baseline, 40 mins and 80 mins | • No diffs between groups at any time, no significant improvement within group over time
RCT-C | | • Severe respiratory distress (very poor air entry, cynanosis or fatigue) | Group 2: 7.0 (2.3–18) | [underlined: Other treatment] | • Mean heart rate at baseline, 40 mins and 80 mins | • No diffs between groups at any time, no significant improvement within group over time
[underlined: Length of enrollment] | | | [underlined: Mean gestational age] | NR | • Mean oxygen saturation at baseline, 40 mins and 80 mins | • No diffs between groups at any time, no significant improvement within group over time
Dec 1989 to Feb 1990, Nov 1990 to March 1991 | | | NR | | Subgroup analysis
[underlined: Masking] | | | [underlined: Comorbidities] | | • First episode of wheezing | • Retraction scores lower for albuterol for first wheezers and RSV positive (P < 0.05), no other significant outcomes
Double-blind | | | None | | • RSV status
| | | | | Adverse events
| | | | | NR
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Ho et al., 1991^62^ | To determine the effect of inhaled salbutamol on SaO_2_among infants with bronchiolitis | • Children admitted with cough and wheeze due to acute bronchiolitis within 5 days of admission | 21 completed study | [underlined: Group A (n = 13)] | Primary outcome | | Fair
[underlined: Setting] | | • Clinical findings of hyperinflation with wheeze and crackles on auscultation | [underlined: Sex] | Nebulized salbutamol 2.5 mg/2 mL | • O_2_ saturation at 5, 10, 15, 20, and 25 mins of first neb., during 10 mins. to next neb., 5, 10, 15, 20, and 25 mins of second nebulizstion | • No significant difference between groups for median maximum falls in SaO_2_ | [underlined: Significant differences at baseline]
Australia, Inpatient | | • Respiratory syncytial virus isolated by immunoflorescence of a postnasal aspirate | NR | Nebulized placebo 2 mL normal saline | - 11 of 13 given salbutamol first had a desaturation from baseline. | | NR
[underlined: Followup] | | [underlined: Exclusion criteria] | [underlined: Mean age at enrollment (range)] | All nebulizations with compressed air at flow rate of 6 L/min for 10 mins, followed by other treatment 30 mins later | - 8 of 8 given salbutamol second had desaturation from baseline | | [underlined: Other comments]
Acute | | • Severely ill children and those with associated chronic disabilities | 3 mos (3 wks to 6 mo) | [underlined: Group B (n = 8)] | Subgroup analysis | | None
[underlined: Study Design] | | • Prior history of respiratory problems | [underlined: Mean gestational age] | Identical interventions in reverse order | None
RCT-C | | | NR | [underlined: Other treatment] | Adverse events
[underlined: Length of enrollment] | | | [underlined: Comorbidities] | Supplemental oxygen for 3 subjects | NR, see primary outcome
NR | | | None
[underlined: Masking]
Double-blind
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Klassen et al., 1991^21^ | To test the hypothesis that nebulized salbutamol would provide greater short term improvement in respiratory status than a placebo in young children with bronchiolitis | • <24 months old | 85 eligible, 83 completed study | [underlined: Group A (n = 42)] | Primary outcome | | Excellent
[underlined: Setting] | | • Wheezing present on auscultation at initial presentation and at least 5 mins later on examination by one of the investigators | [underlined: Sex] | Nebulized salbutamol | • RDAI score at baseline, 30 mins and 60 mins (salbutamol vs. placebo) | • Yes (P= 0.04 at 30 mins alone) | [underlined: Significant differences at baseline]
Canada, Emergency department | | • RDAI > 3 | Salbutamol: 52% male (22/42) | 0.1 mg/kg added to 2 ml of 0.9% saline solution administered through updraft nebulizer for 5 to 8 mins with continuous flow of oxygen for 5 to 6 L/min | Secondary outcomes | | None
[underlined: Followup] | | [underlined: Exclusion criteria] | Placebo: 61% male (25/41) | Treatment repeated 30 mins after study entry | • Heart rate at baseline, 30 mins and 60 mins (salbutamol vs. placebo) | • No | [underlined: Other comments]
Acute | | • History of bronchodilator therapy | [underlined: Mean age at enrollment (mo ± SE)] | [underlined: Group B (n = 41)] | • Respiratory rate at baseline, 30 mins and 60 mins (salbutamol vs. placebo) | • No | None
[underlined: Study design] | | • History of chronic disease (including asthma) | Salbutamol: 7.3 ± 4.2 | Nebulized saline | • Oxygen saturation at baseline, 30 mins and 60 mins (salbutamol vs. placebo) | • No
RCT-P | | • Severe respiratory disease as evidenced by a pulse rate > 200 beats/min, a respiratory rate > 80 breaths/min an RDAI score > 15, or profound lethargy | Placebo: 7.0 ± 3.9 | 0.02 ml/kg of 0.9% saline, administered as above | Subgroup analysis
[underlined: Masking] | | | [underlined: Mean gestational age (wk ± SE)] | [underlined: Other treatment] | • Age < 1 yr | • P= 0.01 at 30 mins, P= 0.08 at 60 mins
Double-blind | | | NR | If after 60 mins, improvement in RDAI score < 3, 0.1 mg/kg salbutamol with 2 ml of 0.9% saline | - RDAI score significantly different at 30 mins, but not at 60 mins
[underlined: Length of enrollment] | | | [underlined: Comorbidities] | | • Positive RSV status | • P= 0.04 at 30 mins, P= 0.1 at 60 mins
Nov 1988 – Apr 1990 | | | None | | - RDAI score significantly different at 30 mins in RSV+ infants, but not at 60 mins
| | | | | Adverse events
| | | | | • Heart rate among salbutamol group significantly higher than placebo group (159 ± 16 vs. 151 ± 16) | • Yes (P= 0.03)
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Schuh et al., 1990^44^ | To evaluate the clinical response to nebulized albuterol in infants and young children with acute bronchiolitis | • 6 wks to 24 mon | 40 randomized | [underlined: Group A (n = 21)] | Primary outcome | | Good
[underlined: Setting] | | • History and clinical findings compatible with bronchiolitis | [underlined: Sex] | Nebulized albuterol | • Hospitalization (albuterol vs. placebo): | • NR | [underlined: Significant differences at baseline]
Canada, emergency department | | [underlined: Exclusion criteria] | Overall: 85% male (34/40) | 0.15 mg/kg/dose in 3 mL of 0.9% normal saline x 3 doses at 1 hr intervals | - 19% (4/21) vs. 10.5% (2/19) | | None
[underlined: Followup] | | • History of prematurity or mechanical ventilation | [underlined: Mean age at enrollment (mo ±SE)] | [underlined: Group B (n = 19)] | • Mean percentage decrease in respiratory rate ± SD (albuterol vs. placebo) | • Not significant after dose 1, significant after dose 2 (P= 0.01) | [underlined: Other comments]
Acute | | • History of LRTI, wheezing or bronchodilatory therapy | Albuterol: 6.1 ± 1.3 | Nebulized saline | - After dose 1: 16.2 ± 3.3 vs. 15.5 ± 3.5 | | Study powered to detect difference of 1 SD in respiratory rate
[underlined: Study design] | | • History suggestive of chronic aspiration or cardiac disease | Placebo: 5.3 ± 1.2 | 2 doses of saline 1 hr apart, followed by third dose of nebulized albuterol, as above | - After dose 2: 19.6 ± 3.4 vs. 8.0 ± 3.0
RCT-P | | • Current episode that started more than 2 wks prior to ED evaluation | [underlined: Mean gestational age] | All doses delivered by face mask and nebulizer, driven by oxygen at flow rate of 6 to 7 L/min over 15 mins | Secondary outcomes
[underlined: Masking] | | • Presentation between 12 midnight and 8 am | NR | [underlined: Other treatment] | • Mean decrease in AMS ± SD (albuterol vs. placebo) | • Yes (P= 0.01 after dose 1, P <0.01 after dose 2)
Double-blind | | | [underlined: Comorbidities] | As indicated | - After dose 1: 0.7 ± 0.1 vs. 0.3 ± 0.1
[underlined: Length of enrollment] | | | None | | - After dose 2: 0.86 ± 0.1 vs. 0.37± 0.1
Dec 1988 to Apr 1989 | | | | | • Mean decrease in wheeze score ± SD (albuterol vs. placebo) | • No significant differences
| | | | | - After dose 1: 0.43 ± 0.1 vs. 0.32 ± 0.1
| | | | | - After dose 2: 0.67 ± 0.1 vs. 0.47± 0.2
| | | | | • Mean change in oxygen saturation ± SD (albuterol vs. placebo) | • Yes (P= 0.01 after dose 1, P =0.01 after dose 2)
| | | | | - After dose 1: +0.71 ± 0.3 vs. -0.47 ± 0.3
| | | | | - After dose 2: +0.76 ± 0.04 vs. -0.79 ± 0.5
| | | | | • Mean change in heart rate ± SD (albuterol vs. placebo) | Not significant after dose 1, significant after dose 2 (P= 0.003)
| | | | | - After dose 1: +4.3 ± 3.2 vs. -1.5 ± 3.0
| | | | | After dose 2: +7.8 ± 2.7 vs. -6.8 ± 3.8
| | | | | [underlined: Subgroup analysis]
| | | | | • History of eczema | • NR
| | | | | - 19.4% decrease in respiratory rate for 13 patients with a family history of eczema vs. 19.7% for 8 patients without family history of eczema
| | | | | - 0.92 drop in accessory muscle score for 13 patients with a family history of eczema vs. 0.75 for 8 patients without family history of eczema
| | | | | Adverse events
| | | | | Increase in heart rate in albuterol group from mean of 153.2 to 160.9 beats/min | • NR
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Schweich et al., 1992^56^ | To evaluate the efficacy of nebulized albuterol in the treatment of wheezing infants | • < 2 yrs old | 25 patients enrolled and randomized | [underlined: Group A (n=12)] | Primary outcomes | | Good
[underlined: Setting:] | | • Wheezing | [underlined: Sex] | Albuterol | • Mean change in retraction score after first treatment ± SD (albuterol vs. placebo) | • No, P value NR | [underlined: Significant differences at baseline]
United States, ED | | [underlined: Exclusion criteria] | Placebo: 50% male (6/12) | 0.15 mg/kg in 3 ml of normal saline | - -0.54 ± 1.05 vs. -0.58 ± 0.79 | | None
[underlined: Followup:] | | • Current sympathomimetic medicine | Albuterol: 46% male (7/13) | [underlined: Group B (n=13)] | • Mean change in retraction score after second treatment ± SD (albuterol vs. placebo) | • No, P value NR | [underlined: Other comments]
Acute | | • Chronic cardiac or pulmonary disease | [underlined: Mean age at enrollment in mo.] | Placebo | - -1.25 ± 1.35 vs -0.41 ± 0.90 | | None
[underlined: Study design] | | • Other major chronic diseases | Placebo: 8.7 | 0.03 ml/kg normal saline in 3 ml of normal saline | • Mean change in total score after first treatment ± SD (albuterol vs. placebo) | • No, P value NR
RCT-P | | • Impending respiratory failure | Albuterol: 6.0 | 2 blinded treatments 30 mins. apart administered with continuous flow oxygen at 6 L/min | - -1.54 ± 2.36 vs. -1.58 ± 2.46
[underlined: Length of enrollment] | | | [underlined: Mean gestational age] | Code broken 30 mins. after 2^nd^ treatment, placebo patients given albuterol | • Mean change in total score after second treatment ± SD (albuterol vs. placebo) | • Yes (P = 0.019)
November 1989–March 1990 | | | NR | [underlined: Other treatment] | - -4.08 ± 2.91 vs -1.33 ± 2.38
[underlined: Masking] | | | [underlined: Comorbidities] | Supplemental oxygen as needed | Secondary outcomes
Double-blind | | | None | | • Mean change in wheeze score after first treatment ± SD (albuterol vs. placebo) | • No, P value NR
| | | | | - -1.00 ± 2.00 vs. -1.00 ± 2.04
| | | | | • Mean change in wheeze score after second treatment ± SD (albuterol vs. placebo) | • Yes (P = 0.039)
| | | | | - -2.83 ± 2.55 vs. -0.92 ± 1.62
| | | | | • Mean change in respiratory rate after first treatment (albuterol vs. placebo) | • No, P value NR
| | | | | - -1.8 vs. 2.9
| | | | | • Mean change in respiratory rate after second treatment (albuterol vs. placebo) | • No, P value NR
| | | | | - -1.4 vs. -0.5
| | | | | • Mean change in retraction rate after first treatment (albuterol vs. placebo) | • Yes (P = 0.018)
| | | | | - -3.5 vs. 0.7
| | | | | • Mean change in retraction rate after second treatment (albuterol vs. placebo) | • No, P value NR
| | | | | - 2.4 vs. -0.4
| | | | | • Mean change in heart rate after first treatment (albuterol vs. placebo) | • No, P value NR
| | | | | - -14 vs. -9 | • No, P value NR
| | | | | • Mean change in heart rate after second treatment (albuterol vs. placebo)
| | | | | - -13 vs. -15
| | | | | Subgroup analysis
| | | | | RSV status | P value NR (n too low for statistical testing)
| | | | | Adverse events
| | | | | Small decrease in oxygen saturation in albuterol group

Evidence Table 5. Nebulized Salbutamol or Albuterol plus Nebulized Ipratropium Bromide vs. Bronchodilators or Ipratropium Bromide Alone and/or Saline Placebo

Study Characteristics | Stated Objective of Study | Inclusion/Exclusion Criteria | Demographic Characteristics and Cormorbidities | Intervention | Outcome | | Quality
[underlined: Author] | To compare the efficacy of salbutamol, ipratropium bromide, and a combination of both vs. saline placebo in treating children hospitalized for bronchiolitis | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Chowdhury et al., 1995^63^ | | • Admission for bronchiolitis defined as history of cough and/or wheeze, tachypnea, intercostals retractions, and on auscultation, rhonchi and rales | 102 eligible, 89 completed study | [underlined: Group A (n = 20)] | Primary outcome | | Fair
[underlined: Setting:] | | • < 2 yrs | [underlined: Sex] | Salbutamol | • Mean duration of hospitalization in days ± SD | • No (P= 0.79) | [underlined: Significant differences at baseline]
Saudi Arabia, inpatient | | • Presence of wheezing - audible or auscultation | Salbutamol^2^: 70% male (14/20) | 0.15 mg/kg nebulized q. 6 hrs × 36 hrs | - S: 4.5 ± 1.3 | | None
[underlined: Followup] | | [underlined: Exclusion criteria] | lpratropium bromide:70% male (16/23) | [underlined: Group B (n = 23)] | - I: 4.4± 1.4 | | [underlined: Other comments]
• Acute | | • Previous history of wheezing or use of bronchodilators | Salbutamol + lpratropium bromide: 70% male (16/23) | lpratropium bromide | - S+I: 4.6 ± 1.4 | | Investigators unblinded at 36 hrs
• Short term | | • Chronic pulmonary disease | Placebo: 77% male (17/22) | 12.5 μg/kg nebulized q.6 hrs × 36 hrs | - P: 4.3 ± 1.1
[underlined: Study design] | | • Congenital heart disease | [underlined: Mean age at enrollment (mo±SE)] | [underlined: Group C (n = 24)] | • Clinical score at 30 mins, 60 mins, 6 hrs, 12 hrs, 24 hrs, 36 hrs | • No (P values ranged from 0.23 at 30 mins to 0.93 at 60 mins
RCT-P | | • CXR evidence of consolidation | Salbutamol: 3.9 ±2.3 | Salbutamol + lpratropium bromide nebulized | Subgroup analysis
[underlined: Length of enrollment] | | • Patients judged by admitting resident to be not sufficiently sick or to require intensive monitoring or therapy | lpratropium bromide: 4.2 ± 2.4 | Same dosing and schedule as Groups A and B | • Age | • No
Oct 1992 to Jan 1993 | | | Salbutamol + lpratropium bromide: 3.6 ± 1.8 | [underlined: Group D (n = 22)] | - < 3 mo.
[underlined: Masking] | | | Placebo: 3.7 ± 2.3 | Placebo | - > 3 mo.
Double-blind until 36 hrs, investigator unblended thereafter | | | [underlined: Mean gestational age] | 0.3 mg/kg | • RSV status | • No
| | | NR | All doses with 100% oxygen at 6 to 7 L/min with pediatric nebulizers | Adverse events
| | | [underlined: Comorbidities] | [underlined: Other treatment] | NR
| | | None | NR
[underlined: Author] | To determine whether infants with bronchiolitis would show a greater clinical response to nebulized albuterol-ipratropium combination compared with albuterol alone | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Schuh et al., 1992^64^ | | • 6 wks to 24 months of age | 72 enrolled, 69 completed study | [underlined: Group A (n = 36)] | Primary Outcomes | | Good
[underlined: Setting] | | • Acute bronchiolitis, including upper respiratory tract infection with wheezing and respiratory distress (defined as respiratory rate ≥ 40 minute and/or chest retractions) | [underlined: Sex] | Nebulized albuterol 0.15 mg/kg and Nebulized ipatropium bromide 250 μg/kg; 2 doses 1 hr apart | • Mean change in respiraory rate from baseline to 120 mins ± SD (I+A vs.P+A) | • No (P > 0.42) | [underlined: Significant differences between study groups]
Canada, emergency department | | • Presentation in ER between 8 am and midnight | NR | [underlined: Group B(n = 33)] | - 10.6 ± 10.0 vs. 8.6 ± 10.2 | | None
[underlined: Followup] | | • First episode of wheezing | [underlined: Mean age at enrollment (mos ± SD]) | Nebulized albuterol 0.15 mg/kg and saline placebo; 2 doses 1 hr apart | Secondary Outcomes | | [underlined: Other comments]
Acute | | [underlined: Exclusion criteria] | I+A^3^: 9.4 ± 6.1 | All doses delivered via nebulizer with a tight - fitting small face mask, driven by oxygen at flow rate of 6–7 L/min | Mean change from baseline to 120 mins in | | None
[underlined: Study Design] | | • Very severe bronchiolitis, defined as either cyanosis at initial examination or initial respiratory rate ≥ 90 per minute with severe restrictions | P+A: 8.7 ± 5.2 | [underlined: Other treatment] | • Accessory muscle score | • No
RCT-P | | • History of mechanical ventilation after birth | [underlined: Mean gestational age] | None reported | • Wheeze score | • No
[underlined: Length of enrollment] | | • Past history of wheezing or bronchodilator therapy | NR | | • SaO_2_ increase | • No
Dec 1989 – March 1991 | | • Concurrent cardiopulmonary disease | [underlined: Comorbidities] | | • Heart rate increase | • No
[underlined: Masking] | | • Recurrent aspiration | None | | • Overall responsiveness | • No
Double-blind | | • Respiratory distress started more than 2 wks prior to hospital visit | | | Subgroup analysis
| | | | | • Atopic history | • No
| | | | | • Age | • NR
| | | | | - < 9 mo. vs. = 9 mo.
| | | | | Adverse events
| | | | | • Decline in oxygen saturation of 3% or more in both groups (2/36 vs. 3/33)
[underlined: Author] | To examine the efficacy of inhaled bronchodilators in hospitalized patients using pulse oximetry and clinical score | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | Significant differences between study groups | [underlined: Quality]
Wang et al., 1992^65^ | | • 2 mos – 2 yrs of age | 150 eligible, 62 randomized | [underlined: Group A (n = 17)] | Primary outcome | | Good
[underlined: Setting] | | • First hospitalization for bronchiolitis | [underlined: Sex] | Salbutamol + Ipratropium | • Mean duration of hospitalization in days ± SE | • No (P values NR) | [underlined: Significant differences at baseline]
Canada, inpatient | | • Did not have adequate improvement with emergency department management which always included salbutamol | S + I:^4^ 53% male (9/17) | Salbutamol: | - S+I: 2.5 ± 0.3 | | Fewer boys in placebo group than other groups
[underlined: Followup:] | | • Bronchiolitis diagnosed in the presence of expiratory wheezing of acute onset accompanied by signs of viral illness such as coryza | S: 57% male (8/14) | 0.15 mg/kg in 2ml saline | - S: 3.2 ± 0.4 | | [underlined: Other comments]
• Acute | | [underlined: Exclusion criteria] | I: 73% male (11/15) | Ipratropium bromide: | - I: 2.4 ± 0.3 | | None
• Short term | | • Known underlying cardiac or pulmonary disease | P: 38% male (6/16) | 125 μg if < 6mo., 250 μg if > 6mo. | - P: 2.9 ± 0.4
[underlined: Study design] | | • Transferred from another hospital | [underlined: Mean age at enrollment] | [underlined: Group B (n = 14)] | [underlined: Secondary outcomes]
RCT-P | | • Condition rapidly deteriorating | NR | Salbutamol | • Mean change in clinical score | • No
[underlined: Length of enrollment] | | • Parental refusal or attending physician refusal | [underlined: Mean gestational age] | 0.15 mg/kg in 2ml saline, then 0.5 ml or 1 ml saline I hr later | • Mean change in oxygen saturation | • Significantly greater for S+I vs. S (P = 0.002) and S+I vs. I (P = 0.04), but not S+I vs. P (P > 0.1).Significantly worse for S vs. P (P = 0.03)
NR | | | NR | [underlined: Group C (n = 15)] | Subgroup analysis
[underlined: Masking] | | | [underlined: Comorbidities] | Ipratropium | None
Double-blind | | | None | 0.03 ml/kg of saline in 2ml saline followed by ipratropium bromide 125 μg if < 6mo., 250 μg if > 6mo. | Adverse events
| | | | [underlined: Group D (n = 16)] | 1 child in salbutamol group had tremulousness, leading to withdrawal from study
| | | | Placebo
| | | | Saline, same volumes as indicated above
| | | | All treatments administered through face mask and nebulizer driven by oxygen at flow rate of 6 – 7 L/min every 4 hrs of hospitalization or 3 days whichever came first
| | | | [underlined: Other treatment]
| | | | Routine care as needed, Ribavirin(1 patient), systematic steroids and theophylline(1 patient)

2 S: Salbutamol

I: Ipratropium bromide

S+ I: Salbutamol and Ipratropium bromide

P: Placebo

3 I+A: Ipratropium bromide plus Albuterol

P+ A: Placebo plus Albuterol

4 S+ I: Salbutamol and Ipratropium bromide

S: Salbutamol

I: Ipratropium bromide

P: Placebo

Evidence Table 6. Oral Corticosteroids vs. Placebo, With or Without Bronchodilators

Study Characteristics | Stated Objective of Study | Inclusion/Exclusion criteria | Demographic Characteristics and Cormorbidities | Intervention | Outcome | | Quality
[underlined: Author] | | [underlined: Inclusion Criteria:] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Berger 1998^70^ | To assess the Short term and Long-term effects of prednisone in infants suffering from mild to moderate bronchiolitis | • 1 – 18 months of age | 42 enrolled, 38 completed 1 - wk followup, 28 contacted for 2 yr followup | [underlined: Group A (n = 20)] | | | Good
[underlined: Setting] | | (Bronchiolitis defined as first episode of wheezing associated with low -grade fever, rhinitis, tachypnea, and increased respiratory effort in a previously healthy infant during the winter months) | [underlined: Sex] | Prednisone | Primary Outcomes | | [underlined: Significant differences at baseline]
Israel, Emergency department at baseline | | [underlined: Exclusion criteria] | NR | Dose: 1 mg/kg PO BID × 3 d | • Mean total score ± SD (prednisone vs. placebo) | • No | None
[underlined: Followup] | | • Chronic cardiopulmonary disease, including asthma | [underlined: Mean age at enrollment (mos ± SD)] | [underlined: Group B (n = 53)] | - Before treatment: 4.4 ± 2 vs. 1.95 ± 1.9 | | [underlined: Comments]
• Acute | | • Proven or suspected acute bacterial infection | prednisone: 5.2 ± 0.7 | Placebo | - After treatment: 1.95 ± 1.9 vs. 2.05 ± 3 | - P = 0.82 | Intent-to-treat analysis not used
• Short term | | • Previous treatment with corticosteroids by any route | Placebo: 4.8 ± 0.9 | Dose: | - Mean change: 2.45 ± 0.12 vs. 2.45 ± 0.3 | - P = 0.59
- 1 wk followup | | • The presence of symptoms more than 7 days | [underlined: Mean gestational age] | Identically appearing solution and schedule | Secondary Outcomes
• Long-term | | • Fever >38.5 C | NR | [underlined: Other treatment] | • Accessory muscle score | • No
- 2 yr telephone followup | | • Respiratory distress or total clinical score >7 | [underlined: Comorbidities] | Inhaled albuterol solution | • Wheezing score | • No
[underlined: Study design] | | • Infant requiring immediate medical care including oxygen | None | Dose: | • Respiratory rate | • No
RCT-P | | | | 0.15mg/kg/dose q. 4 – 6 hrs via aerosol | • SaO_2_ | • No
[underlined: Length of enrollment] | | | | micromist nebulizer as indicated | • Hospitalization rate | • No
Winter months 1993 - 1994 | | | | | - 25% vs. 11%
[underlined: Masking] | | | | | • Parent's report of clinical status at 1 wk followup | • No
Double-blind | | | | | • Need for repeat evaluation in ER or outpatient clinic by 1 wk followup | • No
| | | | | • Need for continued therapy at 1 wk followup | • No
| | | | | • Recurrent respiratory symptoms at 2 yr followup | • NR
| | | | | - 35.7% vs. 28.6%
| | | | | Adverse events
| | | | | NR
[underlined: Author] | | [underlined: Inclusion Criteria:] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Daugbjerg et al., 1993^72^ | To evaluate the effect of nebulized corticosteroids in combination with bronchodilators in the treatment of acute wheezing in children up to 18 months of age | • = 18 months | 124 enrolled, 114 remaining for evaluation | [underlined: Group A (n = 31)] | Primary Outcomes | | Good
[underlined: Setting:] | | • 5–15 kg | [underlined: Sex] | Soluble prednisolone + Placebo inhalation + terbutaline inhalation | • Treatment failures (withdrawal from study because of deterioration of condition) | • Differences between all treatments vs. placebo are significant (P< 0.01), differences among treatment group not significant (P= 0.01) | [underlined: Significant differences at baseline]
Denmark, inpatient | | • Symptom score of 3 or more | P + T^5^: 71% male (22/31) | [underlined: Group B (n = 29)] | - P + T: 16% (5/31) | | None
[underlined: Followup:] | | • First pr recurrent attack of wheezing | B + T: 69% male (20/29) | Soluble placebo + budesonide inhalation + terbutaline inhalation | - B + T: 3% (1/29) | | [underlined: Other Comments]
Acute | | [underlined: Exclusion Criteria] | T: 70% male (19/27) | [underlined: Group C (n=27)] | - T: 11% (3/27)
Short term | | • Pretreatment with steroids | P: 59% male (16/27) | Soluble placebo + placebo inhalation + terbutaline inhalation | - P: 2% (14/27)
[underlined: Study design] | | • Chronic lung disease or heart disease | [underlined: Mean age at enrollment in mo. ± SD] | [underlined: Group D (n=27)] | • Mean days of hospitalization ± SD | • Yes (P = 0.04)
RCT-P | | • Requiring assisted ventilation | P + T: 10.2 ± 4.5 | Soluble placebo + placebo inhalation + normal saline inhalation | - P + T: 3.5± 1.4
[underlined: Length of enrollment] | | • Allergy to the test medication | B + T: 9.1 ± 4.4 | Prednisolone: | - B + T: 3.5± 1.1
Winter seasons | | | T: 8.6 ± 3.6 | Day 1: 4–6 mg/kg | - T: 4.3 ± 1.4
1989-1990, | | | P: 9.3 ± 3.9 | Day 2,3: 1.6–2.6 mg/kg | - P: 4.1 ± 1.0
1990-1991 | | | [underlined: Mean gestational age] | Budesonide: 0.5 mg q. 4 hrs until discharge or for five days | Secondary outcomes
[underlined: Masking] | | | NR | Terbutaline: 1.12–0.2 mg/kg q. 4 hrs until discharge or for five days | • Mean temperature ± SD | • Yes (P= 0.02)
Double-blind | | | [underlined: Comorbidities] | Both budesonide and terbutaline dissolved in normal saline, administered with oxygen at flow of 8 L/min via facemask. Night inhalation omitted if child was asleep, | - P + T: 37.4 ± 0.5
| | | None | [underlined: Other treatment] | - B + T: 37.3 ± 0.6
| | | | NR | - T: 37.5 ± 03
| | | | | - P: 37.2 ± 0.5
| | | | | • Mean respiratory rate ± SD | • Yes (P = 0.08)
| | | | | - P + T: 39 ± 10
| | | | | - B + T: 42 ± 8
| | | | | - T: 41 ± 10
| | | | | - P: 42 ± 5
| | | | | • Mean respiratory rate ± SD | • Yes (P = 0.009)
| | | | | - P + T: 39 ± 10
| | | | | - B + T: 42 ± 8
| | | | | - T: 41 ± 10
| | | | | - P: 42 ± 5
| | | | | Subgroup analysis
| | | | | • Age (Treatment failures for steroids groups vs. terbutaline + placebo)
| | | | | • Under 12 mos
| | | | | • Over 12 mos
| | | | | Adverse events
| | | | | None observed
[underlined: Author] | | [underlined: Inclusion Criteria:] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Goebel et al., 2000^66^ | To compare albuterol plus prednisolone versus albuterol plus placebo in young children with mild to moderate bronchiolitis | • = 23 mos of age | 51 randomized, 48 at conclusion of study, 32 with complete data | [underlined: Group A (n = 24)] | Primary outcome | | Good
[underlined: Setting] | | • Symptoms of viral respiratory tract infection (rhinorrhea, cough, rectal temp to 38.5°C) during fall and winter months | [underlined: Sex] | Prednisolone plus albuterol | • Clinical scores (Prednisolone plus albuterol vs. placebo plus albuterol) | • Significant change for prednisolone plus albuterol between days 0 and 2 (P < 0.05), no significant change for placebo plus albuterol between days 0 and 2 (P > 0.05) | [underlined: Significant differences at baseline]
United States, Emergency department | | • First time wheezing not completely cleared by 1 dose of albuterol | Prednisolone plus albuterol: 75% male (18/24) | Prednisolone: PO 2mg/kg/d PO divided BID × 5 days | - Day 0: 4.5 ± 1.7 vs. 4.9 ± 1.4 | | None
[underlined: Followup] | | [underlined: Exclusion criteria] | Placebo plus albuterol: 67% male (16/24) | Albuterol: | - Day 2: 2.7 ± 1.4 vs. 4.0 ± 1.5 | | [underlined: Other comments]
• Acute | | • History of | [underlined: Median age at enrollment in months (range)] | PO 0.3 mg/kg/day PO, divided TID or 0.15 mg/kg/dose QID by nebulizer | • Clinical scores on Day 3 (values NR) | • No (P value NR) | • Possible confounding effects from different methods of dosing albuterol
• Short term | | - immune defect | Prednisolone plus albuterol: 4.0 (0 – 13) | [underlined: Group B (n = 24)] | • Clinical scores on Day 6 (values NR) | • No (P value NR) | • Incomplete followup
[underlined: Study design] | | - neurologic disease with possible aspiration | Placebo plus albuterol: 4.5 (0 – 16) | Placebo plus albuterol | [underlined: Subgroup analysis] | | • Post-hoc exclusion of 3 subjects
RCT-P and open label albuterol | | - gastroesophageal reflux | [underlined: Mean gestational age] | Placebo: Identically appearing solution, given at same dose and schedule | • RSV status, culture positive vs. culture negative | Trend toward improvement in Grp A regardless of RSV status but not statistically significant (P value NR)
[underlined: Length of enrollment] | | - congenital or acquired heart or lung disease | NR | Albuterol: Same as group A | Adverse events
NR | | - mechanical ventilation | [underlined: Comorbidities] | [underlined: Other treatment] | • 1 subject in Grp A jittery, resolved after reduction of albuterol dosel
[underlined: Masking] | | - birth before 36 wks gestation | None | NR
Double-blind | | • Fever > 38.5°C rectally, antibiotic therapy within 1 wk or antipyretics within 8 hrs
| | • Evidence of bacterial infection
| | • Emesis precluding administration of oral meds
| | • Initial bronchiolitis score < 2 or > 9
[underlined: Author] | | [underlined: Inclusion Criteria:] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Klassen et al., 1997^69^ | To determine the clinical benefit of oral dexamethasone in children admitted to the hospital with bronchiolitis treated with nebulized salbutamol | • First episode of wheezing (lasting < 7days) | 72 eligible, 72 randomized, 67 completed study | [underlined: Group A (n = 32)] | Primary outcome | | Excellent
[underlined: Setting] | | • Clinical evidence of viral infection: | [underlined: Sex] | Plaecbo | • Change in RDAI from baseline to 12, 24, 36, 48 and 60 hrs (placebo vs. dexamethasone) | • No (P values range from 0.23 to 0.74) | [underlined: Significant differences at baseline]
Canada, | | - rhinorrhea | Placebo: 47% male (15/32) | 70% sucrose solution | Secondary Outcomes | | None
Inpatient | | - temp > 37.5°C | Dexamethasone: 63% (22/35) | [underlined: Group B (n = 53)] | • Mean duration of hospitalization in hrs (range) (placebo vs. dexamethasone) | • No (P = 0.19) | [underlined: Other comments]
[underlined: Followup] | | • > 6 wks. to < 15 mo of age | [underlined: Mean age at enrollment in years] | Dexamethasone | - 48 (42, 54) vs. 57 (38, 76) | | None
• Acute | | O_2_< 95% at admission | Placebo: 0.39 | 70% sucrose solution and dexamethasone, 0.5 mg/kg initial, 0.3 mg/kg q. morning until discharge | • Readmission (placebo vs. dexamethasone) | • No (P = 0.36)
• Short term | | • RDAI > 6 | Dexamethasone: 0.39 | [underlined: Other treatment] | - 1 (3%) vs. 4 (11%)
- 1 wk after discharge | | [underlined: Exclusion criteria] | [underlined: Mean questational age] | • Nebulized salbutamol (0.15mg/kg) q 4 hrs × first 24 hrs | • Change in oxygen saturation from baseline to 12, 24, 36, 48 and 60 hrs (placebo vs. dexamethasone) | • No (P values range from 0.28 to 0.47)
[underlined: Study design] | | • Underlying disease which affects cardiopulmonary status: | NR | • 35% O_2_ via plastic tent | • Change in respiratory rate at same intervals (placebo vs. dexamethasone) | • No (P values range from 0.09 to 0.78)
RCT-P | | - Cystic fibrosis | [underlined: Comorbidities] | | • Visits to MD/other health professionals (placebo vs. dexamethasone) | • No (P = 0.77)
[underlined: Length of enrollment] | | - bronchopulmonary dysplasia | None | | - 24 (75%) vs. 29 (83%)
Nov 1993 - Apr 1995 | | - congenital heart disease | | | • Salbutamol at discharge (placebo vs. dexamethasone) | • No (P = 0.82)
[underlined: Masking] | | - immunodeficiency | | | - 6 (19%) vs. 6 (17%)
Double-blind | | • Physician diagnosed asthma | | | • Orciprenaline at discharge (placebo vs. dexamethasone) | • No (P = 0.16)
| | • Wheezing or cough treated by bronchodilators | | | - 2 (6%) vs. 7 (20%)
| | • Steroid treatment within 2 wks of admission | | | • Antibiotic use (placebo vs. dexamethasone) | • No (P = 0.3)
| | | | | - 13 (41%) vs. 10 (29%)
| | | | | • IV hydration (placebo vs. dexamethasone) | • No (P = 0.46)
| | | | | - 5 (16%) vs. 3 (8%)
| | | | | • Number of salbutamol inhalations after first 24 hrs | • No
| | | | | - Details NR
| | | | | Subgroup analysis
| | | | | None
| | | | | Adverse events
| | | | | NR
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Schuh et al., 2002^23^ | To investigate in outpatients younger than 2 yrs with acute bronchiolitis the clinical benefits of oral dexamethasone within 4 hrs of administration in the emergency department and after 5 d of continued therapy after discharge | • 8 wks - 23 mo | 71 eligible, 70 randomized, 67 evaluated at Day 7, 65 contacted on Day 28 | [underlined: Group A (n = 36)] | Primary outcome | | Excellent
[underlined: Setting] | | • First wheezing episode associated with respiratory distress | [underlined: Sex] | Oral dexamethasone | • Rate of hospitalization (dexamethasone vs. placebo) | • Yes (P= 0.039) | [underlined: Significant differences at baseline]
Canada, emergency department | | • RDAI rating of ≥ 6 at baseline | Dexamethasone: 56% male (20/36) | 1 mg/kg in wild cherry syrup | - 44% (15/34) vs. 19% (7/36) | | Dexamethasone group more likely to have family history of atopy (P= 0.013)
[underlined: Followup] | | • Presentation between 8 am to 9 pm | Placebo: 68% male (23/34) | [underlined: Group B (n = 34)] | Secondary Outcomes | | [underlined: Other comments]
• Acute | | [underlined: Exclusion criteria] | [underlined: Mean age at enrollment (mo ± SE)] | Placebo syrup | • Mean RACS from baseline to 240 mins ± SD (dexamethasone vs. placebo) | • Yes (P= 0.029) | None
• Short term | | • Previous history of wheezing or bronchodilator therapy | Dexamethasone: 6.1 ± 3.5 | Identical color, texture, taste and smell | - - 5.0 ± 3.1 vs. - 3.2 ± 3.7
- Day 7 at patient's home | | • Prematurity | Placebo: 6.9 ± 3.9 | [underlined: Other treatment] | • Mean RDAI from baseline to 240 mins ± SD (dexamethasone vs. placebo) | • No (P= 0.064)
- Day 28 by telephone | | • Neonatal ventilation | [underlined: Mean gestational age (wk ± SE)] | • Nebulized albuterol for all patients via vented nebulizer 2.5 mg per dose in 3 mL of normal saline with oxygen flow of 6–7 L/min with a tight - fitting face mask at 0, 30, 60 and 120 mins | - 5.4 ± 2.1 vs. 7.2 ± 2.8
[underlined: Study design] | | • Chronic lung/cardiac disease | NR | • Acetaminophen for fever as indicated | • Mean RACS from baseline to Day 7 ± SD (dexamethasone vs. placebo) | • No (P= 0.75)
RCT-P | | • Aspiration | [underlined: Comorbidities] | • Discharged infants received dexamethasone in 0.6mg/kg/dose PO qd × 5 days or placebo as randomized, and albuterol 1.5 mg (0.3 μL) QID with same nebulizer | - - 8.9 ± 5.2 vs. - 9.3 ± 4.9
[underlined: Masking] | | • Neurologic/neuromus - cular problems | None | | • Mean RDAI from baseline to Day 7 ± SD (dexamethasone vs. placebo) | • No (P= 0.754)
Double-blind | | • Immunodeficiency | | | - 2.4 ± 3.1 vs. 2.6 ± 3.0
[underlined: Length of enrollment] | | • Critically ill infants requiring immediate airway stabilization | | | • Use of additional corticosteroids after discharge (dexamethasone vs. placebo) | • Yes (P= 0.004)
Nov 1997 to Apr 2000 | | • Previous use of oral or inhaled corticosteroids | | | - 0/35 vs. 7/32
| | • Exposure to varicella within 21 days before arrival | | | Subgroup analysis
| | | | | None
| | | | | Adverse events
| | | | | NR
[underlined: Author] | | [underlined: Inclusion criteria of original study] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Van Woensel et al., 2000^67^ | A followup study of van Woensel^68^ to investigate the effect of oral prednisolone vs. placebo during the acute phase of RSV bronchiolitis on the prevalence of wheezing during the first yr of life and asthma at age 5 yrs | • < 2 yrs of age | 54 randomized in original study, 47 completed 5 yr followup | [underlined: Group A (n = 24 at followup)] | Primary outcome | | Fair
[underlined: Setting] | | • Microbiologically proven RSV bronchiolitis | [underlined: Sex] | Oral prednisolone | Wheezing outcomes in past 3 months (prednisolone vs. placebo) | | [underlined: Significant differences at baseline]
Telephone followup of original Inpatient sample | | • Bronchiolitis defined as first attack of acute tachypnea, wheezing and/or decreased breath sounds, cyanosis, and the use of accessory respiratory muscles in the presence of an apparent viral infection | Prednisolone: 63% male (15/24) | 1 mg/kg/day in 2 divided doses × 7 days | • No wheezing | • No (P value NR) | None
[underlined: Followup] | | [underlined: Exclusion criteria of original study] | Placebo: 61% male (14/23) | [underlined: Group B (n = 23 at followup)] | - 8/24 (33%) vs. 9/23 (39%) | | [underlined: Other comments]
5 yrs after original study (Aug 1998 to April 1999) | | • Use of corticosteroids (systemic or by inhalation) during the 2 mos before admission | [underlined: Mean age at enrollment in yrs ± SE] | Placebo | • Transient wheezing (wheezing during first^t^ yr of life, stopped before age 5) | • No (P value NR) | None
[underlined: Study design] | | | Prednisolone: 4.9 ± 0.13 | Identical capsules, broken and dissolved in water | - 2/24 (8%) vs. 4/23 (17%)
RCT-P | | | Placebo: 5.1± 0.16 | [underlined: Other treatment] | • Persistent wheezing (wheezing during first yr of life, asthma or asthma attacks at age 5) | • No (P value NR)
[underlined: Length of enrollment of original study] | | | [underlined: Mean gestational age] | Supplemental oxygen, bronchodilators or antibiotics as indicated (NR in this study, details in original study) | - 10/24 (42%) vs. 7/23 (31%)
Dec 1992 - April 1995 | | | NR | | • Late onset wheezing (no wheezing during first yr of life, asthma or asthma attacks at age 5) | • No (P value NR)
[underlined: Masking] | | | [underlined: Comorbidities] | | - 4/24 (17%) vs. 3/23 (13%)
Double-blind | | | Prematurity, chronic lung disease, heart disease | | Subgroup analysis
| | | - Prednisolone: 5/24 (21%) | | • Severe bronchiolitis | • No (P value NR)
| | | - Placebo: 8/23 (35%) | | - pretreatment severity score = 6 (range: 0–12) and those needing mechanical ventilation
| | | | | Adverse events
| | | | | None
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
van Woensel et al., 1997^68^ | To determine the effect of prednisolone on the clinical course of children admitted to hospital with RSV bronchiolitis, including patients with severe disease | • < 2 yrs of age | 54 randomized, 53 included in efficacy analysis | [underlined: Group A (n = 27)] | Primary outcome | | Good
[underlined: Setting] | | • Microbiologically confirmed RSV bronchiolitis | [underlined: Sex] | Oral prednisolone | • Mean decline in symptom score among non-ventilated patients ± SE (prednisolone vs. placebo, N = 39) | • Yes (P = 0.02) | [underlined: Significant differences at baseline]
Netherlands, Inpatient | | • Bronchiolitis defined as acute tachypnea, wheezing, and/or decreased breath sounds, cyanosis and use of accessory respiratory muscles, in the presence of an apparent viral infection | Prednisolone: 67% male (18/27) | 1mg/kg/day in two divided doses × 7 days | - - 1.2 ± 0.2 vs. 0.6 ± 0.2 | | NR
[underlined: Followup] | | [underlined: Exclusion criteria] | Placebo: 41% male (11/27) | [underlined: Group B (n = 27)] | • Mean duration of hospitalization in days among non-ventilated patients ± SE (prednisolone vs. placebo) | • No (P < 0.54) | [underlined: Other comments]
Acute | | • Corticosteroids (systemic or by inhalation) during the two mos before admission | [underlined: Median age at enrollment in mo. (inter - quartile range)] | Placebo | - 7.3 ± 1.2 vs. 8.3 ± 0.9 | | III study group with high degree of comorbidity
[underlined: Study design] | | | Prednisolone: 3.3 (1.4–5.9) | Identical capsules, broken and dissolved in water | • Mean duration of hospitalization in days among ventilated patients ± SE (prednisolone vs. placebo) | • Yes (P < 0.01)
RCT-P | | | Placebo: 3.9 (1.9–6.1) | [underlined: Other treatment] | - 11.0 ± 0.7 vs. 17.0 ± 2.0
[underlined: Length of enrollment] | | | [underlined: Mean gestational age] | Supplemental oxygen, bronchodilators or antibiotics as indicated | • Mean duration of mechanical ventilation in days ± SE (prednisolone vs. placebo) | • No (P< 0.556)
Dec 1993 - April 1995 | | | NR | | - 4.7 ± 1.1 vs. 6.3 ± 1.6
[underlined: Masking] | | | [underlined: Comorbidities] | | Secondary outcomes
Double-blind | | | Patients on ventilators at entry: 14, 7 in each group | | • Duration of supplemental oxygen | • No
| | | Bronchopulmonary dysplasia: 6/27 for prednisolone vs. 9/27 for placebo | | • Bronchodilator use | • No
| | | | | • Antibiotic use | • No
| | | | | Subgroup analysis
| | | | | • Baseline severity score | • No
| | | | | • Family history of atopic disease | • No
| | | | | • IgE level at entry | • No
| | | | | Adverse events
| | | | | 1 death unrelated to intervention

5 P + T: Prednisolone + terbutaline

B + T: Budesonide + terbutaline

T: Terbutaline

P: Placebo

Evidence Table 7. Parenteral Dexamethasone vs. Placebo

Study Characteristics | Stated Objective of Study | Inclusion/Exclusion Criteria | Demographic Characteristics and Cormorbidities | Intervention | Outcome | | Quality
[underlined: Author] | To reevaluate the efficacy of intravenous corticosteroids in previously healthy infants without underlying disease hospitalized with proven RSV primary infection | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
De Boeck et al., 1997^48^ | | • < 24 months admitted to hospital | 32 enrolled, 29 completed study | [underlined: Group A (n = 51)] | Primary outcome | | Fair
[underlined: Setting] | | • Signs of bronchiolitis: prodromal rhinorrhea, cough, or low-grade fever followed by at least 2 of the following signs: chest retractions, tachypnea, wheezing, or rales | [underlined: Sex] | Dexamethasone | • Mean duration of hospitalization in days ± SE (dexamethasone vs. placebo) | • No (P value NR) | [underlined: Significant differences at baseline]
Belgium, Inpatient | | • Detection of RSV in nasal wash taken on admission by ELISA | NR | 0.6 mg/kg IV × 2 on Day 1, 0.015mg/kg on Days 2 and 3 | -6.0 ± 0.3 vs. 6.6 ± 0.7 | | None
[underlined: Followup] | | • First episode of wheezing or shortness of breath | [underlined: Median age at enrollment in days (range)] | [underlined: Group B (n = 53)] | Secondary outcomes | | [underlined: Other comments]
Acute | | • Onset of illness within previous 5 days | Dexamethasone: 186 (111 – 224) | Placebo | • Improvement in clinical scores after aerosol | • No | None
[underlined: Study design] | | [underlined: Exclusion criteria] | Placebo: 213 (133 – 267) | Details NR | • Respiratory rate | • No
RCT-P | | • Underlying heart, lung, or immune disorder | [underlined: Mean gestational age (wks ± SE)] | [underlined: Other treatment] | • oxygen saturation | • No
[underlined: Length of enrollment] | | • Premature (< 34 wks gestational age) | NR | • Salbutamol (0.5%), 0.25 ml and ipratropium bromide (0.025%), 0.5 ml aerosolized every 6 hrs | • Pulmonary function tests | • No
Epidemic of 1991 to 1992 | | | [underlined: Comorbidities] | • Oxygen to maintain oxygen saturation > 90% | • Treatment with antibiotics | • No
[underlined: Masking] | | | None | • Antibiotics as indicated | [underlined: Subgroup analysis]
Double-blind | | | | • Standardized concomitant therapy | None
| | | | | [underlined: Adverse events]
| | | | | NR
[underlined: Author:] | To assess the efficacy and safety of dexamethasone in infants with bronchiolitis who require hospital management | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervension] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Roosevelt et al., 1996^43^ | | • < 12 mos of age | 122 enrolled, 118 completed study | [underlined: Group A (n = 65)] | [underlined: Primary outcome] | | Good
[underlined: Setting] | | • first episode of wheezing | [underlined: Sex] | Dexamethasone | • Time to resolution (number of 12 hr periods needed for SaO_2_ >95% while receiving no supplemental oxygen, accessory muscle score of 0, wheeze of 0 or 1, and resumption of normal feeding) | • No (P = 0.22) | [underlined: Significant differences at baseline]
United States, Inpatient | | [underlined: Exclusion criteria] | Dexamethasone: 63% male (41/65), | Dose: 1 mg/kg IM q day × 3 days | - Hazard ratio (95% C.I.): 1.3 (0.9 - 1.3) | | Dexamethasone group had significantly more patients with SaO_2_ <95% (79% vs. 59%, P = 0.02)
[underlined: Followup] | | • infants < 4 wks old | Placebo: 62% male (33/53) | [underlined: Group B (n = 53)] | • Duration of oxygen therapy | • No (P = 0.74) | [underlined: Other comments]
• Acute | | • admitted to ICU | [underlined: Mean age at enrollment (mo.± SD)] | Placebo | - Hazard ratio (95% C.I.): 0.9 (0.6 - 1.4) | | None
• Short term | | • known history of congenital heart disease | Dexamethasone: 5.3 ± 3.7 | Dose: Identically appearing solution and schedule | Secondary outcomes
- telephone followup 10 – 14 days after discharge | | • history of intubation, ventilation, supplemental oxygen | Placebo: 5.0 ± 2.5 | [underlined: Other treatment] | • Use of antibiotics, nebulized beta-agonist and other bronchodilators | • No
[underlined: Study design] | | | [underlined: Mean gestational age] | Antibiotics and nebulized bronchodilators used as needed | • Visits to health professionals for respiratory symptoms | • No
RCT-P | | | NR | | • Steroid use started in hospital after study completed | • No
[underlined: Length of enrollment] | | | [underlined: Comorbidities] | | • Symptoms reported by parents at 14 day followup | • No
Dec 1993 to March 1994, Dec 1994 to March 1995 | | | None | | Subgroup analyses
Masking | | | | | • RSV status | • No
Double-blind | | | | | • Hypoxia (<95% SaO_2_) | • No
| | | | | • Family history of atopy | • No
| | | | | • RSV and family history of atopy | • No
| | | | | Adverse events
| | | | | Positive stool for occult blood in 2/65 for dexamethasone vs. 1/53 for placebo

Evidence Table 8. Nebulized Corticosteroids vs. Placebo or Usual Care

Study Characteristics | Stated Objective of Study | Inclusion/Exclusion Criteria | Demographic Characteristics and Cormorbidities | Intervention | Outcome | | Quality
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Cade et al., 2000^71^ | To evaluate the short and long term effects of giving a short course of nebulized budesonide to hospitalized infants with RSV positive bronchiolitis | • < 12 months of age | 165 enrolled, 161 completed study | [underlined: Group A (n = 82)] | Primary outcomes | | Good
[underlined: Setting] | | • Confirmed RSV infection | [underlined: Sex] | Budesonide | • Coughing and wheezing episodes in 12 mo followup period (budesonide vs. placebo) | • No (P =0.98) | [underlined: Significant differences at baseline]
United Kingdom, Inpatient | | • Randomization within 12 hrs of admission | 56% male (45/82) for budesonide | 1mg nebulized twice daily until 14 days after discharge, up to a maximum of 21 days | - 99% vs. 99% | | More furry pets in placebo households (36% vs. 21%)
[underlined: Followup] | | [underlined: Exclusion criteria] | 60% male (47/79) for placebo | [underlined: Group B (n = 79)] | Secondary outcomes | | [underlined: Other comments]
United Kingdom | | • Previous hospital admissions with respiratory tract illness | [underlined: Mean age (days ± SD)] | Placebo | • Days from first nebulization until fit for hospital discharge | • No (P =0.51) | None
[underlined: Study Design] | | • Chronic respiratory illness | Budesonide: 130 ± 85 | Nebulized vehicle given in place of budesonide, using same schedule as Group A | - Hazard ratio (95% C.I.): 1.1 (0.80 – 1.51)
RCT-P | | • Congenital heart disease | Placebo: 120 ± 84 | [underlined: Other interventions] | • Time to become asymptomatic for 48 hrs | • No (P =0.07)
[underlined: Length of enrollment] | | • Prematurity | [underlined: Mean gestational age] | Ipratropium bromide, beta agonists, antibiotics, oral or intravenous steroids as indicated | - Hazard ratio (95% C.I.): 1.41 (0.98 – 2.04)
NR | | • Pre-existing immunodeficiencies | NR | | • Mean number of coughing/ wheezing episodes from discharge to day 28 ± SD (budesonide vs. placebo) | • No (P =0.91)
[underlined: Masking] | | • Recent exposure to varicella or tuberculosis | [underlined: Comorbidities] | | - 17.0 ± 7.6 vs. 17.1 ± 8.5
Double-blind | | • Prolonged exposure to systemic steroids | NR | | • Readmission for respiratory morbidity over 12 months (budesonide vs. placebo) | • No (P =0.78)
| | | | | - 16% vs. 17%
| | | | | • Mean visits for respiratory morbidity(budesonide vs. placebo) | • No (P =0.29)
| | | | | - 4 vs. 4.5
| | | | | • Prescription for bronchodilator (budesonide vs. placebo) | • No (P =0.42)
| | | | | - 60% vs. 67%
| | | | | • Prescription for steroids(budesonide vs. placebo) | • No (P =0.23)
| | | | | - 50% vs. 60%
| | | | | Subgroup analysis
| | | | | • Outcomes (1) Respiratory related readmissions (2) GP respiratory visits by | • No significant differences between budesonide and placebo for both outcomes by all subgroups
| | | | | - Initial severity score
| | | | | - Duration of symptoms at presentation
| | | | | - Atopic history
| | | | | - Exposure to cigarette smoke or damp in household
| | | | | Adverse events
| | | | | NR
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Fox et al., 1999^73^ | To assess the efficacy of inhaled budesonide in reducing the incidence of coughing and wheezing episodes during the first yr after acute viral bronchiolitis | • = 12 mo of age | 60 enrolled, 49 patients with full followup | [underlined: Group A (n = 26)] | Primary outcomes | | Fair
[underlined: Setting] | | • Clinical diagnosis of acute viral bronchiolitis requiring hospital admission | [underlined: Sex] | Budesonide | • Number with wheezing/cough at (budesonide vs. placebo) | • Significant only at 12 mo | [underlined: Significant differences at baseline]
United Kingdom, inpatient at baseline, diary records and Outpatient followup | | • Clinical diagnosis based on tachypnea (respiratory rate > 40/mins), chest hyperinflation, soft tissue recession, and bilateral crackles, with or without wheezes | Budesonide: 77% male (20/26) | 200 μ 1 puff BID × 8 wks by metered dose inhaler and modified spacer and face mask system | - 1 mo: 4/26 vs. 5/28 | - (P = 1.0) | None
[underlined: Followup] | | [underlined: Exclusion criteria] | Placebo: 50% male (14/28) | [underlined: Group B (n = 28)] | - 2 mo: 11/26 vs. 11/28 | - (P = 0.82) | [underlined: Other comments]
• Long term | | • Underlying cardiopulmonary disease | [underlined: Mean age at enrollment in weeks (range)] | Placebo | - 6 mo: 15/26 vs. 12/27 | - (P = 0.49) | • When possible confounding effect of sex is controlled, diff between study groups in symptoms at 12 mo reduces in significance
- 12 months | | • Congenital heart disease | Budesonide: 11 (1–38) | Similar schedule and route as intervention | - 12 mo: 21/25 vs. 12/24 | - (P = 0.03) | • 11 patients concluded from final data analysis for loss to followup, partial loss to followup or poor compliance
[underlined: Study Design] | | • Bronchopulmonary dysplasia | Placebo: 10 (3–42) | [underlined: Other treatment] | • Hospital admissions by 12 mo followup (budesonide vs. placebo): | • No (P = 0.94)
RCT-P | | • Cystic fibrosis | [underlined: Mean gestational age] | Routine supportive care as needed | - 5/25 vs. 6/24
[underlined: Length of enrollment] | | • History of respiratory problems in the neonatal period | NR | | • Number with =3 symptom episodes at 12 mo followup (budesonide vs. placebo): | • No (P =0.27)
NR | | • Requiring mechanical ventilation during present illness | [underlined: Comorbidities] | | - 11/25 vs. 6/24
[underlined: Masking] | | | None | | • Median (range) symptom episodes at 12 mo followup (budesonide vs. placebo): | • Yes (P = 0.02)
Double-blind | | | | | - 2 (0–13) vs. 1(0–11)
| | | | | • Median (range) symptom days at 12 mo. followup (budesonide vs. placebo): | • No (P = 0.08)
| | | | | - 18(0–106) vs. 9(0–90)
| | | | | Subgroup analysis
| | | | | • Logistic regression of symptoms at 12 mo. followup, controlling for differences in sex (no significant differences for sex at baseline, but 24/30 males vs. 9/19 females had symptoms at followup and more males got budesonide) | • No (P = 0.051)
| | | | | Adverse events
| | | | | • Admission to hospital with viral gastroenteritis (1/24 in placebo group)
| | | | | • Mild coughing and wheezing (1/25 in budesonide group)
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Kajosaari et al., 2000^74^ | To determine whether inhaled corticosteroids in infants during and after the acute phase of RSV infections influences their subsequent respiratory status | • 0 – 9 months of age | 117 randomized and initial study size, 109 completed followup study at 2 yrs | [underlined: Group A (n = 41 at baseline, 38 at 2 yr followup)] | Primary outcomes | | Poor
[underlined: Setting] | | • Needing hospital treatment because of RSV bronchiolitis | [underlined: Sex] | Symptomatic treatment: oxygen, bronchodilators and/or racemic epinephrine | • Asthma inhalation therapy at 2 yrs (Grp A vs. Grp B vs. Grp C) | • Yes | [underlined: Significant differences at baseline]
Finland, needing hospital treatment at baseline, Outpatient at 2 and 6 mo, telephone interview at 2 yrs | | • Healthy, full-term babies | NR | [underlined: Group B (n = 40 at baseline, 39 at 2 yr followup)] | - 37% (14/38) vs. 18% (7/39) vs. 12% (4/32) | | Grp A had lower proportion of atopic heredity
[underlined: Followup] | | [underlined: Exclusion criteria] | [underlined: Mean age range at enrollment in months] | Symptomatic treatment + inhaled budesonide | - Odds ratio (95% C.I.) of Grp A vs. Grp C: 4.08 (1.39 – 11.98) | Grp A vs. Grp B: P = 0.006 | [underlined: Other comments]
• Acute | | • Mechanical ventilation | Group A: 0.5 – 5.2 | 500 μg TID × 7 days | - Odds ratio (95% C.I.) of Grp A vs. Grp B: 2.67 (0.98 – 7.27) | - Grp A vs. Grp C: P = 0.01 | 8 children concluded from final analysis: 3 due to loss to followup, 1 for RSV infection, 1 for prematurity, 3 for non-compliance
• Long-term | | • Pre-term babies | Group B: 0.3 – 6.4 | [underlined: Group C (n = 36 at baseline, 32 at 2 yr followup)] | - Odds ratio (95% C.I.) of Grp A vs. (Grp B + Grp C): 3.18 (1.25 – 8.12) | - NR
- 2 mo | | | Group C: 0.5 – 5.9 | Symptomatic treatment + inhaled budesonide | • Atopic status at 6 mo | • NR
- 6 mo | | | [underlined: Mean gestational age] | 500 μg BID × 2 mos | - Grp 1: 13% (5/38)
- 2 yrs | | | NR | [underlined: Other treatment] | - Grp 2: 28% (11/39)
[underlined: Study Design] | | | [underlined: Comorbidities] | Routine care as indicated | - Grp 3: 25% (8/32)
RCT-nonplacebo | | | None | | Secondary outcomes
[underlined: Length of enrollment] | | | | | NR
NR | | | | | Subgroup analysis
[underlined: Masking] | | | | | None
None | | | | | Adverse events
| | | | | NR
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Reijonen 1996^75^ | To determine whether early treatment with nebulized cromolyn sodium or budesonide reduces the frequency of wheezing episodes among infants with acute bronchiolitis | • Hospitalized patients age 1 – 23 mos | 100 enrolled, 98 at 6 wk followup, 92 at 16 wk followup | [underlined: Group A (n = 34)] | Primary outcome | | Fair
[underlined: Setting] | | • Clinical criteria of acute bronchiolitis: wheezing and respiratory distress in patient with acute URTI | [underlined: Sex] | Cromolyn sodium | • Mean days with symptomatic wheezing (cromolyn sodium vs. budesonide vs. no treatment) at | • No | [underlined: Significant differences at baseline]
Finland, inpatient | | [underlined: Exclusion criteria] | Cromolyn sodium: 65% male (22/34) | Dose: | - 1 to 4 wks: 5.1 vs. 4.9 vs. 5.3 | - P = 0.97 | None
[underlined: Followup] | | • Chronic cardiorespiratory disease (asthma, BPD, CHD) | Budesonide: 65% male (22/34) | 20mg QID × 8 wks then | - 5 to 8 wks: 4.5 vs. 3.5 vs. 3.9 | - P = 0.87 | [underlined: Other comments]
• Acute | | • Received medication for any pulmonary disease | Control: 81% male (26/32) | 20mg TID × 8 wks | - 9 to 16 wks: 9.1 vs. 7.5 vs. 2.3 | - P = 0.55 | • No placebo group
• Long-term | | | [underlined: Mean age at enrollment (mo ± SD)] | [underlined: Group B (n = 34)] | - 13 to 16 wks: 2.4 vs. 2.2 vs. 3.0 | - P = 0.87 | • Investigators not blinded
- Outpatient followup at 6 and 16 wks | | | Cromolyn sodium: 9.6 ± 6.2 Budesonide: 10.1 ± 5.0 | Budesonide | • At least one Physician-diagnosed wheezing episode at 1 – 8, 9 – 16 and 1 – 16 wks | • Significantly diff. from control group only at 9 – 16 wks: Cromolyn sodium vs. control (P = 0.01), Budesonide vs. control (P =0.01) | • Percentage of children with history of atopy high
[underlined: Study design] | | | Control: 11.1 ± 6.9 | Dose: | - Cromolyn sodium vs. control at 9 – 16 wks: 6/31 vs. 14/31 | | • All enrollees had participated in a Racemic epinephrine vs. Albuterol trial prior to enrollment in this study^54^
RCT non-placebo | | | [underlined: Mean gestational age] | 500μg BID × 8 wks then 250μg BID × 8 wks | - Budesonide vs. control at 9 to 16 wks: 5/31 vs. 14/31
[underlined: Masking] | | | NR | [underlined: Group C (n = 32)] | • Repeated (2 or more) Physician-diagnosed wheezing episodes at 1 to 16 wks | • Significantly diff. only for budesonide vs. control group (P =0.01)
Investigators not blinded, unclear for others | | | [underlined: Comorbidities] | No treatment | - Cromolyn sodium vs. control: 6/31 vs. 12/31
| | | • 13% with previous history of wheezing (no sig. diffs. among groups) | All meds given with face mask using a foot pump and pumping rate at 60/minute | - Budesonide vs. control 3/31 vs. 12/31
| | | • 29% with atopy (no sig. diffs. among groups) | [underlined: Other treatment] | • Hospital care for repeat wheezers (detail NR) | • No (P values NR)
| | | | • Oral bronchodilating drugs advised for 1 wk after acute bronchiolitis, as needed thereafter | Subgroup analysis
| | | | • Oral slow - release theophylline as needed | • Age (> 1 yr vs. < 1 yr) | • No
| | | | | • Atopic patients (n = 36) | • Not significant for Physician-diagnosed wheezing, (P > 0.05), significant for hospitalization (P < 0.05)
| | | | | - Physician-diagnosed wheezing:
| | | | | Cromolyn sodium: 4/13
| | | | | Budesonide:2/11
| | | | | Control: 8/12
| | | | | - Hospitalized for treatment of wheezing:
| | | | | Cromolyn sodium: 1/13
| | | | | Budesonide:1/11
| | | | | Control: 7/12
| | | | | Adverse events
| | | | | NR
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Richter et al., 1998^76^ | To determine the effectiveness of nebulized budesonide in reducing the severity and duration of lower respiratory symptoms in acute bronchiolitis and in preventing postbronchiolitic cough and wheezing | • < 12 months of age | 40 randomized, 40 completed study | [underlined: Group A (n = 21)] | Primary outcome | | Good
[underlined: Setting] | | • No previous wheezing episodes | [underlined: Sex] | Nebulized budesonide | Acute | | [underlined: Significant differences at baseline]
United Kingdom, Inpatient at baseline, Outpatient at followup | | • Hospitalized with clinical features of bronchiolitis, (tachypnea, recession, wheezing, and crepitations) | Budesonide: 57% male (12/21) | 1 mg in 2 mL BID × 5 days, then 500 μg/mL BID for remainder of 6 wk period | • Days in oxygen after trial entry (budesonide vs. placebo) | • No (P = 0.29) | None
[underlined: Followup] | | [underlined: Exclusion criteria] | Placebo: 53% male (10/19) | [underlined: Group B (n = 19)] | - 1.0 (0 to 7) vs. 1.0 (0 to 6) | | [underlined: Other comments]
• Acute | | • Congenital abnormality | [underlined: Median age at enrollment in wks (range)] | Placebo | • Maximum oxygen requirement after trial entry (budesonide vs. placebo) | • No (P = 0.33) | None
• Short term | | • Preexisting pulmonary disease | Budesonide: 16.3 (4.4 to 40.6) | 2 mL q. 12 hrs × 6 wks | - 30% (21% to 60%) vs. 30% (21% to 50%)
- 6 wks | | • Immune deficiency | Placebo: 10.8 (3.6 to 29.1) | [underlined: Method of delivery] | • Median (range) duration of hospitalization in days from trial entry to discharge (budesonide vs. placebo) | • No (P = 0.65)
• Long-term | | • Need for assisted ventilation | [underlined: Median gestational age in wks (range)] | Side Stream nebulizer with face masks with oxygen flow of 6 L/mins, and Portaneb compressors after discharge | - 2.0 (1 – 11) vs. 3.0 (1 – 7)
- 6 mo | | | Budesonide: 38 (34 to 41) | [underlined: Other treatment] | • Change in clinical scores 48 hrs after trial entry (range) (budesonide vs. placebo) | • No (P = 0.92)
[underlined: Study design] | | | Placebo: 39 (36 to 42) | Other treatment as needed, including terbutaline | - 2.0 (-6 – +6) vs. - 1.0 (-9 – +2)
RCT-P | | | [underlined: Comorbidities] | | Chronic - 6 wks
[underlined: Length of enrollment] | | | None | | • Infants not given bronchodilators during 6 wk treatment (budesonide vs. placebo) | • No (P = 1.0)
NR | | | | | - 9 (45%) vs. 8 (42%)
[underlined: Masking] | | | | | • Infants not given bronchodilators on 5+ occasions during 6 wk treatment (budesonide vs. placebo) | • No (P = 0.1)
Double-blind | | | | | - 10 (50%) vs. 4 (21%)
| | | | | • Mean daily symptom scores (budesonide vs. placebo) | • No (P = 0.94)
| | | | | - 2.7 vs. 1.5
| | | | | • Median no. of symptom - free days (budesonide vs. placebo) | • No (P = 0.57)
| | | | | - 8.5 vs. 12.0
| | | | | Chronic - 6 mos
| | | | | • Prevalence of wheeze during 6 mo followup (budesonide vs. placebo) | • No (P = 1.0)
| | | | | - 15 (75%) vs. 15 (79%)
| | | | | • Infants given bronchodilators during 6 mo followup (budesonide vs. placebo) | • No (P = 0.52)
| | | | | - 13 (65%) vs. 10 (53%)
| | | | | • Infants given inhaled + oral steroids during 6 mo followup (budesonide vs. placebo) | • No (P = 1.0)
| | | | | - 3 (15%) vs. 3 (16%)
| | | | | • Infants readmitted for respiratory problems (budesonide vs. placebo) | • Yes (P = 0.01)
| | | | | - 10 (50%) vs. 2 (10.5%)
| | | | | • Median scores for cough and wheeze (budesonide vs. placebo) | • No (P = 1.0)
| | | | | - 10.0 vs. 10.0
| | | | | • Median scores for wheeze only (budesonide vs. placebo) | • No (P = 0.97)
| | | | | - 4.5 vs. 5.0
| | | | | Subgroup analysis
| | | | | • Family history of atopy | • No significant difference for ny outcome
| | | | | - prevalence of wheeze
| | | | | - median score for cough and wheeze
| | | | | - median score for wheeze alone
| | | | | Adverse events
| | | | | • Median growth in cm/wk (budesonide vs. placebo) | • No (P = 0.16)
| | | | | - 0.43 vs. 0.47
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Wong et al., 2000^77^ | To assess the efficacy and safety of inhaled fluticasone propionate during the trial period, and the following 9 mos | • Age 2 wks to 12 mo | 48 randomized, 43 completed trial, 41 in long-term study | [underlined: Group A (n = 21)] | Primary outcome | | Good
[underlined: Setting] | | • First episode of lower respiratory tract infection | [underlined: Sex] | Fluticasone propionate (FP) | • Overnight oxygen saturation (details NR) | • No (P values NR) | [underlined: Significant differences at baseline]
United Kingdom, inpatient | | [underlined: Exclusion criteria] | Fluticasone propionate: 54% (13/24) | 3 puffs of 50 μg BID × 3 mo. from MDI administered via the babyhaler (spacer) with a face mask attachment | • Night cough events (single cough) during treatment and followup at 3, 6, 12, 24 and 36 wks from baseline | • No (P values range from 0.20 – 0.64) | None
[underlined: Followup] | | • Birth before 36 wks of gestation | Placebo: 58% (14/24) | [underlined: Group B (n = 23)] | • Night cough episodes (period of coughing with = 10 seconds before and after) during treatment and followup at 3, 6, 12, 24 and 36 wks from baseline | • Significant only at 36 wks (P = 0.05), not significant at other time periods | [underlined: Other comments]
• Acute | | • CHD or syndromic abnormalities | [underlined: Mean age at enrollment in mo. (range)] | Placebo | • Symptom frequency as recognized by parent (FP vs. Placebo) | • No (P values NR) | • Missing data value extrapolated from previous visit
• Long term at 3, 6, 9, and 12 mo after entry | | • Established systemic or chronic illnesses | Fluticasone propionate: 3.8 (0.9 – 4.7) | Type of placebo not reported, same delivery as above | - Cough: 95.8 vs. 89.6 | | • 3 FP patients withdrawn, 2 placebo patients withdrawn
[underlined: Study design] | | • Treatment with corticosteroids before entering study | Placebo: 3.9 (1.0 – 10.9) | [underlined: Other treatment] | - Wheeze: 99.7 vs. 94.5
RCT-P | | • Mechanical ventilation before entering study | [underlined: Mean gestational age in wks. (range)] | Bronchodilators, steroids and/or antibiotics as indicated | Secondary outcomes
[underlined: Masking] | | • Parents unable to use inhaler/babyhaler | Fluticasone propionate: 39.4 (36.8 – 43.0) | | • Lung function tests 6 mo. after discharge | • No
Double-blind | | | Placebo: 39.7 (36.0 – 42.0) | | • Use of rescue respiratory medications ß_2_ - agonists, corticosteroids, antibiotics) | • No, however more placebo subjects received bronchodilators/steroids, diff not significant (P = 0.07)
[underlined: Length of enrollment] | | | [underlined: Comorbidities] | | • Increase in respiratory symptoms leading caregivers to seek medical advice | • No
Mar 1994 – Apr 1996 | | | None | | • Hospital admissions at 9 mos after treatment | • No
| | | | | • Received treatment at 9 mos after treatment | • No
| | | | | Subgroup analysis
| | | | | None
| | | | | Adverse events
| | | | | Oral candidiasis (2 FP patients)

Evidence Table 9. Ribavirin vs. Placebo

Study Characteristics | Stated Objective of Study | Inclusion/Exclusion Criteria | Demographic Characteristics and Cormorbidities | Intervention | Outcome | | Quality
[underlined: Author] | To test the efficacy of ribavirin in infants with acute bronchiolitis | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Barry et al., 1986^46^ | | •Diagnosis of bronchiolitis defined as history of URTI followed by cough, breathlessness and wheezing and clinical signs of chest overinflation, tachypnea, rhonchi or crepitations. | 26 enrolled, 26 completed study | [underlined: Group A (n = 14)] | Primary outcome | | Fair
[underlined: Setting] | | [underlined: Exclusion criteria] | [underlined: Sex] | Aerosolized ribavirin | • Median hrs to sustained improvement (ribavirin vs. Placebo) in | •Not significant except for median hrs to sustained improvement in cough and crepitations (P < 0.05) | [underlined: Significant differences at baseline]
United Kingdom, multi-center inpatient | | • < 2 wks old | Ribavirin: 64% male (9/14) | 20 mg/ml | - cough (24 vs. 66) | | None
[underlined: Followup] | | • < 41 wks since mother's last menstrual period | Placebo: 83% male (10/12) | [underlined: Group B (n = 12)] | - nasal discharge | | [underlined: Other comments]
• Acute | | • Underlying chest or heart disease | [underlined: Age at enrollment] | Saline placebo | - feeding | | Details of randomization protocol not provided; however, assignment to treatment or control was specifically to minimize differences in age, arterialized capillary CO_2_, respiratory rate, and interval since onset of chest symptoms
• Short term | | • Previous bronchiolitis | NR | Both administered for 18 out of 24 hrs for at least 3 days | - nasal flare
- length of hospitalization | | • Immune defect | [underlined: Mean gestational age] | [underlined: Other treatment] | - wheeze
[underlined: Study design] | | • > 72 hrs of chest symptoms | NR | Oxygen and antibiotics as indicated | - chest recession
RCT-P | | | [underlined: Comorbidities] | | - rhonchi
[underlined: Length of enrollment] | | | None | | - crepitations (23 vs. 44)
NR | | | | | • Change in respiratory rate | • Yes (P < 0.05)
[underlined: Masking] | | | | | - Graphical data presented with text, specific values not detailed
Double-blind | | | | | • Change in heart rate | • No
| | | | | - Graphical data presented with text, specific values not detailed
| | | | | Subgroup analysis | • Significant difference only for decrease in chest recession (P < 0.05)
| | | | | RSV status
| | | | | Adverse events
| | | | | Transient redness of eyelids possibly from deposition of the drug on the skin (1 ribavirin patient)
[underlined: Author] | To determine the effect of ribavirin therapy on (a) the course of the acute illness (b) bronchial responsiveness at 6 mos and (c) the frequency of lower respiratory tract symptoms in the yr following admission | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Everard et al., 2001^78^ | | • Previously fit infants | 40 randomized, 35 completed study | [underlined: Group A (n = 16)] | Primary outcomes | | Fair
[underlined: Setting] | | • Moderately severe bronchiolitis | [underlined: Sex] | Ribavirin | • Mean days in oxygen (ribavirin vs. placebo) | • No (P = 0.41) | [underlined: Significant differences at baseline]
United Kingdom, Inpatient at baseline, Outpatient at followup | | • No high risk factors for severe disease | Ribavirin: 43% male (9/21) | 6 g in 180 ml H_2_0 by SPAG (Small Particle Aerosol Generator) over 18 hrs per day | - 3.36 vs. 2.52 | | None
[underlined: Followup] | | • Bronchiolitis defined as: evidence of URI followed by development of lower respiratory tract involvement characterized by airways obstruction and widespread crepitations on auscultation | Placebo: 47% male (9/19) | [underlined: Group B (n = 19)] | • Change in clinical score between day 1 and day 0 (ribavirin vs. placebo) | • No (P = 0.83) | [underlined: Other comments]
• Acute | | [underlined: Exclusion criteria] | [underlined: Mean age at enrollment in days (range)] | Normal saline placebo | - - 0.83 vs. -1.05 | | None
• Short term 6 wks | | None listed | Ribavirin: 93.7 (15–188) | Same protocol as Ribavirin group | • Change in oxygen saturation measured in air between day 1 and day 0 (ribavirin vs. placebo) | • No (P = 0.15)
• Long-term 6 mos | | | Placebo: 89.4 (16–266) | [underlined: Other treatment] | - 2.05 vs. 0.57
[underlined: Study design] | | | [underlined: Mean gestational age] | Other treatments as needed | • Days to discharge (ribavirin vs. placebo) | • No (P = 0.11)
RCT-P | | | NR | | - 5.58 vs. 3.95
[underlined: Length of enrollment] | | | [underlined: Comorbidities] | | • Days fit for discharge | • No (P = 0.37)
3 RSV seasons | | | NR | | - 4.77 vs. 3.86
[underlined: Masking] | | | | | Secondary outcomes
Double-blind | | | | | • Bronchial hyperresponsiveness | • No
| | | | | • Admitted with lower respiratory tract (LRT) symptoms during first yr (ribavirin vs. placebo) | • P values NR
| | | | | - 2 (12.5%) vs. 3 (15.8%)
| | | | | • Bronchodilators during first yr (ribavirin vs. placebo) | • P values NR
| | | | | - 5 (31.3) vs. 8 (42.1%)
| | | | | • Inhaled steroids during first yr (ribavirin vs. placebo) | • P values NR
| | | | | - 2 (12.5%) vs. 1 (5.3%)
| | | | | • No LRT symptoms during first yr (ribavirin vs. placebo) | • P values NR
| | | | | - 4 (25%) vs. 5 (26.3%)
| | | | | • Readmission in first yr (ribavirin vs. placebo) | • No (P = 0.46)
| | | | | - 2 (12.5%) vs. 3 (15.8%)
| | | | | Subgroup analysis
| | | | | None
| | | | | Adverse events
| | | | | • 1 patient died some months after discharge, death unrelated to ribavirin therapy
[underlined: Author] | To test the clinical effectiveness of ribavirin in previously well infants without underlying illnesses who require ventilatory support secondary to a first episode of RSV bronchiolitis | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Guerguerian et al., 1999^79^ | | • First episode of bronchiolitis diagnosed with presence of tachypnea, chest retraction, prolonged expiratory time, pulmonary rales, or wheezing and hyperinflation on chest radiograph | 51 eligible, 42 enrolled, 41 used for intent-to-treat analysis | [underlined: Group A (n = 20)] | Primary outcome | | Excellent
[underlined: Setting] | | • Mechanical ventilation instituted for respiratory distress manifested by one or more of the following: | [underlined: Sex] | Aerosolized ribavirin | • Mean length of mechanical ventilation in hrs ± SD (ribavirin vs. Placebo) | • No (P = 0.29) | [underlined: Significant differences at baseline]
Canada, ICU | | - extreme fatigue, or impending respiratory arrest, or severe apnea if preceded by significant respiratory distress | Placebo: 52% male (11/21) | 6 grams diluted w/ sterile water to a volume of 300 ml (20 mg/ml) | - 102.16 ± 65.26 vs. 126.28 ± 78.72 | | More preterm infants (< 37 wks gestation) in control group (P < 0.1)
[underlined: Followup] | | - uncompensated respiratory acidosis (pH < 7.30 and PCO_2_ > 60 mm Hg | Ribavirin: 65% male (13/20) | [underlined: Group B (n = 21)] | Secondary outcomes | | [underlined: Other comments]
| | - hypoxia (PaO_2_ < 60 mm Hg or pulse oximetry saturation [SpO_2_] < 93% with fraction of inspired oxygen [FIO_2_] = 0.6) | [underlined: Mean age at enrollment in days ± SD] | Saline placebo | • Length of aerosol therapy | • No (P = 0.31) | Length of ventilation among ribavirin pts reduces to 90.9 hrs when 1 patient. with ARDS is dropped from the analysis (P = 0.09)
• Acute | | • Proven RSV etiology | Placebo: 62.5 ± 35.9 | 300 ml saline (0.9%) | • Length of ICU stay | • No (P = 0.42)
• Short term | | [underlined: Exclusion criteria:] | Ribavirin: 62.7 ± 30.9 | Both administered by aerosol generator, over 18 hrs every 24 hrs for a maximum of 7 days or extubation | • Length of oxygen therapy | • No (P = 0.44)
- length of hospitalization | | • Cyanotic congenital heart disease, congenital heart disease under medication or associated with pulmonary hypertension | [underlined: Mean gestational age] | [underlined: Other treatment] | • Length of hospitalization | • No (P = 0.32)
[underlined: Study design] | | • Chronic respiratory disease e.g., BPD, CF, chronic aspiration, pulmonary hypoplasia, or neuromuscular disease | NR | Sedation, paralysis, inhaled albuterol, steroids, antibiotics, chest physiotherapy as indicated | Subgroup analysis
RCT-P | | • Central hypoventilation syndrome or altered airway protection | [underlined: Comorbidities] | | No
[underlined: Length of enrollment] | | • Primary or secondary immune deficiency | None | | Adverse events
March 94 to April 97 | | • Chronic liver disease or renal failure | | | • Acute respiratory distress syndrome leading to withdrawal from study (1 ribavirin pt.)
[underlined: Masking] | | • Previous treatment with ribavirin | | | • Right lobar pneumonia (1 placebo patient)
Double-blind | | • Mechanical ventilation for > 24 hrs prior to the start of the aerosol treatment
| | • Nosocomial acquired RSV infection (after 7 d of hospitalization)
| | • Ribavarin administered for less than 18 hrs
[underlined: Author] | To assess the effect of ribavirin on pulmonary function in infants with RSV bronchiolitis | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Janai et al., 1993^80^ | | • Clinical diagnosis of bronchiolitis | 26 randomized, 19 completed study | [underlined: Group A (n = 9)] | Primary outcome | | Fair
[underlined: Setting] | | • Presumptive rapid laboratory identification of RSV | [underlined: Sex] | Placebo | • Respiratory rate (numbers not reported) | • No | [underlined: Significant differences at baseline]
United States, inpatient | | • Previously healthy | Placebo: 56% male (5/9) | 0.9% saline | • Pulmonary function tests (compliance and resistance measured by sedating infant with 50–100 mg chloral hydrate on days 1, 2 and 7) | • Not significant except for change in compliance from day 1 to 7 (P = 0.05) | None
[underlined: Followup] | | • No ongoing cardiac, pulmonary, or immunologic disease | Ribavirin: 50% male (5/10) | [underlined: Group B (n = 10)] | Subgroup analysis | | [underlined: Other comments]
• Acute | | • Products of normal gestation and delivery | [underlined: Age at enrollment in weeks (interquartile range)] | Ribavirin | None | | No clinically relevant outcomes
• Short term | | Bronchiolitis defined by presence of cough, dyspnea, expiratory wheezing, and hyperinflation on chest x-ray | Placebo: 12 (6 to 16) | 20mg/ml | Adverse events
- 7 days after aerosol treatment | | [underlined: Exclusion criteria] | Ribavirin: 14 (6 to 20) | Both delivered by small particle aerosol generator (SPA6) for 18 hrs/day × 3 days (5 days for 1 infant) | None
[underlined: Study design] | | None listed | [underlined: Mean gestational age] | [underlined: Other treatment]
RCT-P | | | NR | Albuterol given prn to 8/9 placebo and 8/10 ribavirin patients
[underlined: Masking] | | | [underlined: Comorbidities] | 0.1 mg/kg/dose × 3 days
Double-blind | | | None | Antibiotics and oxygen when indicated
[underlined: Length of enrollment]
Winter of 1988 to 1989
[underlined: Author] | To assess the clinical and microbiologic effectiveness of ribavirin in the treatment of RSV disease | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Rodriguez 1987^42^ | | Admitted with acute ALRTI | 30 patients enrolled | [underlined: Group A (n = 10)] | Primary outcome | | Good
[underlined: Setting] | | Proven RSV infection | [underlined: Sex] | Placebo | • Mean severity of symptoms on analogue scale for Days 0, 1, 2, 3, and 4 after treatment (placebo vs. ribavirin) | • P values not reported | [underlined: Significant differences at baseline]
United States, Inpatient | | [underlined: Exclusion criteria] | Placebo: 20% male (2/10) | Distilled water | - day 0: 2.4 vs. 2.9 | | None
[underlined: Followup] | | • Congenital heart disease | Ribavirin: 55% male (11/20) | [underlined: Group B (n = 20) Ribavirin] | - day 1: 2.0 vs. 2.0 | | [underlined: Other comments]
• Acute | | | [underlined: Mean age at enrollment] | 6 mg in 300 ml sterile water | - day 2: 1.7 vs. 1.4 | | None
• Short term | | | [underlined: (mo.±SD)] | Aerosols administered at the rate of 12.5 l/mins continuously (except for 1–3 period before daily nasal specimen collection or during nursing or medical procedures which required removing the infant from the tent) until considerable clinical improvement until 1+ on the analogue severity scale | - day 3: 1.2 vs. 0.7
- 4 days after treatment | | | Placebo: 3.2 ± 2.30 | [underlined: Other treatment] | - day 4: 1.2 vs. 0.6
[underlined: Study design] | | | Ribavirin: 6.1 ± 7.1 | O_2_ as indicated | • Rate of change of symptom severity | • Yes
RCT-P | | | [underlined: Mean gestational age] | | - day 0 to day 2 | - P = 0.007
[underlined: Length of enrollment] | | | [underlined: (wks)] | | - day 0 to day 3 | - P = 0.001
Dec 1983 – Mar 1984 | | | Placebo: 37.2 | | • Mean length of treatment in hrs (placebo vs. ribavirin) | • No (P = 0.63)
[underlined: Masking] | | | Ribavirin: 37.8 | | - 58.6 vs. 55.7
Double-blind | | | [underlined: Comorbidities] | | Secondary outcomes
| | | • Prematurity (20% in placebo grp, 15% in ribavirin grp) | | • Number of days treated | • No (P = 0.46)
| | | • Intraventricular hemorrhage (1 ribavirin pt) | | • Number. of followup days in the hospital | • No (P = 0.09)
| | | • BPD: (20% in placebo grp, 10% in ribavirin grp) | | • Rectal temperatures | • Ribavirin patients had significantly higher rectal temperatures on Day 1 (P = 0.02) and Day 2 (P = 0.01) but not thereafter
| | | | | • Days of fever from onset of illness | • No (P = 0.54)
| | | | | • Days of fever from start of therapy | • No (P =0.61)
| | | | | • Rate of improvement in oxygen saturation from first day to last | • Significant only for ribavirin grp (P = 0.02)
| | | | | Subgroup analysis
| | | | | None
| | | | | Adverse events
| | | | | 2 deaths after treatment period (unrelated to intervention), 1 in placebo group (BPD and respiratory failure) and 1 in ribavirin grp (BPD, chronic hypoxemia, bronchiolitis, respiratory failure)
[underlined: Author] | To determine any long-term differences in adverse effects and pulmonary function between infants with respiratory syncytial virus and lower respiratory tract infection who were treated with ribavirin and a control group | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Rodriguez et al., 1999^81^ | | This study consists of the longitudinal evaluation of patients prospectively randomized to a ribavirin or a placebo control group. | 42 enrolled, 35 completed study (N varies by outcome) | [underlined: Group A (n = 24)] | Primary outcome | | Good
[underlined: Setting] | | Initial therapeutic study | Initial study had N = 30 for this study. N for this study includes enrollees from next season | Ribavirin | • Mean score for presence of Pneumonia, RAD and wheezing during yrs 1–3 after RSV Bronchiolitis ± SD (ribavirin vs. placebo) | • No (P = 0.10) | [underlined: Significant differences at baseline]
Followup after hospital discharge of prior study^42^(Initial study Dec 1983 to February 1985) | | • Infants = 1 month old | [underlined: Sex] | [underlined: Group B (n = 11)] | - 16.02 ± 27.69 vs. 22.31 ± 27.69 | | NR
[underlined: Followup] | | • Admitted to the hospital with ALRTI | Ribavirin: 63% male (15/24) | Placebo | • Mean score for presence of Pneumonia, RAD and wheezing during yrs 1–6 after RSV Bronchiolitis ± SD (ribavirin vs. placebo) | • No (P = 0.10) | [underlined: Other comments]
Up to 6 yrs after RSV bronchiolitis | | • Proven RSV infection confirmed with indirect immunoflorescent antibody methods | Placebo: 73% male (8/11) | [underlined: Other treatment] | - 16.08 ± 27.78 vs. 22.18 ± 27.78 | | • Followup study participation rate 96% in ribavirin grp is 65% in placebo (P < 0.02)
[underlined: Study design] | | • Infants who were expected to stay 3 days or longer in the hospital | [underlined: Mean age at enrollment (mo)] | NR | • Number. with 2 or more wheezing episodes during yrs 1–6 (ribavirin vs. placebo) | • Yes (P = 0.04) | • Followup (N = 42) greater than for baseline (30)^42^
RCT-P (initial protocol) | | [underlined: Exclusion criteria] | Ribavirin: 4 | | - 17% (4/24 ) vs. 55% (6/11)
[underlined: Length of enrollment] | | • Congenital heart disease | Placebo: 3.3 | | Secondary outcomes
Dec 1983 to Feb 1985 | | | [underlined: Mean gestational age (wks ± SE)] | | • PFTs measured on 6 placebo and 13 Ribavirin patients | • Placebo patients more likely to have moderate to severe findings compared to ribavirin group (P = 0.043)
[underlined: Masking] | | | NR | | • Methacholine challenge on 5 placebo and 7 ribavirin patients | • Results in favor of less severity in ribavirin group, significant only when weighted for disease severity without correction for small sample size
Double-blind for initial study; not clear if masking maintained for followup | | | [underlined: Comorbidities] | | Subgroup analysis
| | | Patients with chronic pulmonary disease and prematurity included | | RSV status
| | | | | Adverse events
| | | | | NR
[underlined: Author] | To examine the efficacy of ribavirin in the treatment of bronchiolitis associated with RSV infection in infants | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Taber et al., 1983^45^ | | • Hospitalization | 26 eligible and initiated study | [underlined: Group A (n = 12)] | Primary outcome | | Fair
[underlined: Setting] | | • Recent onset of acute lower respiratory infection consistent with bronchiolitis | [underlined: Sex] | Ribavirin by aerosol | • Mean symptom score from 0–3+ on Day 0, 1, 2, and 3 (ribavirin vs. control) | • Significantly diff on day 3 alone (P = 0.044) | [underlined: Significant differences at baseline]
United States, 2 hospitals Inpatient at baseline, not specified at followup | | • RSV in nasal secretions | Ribavirin: 33% male (4/12) | 0.8 mg/kg/hr for ~ 12 hrs/day up to 4 days | - Day 0 (Grp A= 14, Grp B=16): 2.0 vs. 2.0 | | Patients in control group had symptoms longer before beginning treatment, diff not statistically significant
[underlined: Followup] | | [underlined: Exclusion criteria] | Control: 71% male (10/14) | [underlined: Group B (n = 14)] | - Day 1 (Grp A= 11, Grp B=12): 1.5 vs. 1.7 | | [underlined: Other comments]
• Acute | | All infants were full term and without cardiac and pulmonary disease. Unclear whether exclusion criteria or chance | [underlined: Mean age at enrollment in mo. ± SE] | Control (saline aerosol) no additional details provided | - Day 2 (Grp A= 9, Grp B=11): 1.0 vs. 1.3 | | • No Intent-to-treat analysis
• Short term | | | Ribavirin: 3.9 ± 3.3 | [underlined: Other treatment] | - Day 3 (Grp A= 7, Grp B=10): 0.6 vs. 1.3 | | • Only 17 of 26 patients remained for the one outcome that was significant
- 2 wks | | | Control: 3.7 ± 2.9 | Standard care, details not reported | Secondary outcomes | | • Results do not support conclusion
[underlined: Study Design] | | | [underlined: Mean gestational age] | | • Length of treatment | • No
RCT-P | | | NR | | • End of treatment to discharge | • No
[underlined: Length of enrollment] | | | [underlined: Comorbidities] | | • Total time, onset to discharge | • No
Dec 1981 to Feb 1982 | | | None | | • RSV Titers in nasal secretions | • No
[underlined: Masking] | | | | | • RSV Neutralizing antibody response | • Yes (P = 0.045)
Partial blinding of observers | | | | | • Hematologic indices | • No
| | | | | Subgroup analysis
| | | | | None
| | | | | Adverse events
| | | | | None

Evidence Table 10. Antibiotics vs. No Treatment or Other Antibiotics

Study Characteristics | Stated Objective of Study | Inclusion/Exclusion Criteria | Demographic Characteristics and Cormorbidities | Intervention | Outcome | | Quality
[underlined: Author] | To assess the effect of routine administration of antibiotics in the treatment of viral pneumonia and bronchiolitis | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Friis et al., 1984^49^ | | • Children with pneumonia admitted to pediatric wards | 136 eligible of which 61 had RSV (evidence table limited to RSV Subgroup) | [underlined: Group A (n = 34)] | Primary outcome | • No, P value NR | Fair
[underlined: Setting] | | • Ill for less than one wk | [underlined: Sex] | Antibiotics | • Mean duration of hospitalization in days ± SE (antibiotics vs. control for RSV subgroup) | • No, P value NR | [underlined: Significant differences at baseline]
Denmark, Inpatient | | • No antibiotics before hospital admission | Antibiotics: 65% male (47/72) | If < 2 yrs, Ampicillin PO | - 5.2 ± 0.3 vs. 5.4 ± 0.4 | • No, P value NR | NR
[underlined: Followup] | | [underlined: Exclusion criteria] | Control: 67% male (44/66) | 100mg/kg/day TID × 6 days | • ‘Pulmonarily healthy’ on day 3 (antibiotics vs. control for RSV subgroup) | • No, P value NR | [underlined: Other comments]
• Acute | | • Chronic pulmonary or cardiac disease | [underlined: Median age at enrollment in mos] | If > 2 yrs, V Penicillin 300000 IU TID × 6 days | - 11 (32.4%) vs. 9 (33.3%) | • No, P value NR | • Neither patients nor investigators were blinded
• Short term | | • Mental retardation | Antibiotics: 18 | If > 2 yrs with penicillin allergy, erythromycin 30 – 50mg/kg/day TID × 6 days | ‘Pulmonarily healthy’ at discharge (antibiotics vs. control for RSV subgroup) | • No, P value NR
- 3 wks | | • Oncologic diseases | Control: 17.5 | Treatment changed if strains were resistant (No details reported) | - 25 (73.5%) vs. 24 (88.9%)
[underlined: Study design] | | • Severe breathing difficulties or cyanosis | [underlined: Mean gestational age] | [underlined: Group B (n = 27)] | • ‘Pulmonarily healthy’ after 3 wks (antibiotics vs. control for RSV subgroup)
RCT - No placebo | | • Oxygen treatment or artificial ventilation | NR | Control | - 27 (79.4%) vs. 20 (74.1%)
[underlined: Length of enrollment] | | • Suspected septicemia | [underlined: Comorbidities] | No therapy, 7 patients given antibiotics when they developed cyanosis, or bacterial complications, or fever lasting more than 4 days without viral infection diagnosed by IFA antibody test | Secondary outcomes
Dec 1979 to Nov 1982 | | | None | [underlined: Other treatment] | • Respiratory rate per mins measured at days 1, 2, 3 and discharge
[underlined: Masking] | | | | NR | • Radiological findings on admission and after 3 wks
Open label | | | | | Adverse events
| | | | | Fever, respiratory distress, coughing, otalgia, skin eruptions, GI symptoms, medical attention, antibiotics after day 10 for all patients, details NR for bronchiolitis group
[underlined: Author] | To compare cefpodoxime proxetil with amoxicillin/clavanulate in the treatment of community - acquired acute febrile lower respiratory tract infections (14 patients with bronchiolitis were included) | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Klein 1995^82^ | | • Age 3 mos to 10 yrs | 348 enrolled, 278 at Day 12 – 13, 233 at followup | [underlined: Group A (n = 234, n for bronchiolitis subgroup NR)] | Primary outcome | • NR | Poor
[underlined: Setting:] | | • Weight = 7 kg | 19 with bronchiolitis | Cefpodoxime proxetil | • Clinical cure or improvement for bronchiolitis subgroup (%: Grp A vs. Grp B) | | [underlined: Significant differences at baseline]
France, Belgium, Germany, South Africa; setting for enrollment NR | | • Fever = 38°C | [underlined: Sex] | Scheduled dose: | - 90 (9/10) vs. 100 (4/4) | | Grp A younger than Grp B, P =0.03
[underlined: Followup] | | • Suspected bacterial infection | NR | 40 mg BID if >7 to <15 kg | Adverse events | | [underlined: Other comments]
• Short term | | • Abnormal chest x-ray | [underlined: Mean age at enrollment(yrs)] | 80 mg BID if =15 kg | • Vomiting, viral disease, bronchospasm, diarrhea and rash for all patients (not reported for bronchiolitis subgroup) | | • Patients with Bronchiolitis made up only 4% of patients in study
- end of treatment at Day 12 – 13 | | • Signs and symptoms of acute lower respiratory tract infection such as cough, tachypnea, wheezes (rhonchi) and crackles (rales) | Grp A: 1.8 | Actual dose: | • 4 patients in 0 overall study group discontinued due to side effects | | • Loss to followup 20% without accounting for reasons
• Long term | | [underlined: Exclusion criteria] | Grp B: 3.1 | 5 to 12 mg/kg/day BID | | | • Outcomes for 14 out of 19 bronchiolitis patients, loss not explained
- days 20 – 30 | | • Allergy to beta-lactams | [underlined: Mean gestational age] | [underlined: Group B (n = 114, n for bronchiolitis subgroup NR)]
[underlined: Study design] | | • Tuberculosis present or suspected | NR | Amoxicillin/clavanulate
RCT non-placebo | | • Bronchiectasis or congenital respiratory anomalies | [underlined: Comorbidities] | Scheduled dose:
[underlined: Masking] | | • Nosocomial pneumonia | NR | 125/31.25 mg TID if >7 to <15 kg
Open label | | • Need for parenteral antibiotics | | 250/62.5 mg TID if =15 kg
| | • Antibiotic therapy within previous 48 hrs | | Actual dose:
| | | | 25 to 53/6 to 13 mg/kg/day TID
| | | | [underlined: Other treatment]
| | | | Analgesics, antipyretics, bronchodilators, physiotherapy as needed

Evidence Table 11. RSVIG IV as Treatment for Bronchiolitis

Study Characteristics | Stated Objective of Study | Inclusion/Exclusion Criteria | Demographic Characteristics and Cormorbidities | Intervention | Outcome | | Quality
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention Group A (n = 46)] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Rodriguez et al., 1997^25^ | To determine the safety and efficacy of RSVIG in the treatment of previously healthy children hospitalized with RSV infection | • Previously healthy | 101 eligible, 98 completed study | RSVIG | | | Good
[underlined: Setting] | | • = 2 yrs of age | [underlined: Sex] | 30ml/kg (1500 mg/kg) | Primary outcome | | [underlined: Significant differences at baseline]
United States, Inpatient at baseline, telephone followup | | • Hospitalized with bronchiolitis and/or pneumonia with nasal wash specimens positive for RSV | RSVIG: 48% male (22/46) | IV infusion × 1 dose | • Mean duration of hospitalization in days ± SE (RSVIG vs. Placebo) | • No (P = 0.24) | • RSVIG grp more likely to have = 85% study entry O_2_ saturation level (46% vs. 29%, P = 0.07)
[underlined: Followup] | | • Acute lower respiratory symptoms of less than 4 days duration | Placebo 50% male (26/52) | [underlined: Group B (n = 52)] | - 4.58 ± 0.4 vs. 5.52 ± 0.69 | | • Placebo grp more likely to need ICU care and mechanical ventilation (P value NR)
• Acute | | • Respiratory score of = 2.5 | [underlined: Mean age at enrollment (yr.± SD)] | Placebo | • Mean duration of stay in ICU in days ± SE (RSVIG vs. placebo) | • No (P = 0.06) | [underlined: Other comments]
•Short term | | [underlined: Exclusion criteria] | RSVIG: 0.20 ± 0.03 | IV Albumin 0.5%, same volume as intervention | - 3.92 ± 0.58 (n = 25) vs. 6.60 ± 1.31 (n = 33) | | • If pt received 25% of infusion, was eligible for adverse outcomes reporting and if 75% of infusion then also for all other outcomes
- Monthly telephone calls | | • Known or suspected cardiopulmonary disease | Placebo: 0.19 ± 0.03 | [underlined: Other treatment] | Secondary outcomes
• Long -term at 1 yr after intervention | | • Premature birth with a gestational age < 32 wks | [underlined: Mean gestational age (wk.± SD)] | Ribavirin therapy, IV fluids, nebulization treatments, steroids or antibiotics, supplemental oxygen, mechanical ventilation | • Duration of mechanical ventilation | • No (P = 0.45)
[underlined: Study design] | | • Immunodeficiency disease (including human immunodeficiency virus infection) | RSVIG: 38.0 ± 0.4 | | • Duration of oxygen therapy | • No
RCT -P | | • Known serum IgA deficiency | Placebo: 38.2 ± 0.4 | | • Use of ribavirin | • No
[underlined: Length of enrollment] | | • Renal failure | [underlined: Comorbidities] | | • Supplemental oxygen | • No
4 RSV seasons (yrs not stated) | | • Previous reaction to blood products | Patients on ventilators: | | • RSV neutralizing antibody | • No
[underlined: Masking] | | • Receipt of blood or blood products in the preceding 60 days | RSVIG: 12/46 (26%) | | • Proportion of cultures for RSV | • No
Double-blind | | • Established diagnosis of reactive airway disease | Placebo: 19/52 (37%) | | • Hospitalization of LRI in subsequent season | • NR
| | • Apnea without evidence of LRI on presentation | | | • Hospitalization of RSV LRI in subsequent season | • NR
| | • Inability to establish an intravenous line after 4 attempts | | | Subgroup analysis
| | • Admitted for Ribavarin therapy | | | • Severity of illness | • P values not provided, n too small
| | | | | - Among subgroup with more severe disease (respiratory scores = 3.0), lower duration of hospitalization in RSVIG grp than placebo
| | | | | • ICU stay at entry | • P values not provided, n too small
| | | | | - Lower duration of hospitalization in RSVIG grp than placebo
| | | | | Adverse events
| | | | | • Benign nocturnal myoclonus not related to RSVIG (1 RSVIG pt.)
| | | | | • Cardiopulmonary findings (6 RSVIG pts, 8 placebo pts)
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention Group A (n = 51)] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Rodriguez et al., 1997^41^ | To evaluate the efficacy of intravenous RSVIG to treat severe RSV in high risk infants | • High risk infants and children 2 yrs and younger | 107 enrolled, 102 received adequate dose, 96 at 8 wk followup, 98 at 1 yr followup | RSVIG | | | Excellent
[underlined: Year] | | • Hospitalized for RSV, bronchiolitis and/or pneumonia | [underlined: Sex] | 30 mL/kg (1.5 mg/kg) | Primary outcomes | | [underlined: Significant differences at baseline]
1997 | | • Positive for RSV antigens | RSVIG: 45% male (23/51) | IV × 1 dose over 12 hrs | • Mean duration of hospitalization in days ± SE (RSVIG vs. placebo) | • No (P = 0.73) | RSVIG group had more severe disease than placebo group:
[underlined: Setting:] | | High- risk criteria definitions: | Placebo: 57% male (29/51) | [underlined: Group B (n = 53)] | - 8.41± 0.97 vs. 8.89 ±0.99 | | - ICU admission: 47% vs. 28% (P = 0.03)
United States, Multi-left, Inpatient | | - severe BPD | [underlined: Mean age at enrollment (yr.± SE)] | Placebo | • Mean duration of ICU stay in days ± SE (RSVIG vs. placebo) | • No (p = 0.90) | - Mechanical ventilation: 31% vs. 18% (P = 0.01)
[underlined: Followup] | | - other serious chronic lung disease | RSVIG: 0.55 ± 0.07 | 0.15 mg/kg albumin (identically appearing solution and schedule) | - 9.77± 1.66 (n = 31) vs. 10.27 ± 1.81 (n = 18) | | - Mean respiratory scores of 4 – 5: 45% vs. 29% (P = 0.38)
• Acute | | - congenital heart disease | Placebo: 0.58 ± 0.06 | [underlined: Other treatment] | • Development of RSV in hospitalized patients during subsequent respiratory season | • No (P value NR) | [underlined: Other comments]
• Short term | | - preterm infants <6 months old and <32 wks gestation | [underlined: Mean gestational age (wk.± SE)] | supplemental oxygen, mechanical ventilation, Ribavirin therapy | - 3/48 (6%) vs. 3/50 (6%)
- Monthly telephone calls | | [underlined: Exclusion criteria] | RSVIG: 31.0 ± 0.8 | | • Readmission during subsequent respiratory season(RSVIG vs. placebo) | • No (P value NR)
• Long -term at 1 yr after intervention | | • Poorly controlled congestive heart failure before RSV illness | Placebo: 30.7 ± 0.7 | | - 5/48 (10%) vs. 6/50 (12%)
[underlined: Study design] | | • Renal failure | [underlined: Comorbidities] | | Secondary outcomes
RCT -P | | • Ventilator dependency before RSV illness | • Groups balanced at entry for BPD, congenital heart disease and prematurity. | | • Duration of mechanical ventilation | • No
[underlined: Masking] | | • Life expectancy< 6 months from study onset | • History of LRI significantly more frequent in placebo group (37% for placebo vs. 18% for RSVIG) | | • Requirement for supplemental oxygen during hospitalization | • No
Double-blind | | • Treatment with ribavirin before enrollment | | | • Change in respiratory scores 24, 48, 72 and 96 hrs after infusion | • No
| | • Previous adverse reaction to blood products | | | • Bronchodilator use | • No
| | • Known IgA or other immunodeficiency | | | • Ribavirin use | • No
| | • Enrollment in concurrent RSVIG study | | | • Steroid use | • No
| | • Cystic fibrosis | | | Subgroup analysis
| | • Asthma | | | • Underlying diagnosis | • No
| | • Reactive airway disease w/o BPD | | | • Gestational age, year, center | • No
| | • Apnea w/o LRI | | | • Respiratory score | • No
| | • Admission for ribavirin therapy | | | • ICU stay at entry | • No
| | | | | Adverse events
| | | | | • RSVIG
| | | | | - 22 events in 16 patients
| | | | | - 16/22 possibly drug - related
| | | | | • Placebo
| | | | | - 11 events in 10 patients
| | | | | - 8/11 events possibly drug - related

Evidence Table 12. Other Miscellaneous Treatments for Bronchiolitis

Study Characteristics | Stated Objective of Study | Inclusion/Exclusion Criteria | Demographic Characteristics and Cormorbidities | Intervention | Outcome | | Quality
[underlined: Author] | To test whether the treatment of RSV bronchiolitis with alpha-2A-interferon (IFN) results in decreased symptoms and duration of illness | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Chipps et al., 1993^47^ | | • < 24 mos of age | 22 completed study | [underlined: Group A (n = 11)] | Primary outcomes | | Good
[underlined: Setting] | | • Lower respiratory disease caused by RSV (increased work of breathing, elevated respiratory rate, rales and/or wheezing) | [underlined: Sex] | IFN | • Total symptom score | • No (P > 0.05) | [underlined: Significant differences at baseline]
United States, Multi-center, Inpatient | | • Supplemental oxygen needed to maintain O_2_ saturation > 92% | NR | 70,000 units/kg/day IM q × 5 days | - wheezing | | • Significant differences in baseline symptom scores suggesting failure of randomization
[underlined: Followup] | | [underlined: Exclusion criteria] | [underlined: Age at enrollment] | [underlined: Group B (n = 11)] | - muscle retractions | | • Mechanical ventilation for 4 IFN patients vs. 2 placebo patients
None | | • Cyanotic congenital heart disease | NR | Placebo | - accessory muscle use | | [underlined: Other comments]
[underlined: Study design] | | • Underlying chronic disease | [underlined: Mean gestational age] | 0.9% saline in similar volume IM | • Number of day of O_2_ therapy to maintain O_2_ > 92% | • No (P values NR) | • Power is too low to detect differences in scores between study groups (study was halted because of concerns about cardiotoxicity in other studies, although none noted in this study)
RCT-P | | | NR | [underlined: Other treatment] | Secondary outcomes | | • Dose possibly too low to produce therapeutic effect
[underlined: Length of enrollment] | | | [underlined: Comorbidities] | Inhaled beta-agonists, oxygen, antibiotics when indicated and fluids for hydration | • Respiratory rate | • No (P > 0.05)
Winters of 1989 to 1990 and 1990 to 1991 | | | Patients on ventilators: 6 | | • Pulse rate | • No (P > 0.05)
[underlined: Masking] | | | | | • ELISA assays for RSV antigens | • No (P values NR)
Double-blind | | | | | • RSV shedding in nasal secretions | • No (P values NR)
| | | | | Subgroup analysis
| | | | | None
| | | | | Adverse events
| | | | | None
[underlined: Author] | To determine the efficacy of a helium-oxygen mixture in children admitted to the pediatric intensive care unit with acute respiratory syncytial virus (RSV) bronchiolitis | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Hollman et al., 1998^84^ | | • Positive for RSV | 21 eligible, 3 excluded for technical reasons, 18 studied, 13 randomized | For randomized patients (n = 13): | Primary outcome | | Fair
[underlined: Setting] | | • Signs of lower respiratory tract disease | [underlined: Sex] | [underlined: Group A (n = 6)] | • Mean change in Clinical Asthma scores ± SE, compared with baseline | • Significant only for helium-oxygen mixture | [underlined: Significant differences at baseline]
United States, Intensive care unit | | [underlined: Exclusion criteria] | NR | Helium-oxygen mixture, followed by air-oxygen mixture, each for 20 mins | - Helium-oxygen mixture: 0.46 ± 0.18 | -P < 0.05 | NR
[underlined: Followup] | | • FIO_2_ > 0.50 requirement | [underlined: Median age] | [underlined: Group B (n = 7)] | - Air-oxygen mixture: 0.04 (SE not provided) | - Not significant, P value NR | [underlined: Other comments]
Acute | | • Helium concentrations < 50% | 2.5 mos (3 wks – 24 mos) | Air-oxygen mixture, followed by helium-oxygen mixture, each for 20 mins | Secondary outcomes | | None
[underlined: Study design] | | • Intubated | [underlined: Mean gestational age] | For non - randomized patients (Clinical Asthma score≥ 6) (n = 5): | • Mean heart rate | • No
RCT-C (not all patients randomized) | | • Signs of upper airway obstruction | NR | Helium-oxygen mixture | • Respiratory rate | • No
[underlined: Length of enrollment] | | | [underlined: Comorbidities] | [underlined: Other treatment] | Adverse events
NR | | | Clinical asthma: 12 | Nebulized albuterol (17/18) | Mechanical ventilation, intubation and balloon angioplasty in 1 patient with coarctation of the aorta
[underlined: Masking] | | | Underlying cardiac disease: 5
Double-blind | | | History of laryngomalacia: 1
| | | Treacher Collins syndrome: 1
[underlined: Author:] | To test the hypothesis that Shuang Huang Lian is a safe and effective treatment of acute bronchiolitis | [underlined: Inclusion criteria:] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Kong et al., 1993^51^ | | Children admitted with lower respiratory tract disease and serological evidence of RSV | 96 enrolled, 96 completed study | [underlined: Group A (n = 32)] | Primary outcomes | | Fair
[underlined: Setting:] | | [underlined: Exclusion criteria:] | [underlined: Sex] | Shuang Huang Lian | • Mean days of wheezing (95% C.I.) (n = 87) | • Yes for groups AB combined vs. C (P < 0.01) | [underlined: Significant differences at baseline]
China, Inpatient | | Underlying illness such as congenital heart disease | Grp A: 68.8% male (22/32) | <6 mo.: 20 ml IV | - Grp A: 4.2 (3.7 – 4.9) | | None
| | | Grp B: 67.6% male (23/34) | 7 – 36 mo.:40 ml IV | - Grp B: 4.0 (3.4 – 4.6) | | [underlined: Other comments:]
[underlined: Followup] | | | Grp C: 63.3% male (19/30) | 36+ mo.: 60 ml IV | - Grp C: 6.1 (5.2 – 7.3) | | • No rationale provided for the use of two different antibiotics
• Acute | | | [underlined: Median age at enrollment in months (range)] | qd × 7 d. | • Mean days of any sign or symptom (C.I.) (n = 96) | • Yes for groups AB combined vs. C (P < 0.01) | • 7 day stay in hospital impractical in Western context
• Short term | | | Grp A: 12 (3 – 48) | [underlined: Group B (n = 34)] | - Grp A: 6.4 (5.6 – 7.3) | | • Statistical tests compared grp A and B compared with grp C
[underlined: Study design] | | | Grp B: 12 (2 – 36) | Shuang Huang Lian plus antibiotics | - Grp B: 6.0 (5.0 – 7.1)
RCT-AT | | | Grp C: 10 (2 – 48) | Shuang Huang Lian: same dose and schedule as Group A, qd × 7 d. | - Grp C: 8.6 (7.5 – 9.8)
[underlined: Length of enrollment] | | | [underlined: Mean gestational age] | Antibiotics: | • Hospital stay (C.I.) (n = 96) | • Yes for groups AB combined vs. C (P < 0.01)
1988 - 1989 | | | NR | Lincomycin IV 30 mg/kg/day or | - Grp A: 7.8 (7.0 – 8.6)
[underlined: Masking] | | | [underlined: Comorbidities] | Cephazolin IV 100mg/kg/day, qd × 7 d. | - Grp B: 7.0 (6.3 – 7.8)
Single-blind trial (investigator blind to treatment) | | | None, previous history of LRI not reported | [underlined: Group C (n = 30)] | - Grp C: 9.8 (8.8 – 11.0)
| | | | Antibiotics, same dose and schedule as Group B | Secondary outcomes
| | | | [underlined: Other treatment] | • Cough | • Yes for groups AB combined vs. C (P < 0.01)
| | | | Aspirin as indicated | • Fever | • No
| | | | | • Chest wheezes | • Yes for groups AB combined vs. C (P < 0.01)
| | | | | • Chest crackles | • Yes for groups AB combined vs. C (P < 0.01)
| | | | | Subgroup analysis
| | | | | None
| | | | | Adverse events
| | | | | None observed
[underlined: Author] | To assess the effect of surfactant treatment on gas exchange, PIP, duration of mechanical ventilation and ICU stay in children with severe bronchiolitis | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Luchetti et al., 1998^39^ | | • 20 days – 2.5 yrs | 20 completed study | [underlined: Group A (n = 10) CPPV + porcine-derived surfactant] | Primary outcome | | Fair
[underlined: Setting] | | • Severe bronchiolitis requiring mechanical ventilation | [underlined: Sex] | Surfactant 50 mg/kg instilled into trachea in 2 to 3 doses (details NR) | • Mean duration of ICU stay in days ± SD (CPPV + surfactant vs. CPPV): | • Yes (P < 0.05) | [underlined: Significant differences at baseline]
Italy, intensive care unit | | • On CPPV for 24 hrs without significant improvement | Surfactant: 60% male (6/10) | CPPV | - 10.1 ± 1.2 vs. 15.7 ± 1.5 | | None
[underlined: Followup] | | • PIP > 35 cm H_2_O after 24 hrs of CPPV | Control: 50% male (5/10) | • Postural drainage and chest clapping performed between doses | • Mean duration of CPPV in days ± SD (CPPV + surfactant vs. CPPV): | • Yes (P < 0.05) | [underlined: Other comments]
Acute | | [underlined: Exclusion criteria] | [underlined: Mean age at enrollment (mo ± SE)] | • Ventilatory management same for 2 groups | - 4.4 ± 0.4 vs. 8.9 ± 1.0 | | Masking of investigators not reported
[underlined: Study Design] | | None listed | Surfactant: 10.4 ± 1.8 | • Respiratory rate 20 – 40 breaths/min based on age of child | Secondary outcomes
RCT non-placebo | | | Control: 11.2 ± 2.0 | • Tidal vol. 10 ml/kg. | • Mean PaO_2_/FiO_2_ ratio ± SD (CPPV + surfactant vs. CPPV) at: | • Significant for all time periods
[underlined: Length of enrollment] | | | [underlined: Mean gestational age (wk ± SE)] | • PEEP always used increasing from 5 – 10 cm H_2_O over 12 – 24 hrs | - 1 hr: 25.7 ± 2.2 vs. 19.0 ± 1.8 | - (P < 0.05)
Winters of 1995 - 1996 and 1996 - 1997 | | | NR | • FiO_2_ as low as possible. | - 3 hr: 23.7 ± 1.9 vs. 18.3 ± 1.9 | - (P < 0.05)
[underlined: Masking] | | | [underlined: Comorbidities] | • Children sedated and paralyzed during surfactant administration. | - 12 hr: 30.0 ± 2.5 vs. 19.7 ± 1.9 | - (P < 0.05)
Cannot determine | | | None reported | • CPPV discontinued when clinical and x-ray signs of disease disappeared and blood gas values as follows: | - 24 hr: 30.8 ± 2.7 vs. 19.4 ± 1.6 | - (P < 0.05)
| | | | • PaO_2_= 12.6 KPa with FiO_2_ =0.3 | • PaCO_2_at 12 and 24 hrs | • Yes (all P < 0.05)
| | | | • PaCO_2_ = 5.6 KPa | • Peak inspiratory rate at 3, 12 and 24 hrs | • Yes (all P < 0.05)
| | | | [underlined: Group B (n = 10)] | Subgroup analysis
| | | | CPPV | None
| | | | [underlined: Other treatment] | Adverse events
| | | | • All patients received O_2_, ß2 - agonists and antibiotics. | None
[underlined: Author] | To study the effects of aerosolized furosemide on: | [underlined: Inclusion criteria] | [underlined: Number] | • Aminophylline and systematic corticosteroids for some patients, no significant differences across study groups | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Van Bever et al., 1995^85^ | • acutely wheezing babies and | • Initial attack of acute bronchiolitis for Part A inclusion | 48 total enrolled, 28 in Part A (acute wheezing), 20 in Part B (intermittent wheezing) | [underlined: Intervention] | Primary outcome | | Good
[underlined: Setting] | • intermittently wheezing babies | [underlined: Exclusion criteria] | [underlined: Sex] | [underlined: Part A (n = 28)] | • Log of total clinical score ± SD at baseline, 15 mins and 30 mins after therapy for Part A (mean ± SD for Furosemide vs. placebo) | • No (P values NR) | [underlined: Significant differences at baseline]
Belgium, emergency department | Study also enrolled a second population of “intermittently wheezing babies” using PFTs as primary outcome. These data were excluded from this evidence table | • Previous bronchodilator therapy | Part A: 61% male | Nebulized furosemide (N not reported) | - Baseline: 0.72 ± 0.16 vs. 0.71 ± 0.19 | | None
[underlined: Followup] | | • Severe dyspnea | [underlined: Mean age at enrollment (mo ± SE)] | 10 mg over 10 mins, with nebulizer flow at 6 to 8 L/min | - 15 mins: 0.67 ± 0.19 vs. 0.62 ± 0.27 | | [underlined: Other comments]
None | | • Lethargy | Part A: 6.1 ± 3.2 mos | Placebo (N not reported) | - 30 mins: 0.59 ± 0.28 vs. 0.56 ± 0.24 | | None
[underlined: Study design] | | • Underlying cardiorespiratory disease | [underlined: Mean gestational age] | 4 ml saline over 10 mins | Subgroup analysis
RCT-P | | • Underlying metabolic disease | NR | [underlined: Other treatment] | None
[underlined: Length of enrollment] | | • Underlying liver disease | [underlined: Comorbidities] | NR | Adverse events
NR | | • Underlying renal disease | None for Part A | | NR
[underlined: Masking] | | • Premature babies with bronchopulmonary disease
Double-blind
[underlined: Author] | To test whether therapy with recombinant human deoxyribonuclease (rhDNase) may result in shorter length of hospitalization, improved clinical scores, and improved CXR's in hospitalized infants with RSV infection as a result of its mucolytic properties | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Nasr et al., 2001^40^ | | • = 2 yrs of age | 86 enrolled, 75 completed study | [underlined: Group A (n = 35)] | Primary outcome | | Good
[underlined: Setting] | | • Previously healthy full-term neonates | [underlined: Sex] | Placebo | • Mean duration of hospitalization in days ± SD (Placebo vs. rhDNase): | • No (P = 0.97) | [underlined: Significant differences at baseline]
United States, two-center study, inpatient | | • Proven RSV infection | Placebo: 63% male (22/35) | 2.5 mL excipient once daily up to 5 days | - 3.34 ± 2.3 vs. 3.33 ± 2.00 | | Trends suggest rhDNase grp more ill than placebo grp, no significant differences
[underlined: Followup] | | [underlined: Exclusion criteria] | rhDNase: 63% male (25/40) | [underlined: Group B (n = 40)] | Secondary outcomes | | [underlined: Other comments]
Acute | | None listed | [underlined: Mean age at enrollment (mo.± SD)] | rhDNase | • Mean change between hospital admission and discharge ± SD (Placebo vs. rhDNase) for | • No significant differences for any outcome other than CXR score (P < 0.001) | None
[underlined: Study design] | | | Placebo: 4.53 (4.56) | 2.5 mg (1mg/mL) in 2.5 mL of excipient once daily up to 5 days, nebulized using tight - fitting face mask | - Respiratory score
RCT-P | | | rhDNase: 5.43 (6.26) | [underlined: Other treatment] | - Wheezing score
[underlined: Length of enrollment] | | | [underlined: Mean gestational age] | Nebulized albuterol as per institutional RSV protocol | - Retraction score
Feb 1996 – Mar 1998 | | | NR | | - CXR score: - 0.60 ± 1.38 vs. 0.46 ± 1.06
[underlined: Masking] | | | [underlined: Comorbidities] | | Adverse events
Double-blind | | | Patients on ventilators: 6 | | None

Evidence Table 13. RSVIG IV vs. Placebo or Standard Care to Prevent RSV Bronchiolitis

Study Characteristics | Stated Objective of Study | Inclusion/Exclusion Criteria | Demographic Characteristics and Cormorbidities | Intervention | Outcome | | Quality
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention Group A (n = 81)] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Groothuis et al., 1993^87^ | To test whether RSV infection could be attenuated or prevented in high-risk children by monthly infusions of RSVIG during the RSV season | • Less than 48 mos old at beginning of study | 249 enrolled, data on 249 in first season study, 210 contacted for followup in subsequent season | High-dose RSVIG | Primary outcome | | Good
[underlined: Setting:] | | • Had congenital heart disease or cardiomyopathy, bronchopulmonary dysplasia, or premature delivery ( = 35 wks) and a chronological age of less than 6 mos | [underlined: Sex] | 750 mg/kg IV per month | • RSV-related acute respiratory disease | • No | [underlined: Significant differences at baseline]
United States, multi-center, outpatient at baseline, telephone survey at followup | | [underlined: Exclusion criteria] | High-dose RSVIG: 57% male (46/81) | [underlined: Group B (n = 79)] | - Grp A: 19 | - Grp A vs. Grp C: P = 0.19 | History of hospitalization for proven RSV illness more common among high-dose RSVIG group (P= 0.05)
[underlined: Followup] | | • Immunodeficiency | Low - dose RSVIG 49% male (39/79) | Low - dose RSVIG | - Grp B: 16 | - Grp B vs. Grp C: P= 0.08 | [underlined: Other comments]
• Long-term | | • Poorly controlled heart or renal failure | Control: 63% (56/89) | 150 mg/kg IV per month | - Grp C: 29 | | Benefit statistics tend to be greatest for preterm infants and infants with BPD but supporting data were not reported
- monthly for 5 months during initial RSV season | | • Dependence on a ventilator | [underlined: Mean age at enrollment (mo.± SE)] | [underlined: Group C (n = 89)] | • Non-RSV acute respiratory disease | • No
- subsequent RSV season | | • Expected survival of less than 6 mos | High-dose RSVIG: 8.4 ± 6.1 | Control | - Grp A: 65 | - Grp A vs. Grp C: P = 0.99
[underlined: Study design] | | | Low - dose RSVIG: 7.6 ± 6.1 | Standard care, no RSVIG | - Grp B: 77 | - Grp B vs. Grp C: P = 0.49
RCT non-placebo | | | Control: 8.4 ± 7.2 | [underlined: Other treatment] | - Grp C: 72
[underlined: Masking] | | | [underlined: Mean gestational age (wk.± SE)] | Routine care as needed, including ribavirin, hospitalization or ICU admission, mechanical ventilation | • RSV-related lower respiratory tract infections (respiratory score of 2+) | • Significant for some comparisons
Non-blinded team responsible for enrollment and well-baby exams and exams at the time of infusion; blinded team responsible for weekly followup and evaluation of all respiratory illnesses | | | NR | | - Grp A: 7 | - Grp A vs. Grp C: P = 0.01
| | | [underlined: Comorbidities] | | - Grp B: 13 | - Grp B vs. Grp C: P = 0.35
| | | See inclusion criteria | | - Grp C: 20
| | | | | • Non-RSV lower respiratory tract infections (respiratory score of 2+) | • No
| | | | | - Grp A: 14 | - Grp A vs. Grp C: P = 0.20
| | | | | - Grp B: 22 | - Grp B vs. Grp C: P= 0.79
| | | | | - Grp C: 24
| | | | | • Moderate to severe RSV-related lower respiratory tract infections (respiratory score of 3+) | • Significant for some comparisons
| | | | | - Grp A: 3 | - Grp A vs. Grp C: P = 0.03
| | | | | - Grp B: 5 | - Grp B vs. Grp C: P = 0.13
| | | | | - Grp C: 12
| | | | | • Moderate to severe Non-RSV lower respiratory tract infections (respiratory score of 3+) | • No
| | | | | - Grp A: 2 | - Grp A vs. Grp C: P = 0.45
| | | | | - Grp B: 4 | - Grp B vs. Grp C: P = 0.99
| | | | | - Grp C: 5
| | | | | Secondary Outcomes
| | | | | • Hospitalizations | • Significant for some comparisons
| | | | | - Grp A: 6 | - Grp A vs. Grp C: P = 0.02
| | | | | - Grp B: 10 | - Grp B vs. Grp C:P = 0.19
| | | | | - Grp C:18
| | | | | • Hospital days | • Significant for some comparisons
| | | | | - Grp A: 43 | - Grp A vs. Grp C: P = 0.02
| | | | | - Grp B: 63 | - Grp B vs. Grp C: P= 0.12
| | | | | - Grp C: 128
| | | | | • Admission to ICU | • Significant for some comparisons
| | | | | - Grp A: 1 | - Grp A vs. Grp C: P = 0.12
| | | | | - Grp B: 0 | - Grp B vs. Grp C: P= 0.03
| | | | | - Grp C: 6
| | | | | • Days in ICU | • Yes
| | | | | - Grp A: 1 | - Grp A vs. Grp C: P = 0.05
| | | | | - Grp B: 0 | - Grp B vs. Grp C: P= 0.03
| | | | | - Grp C: 34
| | | | | Adverse events
| | | | | 19 in 580 infusions (3%)
| | | | | • Fluid overload (5 pts)
| | | | | • Oxygen desaturation (8 pts)
| | | | | • Fever
| | | | | • Death (unrelated to intervention)
| | | | | • At least 1 problem with IV success in 60% of children
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention Group A (n = 58)] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Groothuis et al., 1995^86^ | Subgroup analysis study of original trial to evaluate the safety and efficacy of RSVIG in the prevention of severe RSV lower respiratory tract infection in infants born prematurely, with or without BPD | • Infants enrolled in prophylaxis trial by Groothuis and colleagues | 249 enrolled, data on 249 in first season study, 210 contacted for followup in subsequent season in original study, 116 (58 high-dose RSVIG and 58 control) in this analysis out of a total 162 preterm children | RSVIG | Primary outcome | | Good
[underlined: Setting] | | • = 35 wks gestational age | [underlined: Sex] | High-dose RSVIG | • Incidence of RSV LRTI (score = 2) (RSVIG vs. control) | • Yes (P equals;0.01) | [underlined: Significant differences at baseline]
United States, multicenter, outpatient at baseline, telephone survey at followup | | • With or without BPD | NR | 750 mg/kg IV per month for a total of 3 to 5 doses during RSV season | - 4 (6.9%) vs. 14 (24.1%) | | History of hospitalization for proven RSV illness more common among high-dose RSVIG group (P equals;0.05)
[underlined: Followup] | | [underlined: Exclusion criteria] | [underlined: Mean age at enrollment] | [underlined: Group B (n = 58)] | • Incidence of moderate to severe RSV LRTI (respiratory score = 3) (RSVIG vs. control) | • Yes (P = 0006) | [underlined: Other comments]
• (From Groothuis 1993,^87^ details NR in this study) | | • Congenital heart disease | NR | Control | - 1 (1.7%) vs. 10 (17.2%) | | None
• Long-term | | | [underlined: Mean gestational age] | Standard care, no RSVIG | • Hospitalization for RSV infection (RSVIG vs. control) | • Yes (P = 0.02)
- monthly for 5 months during initial RSV season | | | NR | [underlined: Other treatment] | - 4 (6.9%) vs. 13 (22.4%)
- subsequent RSV season | | | [underlined: Comorbidities] | (From Groothuis 1993 , details NR in this study) | • Mean duration of hospitalization in days (RSVIG vs. control) | • No (P = 06)
[underlined: Study design] | | | All preterm with BPD: 102 | Routine care as needed, including ribavirin, hospitalization or ICU admission, mechanical ventilation | - 31 vs. 83
[underlined: Study design] | | | All preterm without BPD: 60 | [underlined: Masking] | • Mean duration in ICU in days (RSVIG vs. control) | • Yes (P = 005)
•(From Groothuis 1993,^87^ details NR in this study) RCT non-placebo | | | Details NR for subset in this analysis of high-dose RSVIG vs. control (n = 116) | • (From Groothuis 1993,^87^ details NR in this study) Unblinded team responsible for enrollment and well-baby exams and exams at the time of infusion | - 1 vs. 30
[underlined: Length of enrollment] | | | | • Blinded team responsible for weekly followup and evaluation of all respiratory illnesses | • Mean worst respiratory score with RSV ± SD | • Yes (P = 02)
3 RSV seasons | | | | | - 1.5 ± 0.26 vs. 2.63 ± 0.31
| | | | | Subgroup analysis
| | | | | None
| | | | | Adverse events
| | | | | 5% of all RSVIG infusions resulted in acute reactions, details NR in this study
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between groups] | [underlined: Quality]
Simoes et al., 1998^88^ | To examine the effectiveness of Respiratory syncytial virus immune globulin administered intravenously in reducing hospitalization for treatment of RSV in children with congenital heart disease | • < 48 mos of age | 425 enrolled, 416 completed study, no explanation provided for dropouts | [underlined: Group A (n = 202)] | Primary outcomes | | Good
[underlined: Setting] | | • Congenital heart disease or cardiomyopathy | [underlined: Sex] | RSVIG IV | • Acute respiratory illness (RSVIG IV vs. control) | • Yes (P = 0.02) | [underlined: Significant differences at baseline]
United States, multi-center | | [underlined: Exclusion criteria] | RSVIG: 53% male (108/202) | 750 mg/kg (15ml/kg) IV of q month during RSV season | - 73% vs. 82% | | • More children with tetralogy of Fallot or tricuspid atresia in RSVIG IV group
[underlined: Followup] | | • Immunodeficiency disease | Control: 53% male (114/214) | [underlined: Group B (n = 214)] | • RSV URI (RSVIG IV vs. control) | • No (P = 0.97) | • More children with left-to-right shunt in control group)
Short term | | • RSV infection immediately before study entry | [underlined: Mean age in mo ± SD] | Control | - 6% vs. 7% | | [underlined: Other comments]
[underlined: Study Design] | | • Previous reaction to blood products | RSVIG: 9.3 ± 9.4 | [underlined: Other interventions] | • RSV LRI (RSVIG IV vs. control) | • No (P = 0.26) | None
RCT non-placebo | | • Poor venous access | Control:10.7 ± 10.1 | Not reported | - 19% vs. 24%
[underlined: Length of enrollment] | | • Renal failure | [underlined: Mean gestational age in wks ± SD] | | • All LRI associated hospitalizations (RSVIG IV vs. control) | • Yes (P = 0.02)
3 RSV seasons from 1992 to 1995 | | • Ventilator dependency | RSVIG: 38.6 ± 2.2 | | - 17% vs. 27%
[underlined: Masking] | | • Heart transplant candidates | Control:38.3 ± 2.9 | | • RSV LRI associated hospitalizations (RSVIG IV vs. control) | • No (P = 0.16)
Enrollment and treatment team non-blinded, weekly surveillance and clinical evaluation team blinded | | • Life expectancy < 6 mos | [underlined: Comorbidities] | | - 10% vs. 15%
| | | See inclusion criteria | | • Non-RSV LRI associated hospitalizations (RSVIG IV vs. control) | • No (P = 0.06)
| | | | | - 6% vs. 12%
| | | | | • RSV-LRI score = 3 (RSVIG IV vs. control) | • No (P = 0.36)
| | | | | - 5% vs. 7%
| | | | | Secondary outcomes
| | | | | • Admission to ICU for RSV LRI | • No
| | | | | • Mechanical ventilator for RSV LRI | • No
| | | | | • RSV hospital days/100 children | • No
| | | | | • RSV hospital days with a score = 3/100 children | • No
| | | | | • RSV ICU days/100 children | • No
| | | | | • RSV mechanical ventilation/100 children | • No
| | | | | Subgroup analysis
| | | | | RSV hospitalization by age and cardiac subgroup | • Significant for all cardiac subgroups for age < 6 mos (P) = 0.02), not significant for age = 6 mos (P = 0.74)
| | | | | • Age:
| | | | | - < 6 months vs. = 6 months
| | | | | • Cardiac subgroup
| | | | | - Subgroup 1: biventricular heart without shunts
| | | | | - Subgroup 2: biventricular heart with right-to-left shunt
| | | | | - Subgroup 3: biventricular heart with left-to-right shunt
| | | | | - Subgroup 4: single ventricle or hypoplastic left heart
| | | | | Adverse events
| | | | | Several listed | • Significantly greater for treatment groups for cardiac surgery associated adverse events other than death
[underlined: Author] | | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention Group A (n = 260)] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
The PREVENT Study Group, 1997^89^ | To determine the safety and efficacy of RSVIG IV prophylaxis for reducing the rate of RSV hospitalization among children with BPD and/or a history of prematurity | • ≤ 24 months old with BPD (diagnosed by a neonatologist or pulmonologist) and a requirement for supplemental oxygen within the past 6 months or | 510 randomized, 510 completed study | Placebo | Primary outcome | | Excellent
[underlined: Setting] | | • <6 mos old and premature at birth (35 wks gestation or less) | [underlined: Sex] | 1% albumin, administered by IV infusion | • Incidence of RSV hospitalizations (placebo vs. RSVIG IV) | • Yes (P = 0.047) | [underlined: Significant differences at baseline]
United States, multi-center, outpatient | | [underlined: Exclusion criteria] | Placebo: 57.7% male (150/260) | [underlined: Group B (n = 250)] | - 35/260 (13.5%) vs. 20/250 (8.0%) | | None
[underlined: Followup] | | • Required hospitalization at time of randomization (unless discharge was anticipated within 30 days) | RSVIG IV: 57.2% male (143/250) | RSVIG IV | • Total number of RSV hospitalization days/100 children (placebo vs. RSVIG IV) | • Yes (P = 0.045) | [underlined: Other comments]
Long-term | | • Mechanically ventilated | [underlined: Mean age at enrollment (mos ± SE)] | 750 mL/kg, administered by IV infusion at a rate of 1.5 mL/kg/hr for the first 15 mins, then 3 mL/kg/hr from 15 - 30 mins, then 6 mL/kg/hr until the end of infusion | - 129 vs. 60 | | 94% in placebo and 95% in RSVIG IV group completed protocol
[underlined: Study design] | | • Life expectancy < 6 mos | Placebo: 5.9 ± 0.27 | Both placebo and RSVIG IV administered every 30 days from Nov Dec 1994 through April 1995 | • Total days of RSV hospitalization requiring supplemental oxygen/100 children (placebo vs. RSVIG IV) | • Yes (P = 0.007)
RCT-P | | • Active or recent RSV infection | RSVIG IV: 5.6 ± 0.29 | [underlined: Other treatment] | - 85 days vs. 34 days
[underlined: Length of enrollment] | | • Known immunoglobulin A deficiency | [underlined: Mean gestational age (wks ± SE)] | Hospitalization, supplemental oxygen, ICU care, mechanical ventilation as indicated | • Hospital days/100 children on which LRI score ≥ 3 (placebo vs. RSVIG IV) | • Yes (P = 0.049)
1994 - 1995 RSV season | | • Known immunodeficiency | Placebo: 28.6 ± 0.21 | | - 106 vs. 49
[underlined: Masking] | | • Previous reaction to blood products, albumin, or immune globulin (intravenous) [IGIV] | RSVIG IV: 28.5 ± 0.20 | | • ICU care for RSV (placebo vs. RSVIG IV) | • No (P value NR)
Double-blinding | | • Treated with IGIV or any other immunoglobulin product within the previous 2 mos | [underlined: Comorbidities] | | - 12/260 (4.6%) vs. 8/250 (3.2%)
| | • Known renal impairment (creatinine > 2.5 mg/dL) | BPD and prematurity, no other Comorbidities | | • Mechanical ventilation (placebo vs. RSVIG IV) | • No (P value NR)
| | | | | - 5/260 vs. 5/250
| | | | | • Incidence of overall respiratory hospitalizations (placebo vs. RSVIG IV) | • Yes (P = 0.005)
| | | | | - 69 (27%) vs. 41 (16%)
| | | | | • Total number of respiratory hospital days/100 children (placebo vs. RSVIG IV) | • Yes (P = 0.005)
| | | | | - 317 vs. 170
| | | | | Secondary outcomes
| | | | | • Ribavirin use (placebo vs. RSVIG IV) | • No (P = 0.62)
| | | | | - 10/35 (29%) vs. 7/20 (35%)
| | | | | Subgroup analysis
| | | | | • Prematurity | • Trend toward fewer hospitalizations in all subgroup analyses for patients receiving RSVIG IV with reductions in hospitalizations ranging from 17% to 58%
| | | | | • ≤ 6 mo at entry
| | | | | - ≤ 3 mo at entry
| | | | | • BPD
| | | | | • Age
| | | | | • 6 mo at entry
| | | | | • Weight or < 4.3 kg
| | | | | Adverse events
| | | | | • Fever (1 in placebo, 2 in RSVIG IV)
| | | | | • Rash (1 in placebo)
| | | | | • Erythema multiforme (1 in placebo)
| | | | | • Respiratory distress (2 in RSVIG IV)
| | | | | • Acrocyanosis (2 in RSVIG IV)
| | | | | • Agitation and tachypnea ( 1 in RSVIG IV)
| | | | | • Decreased O_2_saturation (1 in RSVIG IV)
| | | | | • Death due to complications of prematurity and/or underlying chronic illness unrelated to study assignment
| | | | | • Adverse events judged potentially related to study drug as a reason for incomplete or prolonged infusion (1% in placebo vs. 3.2% in RSVIG IV)

Evidence Table 14. Monoclonal Antibody for Prophylaxis of RSV Bronchiolitis

Study Characteristics | Stated Objective of Study | Inclusion/Exclusion Criteria | Demographic Characteristics and Cormorbidities | Intervention | Outcome | | Quality
[underlined: Author] | To evaluate the safety and effectiveness of monthly administration of palivizumab as prophylaxis for serious RSV illness in high-risk children | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention Group A (n = 500)] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
The IMpact - RSV Study Group 1998^91^ | | • ≤ 35 wks gestation and ≤ 6 mos old or | 1502 randomized, 1486 completed followup | Placebo | Primary outcome | | Excellent
[underlined: Setting] | | • ≤ 24 mos old and had a clinical diagnosis of BPD requiring ongoing medical treatment (i.e. supplemental oxygen, steroids, bronchodilators, or diuretics within the past 6 mos | [underlined: Sex] | 0.02 % Tween - 80 added to sterile water, IM every 30 days for a total 5 days, identical in appearance to palivizumab | • Incidence of RSV hospitalizations (placebo vs. palivizumab) | • Yes (P < 0.001) | [underlined: Significant differences at baseline]
United States, United Kingdom, Canada, Inpatient and Outpatient | | [underlined: Exclusion criteria] | Placebo: 56.8% male (284/500) | [underlined: Group B (n = 1002)] | - 53/500 (10.6%) vs. 48/1002 (4.8%) | | None
[underlined: Followup] | | • Hospitalization at the time of entry that was anticipated to last more than 30 days | Palivizumab: 56.9% male (570/1002) | Palivizumab | Secondary outcomes | | [underlined: Other comments]
• Long-term | | • Mechanical ventilation at the time of entry | [underlined: Mean age at enrollment in mos± SE] | 15 mg/kg IM every 30 days for a total of 5 doses (final concentration of palivizumab = 100 mg/mL) | • Total number of RSV hospitalization days/100 children (placebo vs. palivizumab) | • Yes (P < 0.001) | None
- 150 days | | • Life expectancy less than 6 months | Placebo: 6.0 ± 0.21 | [underlined: Other treatment] | - 62.6 days vs. 36.4 days
[underlined: Study design] | | • Active or recent RSV infection | Palivizumab: 5.7 ± 0.15 | Hospitalization, oxygen supplementation, ICU care and mechanical ventilation as needed | • Total days of RSV hospitalization requiring supplemental oxygen/100 children (placebo vs. palivizumab) | • Yes (P <0.001)
RCT-P (2:1 randomization) | | • Known hepatic or renal dysfunction, seizure disorder, immunodeficiency, allergy to 1gG products | [underlined: Mean gestational age in wks± SE] | | - 50.6 days vs. 30.3 days
[underlined: Length of enrollment] | | • Receipt of RSV immune globulin within past 3 months | Placebo: 29 ± 0.14 | | • Hospital days/100 children on which LRI score ≥ 3 (placebo vs. palivizumab) | • Yes (P <0.001)
1996 - 1997 RSV seasons | | • Previous receipt of palivizumab, other monoclonal antibodies, RSV vaccines, or other investigational agents | Palivizumab: 29 ± 0.10 | | - 47.4 vs. 29.6
[underlined: Masking] | | • Congenital heart disease, except children with patent ductus arteriosus or a septal defect that was uncomplicated and homodynamically insignificant | [underlined: Comorbidities] | | • Incidence of ICU care for RSV (placebo vs. palivizumab) | • Yes (P =0.026)
Double-blind | | | None other than prematurity and BPD | | - 3% vs. 1.3%
| | | | | • Total days ICU care (placebo vs. palivizumab) | • Yes (P =0.023)
| | | | | - 12.7 vs. 13.3
| | | | | • Incidence of mechanical ventilation (placebo vs. palivizumab) | • No (P =0.28)
| | | | | - 0.2% vs. 0.7%
| | | | | • Total days of mechanical ventilation (placebo vs. palivizumab) | • No (P =0.21)
| | | | | - 1.7 vs. 8.4
| | | | | • Incidence of respiratory hospitalizations unrelated to RSV (placebo vs. palivizumab) | • No (P =0.470)
| | | | | - 14% vs. 13%
| | | | | • % children with at least 1 episode of otitis media | • No (P =0.505)
| | | | | - 40% vs. 42%
| | | | | Subgroup analysis
| | | | | • Incidence of RSV hospitalizations by weight | • Yes
| | | | | - > 5 kg | - (P 0.014)
| | | | | - ≤ 5 kg | - (P = 0.001)
| | | | | • Incidence of RSV hospitalizations by primary inclusion populations | • Yes
| | | | | - Prematurity (no BPD) | - (P 0.001)
| | | | | - BPD | - (P = 0.038)
| | | | | • Incidence of RSV hospitalizations by length of gestation | • Yes
| | | | | - <32 wks | - (P 0.003)
| | | | | - 32–35 wks | - (P = 0.002)
| | | | | Adverse events
| | | | | • Fever | • No
| | | | | • Nervousness | • No
| | | | | • Injection site reaction | • No
| | | | | • Diarrhea | • No
| | | | | • Rash | • No
| | | | | • Upper respiratory infection | • No
| | | | | • Liver function abnormalities | • No
| | | | | • Vomiting | • No
| | | | | • Cough | • No
| | | | | • Rhinitis | • No
| | | | | • Death unrelated to study drug (5 in placebo group, 4 in palivizumab group) | • NR
[underlined: Author] | To evaluate the safety and pharmacokinetics of single and repeat in specified intramuscular doses of a humanized monoclonal antibody against RSV in a pediatric population at risk for severe RSV disease | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention Group A (n = 8)] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Meissner et al., 1999^92^ | | • Born prematurely (= 35 wks), chronological age = 6 months | 43 randomized, 42 completed study | 0.25 mg/kg SB209763 (n = 6) | Primary clinical outcome | | Good
[underlined: Setting] | | or | [underlined: Sex] | IM into single thigh muscle, reconstituted with sterile water to a concentration of 45 mg/ml | • RSV infection episodes/dosage (10 mg/kg SB209763 vs. placebo) | • No (P = 0.20) | [underlined: Significant differences at baseline]
Unspecified, Multi-center | | • Less than 37 months of age and history of BPD | 0.25 mg/kg SB209763: 38% male (3/8) | Placebo (n = 2) | - 1/22 vs. 2/10 | | None
[underlined: Followup] | | • Life expectancy of at least 6 mos | 1.25 mg/kg SB209763: 45% male (5/11) | Similar volume as intervention | • RSV infection episodes/dosage (5 mg/kg SB209763 vs. placebo) | • No (P = 0.49) | [underlined: Other comments]
• Acute | | [underlined: Exclusion criteria] | 5.0 mg/kg SB209763: 27% male (3/11) | After 8 wks, placebo group crossed over to SB209763 and both groups received 2^nd^IM dose | - 2/19 vs. 2/10 | | • High dose group mostly male
• Short term | | • Known preexisting heart, liver, or renal disease | 10.0 mg/kg SB209763: 77% male (10/13) | [underlined: Group B (n = 11)] | • RSV infection episodes/dosage (1.25 mg/kg SB209763 vs. placebo) | • No (P = 0.46) | • Primary purpose of study was safety and pharmaco - dynamics, not efficacy
- 8 wk followup | | • Recognized immune system abnormality | [underlined: Mean age at enrollment in months (range)] | 1.25 mg/kg SB209763 (n = 9) | - 2/20 vs. 2/10
[underlined: Study design] | | • Severe respiratory illness requiring assisted ventilation | 0.25 mg/kg SB209763: 6.0 (4–11) | IM into single thigh muscle | • RSV infection episodes/dosage (0.25 mg/kg SB209763 vs. placebo) | • No (P = 0.72)
RCT-C | | • Previous gamma globulin infusion | 1.25 mg/kg SB209763: 9.8 (0.75 - 30) | Placebo (n =2) Similar volume as intervention | - 2/14 vs. 2/10
[underlined: Length of enrollment] | | | 5.0 mg/kg SB209763: 9.8 (0.25 - 33) | Dosing schedule: Similar crossover as Group A (placebo to intervention at 8 wks, second dose IM) | Adverse events
1995 - 1996 RSV season | | | 10.0 mg/kg SB209763: 5.4 (0.75 - 13) | [underlined: Group C (n = 12)] | • Safety (SB209763 vs. placebo)
[underlined: Masking] | | | [underlined: Mean gestational age] | 5.0 mg/kg SB209763 (n = 8) | - 37 events in 10 patients receiving placebo
Double-blind | | | NR | Divided into 2 doses, IM into each thigh muscle | - 192 events in 35 patients receiving SB209763
| | | [underlined: Comorbidities] | Placebo (n = 3) Similar volume as intervention | • 4 events considered related to study
| | | Prematurity:11 | Similar volume as intervention | - 3 episodes of mild to moderate purpura
| | | BPD plus prematurity:15 | Dosing schedule: Similar crossover as Group A (placebo to intervention at 8 wks, second dose IM) | - 1 episode of thrombocytosis
| | | BPD alone:17 | [underlined: Group D (n = 13)]
| | | | 10.0 mg/kg SB209763 (n = 10) Divided into 2 doses, IM into each thigh muscle
| | | | Placebo (n = 3) Similar volume as intervention
| | | | Dosing schedule: Similar crossover as Group A (placebo to intervention at 8 wks, second dose IM)
| | | | Max volume at highest dose 0.22ml/kg
| | | | [underlined: Other treatment]
| | | | NR

Evidence Table 15. Vaccines to Prevent RSV Bronchiolitis

Study Characteristics | Stated Objective of Study | Inclusion/Exclusion Criteria | Demographic Characteristics and Cormorbidities | Intervention | Outcome | | Quality
[underlined: Author] | To assess the safety, immunogenicity, and efficacy of an improved purified F protein vaccine (PFP-2) in a high-risk population of young seropositive children with BPD | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Groothuis et al., 1998^93^ | | • < 12 months of age with bronchopulmonary dysplasia | 21 randomized, 21 completed study | [underlined: Group A (n = 10)] | | | Good
[underlined: Setting] | | • Proven RSV infections in a previous respiratory season | [underlined: Sex] | PFP-2 vaccine | Primary outcome | | [underlined: Significant differences at baseline]
United States, Outpatient at baseline, weekly telephone followup, Outpatient at 1 mo. and 6 mo. after intervention | | • Influenza vaccination in previous year | NR | 0.5 ml IM | • RSV infections in subsequent season (PFP-2 vs. Influenza vaccine) | • No (P =0.06) | None
[underlined: Followup] | | • Outpatients in Neonatal High Risk Follow Up Program at Children's Hospital, Denver | [underlined: Age at enrollment in months] | [underlined: Group B (n = 11)] | - 1/10 vs. 6/11 | | [underlined: Other comments]
• Short term: 1 mo. after intervention | | [underlined: Exclusion criteria] | PFP-2: 32.2 | Trivalent influenza vaccine | Secondary outcome
• Long-term: 6 mo. after intervention and the subsequent RSV season | | None listed | Placebo: 30.0 | 0.5 ml IM | • Mean F protein antibody before vaccination PFP-2 vs. Influenza vaccine) | • No (P =0.22)
[underlined: Study design] | | | [underlined: Mean gestational age] | [underlined: Other treatment] | • Mean F protein antibody 1 month after vaccination (PFP-2 vs. Influenza vaccine) | • Yes (P0.0001)
RCT non-placebo | | | NR | All patients received unblinded dose of trivalent influenza vaccine 4–6 wks after study vaccine | • Mean F protein antibody 6 month after vaccination (PFP-2 vs. Influenza vaccine) | • Yes (P =0.002)
[underlined: Length of enrollment] | | | [underlined: Comorbidities] | | • Mean neutralizing antibody before vaccination (PFP-2 vs. Influenza vaccine) | • No (P =0.78)
Oct and Nov 1991 | | | NR | | • Mean neutralizing antibody 1 month after vaccination (PFP-2 vs. Influenza vaccine) | • Yes (P =0.006)
[underlined: Masking] | | | | | • Mean neutralizing antibody 6 month after vaccination (PFP-2 vs. Influenza vaccine) | • Yes (P =0.009)
Double-blind | | | | | Subgroup analysis
| | | | | None
| | | | | Adverse events
| | | | | • Irritability (2 PFP - 2 patients, 2 influenza vaccine)
| | | | | • Drowsiness (1 PFP - 2 patient)
| | | | | • Plain and tenderness (1 PFP - 2 patients, 1 influenza vaccine)
| | | | | • Redness (1 PFP - 2 patient)
[underlined: Author] | To determine the safety and immunogenicity of the PFP-2 vaccine in children with CF who are at high risk of LRTI with RSV infection | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Piedra et al., 1996^94^ | | • Diagnosis of CF based on two of following criteria: | 34 completed study | [underlined: Group A (n = 17)] | | | Good
[underlined: Setting] | | - sweat chloride > 60 meq/l | [underlined: Sex] | PFP-2 | Primary outcomes | | [underlined: Significant differences at baseline]
United States, Outpatient at baseline, telephone interview at followup | | - genetic testing demonstrating homozygosity for the delta F508 allele | PFP-2: 59% male | IM 50 μg of PFP-2 composed of F glycoprotein of the A2 strain of RSV compounded with alum, 1 dose | • Development of RSV ± SD (PFP-2 vs. Saline) | • No (P =0.73) | PFP-2 group significantly taller, older, and had lower triceps fat fold thickness
[underlined: Followup] | | - clinical features consistent with cystic fibrosis | Saline: 65% male | [underlined: Group B (n = 17)] | - 7/17 (41%) vs. 9/17 (53%) | | [underlined: Other comments]
• Short term | | [underlined: Exclusion criteria] | [underlined: Mean age at enrollment in years ± SD] | IM Saline | • Total days of illness of RSV infection ± SD (PFP-2 vs. Saline) | • NR | None
- length of the RSV season | | • Pre-vaccine RSV serum neutralizing antibody filter of < 1:4 | PFP-2 4.5 ± 1.6 | 0.5 ml | - 45 vs. 119
[underlined: Study design] | | • History of epilepsy | Saline: 5.8 ± 1.6 | [underlined: Other treatment] | • Hospitalization | • No (P =0.087)
RCT-P | | • Recent history of febrile seizure | [underlined: Mean gestational age] | Antibiotics | - 1/17 vs. 5/17
[underlined: Length of enrollment] | | | NR | | • No. with = 1 ALRTI (acute lower respiratory tract infection) | • Yes (P =0.024)
1993 to 1994 | | | [underlined: Comorbidities] | | - 9/17 vs. 15/17
RSV season | | | All enrollees had CF | | • Mean no. of AURTI/subject (acute upper respiratory tract infection) ± SD (PFP-2 vs. Saline) | • No (P =0.035)
[underlined: Masking] | | | | | - 2.0 ± 1.5 vs. 2.5 ± 1.6
Double-blind | | | | | • Mean no. of ALRTI/subject ± SD (PFP-2 vs. Saline) | • Yes (P =0.005)
| | | | | - 0.8 ± 0.9 vs. 2.1 ± 1.4
| | | | | • Mean no. of antibiotic courses/subject ± SD (PFP-2 vs. Saline) | • Yes (P <0.001)
| | | | | - 2.2 ± 1.3 vs. 4.5 ± 1.5
| | | | | • Mean no. of days ill/subject | • Yes (P <0.001)
| | | | | - 30.5 ± 16.1 vs. 67 ± 25.8
| | | | | Subgroup analysis
| | | | | • RSV exposure status | • No significant differences
| | | | | Adverse events
| | | | | • Weakness/ache/nausea | • No significant differences
| | | | | • Any systematic symptoms (PFP-2 vs. saline) | • No significant differences
| | | | | - 5 vs. 6
| | | | | • Any local reaction (PFP2 vs. saline) | • No significant differences
| | | | | - 8 vs. 4
[underlined: Author] | To determine the safety and immunogenicity of the PFP-2 vaccine in children with cystic fibrosis | [underlined: Inclusion criteria] | [underlined: Number] | [underlined: Intervention] | [underlined: Outcomes] | [underlined: Significant differences between study groups] | [underlined: Quality]
Piedra et al., 1998^95^ | Note: This is a followup of Piedra et al. 1996. | Diagnosis of CF as previously described in Piedra et al.^94^ on two of following criteria: | 34 in initial study, 29 completed this 2^nd^study | [underlined: Group A (n = 14)] | | | Fair
[underlined: Setting] | | - sweat chloride > 60 meq/l | [underlined: Sex] | PFP/PFP | Primary outcome | | [underlined: Significant differences at baseline]
United States, Outpatient | | - genetic testing demonstrating homozygosity for the delta F508 allele | PFP/PFP: 57% male (8/14) | IM 50 μg of PFP-2 in 0.5 ml in Fall 1993 and Fall 1994 | • No. with = 1 ALRTI | • Yes (P =0.035) | • Saline/PFP taller (Pvalue NR) and older (P =.06)
[underlined: Followup] | | - clinical features consistent with cystic fibrosis | Saline/PFP: 60% male (9/15) | [underlined: Group B (n = 15)] | - 9/13 vs. 15/15 | | • Saline/PFP children more likely to attend daycare/ school (P =0.08)
• Acute | | [underlined: Exclusion criteria] | [underlined: Mean age at enrollment in years ± SD] | Saline/PFP | • Mean no. of illnesses/subject ± SD (PFP/PFP vs. Saline/PFP) | • No (P =0.098) | [underlined: Other comments]
• Short term | | Details NR in this study. Piedra et al. 1996^94^ states | PFP/PFP: 5.6 ± 1.8 | Saline/PFP Saline placebo in Fall 1993 (details not reported) | - 3.2 ± 1.5 vs. 4.1 ± 1.2 | | • Significant effects may be explained by lower incidence of RSV exposure in PFP/PFP group due to lower daycare attendance
- 1 yr after initial vaccine | | • Pre - vaccine RSV serum neutralizing antibody filter of < 1:4 | Saline/PFP: 6.8 ± 1.5 | PFP/PFP: IM 50 μg of PFP-2 in 0.5 ml in Fall 1994 | • Mean no. of AURTI/subject ± SD (PFP/PFP vs. Saline/PFP) | • No (P =0.98) | • N for subgroup analysis very low
[underlined: Length of enrollment] | | • History of epilepsy | [underlined: Mean gestational age] | [underlined: Other treatment] | - 2.1 ± 1.3 vs. 2.1 ± 1.2
1993-1995 | | • Recent history of febrile seizure | NR | Antibiotics | • Mean no. of antibiotic courses/subject ± SD (PFP/PFP vs. Saline/PFP) | • Yes (P =0.004)
[underlined: Study design] | | | [underlined: Comorbidities] | | - 1.2 ± 1.0 vs. 2.1 ± 0.5
Open - label followup of original study that was RCT-P, all patients received followup vaccine | | | CF, mild lung disease | | • Mean no. of antibiotic courses/subject ± SD (PFP/PFP vs. Saline/PFP) | • No (P =0.077)
[underlined: Masking] | | | | | - 2.18 ± 2.5 vs. 4.4 ± 2.0
Not clear if parents/caregivers were unblinded in this study | | | | | • Mean no. of days ill/subject | • Yes (P =0.001)
| | | | | - 36. ± 19.4 vs. 64.8 ± 27.0
| | | | | Subgroup analysis
| | | | | • Confirmed RSV infection | • Some outcomes significantly different between groups
| | | | | - No. with = 1 ALRTI
| | | | | - Mean no. of illnesses/subject ± SD (PFP/PFP vs. Saline/PFP)
| | | | | - Mean no. of AURTI/subject ± SD (PFP/PFP vs. Saline/PFP)
| | | | | - Mean no. of ALRTI/subject ± SD (PFP/PFP vs. Saline/PFP)
| | | | | - Mean no. of antibiotic courses/subject ± SD (PFP/PFP vs. Saline/PFP)
| | | | | - Mean no. of days ill/subject
| | | | | Adverse events
| | | | | • 1 death unrelated to vaccination or RSV infection (1 PFP/PFP pt.) | • No significant differences between groups
| | | | | • Weakness/ache/nausea
| | | | | • Fever
| | | | | • Headache
| | | | | • Any systemic reaction
| | | | | - 7/14 vs. 7/15
| | | | | • Tenderness at vaccine site
| | | | | • Edema at vaccine site
| | | | | • Red at vaccine site
| | | | | • Any local reaction
| | | | | - 4/14 vs. 5/15