# Glossary for Evidence Tables

ALRTI | acute lower respiratory tract infection
AMS | accessory muscle score
ARDS | acute respiratory distress syndrom
AURTI | acute upper respiratory tract infection
BID | twice daily
BPD | bronchopulmonary dysplasia
C | Celsius
C_DYN_ | dynamic compliance
CF | cystic fibrosis
CHD | congenital heart disease
CI | confidence interval
CPPV | continuous positive pressure ventilation
CXR | chest radiograph
d | days
Diff(s) | difference(s)
ED | emergency department
ELISA | Enzyme - Linked Immunosorbent Assay
ER | emergency room
GI | gastrointestinal
Grp | group
Hr(s) | hour(s)
ICU | intensive care unit
IFA | immunofluorescent assay
IFN | Interferon
IGIV | immunoglobulin intravenous
IM | intramuscular
IV | intravenous
Kg | kilogram
L/min | liters per minute
LRI | lower respiratory infection
LRTI | lower respiratory tract infection
MDI | metered dose inhaler
meq/L | milliequivalents per liter
Mg | milligram
Min(s) | Minute(s)
Ml | millileter
mmHg | millimeters of mercury
Mo(s) | month(s)
N | number of patients
NR | not reported
O_2_ | oxygen
PEEP | positive end expiratory pressure
PFP | purified F protein
PIP | peak inspiratory pressure
PO | oral
Pt(s) | patient(s)
Q | every
QID | four times daily
RCT | randomized controlled trials
RCT-C | randomized controlled trials - Crossover
RCT-P | randomized controlled trials - Placebo
RDAI | Respiratory Distress Assessment Instrument
RDS | respiratory distress score
rhDNASE | recombinant human deoxyribonuclease
RR | respiratory rate
RSV | respiratory syncytial virus
RSVIG | respiratory syncytial virus immunoglobulin
SaO_2_ | transcutaneous hemoglobin oxygen saturation
SD | standard deviation
SE | standard error
Sig | significant
TcPo_2_(kPa) | transcutaneous oxygen tension (measure of blood gases)
TID | three times daily
Ti/Ttot | duration of inspiration as fraction of total breath duration
URI | upper respiratory infection
URTI | upper respiratory tract infection
vs. | versus
V_T_ | tdal volume
Wk(s) | weeks
Yr(s) | year(s)