# Acknowledgments

This study was supported by Contract 290-97-0011 from the Agency of Healthcare Research and Quality (AHRQ)(Task No. 9). We acknowledge the continuing support of Jacqueline Besteman, J.D., MA, director of the AHRQ Evidence-based Practice Center program and to Marian James, Ph.D., the AHRQ Task Order Officer for this project.

The investigators deeply appreciate the considerable support, commitment, and contributions from RTI staff Nash Herndon, M.A., Linda Lux, M.P.A., Loraine Monroe, and Philip Salib, B.A. In addition, we appreciate the contributions of our data abstractors, Sonya Harris-Haywood, M.D., Mary Maniscalco, M.D., and Laura Sterling, M.D., and our methods abstractor, Cheryl Coon, Ph.D., all of the University of North Carolina at Chapel Hill (UNC). We are also thankful for the research support provided by Joy Harris and Donna Curasi, also of UNC.

In addition, we extend our appreciation to the members of our Technical Expert Advisory Group (TEAG), who served as vital resources throughout our process. They are: Henry L. Dorkin, M.D., Massachusetts General Hospital and Harvard Medical School, Boston, Mass; Bernard Ewigman, M.D., M.S.P.H., School of Medicine, University of Missouri-Columbia, Columbia, Mo; Glenn Flores, M.D., Boston University School of Medicine, Boston, Mass; Anne Haddix, Ph.D., Rollins School of of Public Health, Emory University, Atlanta, Ga; Allan S. Liberthal, M.D., (representing the American Academy of Pediatrics) Southern CA-Permanente Medical Group, Panorama City, Calif; H. Cody Meissner, M.D., New England Medical Center, Boston, Mass; Jonathan L. Temte, M.D., Ph.D., (representing the American Academy of Family Physicians), Department of Family Medicine, University of Wisconsin, Madison Wis; and Steve Wegner, M.D., NC Access, Inc, Morrisville, NC.

We owe our thanks as well to our external peer reviewers, who provided constructive feedback and insightful suggestions for improvement of our report. Other peer reviewers were: Alan H.Cohen, M.D., Senior Director, Medical Affairs, MedImmune Inc. and Johns Hopkins Medical School, Gaithersburg, Md; Jeffrey M. Ewig, M.D., Pediatric Pulmonary Associates, PA, St. Petersburg, Fla; Anne Haddix, Ph.D., Rollins School of Public Health, Emory University, Atlanta, Ga; Elizabeth Susan Hodgson, M.D., Princeton, NJ; Allan S. Liberthal, M.D., Southern CA-Permanente Medical Group, Panorama City, Calif; Michael Light, M.D., University of Miami, North Miami Beach, Fla; H. Cody Meissner, M.D., New England Medical Center, Boston, Mass; Jeff Michael, D.O., University of Missouri-Columbia, Columia, Mo; and Tonse NK Raju, M.D., National Institute of Child Health and Human Development, Washington, DC.