# Evidence Tables

Evidence Table 1. Description of systematic reviews of low molecular weight heparin compared to unfractionated heparin for treatment of venous thromboembolism

| | | | | | Systematic review quality scores
Author, Year | Study aim | # trials | Most recent study | # pts | LMWH used in trials^ a^ | Overall^ b^ | Search^ c^ | Eligibility^ d^ | Study Quality^ e^ | Combining Results^ f^ | Aims & Conclusions^ g^
Green, 1994 | To compare IV or SQ LMWH to IV or SQ UFH for tx of DVT | 9 | 1993 | 1308 | 1, 2, 3, 4, 5 | 22 | 0 | 33 | 0 | 0 | 75
Hirsh, 1995 | To compare IV or SQ LMWH to IV or SQ UFH for first episode of VTE | 13 | 1993 | 1723 | 1, 2, 3, 4, 5 | 77 | 50 | 83 | 75 | 75 | 100
Lensing, 1995 | To compare IV or SQ LMWH to IV or SQ UFH for tx of DVT | 10 | 1994 | 1512 | 1, 2, 3, 4, 6 | 67 | 67 | 67 | 0 | 100 | 100
Leizorovicz, 1996 | To compare IV or SQ LMWH to IV or SQ UFH for tx of DVT | 20 | 1996 | 3333 | 2, 5, 7, 8, 9, 10, 11 | 37 | 17 | 17 | 0 | 75 | 75
Howard, 1997 | To compare IV or SQ dalteparin to IV or SQ UFH for tx of VTE | 8 | 1995 | 863 | 7 | 42 | 50 | 33 | 0 | 25 | 100
Brewer, 1998 ^h^ | To compare LMWH to UFH for tx of adults with DVT | 6 | 1997 | 2986 | 5, 7, 10, 11, 12 | | 50 | 67 | 0 | 50
Hettiarachchi, 1998 | To compare SQ LMWH to UFH for tx of VTE | 13 | 1998 | 4509 | 2, 5, 7, 10, 11, 12 | 65 | 67 | 83 | 0 | 75 | 100
Hunt, 1998 | To compare LMWH to UFH for tx of VTE | 10 | 1997 | i | 5, 7, 10, 11, 12 | 22 | 33 | 0 | 0 | 0 | 75
Martineau, 1998 | To compare IV or SQ LMWH to IV or SQ UFH for tx of DVT | 13 | 1996 | 2825 | 5, 7, 10, 11 | 43 | 33 | 83 | 0 | 0 | 100
van der Heijden, 2000 | To compare SQ LMWH to IV or SQ UFH for VTE | 16 | 2000 | 6055 | 2, 5, 7, 9, 10, 11, 12 | 60 | 33 | 67 | 0 | 100 | 100

a LMWH: 1=fragmin, 2=CY222, 3=fraxiparin, 4=logiparin, 5=enoxaparin, 6=clexane, 7=dalteparin, 8=parnaparin, 9=certoparin, 10=nadroparin, 11=tinzaparin, 12=reviparin, 13=OP2123

b Overall Quality Score: The mean of the percentage scores from the categories: Search Methods, Inclusion & Description, Quality Assessment, Methods of Combination, and Aims/Conclusions (see below).

c Search Methods: Percentage score based on a total maximum score of 6 points. This included description of search methods (2 points), comprehensiveness of search methods (2 points), and reproducibility of review methods (2 points).

d Eligibility and Description: Percentage score based on a total maximum score of 6 points. This included description of study inclusion criteria (2 points), appropriateness of study inclusion criteria (2 points), and discussion of variation in the original literature based on differences in study design (2 points).

e Study Quality Assessment: Percentage score based on a total maximum score of 4 points. This included description of quality assessment (2 points), and appropriateness of quality assessment (2 points).

f Combining Results: Percentage score based on a total maximum score of 4 points. This included description of methods used to combine study results (2 points), and appropriateness of methods used to combine study results (2 points).

g Aims & Conclusions: Percentage score based on a total maximum score of 4 points. This included whether the question to be addressed by the review was clearly stated (2 points), and whether the conclusions reached by the review were supported by data and/or analyses (2 points).

h Review examined 3 meta-analyses and 6 RCTs. Only the data from RCTs is presented here.

i Not reported. Review also included 1 study (Simmoneau, 1997) that examined LMWH vs. UFH for PE.

Evidence Table 2. Results of systematic reviews of low molecular weight heparin compared to unfractionated heparin for treatment of venous thromboembolism

Author, Year | Pt populations in RCTs | Recurrence of symptomatic VTE (LMWH vs UFH) | Thrombus extension (LMWH vs UFH) | Major bleeding during tx (LMWH vs UFH) | All deaths (LMWH vs UFH) | Other outcomes/comments (LMWH vs UFH)
Green, 1994 | Pts w/DVT | During mos 3 to 6: incidence 2.7 vs 7.4%; RRR 63% [CI 30–80%], 8 trials | 64 vs 50% had thrombus size reduction, 6 vs 12% had increase in size, p<0.001; 8 trials | 0.9 vs 3.2%; RRR 71% [CI 33–88%]; 8 trials
Hirsh, 1995 | Pts w/first episode of VTE | Day 1–15: incidence 0.8 vs 2.4%; RRR 68%; p=0.02; 6 trials | | 2.2 vs 4.7%; RRR 66%, p=0.04; 10 trials | 0.6 vs 1%; days 1–15: RRR 39%, p=0.3; 12 trials. | No difference in minor bleeding; 10 trials.
| | | | | | Fatal PE, 0.4 vs 0.7%, p=0.4.
| | Day 16–90: incidence 1.6 vs 2% RRR 26%; p=0.8; 6 trials | | | 2.5 vs 4.5%; days 16–90: RRR 52%, p=0.03; 12 trials. | Pts w/ca: mortality 13.5 vs. 28.4%; RRR 67%, p=0.01; pts w/o ca: 1.9 vs 2.6%, p=0.40; 4 trials.
| | Day 1–90: incidence 2.4 vs 4.5%; RRR 50%, p=0.02; 6 trials | | | 3.3 vs 5.9%; days 1–90: RRR 49%, p=0.01; 12 trials. | Level 1 studies^a^ (3 trials): VTE recurrence, Day 1–15: RR 0.24 [CI 0.06–0.8]; Day 16–90: RR 0.60 [CI 0.2–1.5]; RR 0.39 [CI 0.3–0.8];
| | | | | | Major bleeding: RR 0.42 [CI 0.2–0.9].
Lensing, 1995 | Pts w/DVT | Incidence 3.1 vs 6.6%; RRR 53% [CI 18–73%]; 5 trials | 63 vs 52% had reduction in thrombus size; 6 vs 12% had increase in thrombus size; p<0.001; 9 trials. | 0.9 vs 3.2%; RRR 68% [CI 31–85%]; 10 trials. | 3.9 vs 7.1%; RRR 47% [CI 10–69%]; 5 trials. | Subgroup of pts w/ca: all deaths 12 vs 28%; RRR 56% [CI 17–77%].
Leizorovicz, 1996 | Pts w/DVT | Incidence 3.8 vs 5.2%; OR 0.77 [CI 0.55–1.08]; 20 trials | 6.0 vs 9.5%; OR 0.65 [CI 0.44–0.96]; 12 trials | 1.5 vs 3.1%; OR 0.59 [CI 0.35–0.98]; 20 trials | 3.7 vs 5.4%; OR 0.70 [CI 0.50–0.98]; 20 trials. | Results similar for safety and efficacy for LMWH daily or bid.
| | | | | | LMWH reduced VTE recurrence and mortality when provided at home (UFH in-hospital; 2 trials) or in-hospital (UFH in-hospital, 18 trials).
Howard, 1997 | Pts w/VTE | | | | | Descriptive study.^b^ Authors concluded that dalteparin may be as effective as UFH in tx for DVT and PE; more data needed.
Brewer, 1998 | Adults w/VTE | | | | | Descriptive study.^b^ Authors concluded that LMWH as effective and safe as UFH. Thrombocytopenia less frequent w/ LMWH. Osteoporosis may be less common w/LMWH.
Hettiarachchi, 1998 | Pts w/VTE | Incidence 3.8 vs 4.8%; OR 0.77[CI 0.56–1.04]; 10 trials | | 1.3 vs 2.2%; OR 0.60 [CI 0.38–0.95]; 13 trials. | 4.8 vs 6.5%; OR 0.72 [CI 0.55–0.96]; 9 trials. | Results similar w/ or w/o ca.
| | | | | | Pts w/PE: VTE recurrence OR 0.91 [CI 0.42–1.97]; 2 trials.
Hunt, 1998 | Pts w/VTE | | | | | Descriptive study.^b^ Authors concluded that LMWH cheaper, better tolerated, potentially more effective than UFH for DVT. Insufficient data regarding PE.
Martineau, 1998 | Pts w/first episode of DVT | | | | | Descriptive study.^b^ Authors concluded LMWH as safe and effective as UFH.
Gould, 1999 | Pts w/acute DVT | Incidence 4.6 vs 5.4%; OR 0.85 [CI 0.63 to 1.14]; ARR 0.88% [CI -0.48–2.24%], NNT 114; 11 trials | | Random-effects model: OR 0.71 [CI 0.40 to 1.27]; 11 trials | 5.0 vs 6.8%; OR 0.71 [CI 0.53–0.94]; ARR 1.65% [CI 0.36–2.94], NNT 61; 11 trials | Minor bleeding: OR 0.98 [CI 0.63 to 1.51]. Thrombocytopenia: OR 0.74 [CI 0.37–1.48]. PE during tx: OR 0.84 [CI 0.51–0.36]. DVT during tx: OR 0.85 [CI 0.59–1.23].
| | | | 1.1 vs 1.9%; fixed-effects model OR 0.57[CI 0.33 to 0.99]; ARR 0.61% [CI -0.04% to 1.26%], NNT 164; 11 trials | | Pts w/ca: Mortality 16.7 vs 25.9%; OR 0.57 [CI 0.31 to 1.03]; ARR 9.75% [CI 0.34% to 19.2%], NNT 10.
| | | | | | Reduced mortality benefit in more recent studies. Dalteparin, tizaparin, and nadroparin favored LMWH whereas studies using enoxaparin or reviparin favored UFH. Benefit of LMWH noted if all pts received inpt LMWH, but not if LMWH was permitted as outpt.
Dolovich, 2000 | Pts w/VTE | Incidence 4.3 vs 5.1%; RR 0.85 [CI 0.65–1.12]; 13 trials | | 1.5 vs 2.6%; RR 0.63 [CI 0.37–1.05]; 13 trials | 4.9 vs 6.5%; RR 0.76 [CI 0.59–0.98]; 10 trials. | PE: 1.9 vs 1.8%; RR 1.02 [CI 0.64–1.62]; 12 trials.
| | | | | | Minor bleeding: 5.6 vs 4.7%; RR 1.18 [CI 0.87–1.61]; 12 trials.
| | | | | | Thrombocytopenia: 1.0 vs 1.3%; RR 0.85 [CI 0.45–1.62]; 11 trials.
| | | | | | Results similar whether LMWH daily or bid.
Rocha, 2000 | Pts w/VTE | OR 0.78 [CI 0.59–1.04]; 13 trials | OR for extension 0.73 [CI 0.59–0.90]; 12 trials | OR 0.65 [CI 0.43–0.98]; 8 trials | OR 0.68 [CI 0.50–0.91]; 9 trials. | Bid LMWH formulations more effective than UFH to prevent thrombus extension (p=0.004). Daily less likely than UFH to cause major bleeding (p=0.025). NSD between once daily and bid for VTE recurrence or mortality.
van den Belt, 2000 | Pts w/VTE | Initial tx: incidence 1.8 vs 2.6%; OR 0.70 [CI 0.46–1.06]; 11 trials. | 60 vs 54% had reduction in thrombus size; OR 0.77 [CI 0.61–0.97] for better venographic outcome; 8 trials | 1.3 vs 2.1%; OR 0.60 [CI 0.39 to 0.93]; 14 trials | 6.4 vs 8.0%; OR 0.78 [CI 0.62–0.99]; 11 trials. | Pts w/PE: VTE recurrence OR 0.91 [CI 0.42–1.97].
| | | | | | Pts w/ca: Mortality OR 0.53 [CI 0.33–0.85]; pts w/o ca: OR 0.97 [CI 0.61–1.56]; 6 trials.
| | | | | | Pts w/proximal DVT: VTE recurrence, major hemorrhage and mortality all significantly lower w/LMWH.
| | | | | | Studies that reported concealed allocation (7 studies): similar results as all studies but ORs were not significant.
| | 3 months f/u: incidence 3.8 vs 5.1%; OR 0.75 [CI 0.46–1.01], 9 trials
| | 6 months f/u: OR 0.76 [CI 0.44–1.30]; 3 trials
| | End of f/u: incidence 4.3 vs 5.6%; OR 0.76 [CI 0.57–1.01]; 11 trials
van der Heijden, 2000 | Pts w/VTE | OR 0.66 [CI 0.51–0.86]; 13 trials | | OR 0.56 [CI 0.38–0.83]; 16 trials | OR 0.68 [CI 0.53–0.88]; 12 trials. | Greater benefit from LMWH in studies w/ higher rates of VTE recurrence in UFH group. LMWH benefit unrelated to incidence of outcomes for major hemorrhage or mortality.

a Blind assessment

b No quantitative pooling of data.

Evidence Table 3. Description of studies comparing outpatient to inpatient treatment of venous Thromboembolism

| | | | | | | | Exclusions
Author, Year | Location | Study aims | Design | Recruit dates | Mean f/u (mos) | Surveillance | VTE character | General criteria | Risk factors
LMWH at home compared to UFH in the hospital
Koopman, 1996 | Europe & Australia | To demonstrate equivalence in efficacy and safety and evaluate use of resources. | RCT | | 6 | N | No PE | Preg/childbirth; unlikely to comply; LE < 6 mos; tx w/ heparin for 24 hrs; age < 18yrs | Previous VTE; known thrombophilia; known malignancy
Levine, 1996 | Canada | To compare use of UFH in the hospital with LMWH at home for acute DVT tx. | RCT | 1992-95 | 3 | Y | No: calf vein only, PE | Unlikely to comply; hereditary bleeding; contraindication to AC | VTE in preceding 6 months
Belcaro, 1999 | Europe | To compare IV heparin or SQ heparin w/LMWH either at home or in hospital, with oral anticoagulant for tx of proximal DVT. | RCT | 1992-95 | 3 | Y | No: PE, thromb-cytopenia | Preg/childbirth; unlikely to comply; hereditary bleeding
Pearson, 1999 | United States | To present short-term outcomes of pts treated as outpt and to compare associated costs before and after implementation. | CohR | 1996-97 | 0.5 | N | No PE
Grau, 2001 | Europe | To compare incidence of recurrent VTE in UFH inpts and LMWH outpts. | CohR | 1986-99 | | N | No PE | Inclusion: Preg/childbirth; OCPs/HRT; recent fracture/cast | Known thrombophilia
Vinson, 2001 | United States | To evaluate effectiveness & safety of outpt care pathway for tx of DVT with LMWH. | CohP | 1994-99 | 0.5 | N | No: UE, calf vein only, PE, CVA, anemia | Preg/childbirth; allergy; unlikely to comply; hereditary bleeding; contraindication to AC, age <18
Huse, 2002 | United States | To quantify the economic benefits of early discharge of pts treated for DVT with LMWH using data from managed health care plans. | CohR | | | N | | Unlikely to comply | Known thrombophilia; recent surgery; previous VTE; positive family history
Smith, 2002 | Australia | To perform a cost minimization analysis in pts receiving LMWH managed w/o hospitalization. To evaluate costs and satisfaction with at-home tx of DVT using enoxaparin vs. inpt care w/UFH. | | 1999-99 | | N | No PE | Preg/childbirth; LE < 2 yrs; allergy; unlikely to comply; hereditary bleeding; contraindication to AC | Known thrombophilia; known malignancy; recent fracture/cast; previous VTE
LWMH at home compared to LMWH in the hospital
Boccalon, 2000 | Europe | To compare LMWH inpts versus outpts for efficacy and cost. | RCT | 1993-97 | 6 | Y | No: calf vein only, PE | Preg/childbirth; unlikely to comply; contraindication to AC, age <18 or age >85 | Previous VTE
Kovacs, 2000 | Canada | To evaluate the use of dalteparin in outpts w/PE. | CohP | 1996-98 | 3 | N | PE | Unlikely to comply, age <18 | Unstable (O_2_ requirements; hemodynamic instability; pain)

Evidence Table 4. Quality of studies comparing outpatient to inpatient treatment of venous thromboembolism

Author, Year | Overall ^a^ | Representativeness of study population ^b^ | Bias & confounding ^c^ | Description of treatment ^d^ | Outcomes & f/u ^e^ | Statistical quality & interpretation ^f^
LMWH at home compared to UFH in the hospital
Koopman, 1996 | 79 | 88 | 88 | 50 | 85 | 83
Levine, 1996 | 78 | 100 | 81 | 50 | 75 | 83
Belcaro, 1999 | 67 | 100 | 75 | 50 | 60 | 50
Pearson, 1999 | 38 | 88 | 31 | 25 | 10 | 38
Grau, 2001 | 47 | 88 | 31 | 25 | 30 | 63
Vinson, 2001 | 57 | 100 | 38 | 50 | 30 | 67
Huse, 2002 | 41 | 50 | 13 | 0 | 65 | 75
Smith, 2002 | 41 | 75 | 31 | 25 | 10 | 63
LMWH at home compared to LMWH in the hospital
Boccalon, 2000 | 64 | 63 | 63 | 75 | 80 | 38
Kovacs, 2000 | 54 | 75 | 44 | 50 | 70 | 33

a Overall: The mean of the percentage scores from categories: Representativeness of Study Population, Bias and Confounding, Description of Treatment, Outcomes and Followup, and Statistical Quality and Interpretation (see below).

b Representativeness of Study Population: Percentage score based on a total maximum score of 8 points. This included description of study setting and population (2 points), description of inclusion/exclusion criteria (2 points), information on excluded or non-participating patients (2 points), and description of key patient characteristics (2 points).

c Bias and Confounding: Percentage score based on a total maximum score of 6 points. This included random assignment of patients to study groups (2 points), differences between study groups in key patient characteristics (2 points), and blinding of clinicians, patients, and outcome assessors (2 points).

d Description of Treatment: Percentage score based on a total maximum score of 4 points. This included description of the details of the treatment regimen (2 points), and description of other treatments given to each study group (2 points).

e Outcomes and Followup: Percentage score based on a total maximum score of 10 points. This included description of the criteria used for determining outcomes (2 points), description of adverse events experienced by patients (2 points), reporting on numbers and reasons for withdrawals or patients lost to followup (2 points), proportion of patients who withdrew or were lost to followup (2 points), and adequacy of the planned length of followup (2 points).

f Statistical Quality and Interpretation: Percentage score based on a total maximum score of 8 points. This included reporting on the magnitude of differences between groups with an index of variability (2 points), clear identification of all statistical analyses (2 points), use of multivariate or stratified analyses to adjust for potential confounders (2 points), and appropriate handling of withdrawals, crossovers, and loss to followup (2 points).

Evidence Table 5. Characteristics of patients in studies comparing outpatient to inpatient treatment of venous thromboembolism

| | | | | Clinical characteristics
Author, Year | Intervention | LMWH | Therapy duration (days) | Adjuvant therapy during f/u | Mean age (yrs) | Male (%) | Prior VTE (%) / Family hx (%) / Thrombophilia (%) | Recent surgery/ TRF (%)
LMWH at home compared to UFH in the hospital
Koopman, 1996 | LMWH in/outpt^a^, 250 IU/kg bid | Nadroparin | 6 | Warfarin or other AC | 59 | 53 | 20 / NR / NR | 49 / 69
| UFH, 5000 u then 1250 u/hr | | 6 | " | 62 | 48 | 19 / NR / NR | 52 / 68
Levine, 1996 | LMWH in/outpt, 1 mg/kg bid | Enoxaparin | 5 | Warfarin | 57 | 62 | 21 / NR / 0 | 29 / 100
| UFH, 5000 u then 1280 u/hr | | 5 | " | 59 | 58 | 14 / NR / 0 | 28 / 100
Belcaro, 1999 | LMWH in/outpt, 100 IU/kg bid | Nadroparin | 14 | Warfarin | 54 | 55 | 7 / NR / 0 | 20 / 100
| UFH, 5000 u then 1300 u/hr | | | " | 53 | 59 | 7 / NR / 0 | 22 / 100
| UFH, 12500 IU bid | | 90 | None | 54 | 53 | 9 / NR / 0 | 22 / 100
Pearson, 1999 | LMWH in/outpt, 1 mg/kg bid | Enoxaparin | 5 | Warfarin | 57 | 42 | NR / NR / NR | NR / NR
| UFH | | | " | 56 | 43 | NR / NR / NR | NR / NR
Grau, 2001 | LMWH outpt, 175 u/kg bid | Nadroparin | 5 | Acencoumarol | 68 | 58 | 2.3 / NR / NR | 30 / 81
| UFH | | 5 | " | 59 | 58 | 3.4 / NR / NR | 37 / 79
Vinson, 2001 | LMWH outpt, 1 mg/kg bid | Enoxaparin | 7 | Warfarin, Comp stockings | 63 | 56 | 14 / NR / 0 | 25 / 100
| UFH | | | Warfarin | 63 | 46 | 20 / NR / 0 | 32 / 100
Huse, 2002 | LMWH in/outpt | Enoxaparin | | Warfarin | 48 | 46 | NR / NR / NR | NR / NR
| UFH | | | " | 54 | 44 | NR / NR / NR | NR / NR
Smith, 2002 | LMWH outpt, 1 mg/kg bid | Enoxaparin | 5 | Warfarin | 57 | 61 | 0 / NR / NR | NR / NR
| UFH | | 5 | " | 57 | 61 | 0 / NR / NR | NR / NR
LMWH at home compared to LMWH in the hospital
Boccalon, 2000 | LMWH outpt | Dalateparin or enoxaparin or nadroparin | | Comp stockings, vitamin K antagonist, or fluindione | 65 | 54 | NR / NR / NR | NR / NR
| LMWH inpt | | | " | 63 | 59 | NR / NR / NR | NR / NR
Kovacs, 2000 | LMWH outpt, 200 u/kg qd | Dalteparin | 5 | Warfarin | | 56 | NR / NR / 12 | NR / NR
| LMWH in/outpt, 200 u/kg qd | | 5 | " | | 59 | NR / NR / 7 | NR / NR

a Outpatient treatment after a brief inpatient stay

Evidence Table 6. Results of studies comparing outpatient to inpatient treatment of venous thromboembolism

| | | | | | Outcomes n (%)
Author, Year | Group | # pts | F/u (mos) | DVT | PE | Major bleeding | Minor bleeding | Deaths | Inpt days | Costs /pt | Costs included in tabulation
LMWH at home compared to UFH in the hospital
Koopman, 1996 | Outpt | 202 | | 10 (5) | 4 (2) | 1 (0.5) | 27 (13) | 14 (7) | 2.7
| Inpt | 190 | | 12 (6) | 5 (3) | 4 (2) | 15 (8) | 16 (8) | 8.1
Levine, 1996 | Outpt | 247 | 3 | 11 (4) | 2 (1) | 5 (2) | 6 (2) | 11 (4) | 1.1
| Inpt | 253 | 3 | 15 (6) | 2 (1) | 3 (1) | 6 (2) | 17 (7) | 6.5
Belcaro, 1999 | Outpt | 98 | | 6 (6) | 0 (0) | 0 (0) | 3 (3) | | 5.1 | 773 USD | Hospital, tx and monitoring costs.
| Inpt | 97 | | 6 (6) | 0 (0) | 0 (0) | 4 (4) | | 5.4 | 2,760 USD
| Outpt | 99 | | 7 (7) | 0 (0) | 0 (0) | 1 (1) | | 0 | 220 USD
Pearson, 1999 | Outpt | 40 | 0.5 | 1 (2.5) | 0 (0) | 0 (0) | | 0 (0) | | 3,719 USD ^a^ | Hospital, drug, home care, and outpt visit costs.
| Inpt | 67 | | | | | | | | 5,465 USD ^a^
Grau, 2001 | Outpt | 130 | 21.6 | 5 (4) | 1 (1) | 3 (2) | 1 (1) | 11 (8)
| Inpt | 149 | 35 | 13 (9) | 9 (6) | 1 (1) | 4 (3) | 17 (11)
Vinson, 2001 | Outpt | 178 | 0.5 | 0 (0) | 1 (1) | 0 (0) | 2 (1) | 0 (0) | 0.03
| Inpt | 96 | 0.5 | 0 (0) | 1 (1) | 1 (1) | 1 (1) | 0 (0) | 4
Huse, 2002 | Outpt | 164 | 12 | 11 (7) ^a^ | | 1 (1) | | | 4.2 | 1,886 USD | Outpt costs only.
| Inpt | 1696 | 12 | 153 (9)^a^ | | 14 (1) | | | 6.8 | 986 USD
Smith, 2002 | Outpt | 28 | | | | | | | | 756 USD | U/S, doctors, nurse visits, drug, monitoring, office staff, discharge planning costs.
| Inpt | 28 | | | | | | | | 2,208 USD
LMWH at home compared to LMWH in the hospital
Boccalon, 2000 | Outpt | 99 | | 1 (1) | | 2 (2) | 17 (17) | 0 (0) | 1 | 9,230 FRF ^a^ | U/S, doctors, nurse visits, monitoring, hospital costs, drug costs.
| Inpt | 102 | | 2 (2) | | 2 (2) | 11 (11) | 2 (2) | 9.6 | 20,932 FRF ^a^
Kovacs, 2000 | Outpt | 81 | | 0 (0) | 5 (6) | 1 (1) | 3 (4) | 4 (5)
| Inpt | 27 | | 1 (4) | 0 (0) | 1 (4) | 2 (7) | 0 (0)

a p < 0.05 for difference

Evidence Table 7. Description of modeled analysis of the costs of using low molecular weight heparin compared to unfractionated heparin for treatment of venous thromboembolism

Author, year | Aims | Total quality score (%) ^a^
Hull, 1997 | To perform an economic evaluation comparing tinzaparin to UFH for inpt tx of prox DVT. | 100
Rodger, 1998 | To assess the cost-effectiveness of LMWH and UFH using data from a meta-analysis and patient-specific case-costing data. | 83
Gould, 1999 | To evaluate the costs and health effects of a LMWH compared to UFH for inpt tx of acute DVT. | 100
Estrada, 2000 | To perform an economic evaluation comparing LMWH to UFH for treating a DVT in inpts and outpts. | 89
Lloyd, 1997 | To evaluate the inpt cost of treating a DVT with nadroparin compared to UFH. | 83
van den Belt, 1998 | To assess the cost consequences of outpt management in the treatment of DVT. | 89
O'Brien, 1999 | To evaluate the overall cost of treating a prox DVT with enoxoparin as outpt vs UFH as inpt. | 78
deLissovoy, 2000 | To evaluate the overall inpt cost of treating an acute VTE with enoxoparin vs UFH. | 94
Tillman, 2000 | To evaluate the clinical and economic outcomes associated with implementation of outpt DVT tx w/ LMWH. | 67

a Total quality score: Percentage score based on a total maximum score of 18 points (See Appendix H, items 1–9).

Evidence Table 8. Designs of the modeled analyses of the costs of using low molecular weight heparin compared to unfractionated heparin for treatment of venous thromboembolism

Author, Year | Design | Perspective | Time-horizon | Comparisons | Sources of cost estimates^a^ | Sources of estimates of event rates | Units of benefits | Sensitivity analyses
Hull, 1997 | CE | Payor | 3 mos. | a. Inpt tinzaparin (175 IU/kg qd).; b. Inpt UFH. | Direct medical costs in pts enrolled (1992 CAD and USD). | Observed in trial. | Deaths averted, recurrences averted. | Varied across range of observed data in centers.
Rodger, 1998 | CE | Payor | 3 mos. | a. Outpt LMWH if eligible or inpt LMWH.; b. Outpt LMWH if eligible or inpt UFH.; c. Inpt LMWH.; d. Inpt UFH. | Case-costing using an online resource-utilization- based patient-specific cost accounting system (1995 CAD). | Systematic literature review. | Deaths averted. | Ran model using “worst case scenario”, biased against LMWH.
Gould, 1999 | CE | Society | Death or age 99 yrs. | a. Inpt enoxaparin (1mg/kg bid).; b. Inpt UFH (includes 2° analysis of outpt enoxaparin). | ME reimbursement rates, rx costs, wholesale prices (1997 USD), (analysis included 3%/yr discounting). | From the literature, also used US life table to construct survival curves. | Quality-adjusted and unadjusted LY. | Varied across 95% CI of base case estimates.
Estrada, 2000 | CE | Payor | 3 mos. | a. LMWH: outpt if eligible or inpt LMWH.; b. LMWH: outpt if eligible or inpt UFH.; c. Inpt UFH. | Direct medical costs taken from literature review, institutional accounting, and costs to ME (1996 USD). | Literature. | Deaths averted, recurrences averted. | Based on literature.
Lloyd, 1997 | Cost-minimization | Payor | 5 days. | a. Inpt nadroparin (weight-based bid).; b. Inpt UFH (two routes: SQ or IV). | Direct costs measured as hospital charges to payor (Swiss sickness fund), public list prices of drugs. (1994 USD) | Assumed equivalent in all arms. | USD. | Did not vary the costs.
van den Belt, 1998 | Cost-minimization | Payor | 6 mos. | a. Outpt fraxaparine (weight adjusted).; b. Inpt UFH. | Direct medical costs measured in 1 of 9 settings participating in clinical trial (1993 NLG). | Rates observed in all trial sites, considered equivalent in both groups. | NLG. | Monte Carlo simulations and one-way analyses; ranges.
O'Brien, 1999 | Cost-minimization | Society | 3 mos. | a. Outpt enoxaparin (1mg/kg bid).; b. Inpt UFH. | Canadian national data-systems, local labor and rx costs (1997 CAD). | Observed in trial, measured health related quality of life. | Health related quality of life.
deLissovoy, 2000 | Cost-minimization | Payor | 3 mos. | a. Inpt enoxaparin (1.5 mg/kg qd or 1.0 mg/kg bid).; b. Inpt UFH. | Direct medical costs from 33 US sites participating in a multicenter trial (1997 USD). | Observed in the 33 US trial sites. | USD. | Varied cost data from 50 to 150% of base case.
Tillman, 2000 | Decision-model | Payor | 3 mos. | a. Outpt enoxaparin (1 mg/kg bid).; b. Inpt UFH. | Direct medical costs measured in 391 pts treated as outpts in group-model HMO; source of inpt costs is unclear (1998 USD). | Measured in outpts. | USD. | Varied cost data from 50 to 300% of base case estimates.

a See Acronyms and Abbreviations list for international currencies

Evidence Table 9. Results of the modeled analyses of the costs of using low molecular weight heparin compared to unfractionated heparin for treatment of venous thromboembolism

Author, Year | Least costly strategy | Strategy with greatest benefits | Incremental cost-effectiveness | Cost-savings | Sensitivity analysis | Comments
Hull, 1997 | Inpt tinzaparin | Inpt tinzaparin. | Tinzaparin dominates. | 401 USD per person w/ tinzaparin, (11% savings). | Robust to all one-way analyses, when cost of tinzaparin is 5.8 times base cost per case it is not cost-saving. | If 37% treated as outpt, cost saving 913 USD per person.
Rodger, 1998 | LMWH outpt if eligible/ LMWH inpt | Either LMWH all inpt or LMWH outpts if eligible/LMWH inpts. | LMWH outpts dominate if eligible. | 767 USD per person w/ LMWH outpts/ inpts relative to UFH, (23% savings). | Even using “worst case” estimates, cost effectiveness of inpt LMWH relative to inpt UFH is 25,667 USD per life saved at 3 mos. | If equivalent efficacy and safety in all arms is assumed, LMWH is cheaper to deliver in any tx setting and dominates model.
Gould, 1999 | Inpt UFH | Inpt enoxaparin. | 6,910 USD per LY or 7,820 USD per QALY w/ enoxaparin. | | Cost-saving when 8% of enoxaparin pts receive tx as outpts, or when 13% have an early discharge. Model sensitive to frequency of late complications, robust to other analyses. | Robustly cost-effective; becomes cost-saving if treated as outpts w/LMWH.
Estrada, 2000 | LMWH in outpts/UFH in inpts | LMWH in outpts and inpts. | 9,667 USD per recurrence averted or 80,685 USD per death averted w/ LWMH in outpt/inpt relative to LWMH outpt/UFH inpts. | 310 USD per person for LWMH outpts/ inpts relative to UFH (10% savings). | Results sensitive to the % of pts eligible for outpt tx: if fewer than 14% eligible then UFH is less costly than LMWH outpt/inpt. Model sensitive to costs of UFH. | Lower costs primarily due to inpt savings.
Lloyd, 1997 | Inpt nadroparin | NA: assumed to be equivalent for model. | | 153 USD per person with nadroparin 57%. | Robust even to all one-way analyses; savings if nadroparin pts have daily PTT measurement.
van den Belt, 1998 | Outpt fraxaparine | NA: assumed to be equivalent for model. | | 5,528 NLG per person with fraxaparine (64% savings). | Fraxaparine cost saving w/50% home care visits, cost saving w/ 50% requiring inpt care.
O'Brien, 1999 | Outpt enoxaparin | Higher social functioning on SF 36 in the enoxaparin group, otherwise NSD in health-related QOL or events. | | 3,045 USD per person w/ enoxaparin (57% savings). | Robust to all one-way analyses.
deLissovoy, 2000 | NSD | Inpt enoxaparin bid. Fewest readmissions for recurrent DVT and for all causes. | | None. | Robust to all one-way analyses. | Protocol blood testing and costs of medication offset by fewer readmissions with enoxaprin.
Tillman, 2000 | Outpt enoxaparin | Unknown. | | 2,828 USD per person w/enoxaparin (60% savings). | Enoxaparin not cost saving if drug cost increase 750% or if hospitalization costs decrease 77%. | Rates of events in the UFH arm not explicitly stated.

Evidence Table 10. Description of the studies evaluating optimal duration of therapy with warfarin after venous thromboembolism

| | | | | | | Inclusion/exclusion criteria
Author, Year | Location | Design | Aims | Recruitment yrs | Planned f/u (mos) | Recurrence surveillance | Inclusion criteria (Participants %) | Exclusion criteria
O'Sullivan, 1972 | Australia | Single site RCT | To determine: 1) the number of recurrent VTE & bleeding episodes after 6 wks vs 6 mos of warfarin, 2) whether a gradual decrease or abrupt discontinuation of warfarin results in more thrombotic complications. | | > 12 | None | DVT ± PE (DVT alone-63%, DVT+PE-20%, PE-16%) | Depends on attending MD preference.
Holmgren, 1985 | Europe | Multicenter RCT | To study VTE recurrence rate among patients with a 1st DVT treated for 1 vs 6 mos w/warfarin. | 1979 - 81 | 12 | IPG or thermography in 48% | 1st DVT, calf or proximal (Proximal-83%, Calf-17%) | Contraindication to AC.
Lagerstedt, 1985 | Europe | Single site RCT | To assess the need for oral AC after calf DVT. | 1981 - 84 | 12 | 99m Tc-plasmin isotope scans | Calf vein DVT | Unlikely to comply; requires LT AC; sx of PE; predisposition to recurrence or malignancy.
Schulman, 1985 | Europe | Single site RCT | To evaluate whether a shorter course of warfarin can be given w/o risks to pts with a 1st DVT & a TRF, 1st DVT and a PRF or 2nd DVT. | | > 15 | IPG | Proximal DVT | Preg; low compliance.
Petitti, 1986 | United States | Retro-spective Multicenter CohR | To determine the risk of thrombosis & bleeding with warfarin in retrospective review of patients treated in Kaiser-Permanente clinics in Northern CA. | 1970 - 80 | | None | DVT ± PE | Preg/childbirth; systemic disease associated with thrombophilia; malignancy; recent surgery or trauma (w/i 6 wks); death w/i 1 wk of admission; missing chart.
Fennerty, 1987 | Europe | Single site RCT | To compare outcomes w/3 wks vs 6 wks of AC after DVT/PE. | | 12 | None | DVT ± PE | Preg; malignancy; prolonged immobility; previous VTE w/in 5 yrs.
British Thoracic Society (BTS), 1992 | Europe | Multicenter RCT | To compare efficacy of 4 wks vs 3 mos of AC for VTE. | 1988 - 90 | 12 | None | DVT± PE. (DVT-51%, DVT+PE-19%, PE-31%) | Preg/childbirth; requires LT AC; thrombolytic therapy; pulmonary embolectomy; malignancy; prolonged immobility; previous VTE in last 3 yrs.
Levine, 1995 | Canada & Europe | Multicenter RCT | To test whether 1) normal IPG after 4 wks of warfarin for a proximal DVT identifies a group whose warfarin can be d/c 2) normal IPG at 4 wks predicts a lower risk of recurrence than an abnormal IPG 3) continuing risk factors are associated w/ recurrence. | 1987 - 92 | 11 | IPG | Proximal DVT | Preg; major psychiatric disorder; life expectancy < 3 mos; unlikely to f/u; requires LT AC; familial bleeding disorder; active bleeding; peptic ulcer; thrombophilia; ≥2 previous VTE.
Schulman, 1995 | Europe | Multicenter RCT | To compare 6 wks with 6 mos of AC for a 1st VTE. | 1988 - 91 | 24 | None | 1st VTE, DVT ±PE (DVT-88%, PE-12%) | Preg; allergy; requires LT AC; unable to f/u; arterial insufficiency; venous ulcerations precluding compression stockings; age < 14 yrs; thrombophilia; malignancy; previous VTE; total limb paresis.
Schulman, 1997 | Europe | Multicenter RCT | To compare 6 mos vs indefinite oral AC for a 2nd VTE. | 1988 - 91 | 48 | None | 2nd VTE, DVT ± PE (DVT-85%, PE - 15%) | Preg; allergy to warfarin/ dicoumarol; requires LT AC; unable to f/u; arterial insufficiency; venous ulcerations precluding comp stockings; age <14 yrs; thrombophilia; malignancy; or total limb paresis.
Kearon, 1999 | United States & Canada | Multicenter RCT | To determine whether 24 additional mos of warfarin is more effective than 3 mos for 1st idiopathic VTE. | 1994 - 97 | 24 | None | 1st idiopathic VTE, DVT±PE (DVT-75%, PE - 25%) | Preg; major psychiatric disorder; life expectancy <2 yrs; requires LT therapy w/ASA/NSAIDs or AC; allergy; unlikely to comply; familial bleeding disorder; contraindication to AC; or tx w/unlicenced LMWH preparation; thrombophilia; malignancy within last 5 yrs; immobilization for > 3 days; recent fracture or cast of lower limb; recent general anesthesia.
Agnelli, 2001 | Europe | Multicenter RCT | To evaluate LT benefit of extending AC from 3 mos to 1 yrs after a 1st idiopathic DVT in terms of symptomatic recurrence, bleeding, & death. | 1995 - 98 | 24 | None | 1st idiopathic proximal DVT | Preg/childbirth; major psychiatric disorder; life expectancy < 2 yrs; unlikely to f/u; requires LT AC; age <15 or >85 yrs; thrombophilia or malignancy; recent surgery or trauma (w/in 3 mos); immobilization >7 days; OCPs.
Pinede, 2001 | Europe | Multicenter RCT | To determine optimal duration of oral AC for a 1st proximal or calf DVT or PE. | 1993 - 98 | 15 | None | 1st DVT, calf or proximal, or PE (Proximal DVT- 43%, Proximal DVT+PE-18%, Calf DVT-27%, Calf DVT+PE -7%) | Preg; BF; requires LT AC; thrombolytic therapy; surgical thrombectomy; free-floating IVC clot; liver disease; severe PE; age < 18 yrs; thrombophilia; malignancy; previous DVT; vena caval filter.

Evidence Table 11. Quality of the studies evaluating optimal duration of therapy with warfarin after venous thromboembolism

Author, Year | Overall ^a^ | Representativeness of study population ^b^ | Bias & confounding ^c^ | Description of tx ^d^ | Outcomes & f/u ^e^ | Statistical quality & interpretation ^f^
O'Sullivan, 1972 | 15 | 0 | 25 | 25 | 25 | 0
Holmgren, 1985 | 46 | 75 | 50 | 50 | 55 | 0
Lagerstedt, 1985 | 73 | 50 | 63 | 100 | 70 | 83
Schulman, 1985 | 63 | 50 | 69 | 50 | 80 | 67
Petitti, 1986 | 46 | 75 | 0 | 0 | 80 | 75
Fennerty, 1987 | 31 | 25 | 25 | 25 | 45 | 33
BTS, 1992 | 53 | 50 | 63 | 25 | 60 | 67
Levine, 1995 | 83 | 100 | 88 | 50 | 75 | 100
Schulman, 1995 | 90 | 88 | 81 | 100 | 80 | 100
Schulman, 1997 | 86 | 88 | 88 | 75 | 80 | 100
Kearon, 1999 | 82 | 75 | 100 | 50 | 85 | 100
Agnelli, 2001 | 87 | 100 | 88 | 50 | 95 | 100
Pinede, 2001 | 82 | 75 | 88 | 75 | 70 | 100

a Overall The mean of the percentage scores from categories: Representativeness of Study Population, Bias and Confounding, Description of Treatment, Outcomes and Followup, and Statistical Quality and Interpretation (see below).

b Representativeness of Study Population: Percentage score based on a total maximum score of 8 points. This included description of study setting and population (2 points), description of inclusion/exclusion criteria (2 points), information on excluded or non-participating patients (2 points), and description of key patient characteristics (2 points).

c Bias and Confounding: Percentage score based on a total maximum score of 6 points. This included random assignment of patients to study groups (2 points), differences between study groups in key patient characteristics (2 points), and blinding of clinicians, patients, and outcome assessors (2 points).

d Description of Treatment: Percentage score based on a total maximum score of 4 points. This included description of the details of the treatment regimen (2 points), and description of other treatments given to each study group (2 points).

e Outcomes and Followup: Percentage score based on a total maximum score of 10 points. This included description of the criteria used for determining outcomes (2 points), description of adverse events experienced by patients (2 points), reporting on numbers and reasons for withdrawals or patients lost to followup (2 points), proportion of patients who withdrew or were lost to followup (2 points), and adequacy of the planned length of followup (2 points).

f Statistical Quality and Interpretation: Percentage score based on a total maximum score of 8 points. This included reporting on the magnitude of differences between groups with an index of variability (2 points), clear identification of all statistical analyses (2 points), use of multivariate or stratified analyses to adjust for potential confounders (2 points), and appropriate handling of withdrawals, crossovers, and loss to followup (2 points).

Evidence Table 12. Characteristics of patients in studies evaluating optimal duration of therapy with warfarin after venous thromboembolism

| | Intervention
Author, year | Group^a^ | Drug | Duration (days) | Type of VTE | Mean age (yrs) | Male (%) | % Prior VTE/ % Family hx/ % Thrombophilia | TRF/ Proximal DVT (%)
O'Sullivan, 1972 | I | Warfarin | 42 | | | | NR / NR / NR | NR / NR
| III | " | 180 | | | | NR / NR / NR | NR / NR
Holmgren, 1985 | I | Warfarin | 30 | Comp stockings | 62 | 59 | NR / NR / NR | NR / 87
| III | " | 180 | " | 62 | 64 | NR / NR / NR | NR / 79
Lagerstedt, 1985 | NA | No warfarin | | Comp stockings | 61 | 54 | 21 / NR / NR | NR / NR
| II | Warfarin | 90 | " | 65 | 61 | 13 / NR / NR | NR / NR
Schulman, 1985 | I | Warfarin | 45 | | 56 | 50 | NR / NR / NR | 100 / NR
| II | " | 90 | | 60 | 50 | NR / NR / NR | 100 / NR
| II^b^ | " | 90 | | 58 | 60 | NR / NR / NR | NR / NR
| III^b^ | " | 180 | | 66 | 75 | NR / NR / NR | NR / NR
| III | " | 180 | | 64 | 40 | 100 / NR / NR | NR / NR
| IV | " | 360 | | 66 | 40 | 100/ NR / NR | NR / NR
Petitti, 1986 | I | Warfarin | 7–42 | | | | NR / NR / NR | NR / NR
| I/II/III | " | 49–182 | | | | NR / NR / NR | NR / NR
| IV | " | >182 | | | | NR / NR / NR | NR / NR
Fennerty, 1987 | I | Warfarin | 21 | | 56 | 51 | NR / NR / NR | NR / NR
| I | " | 42 | | 57 | 61 | NR / NR / NR | NR / NR
BTS, 1992 | I | Warfarin | 28 | | 58 | 56 | NR / NR / NR | NR / NR
| II | " | 90 | | 58 | 51 | NR / NR / NR | NR / NR
Levine, 1995 | I/I | Warfarin/ warfarin | 28/56 | | 63 | 48 | 10 / NR / NR | 40 / NR
| I/I | Warfarin/ placebo | 28/56 | | 63 | 54 | 8 / NR / NR | 36 / NR
| II | Warfarin | 90 | | 62 | 59 | 9 / NR / NR | 24 / NR
Schulman, 1995 | I | Warfarin or dicumarol | 42 | Comp stockings | 61 | 56 | NR / 16 / NR | NR / 55
| III | " | 180 | " | 61 | 57 | NR / 14 / NR | NR / 58
Schulman, 1997 | III | Warfarin or dicumarol | 180 | " | 65 | 63 | NR / 22 / NR | 20 / 72
| IV | " | 1460 | " | 64 | 59 | NR / 19 / NR | 18 / 66
Kearon, 1999 | II/IV | Warfarin/ placebo | 90/720 | | 58 | 53 | 4 / NR / NR | NR / NR
| II/IV | Warfarin/ warfarin | 90/720 | | 59 | 68 | 6 / NR / NR | NR / NR
Agnelli, 2001 | II | Warfarin/ acenocoumarol | 90 | | 68 | 61 | NR / NR / NR | NR / 100
| IV | " | 360 | | 67 | 55 | NR / NR / NR | NR / 100
Pinede, 2001 ^c^ | I | Fluindione | 42 | | | | NR / 19.2 / NR | 68.3 / NR
| I | " | 84 | | | | NR / 25.8 / NR | 69.7 / NR
| I | " | 84 | | | | NR / 15.5 / NR | 45.8 / NR
| III | " | 168 | | | | NR / 15.2 / NR | 46 / NR

a I: Less than 3 months (1 – 89 days); II: 3 to 4 months (90 – 149 days); III: 5 to 6 months (150 – 180 days); IV: Greater than 6 months (181+ days); NA: not applicable

b All had first DVT with a permanent risk factor

c The first two subject groups consist of patients with calf vein DVT (comparing 42 and 84 days of therapy) while the third and fourth groups consist of patients with proximal DVT/PE (84 and 168 days of therapy)

Evidence Table 13. Results of studies evaluating optimal duration of therapy with warfarin after venous thromboembolism

| | | | | VTE Recurrence | | | Adverse Events
Author, Year | Group^a^ | # of pts | Mean f/u (mos) | Intensity of therapy | All VTE n (%) | DVT n (%) | PE n (%) | Major bleeding n (%) | Minor bleeding n (%) | Deaths n (%)
O'Sullivan, 1972 | I | 94 | | | | 6 (6) | 2 (2)
| III | 92 | | | | 9 (9) | 3 (3)
Holmgren, 1985 | I | 69 | | | | 7 (10) | 5 (7) | | | 6 (9)
| III | 66 | | | | 5 (8) | 5 (8) | | | 4 (6)
Lagerstedt, 1985 | NA | 28 | | | 9 (32) ^b^
| II | 23 | | | 1 (4) ^b^
Schulman, 1985 | I | 10 | 24 | ^c^ | | 1 (10) | 0 (0) | | | 0 (0)
| II | 10 | 20 | | | 2 (20) | 0 (0) | | | 0 (0)
| II | 20 | 22 | | | 3 (15) | 1 (5) | | | 3 (15)
| III | 20 | 21 | | | 2 (10) | 0 (0) | | | 2 (10)
| III | 10 | 33 | | | 0 (0) | 1 (10) | | | 1 (10)
| IV | 10 | 28 | | | 3 (30) | 0 (0) | | | 1 (10)
Petitti, 1986 | I | | | | ^d^
| I/II/III | | | | ^d^
| IV | | | | ^d^
Fennerty, 1987 | I | 49 | | | 2 (4) ^e^ | | | | | 1(2)
| I | 51 | | | 2 (4) ^e^ | | | | | 5 (10)
BTS, 1992 | I | 358 | | 86% ^f^ | 14 (4) ^e^ | | | 5 (1) | 10 (3) | 26 (7)
| II | 354 | | 80%^f^ | 7 (2) ^e^ | | | 4 (1) | 18 (5) | 28 (8)
Levine, 1995 | I/I | 109 | | 2.3 (±0.4)^g^ | 7 (7) | 7 (7) | 0 (0) | 1 (1) | | 9 (9)
| I/I | 105 | | | 12 (12)^h^ | 9 (9) | 3(3) | 0 (0) | | 9 (9)
| II | | | | 19 (13)
Schulman, 1995 | I | 443 | | 65% ^i^ | 80 (18) ^b^ | | | 1(0.2) | | 22 (5)
| III | 454 | | 59% ^i^ | 43 (10) ^b^ | | | 5 (1) | | 17 (4)
Schulman, 1997 | III | 111 | | | 23 (21) ^b^ | | | 3 (3) | | 16 (14)
| IV | 116 | | 62% ^j^ | 3 (3) ^b^ | | | 10 (9) | | 10 (9)
Kearon, 1999 | II/IV | 83 | 9 | | | 11 (13) | 6 (7) | 0 (0) | 1 (1) | 3 (4)
| II/IV | 79 | 12 | 2.5 (±1.0)^h^ | | 0 (0) | 1 (1) | 3 (4) | 6 (8) | 1 (1)
Agnelli, 2001 | II | 133 | 37.2 | | 18(14) | 3(2) | 2(2) | | | 7(5)
| IV | 134 | 37.8 | 81% ^j, k^ | | 16 (12) | 5 (4) | 4 (3) | | 7 (5)
Pinede, 2001 | I | 105 | | ^l^ | | 2 (2) | 0 (0) | 1 (1) | 12 (12)
| I | 92 | | | | 2 (2) | 1 (1) | 3 (3) | 16 (18)
| I | 270 | | | | 18 (7) | 6 (2) | 5 (2) | 38 (14)
| III | 269 | | | | 15 (6) | 6 (2) | 7 (3) | 38 (14)

a I: Less than 3 months (1 – 89 days); II: 3 to 4 months (90 – 149 days); III: 5 to 6 months (150 – 180 days); IV: Greater than 6 months (181+ days) NA: Not applicable

b p<0.05 for the difference between groups

c Effective anticoagulation [Thrombotest ® (Nyegaard, Norway) < 13%] achieved in 68% and 67% respectively of the reduced duration and regular duration subjects.

d Relative risk of recurrence: Group A (1–6 weeks of therapy) vs Group C (>26 weeks)= 1.1; Group B (7–26 weeks) vs Group C (>26 weeks)= 0.7.

e Only objectively confirmed events included.

f In therapeutic range 67% of time in 86% of participants in Group A and 80% of participants in Group B. Test and therapeutic range not specified.

g Mean INR (± standard deviation (SD))

h VTE at 2 mos. f/u: Group A= 1 (1%), Group B= 9 (9%), p<0.009

i % w/ effective AC (INR 2.0 for 75% or more of PTT).

j % of pts in target range (INR 2.0–2.85).

k INR was 2.0–3.0 in 81% of tests during additional 9 mos. of therapy.

l Median INR 2.0 in 96% of subjects, distribution similar between arms.

Evidence Table 14. Description of studies evaluating clinical prediction rules used in diagnosis of venous thromboembolism

Author, Year | Location | Study aims | Recruitment dates | Study test | Reference standard | Inclusions | Exclusions
Deep Venous Thrombosis
Nypaver, 1993 | United States | To define clinical criteria that might predict the diagnostic value of VDS. | | Clinical model | | Suspected DVT in inpts | PE.
Wells, 1995 | Canada | To assess the ability of a clinical model to stratify symptomatic outpatients with suspected DVT into groups with high, moderate, and low probability of DVT and to evaluate this model in combination with U/S. | 1992 - 93 | Wells model | Venogram | Referral for suspected DVT in outpts | Preg/childbirth; contrast dye allergy; renal failure; suspected PE; below the knee amputation.
Wells, 1997 | Canada | | 1994 - 96 | Wells model | Venogram U/S | Referral for suspected DVT in outpts | Age < 18 yrs; previous VTE; requires LT AC; PE; imminent death.
Anderson, 1999 | Canada | To determine the accuracy of a clinical model, and determine if the model is safe and feasible. | 1997 | Wells model | U/S | Suspected DVT in ED | Age < 18 yrs; Preg/childbirth; previous VTE; short life expectancy; unlikely to be compliant; hereditary bleeding; contraindication to AC; thrombolytic therapy; PE.
Aschwanden, 1999 | Europe | | 1997 | Wells model Wells model + D-dimer | U/S | Referral for suspected idiopathic DVT
Lennox, 1999 | Europe | To determine the actual value of the D-dimer test and its combination with clinically derived risk stratification in the diagnostic work up of patients with suspected DVT. | | Risk assessment score for DVT (RAS) RAS + D-dimer | U/S | Suspected DVT in inpts/outpts | Previous VTE; chronic DVT on US; symptoms > 1 mos; AC > 48 hours; PE.
Wells, 1999 | Canada | To evaluate the accuracy of D-dimer in hospitalized patients. | 1994 - 96 | Wells Model Wells Model + D-dimer | U/S, thigh/ popliteal | Referral for suspected DVT in inpts | Age < 18 yrs; previous VTE; short life expectancy; unlikely to be compliant; requires LT AC; PE; screening.
Anderson, 2000 | Canada | To determine the accuracy of D-dimer and to determine the potential of combining the D-dimer with the Wells model. | | Wells Model Wells Model + D-Dimer | U/S | Suspected DVT in ED | Age < 18 yrs; hereditary bleeding; contraindication to AC; thrombolytic therapy; PE.
Constans, 2001 | Europe | To determine whether one or two of these scores maintained the same level of performance in various hands. | 1999 - 99 | Kahn model Wells model Sant-Andre hospital model | U/S, thigh/ popliteal | | Previous VTE
Dryjski, 2001 | United States | To evaluate the efficacy and cost effectiveness of a DVT screening protocol consisting of global PTP, selective D-dimer, and selective venous Doppler imaging. | 2000 - 01 | Wells model Wells + D-dimer + PTP | U/S, thigh/ popliteal | Suspected DVT in ED
Funfsinn, 2001 | Europe | To determine the reliability of several rapid D-dimer tests in combination with a simple clinical model to predict the pretest probability. | | Wells model | Venogram, central, thigh/popliteal, calf; U/S, thigh/ popliteal | Referral for suspected DVT | Preg/childbirth; hospitalization; AC for 24 hours.
Kearon, 2001 | Canada | Test if U/S can be withheld from pts w/ low probability scores. | 1995 - 97 | Wells model Wells model + D-dimer | U/S | Referral for suspected DVT
Cornuz, 2002 | Europe | To compare clinical assessment and the Wells score, in isolation and in combination with rapid quantitative D-dimer. | | Wells model Wells model + D-dimer | Venogram, thigh/popliteal; U/S | Referral for suspicion of DVT | Preg/childbirth; PE.
Kraaijenhagen, 2002 | Europe | To study if combination of normal results of compression ultrasonography and rapid whole blood bedside D-dimer assay at referral can safely exclude the presence of thrombosis. | 1995 - 99 | Wells model | U/S | | <18 yrs, previous VTE PE, AC >48 hrs, geographic inaccessibility.
Pulmonary Embolism
Wells, 1998 | Canada | To find a clinical model for safe management of patients with suspected PE. | 1993 - 96 | Wells PE model | V/Q | PE, suspected PE in inpts/ outpts | UE VTE; Preg/childbirth; short life expectancy; contrast dye allergy; recent AC use.
Sanson, 2000 | Europe | To compare the accuracy and variability of the clinical probability estimate between the PIOPED and the two clinical models by Wells. | 1997 - 98 | PIOPED study model Wells simplified model Wells extended model for PE | V/Q, SPECT (tomographic) Helical CT, PA | Unsuspected DVT in inpts/outpts | Age < 18 yrs; Preg/childbirth; undergone testing for PE; inability to complete protocol.
Stollberger, 2000 | Europe | To derive and validate a prediction rule based on clinical and easily obtained instrumental findings by which PE can be diagnosed. | | Clinical model | V/Q | High suspicion for PE (enough to start heparin) | Contraindication for PE evaluation.
Wells, 2000 | Canada | Simplify the clinical model and examine the potential safety and clinical utility of combining the new model with D-dimer results to enable exclusion of PE. | | Wells PE model Wells PE model + D-dimer | V/Q | Suspected PE
Wells, 2001 | Canada | Demonstrate the safety of excluding the diagnosis of pulmonary embolus in an emergency department using diagnostic algorithms that were based on pretest probability and D-dimer assay results. | 1998 - 99 | Wells PE model | V/Q | Acute dyspnea or chest pain less than 30 days. | Suspected DVT of the upper extremity, AC >24 hrs, and short LE contraindication to contrast media, Preg, geographic inaccessibility, age <18 yrs.

Evidence Table 15. Quality of studies evaluating clinical prediction rules used in diagnosis of venous thromboembolism

Author, year | Overall ^a^ | Representativeness of study population ^b^ | Bias & confounding ^c^ | Description of prediction rule ^d^ | Test interpretation ^e^ | Statistical quality & interpretation ^f^
Deep Venous Thrombosis
Nypaver, 1993 | 64 | 38 | 30 | 83 | 67 | 100
Wells, 1995 | 84 | 75 | 60 | 83 | 100 | 100
Wells, 1997 | 82 | 100 | 25 | 100 | 83 | 100
Anderson, 1999 | 78 | 100 | 25 | 83 | 83 | 100
Aschwanden, 1999 | 70 | 38 | 60 | 100 | 100 | 50
Lennox, 1999 | 63 | 63 | 35 | 100 | 67 | 50
Wells, 1999 | 78 | 100 | 25 | 83 | 83 | 100
Anderson, 2000 | 85 | 100 | 40 | 83 | 100 | 100
Constans, 2001 | 66 | 75 | 40 | 100 | 67 | 50
Dryjski, 2001 | 74 | 88 | 30 | 100 | 100 | 50
Funfsinn, 2001 | 71 | 75 | 30 | 67 | 83 | 100
Kearon, 2001 | 75 | 88 | 20 | 83 | 83 | 100
Cornuz, 2002 | 88 | 88 | 50 | 100 | 100 | 100
Kraaijenhagen, 2002 | 93 | 100 | 80 | 100 | 100 | 100
Pulmonary Embolism
Wells, 1998 | 61 | 75 | 45 | 83 | 100 | 0
Sanson, 2000 | 90 | 100 | 50 | 100 | 100 | 100
Stollberger, 2000 | 51 | 50 | 20 | 67 | 67 | 50
Wells, 2000 | 49 | 38 | 25 | 83 | 100 | 0
Wells, 2001 | 84 | 88 | 60 | 100 | 100 | 100

a Overall: The mean of the percentage scores from the categories: Representativeness of Study Population, Bias and Confounding, Description of Test Protocols, Test Interpretation, and Statistical Quality and Interpretation (see below).

b Representativeness of Study Population: Percentage score based on a total maximum score of 8 points. This included description of study setting and population (2 points), description of inclusion/exclusion criteria (2 points), information on excluded or non-participating patients (2 points), and description of key patient characteristics (2 points).

c Bias and Confounding: Percentage score based on a total maximum score of 10 points. This included use of the reference test on all subjects receiving the study test (2 points), use of the study test in the decision to obtain the reference test (2 points), blinding of test interpretation and clinical data (2 points), interpretation of the study test by two or more independent observers (2 points), and interpretation of the reference test by two or more independent observers (2 points).

d Description of Prediction Rule: Percentage score based on a total maximum score of 6 points. This included description of the clinical model being tested (2 points), description of the reference test protocol (2 points), and reporting on the methods used in the development of the clinical model being tested (2 points).

e Test Interpretation: Percentage score based on a total maximum score of 6 points. This included description of the criteria for a positive interpretation of the study test (2 points), description of the criteria for a positive interpretation of the reference test (2 points), and reporting on numbers and reasons for withdrawals or patients lost to followup (2 points).

f Statistical Quality and Interpretation: Percentage score based on a total maximum score of 4 points. This included reporting of a summary index of test performance and of an index of variability (2 points), and use of multivariate or stratified analyses to adjust for potential confounders (2 points).

Evidence Table 16. Characteristics of patients in studies evaluating clinical prediction rules used in diagnosis of venous thromboembolism

| | Age (yrs) | | Male | Prior VTE | Family history | TRF | Malignancy
Author, Year | N | Mean | Range/SD | (%) | (%) | (%) | (%) | (%)
Deep Venous Thrombosis
Nypaver, 1993 | 68
Wells, 1995 | 605
Wells, 1997 | 593 | 57.1 | | 41 | | | 22 | 13
Anderson, 1999 | 344 | 53.8 | | 45 | | | 19 | 5
Aschwanden, 1999 | 343 | 61 ^a^ | 17–94 ^b^
Lennox, 1999 | 200 | 58 | 18–91 ^b^ | 37
Wells, 1999 | 150 | 63.8 | | 49 | | | 49
Anderson, 2000 | 214 | 54.8 | | 45 | | | 19 | 6
Constans, 2001 | 273 | 68 | 17 ^c^ | 38 | 20 | 7 | | 17
Dryjski, 2001 | 66 | 63 | 19–92 ^b^ | 25
Funfsinn, 2001 | 106 | 56.3 | 16–88 ^b^ | 49
Kearon, 2001 | 445
Cornuz, 2002 | 278 | 60 | 19 ^c^ | 62 | 18 | | 10 | 10
Kraaijenhagen, 2002 | 1726 | 60 | 18–96 ^b^ | 37 | | | 15 | 13
Pulmonary Embolism
Wells, 1998 | 1401
Sanson, 2000 | 517 | 51 | | 42 | 14 | 20 | | 10
Stollberger, 2000 | 168 | 64 | 21–86 ^b^ | 47
Wells, 2000 | 295
Wells, 2001 | 903 | 50.5 | 16–93 ^b^ | 37 | | | 16 | 7.2

a Median

b Range

c Standard deviation

Evidence Table 17. Results of studies evaluating clinical prediction rules used in diagnosis of venous thromboembolism

Author, Year | Study test | Clinical prediction probability ^a^ | # pts w/VTE (%) | Sensitivity (%) | Specificity (%) | PPV (%) | NPV (%) | ROC curve area
Deep Venous Thrombosis
Nypaver, 1993 | Clinical model | | | 91 | 51 | 26 | 97
Wells, 1995 | Wells model | High | 69 (81%) | 61 | 97 | 81 | 91 | 0.90
| | Moderate | 34 (24%) | 91 | 70 | 45 | 97
| | Low | 10 (3%) | – | – | – | --
Wells, 1997 | Wells model | High | 53 (75%) | 53 | 96 | 75 | 91 | 0.87
| | Moderate | 35 (18%) | 88 | 64 | 33 | 96
| | Low | 12 (4%) | -- | -- | -- | --
Anderson, 1999 | Wells model | High | 24 (49%) | 53 | 92 | 49 | 93 | 0.79
| | Moderate | 15 (14%) | 87 | 62 | 25 | 97
| | Low | 6 (3%) | -- | -- | -- | --
Aschwanden, 1999 | Wells model | High | | 84 | 56 | 26 | 95
Wells model + D-dimer | High | | 96 | 46 | 32 | 98
Lennox, 1999 | Risk assessment score for DVT (RAS) | High | 30 (67%) | 65 | 90 | 67 | 90 | 0.87
| | Moderate | 12 (18%) | 91 | 54 | 38 | 95
| | Low | 4 (5%) | -- | -- | -- | --
RAS + D-dimer | | | | | | | 0.91
Wells, 1999 | Wells model | High | 22 (76%) | 54 | 94 | 76 | 84 | 0.81
| | Moderate | 14 (20%) | 88 | 41 | 36 | 90
| | Low | 5 (10%) | -- | -- | -- | --
| Wells model + D-dimer | High | | | | 79 | 33
| | Moderate | | | 28 | 89
| | Low | | | | 20 | 96
Anderson, 2000 | Wells model | High | 15 (50%) | 54 | 92 | 50 | 93 | 0.83
| | Moderate | 9 (14%) | 86 | 61 | 25 | 97
| | Low | 4 (3%) | -- | -- | -- | --
| Wells model + D-Dimer | | | | | | | 0.87
Constans, 2001 | Wells model | High | 33 (51%) | 50 | 85 | 52 | 84 | 0.74
| | Moderate | 26 (19%) | 89 | 32 | 31 | 90
| | Low | 7 (10%) | -- | -- | -- | --
| Kahn model | High | 2 (100%) | 3 | 100 | 100 | 75 | 0.59
| | Moderate | 47 (28%) | 74 | 43 | 29 | 81
| | Low | 17 (19%) | -- | -- | -- | --
| Sant-Andre hospital model | High | 13 (76%) | 20 | 98 | 76 | 79 | 0.77
| | Moderate | 38 (33%) | 77 | 61 | 39 | 89
| | Low | 15 (11%) | -- | -- | -- | --
Dryjski, 2001 | Wells model | High | 6 (17%) | 100 | 50 | 17 | 100 | 0.75
| | Moderate | 0 (0%) | 100 | 12 | 10 | 100
| | Low | 0 (0%) | -- | -- | -- | --
| Wells model + D-dimer + PTP | | | 100 | 25 | 12 | 100
Funfsinn, 2001 | Clinical Model (Well's DVT)^b^ | High | 30 (71%) | 75 | 77 | 71 | 80 | 0.77
| | Moderate | 10 (28%) | 100 | 27 | 51 | 100
| | Low | 0 (0%) | -- | -- | -- | --
Kearon, 2001 | Wells model | High | 35 (69%) | 55 | 96 | 69 | 93 | 0.87
| | Moderate | 24 (13%) | 92 | 53 | 25 | 98
| | Low | 5 (2%) | -- | -- | -- | --
| Wells model + D-dimer | Low | | | | | 99
Cornuz, 2002 | Wells model | High | 32 (67%) | 39 | 92 | 67 | 78 | 0.75
| | Moderate | 36 (30%) | 83 | 48 | 40 | 87
| | Low | 14 (13%) | -- | -- | -- | --
| Wells model + D-dimer | High | | | | 73 | 100
| | Moderate | | | | 38 | 90
| | Low | | | | 16 | 100
Kraaijemhagen, 2002 | Wells model | High | 228 (66%) | 53 | 91 | 66 | 91 | 0.87
| | Moderate | 135 (27%) | 85 | 63 | 43 | 63
| | Low | 62 (8%) | -- | -- | -- | --
Pulmonary Embolism
Wells, 1998 | Wells PE model | High | 80 (78%) | 37 | 98 | 78 | 88 | 0.88
| | Moderate | 112 (28%) | 88 | 69 | 38 | 97
| | Low | 25 (3%) | -- | -- | -- | --
Sanson, 2000 | PIOPED study model | High | 35 (45%) | 28 | 85 | 45 | 73 | 0.61
| | Moderate | 80 (29%) | 91 | 16 | 33 | 81
| | Low | 11 (19%) | -- | -- | -- | --
| Wells simplified model | High | 3 (38%) | 2 | 98 | 38 | 71 | 0.52
| | Moderate | 78 (30%) | 66 | 36 | 30 | 72
| | Low | 41 (28%) | -- | -- | -- | --
| Wells extended model for PE pulmonary angiogram | High | 18 (46%) | 20 | 86 | 46 | 64 | 0.58
| | Moderate | 54 (39%) | 81 | 29 | 41 | 72
| | Low | 17 (28%) | -- | -- | -- | --
Stollberger, 2000 | Clinical model | > 0.65 | | 55 | 100
| | > 0.35 | | 98 | 82
| | > 0.02 | | 100 | 5 | 35 | 100
Wells, 2000 | Wells PE model | High | 10 (50%) | 28 | 95 | 50 | 89 | 0.82
| | Moderate | 24 (19%) | 94 | 46 | 23 | 98
| | Low | 2 (2%) | -- | -- | -- | --
| Wells PE model + | | | | | | | 0.85
Wells, 2001 | Wells PE model | High | 24 (41%) | 27 | 95 | 36 | 95 | 0.85
| | Moderate | 55 (16%) | 92 | 62 | 20 | 98
Low | 7 (1.3%) | -- | -- | -- | --

a High probability≥3, moderate probability=1 or 2, low probability<1.

b Models with D-dimer testing also presented in paper.

Evidence Table 18. Summary of systematic reviews on ultrasound in the diagnosis of deep venous thrombosis

| | | Systematic review quality scores
Author, Year | Study aim | Most recent study | Overall ^a^ | Search ^b^ | Eligibility ^c^ | Study quality ^d^ | Combining results ^e^ | Aims & Conclusions ^f^
White, 1989 | To assess accuracy of duplex U/S for the dx of prox DVT in symptomatic pts. | 1988 | 65 | 33 | 67 | 75 | 75 | 75
Becker, 1989 | To review the evidence for the use of real-time U/S in dx of suspected DVT. | 1988 | 73 | 33 | 83 | 100 | 100 | 100
Cogo, 1995 | To assess accuracy of non-invasive dx of 1st episode of suspected DVT. | 1992 | 38 | 17 | 50 | 0 | 75 | 75
Wells, 1995 | To evaluate accuracy of screening U/S for dx of DVT in post-operative orthopedic pts. | 1993 | 82 | 50 | 83 | 75 | 100 | 100
Kearon, 1998 | To review non-invasive methods of dx for a 1st DVT. | 1997 | 83 | 83 | 100 | 50 | 100 | 100
Gottlieb, 1999 | To determine the accuracy of U/S for detection of isolated calf DVT. | 1996 | 58 | 50 | 67 | 0 | 100 | 100
Mustafa, 2002 | To determine sensitivity and specificity of U/S for dx of upper extremity DVT. | 1997 | 63 | 50 | 67 | 75 | 100 | 100

a Overall Quality Score: The mean of the percentage scores from the categories, Search Methods, Inclusion & Description, Quality Assessment, Methods of Combination, and Aims/Conclusions (see below).

b Search Methods: Percentage score based on a total maximum score of 6 points. This included description of search methods (2 points), comprehensiveness of search methods (2 points), and reproducibility of review methods (2 points).

c Eligibility and Description: Percentage score based on a total maximum score of 6 points. This included description of study inclusion criteria (2 points), appropriateness of study inclusion criteria (2 points), and discussion of variation in the original literature based on differences in study design (2 points).

d Study Quality Assessment: Percentage score based on a total maximum score of 4 points. This included description of quality assessment (2 points), and appropriateness of quality assessment (2 points).

e Combining Results: Percentage score based on a total maximum score of 4 points. This included description of methods used to combine study results (2 points), and appropriateness of methods used to combine study results (2 points).

f Aims & Conclusions: Percentage score based on a total maximum score of 4 points. This included whether the question to be addressed by the review was clearly stated (2 points), and whether the conclusions reached by the review were supported by data and/or analyses (2 points).

Evidence Table 19. Results of systematic reviews on ultrasound in the diagnosis of deep venous thrombosis

Author, Year | Design of trials ^a^ | # of trials | Total pts | % DVT | Patient population ^b^ | Ultrasonography | Mean sensitivity (95% CI), % | Mean specificity (95% CI), % | Comments
White, 1989 | Prosp/ consec | 4 | 266 | 46 | Symp/prox DVT/level 1 | Compression | 93 (88–97) | 98 (96–100) | Level 1 studies had both tests w/i 24 hrs of each other; blinded.
| | 9 | 424 | 61 | Symp/prox DVT/level 2 | Compression | 98 (96–100) | 96 (93–99)
Becker, 1989 | | 15 | 1578 | 50 | Symp/lower extremity DVT | Compression +/- Doppler | 96 (92–100) ^c^ | 99 (96–100) ^c^ | Only 3 studies looked for calf DVT.
Cogo, 1995 | Prosp/ consec | 9 | 989 | 43 | Symp/1st prox DVT | Compression | 96 | 98 | Consistency in results despite different qualities of studies. Duplex + color Doppler offered no advantage over compression; low sens for calf DVT.
| | 4 | 247 | 42 | Symp/1st prox DVT | Compression +/- Doppler | 95 | 93
| | 4 | 340 | 37 | Symp/1st prox DVT | Compression +/- color Doppler | 97 | 97
| | 4 | | | Symp/1st calf DVT | All types | 75 (56–88) | N/A
Wells, 1995 | Prosp/ consec | 11 | 1616 | 9 | Asymp/post-op prox DVT/level 1 | Compression +/- Doppler | 62 | 97 | Only moderate sens for detecting DVT in asymp patients; sens lower among studies that minimize potential for bias.
| | 5 | 385 | 17 | Symp/post-op prox DVT/level 2 | Compression +/- Doppler | 95 | 97
| | 2 | | | Symp/post-op calf DVT/level 1 | Compression +/- Doppler | 48 (29–67) | 100
Kearon, 1998 | Prosp/ consec | 18 | 2763 | 40 | Symp/1st prox DVT | Compression +/- Doppler | 89 (85–92) | 94 (90–98) | Sens dependent on presence of symptoms; low sens for calf DVT.
| | 11 ^d^ | 1316 ^d^ | | Calf DVT ^d^ | | 73 (54–93) | N/A
| | 16 | 2035 | 16 | Symp/1st prox DVT | Compression +/- Doppler | 47 (37–57) | 94 (91–98)
| | 12 ^d^ | 1681 ^d^ | N/A | Calf DVT ^d^ | | 53 (32–74) | N/A
Gottlieb, 1998 | | 5 | 212 ^e^ | 25 | Symp/calf vein DVT | Compression | 93 (82–98) | 99 (96–99) | High frequency of indeterminate studies.
Mustafa, 2002 | Prosp | 6 | 170 | 73 | Symp/upper extremity DVT | Doppler +/- compression | (56–100) ^c^ | (77–100) ^c^ | Highest quality study used compression and color Doppler; sens 100 and spec 93.

a Prosp=prospective design, consec=consecutively enrolled patients

b Level 1=higher quality trial, level 2= lower quality trials, post-op=evaluated post-operatively

c Mean and range, or just range

d Subset of studies

e Number of legs screened

Evidence Table 20. Description of the systematic reviews on the use of computed tomography for the diagnosis of pulmonary embolism

| | | | | Systematic review quality scores
Author, Year | Main Inclusion Criteria | Date of most recent study | # studies | Total pts | Overall ^a^ | Search ^b^ | Eligibility ^c^ | Study quality ^d^ | Combining results ^e^ | Aims & Conclusions ^f^
Harvey, 2000 | Prospective and retrospective studies with pulmonary arteriography as reference standard. | 1998 | 11 | 931 | 77 | 50 | 83 | 75 | 75 | 100
Mullins, 2000 | Diagnosis established by pulmonary arteriography or a clinical reference standard. | 1998 | 11 | 714 | 75 | 33 | 67 | 75 | 100 | 100
Rathburn, 2000 | Prospective studies evaluating the use of CT for diagnosis of PE using any reference standard. | 1999 | 15 | 1330 | 78 | 50 | 67 | 75 | 100 | 100
Cueto, 2001 | Prospective studies with positive and negative CT results; pulmonary arteriography reference standard. | 1998 | 7 | 268 | 72 | 50 | 83 | 75 | 50 | 100
van Beek, 2001 | Prospective studies reporting sensitivity and specificity of CT relative to arteriography or V/Q scan. | 1999 | 12 | 1171 | 55 | 33 | 67 | 50 | 50 | 75
Safriel, 2002 | Diagnosis established by pulmonary arteriography or high-probability V/Q scan; not limited to acute PE. | 1999 | 12 | 1250 | 55 | 50 | 83 | 0 | 50 | 75

a Overall Quality Score: The mean of the percentage scores from the categories, Search Methods, Inclusion & Description, Quality Assessment, Methods of Combination, and Aims/Conclusions (see below).

b Search Methods: Percentage score based on a total maximum score of 6 points. This included description of search methods (2 points), comprehensiveness of search methods (2 points), and reproducibility of review methods (2 points).

c Eligibility and Description: Percentage score based on a total maximum score of 6 points. This included description of study inclusion criteria (2 points), appropriateness of study inclusion criteria (2 points), and discussion of variation in the original literature based on differences in study design (2 points).

d Study Quality Assessment: Percentage score based on a total maximum score of 4 points. This included description of quality assessment (2 points), and appropriateness of quality assessment (2 points).

e Combining Results: Percentage score based on a total maximum score of 4 points. This included description of methods used to combine study results (2 points), and appropriateness of methods used to combine study results (2 points).

f Aims & Conclusions: Percentage score based on a total maximum score of 4 points. This included whether the question to be addressed by the review was clearly stated (2 points), and whether the conclusions reached by the review were supported by data and/or analyses (2 points).

Evidence Table 21. Results of the systematic reviews on the use of computed tomography in the diagnosis of pulmonary embolism

Author, Year | Subgroup | Total pts | Overall prevalence of PE (%) | Combined sensitivity % (range) or [95% CI] | Combined specificity % (range) or [95% CI] | Conclusions
Harvey, 2000 | Studies in which all participants had arteriography as reference standard; segmental PE data. | 190 | 46 | 82 (53–100) | 91 (78–100) | CT may be less accurate in diagnosis of PE than previously reported
| Studies in which some or all participants had arteriography reference standard; segmental PE data. | 813 | 34 | 79 (47–100) | 89 (75–100)
| Studies that included data on diagnosis of segmental and subsegmental PE. | 358 | 44 | 66 (45–91) | 91 (78–100)
Mullins, 2000 | Studies that compared CT with arteriography for segmental PE diagnosis. | 367 | 35 | 93 (50–100) | 97 (92–100) | CT may have role as “rule-in” test for large central emboli, but additional research is required to establish its place in clinical practice
Rathburn, 2000 | All studies. | 1330 | | (53–100) | (81–100) | Use of CT in diagnosis of PE has not been adequately evaluated; all studies satisfied few criteria for methodological quality
Cueto, 2001 | All studies. | 268 | | 80 [73–86] | 94 [91–98] | CT may be an appropriate study in clinical evaluation of suspected PE
| Studies reporting segmental PE data. | 166 | | 77 [67–88] | 91 [86–97]
| Studies reporting combined segmental and subsegmental PE data. | 169 | | 81 [72–90] | 98 [95–100]
van Beek, 2001 | All studies. | 1171 | 39 | 88 [83–91] | 92 [89–94] | Exact role of CT in management of suspected PE needs to be determined in prospective studies
Safriel, 2002 | All studies. | 1250 | | 74 [57–100] | 90 [68–100] | CT has acceptable sensitivity and specificity.

Evidence Table 22. Study design and characteristics of patients in studies evaluating computed tomography or magnetic resonance imaging for diagnosis of pulmonary embolism

Author, Year | Location | Aims | Test evaluated | Reference standard | Source of participants | N | Mean age in yrs (range) | Male (%)
Computed tomography
Remy-Jardin, 1992 | Europe | To compare quality and effectiveness of helical CT with results of pulmonary arteriography in dx of central PE. | HCT | PA | Referral with clinically suspected PE or unexplained chest radiograph abnormality. | 42 | 34 (21–65) | 71
Blum, 1994 | Europe | To compare helical CT versus pulmonary arteriography in diagnosis of acute massive PE. | HCT | PA | Clinical suspicion of massive PE. | 10 | 43 (18–76) | 40
Goodman, 1995 | United States | To prospectively compare helical CT with pulmonary arteriography for detecting PE in patients with unresolved clinical and V/Q scan dx. | HCT | PA | Non-diagnostic V/Q scan. | 20 | 53 (25–84) | 60
Remy-Jardin, 1996 | Europe | To evaluate accuracy of helical CT in dx of PE. | HCT | PA | Referral for pulmonary arteriography. | 75 | 59 (22–83) | 43
Christiansen, 1997 | | To test diagnostic validity of CT compared to pulmonary arteriography in acute PE. | HCT | PA | High clinical suspicion of PE. | 70 | 67 (22–87) | 48
Drucker, 1998 | United States | To determine sensitivity and specificity of helical CT for the dx of acute PE. | HCT | PA | Referral for pulmonary arteriography. | 47 | 57 (22–89) | 47
Qanadli, 2000 | Europe | To evaluate the accuracy of dual-section helical CT in acute PE dx. | HCT (dual section) | PA | Referral to radiology department. | 157 | 58 (14)^a^ | 46
Velmahos, 2001 | United States | To evaluate sensitivity and specificity of helical CT for dx of PE in critically ill surgical patients. | HCT | PA | Surgical ICU patients with explicitly defined clinical findings associated with PE. | 22 | 38 (20–75) | 73
Magnetic Resonance Imaging
Grist, 1993 | United States | To study the accuracy of MRA in pts w/PE | MR (fast GRE) | PA | Pts referred for PA. | 14 | (35–82) | 50
Erdman, 1994 | United States | To assess accuracy of MRI in the evaluation of patients with suspected PE. | MRI of clot (SE, GRE) | PA or V/Q | Suspected PE referred for PA or V/Q. | 64 | (18–73) | 47
Loubeyre, 1994 | Europe | To evaluate contrast-enhanced MRA in the diagnosis of thrombi in both the proximal and peripheral portions of the pulmonary arteries | MRA (fast GRE + Gd) | PA | Suspected PE. | 23 | 50 (20–66) | 52
Meaney, 1997 | United States | To compare MRA with PA in for diagnosing PE in patients referred for PA. | MRA (fast GRE + Gd) | PA | Suspected PE referred for PA. | 30 | 52 (22–83) | 50
Berthezene, 1999 | Europe | To assess accuracy of MR perfusion imaging compared with perfusion scintigraphy in patients with suspected lung perfusion defects (due to PE or emphysema). | Perfusion MRI (fast GRE + Gd) | V/Q | Suspected PE referred for V/Q. | 48 | (34–83) | 63
Gupta, 1999 | Australia | To prospectively evaluate MRA to dx pts w/ suspected PE in whom V/Q scans are of intermediate probability or clinical suspicion is high, and who are referred for PA. | MRA (fast GRE + Gd) | PA | Suspected PE referred for PA . | 36 | 59 (28–84) | 47
Oudkerk, 2001 | Europe | To assess accuracy of MRA for diagnosis of PE in non-selected patients with suspected PE and an abnormal V/Q scan. | MRA (fast GRE + Gd) | PA | Suspected PE with abnormal V/Q referred for PA. | 115 | 53 (16–87) | 43

a Standard deviation

Evidence Table 23. Quality of studies evaluating computed tomography or magnetic resonance imaging for diagnosis of pulmonary embolism

Author, year | Overall ^a^ | Representativeness of study population ^b^ | Bias & confounding ^c^ | Description of test protocols ^d^ | Test interpretation ^e^ | Statistical quality & interpretation ^f^
Computed tomography
Remy-Jardin, 1992 | 82 | 88 | 70 | 100 | 100 | 50
Blum, 1994 | 44 | 25 | 70 | 50 | 25 | 50
Goodman, 1995 | 74 | 88 | 80 | 100 | 100 | 0
Remy-Jardin, 1996 | 77 | 75 | 60 | 100 | 100 | 50
Christiansen, 1997 | 61 | 0 | 30 | 75 | 100 | 100
Drucker, 1998 | 81 | 75 | 80 | 100 | 100 | 50
Qanadli, 2000 | 84 | 88 | 80 | 100 | 100 | 50
Velmahos, 2001 | 83 | 100 | 90 | 75 | 100 | 50
Magnetic Resonance Imaging
Grist, 1993 | 75 | 38 | 70 | 75 | 100 | 50
Erdman 1994 | 67 | 63 | 20 | 100 | 100 | 50
Loubeyre | 68 | 25 | 60 | 100 | 100 | 50
Meaney 1997 | 77 | 75 | 10 | 100 | 100 | 100
Berthezene 1999 | 60 | 13 | 10 | 100 | 75 | 100
Gupta 1999 | 77 | 75 | 10 | 100 | 100 | 100
Oudkerk, 2001 | 76 | 75 | 5 | 100 | 100 | 100

a Overall: The mean of the percentage scores from the categories: Representativeness of Study Population, Bias and Confounding, Description of Test Protocols, Test Interpretation, and Statistical Quality and Interpretation (see below).

b Representativeness of Study Population: Percentage score based on a total maximum score of 8 points. This included description of study setting and population (2 points), description of inclusion/exclusion criteria (2 points), information on excluded or non-participating patients (2 points), and description of key patient characteristics (2 points).

c Bias and Confounding: Percentage score based on a total maximum score of 10 points. This included use of the reference test on all subjects receiving the study test (2 points), use of the study test in the decision to obtain the reference test (2 points), blinding of test interpretation and clinical data (2 points), interpretation of the study test by two or more independent observers (2 points), and interpretation of the reference test by two or more independent observers (2 points).

d Description of Test Protocols: Percentage score based on a total maximum score of 4 points. This included description of the study test protocol (2 points), and description of the reference test protocol (2 points).

e Test Interpretation: Percentage score based on a total maximum score of 6 points. This included description of the criteria for a positive interpretation of the study test (2 points), description of the criteria for a positive interpretation of the reference test (2 points), and reporting on numbers and reasons for withdrawals or patients lost to followup (2 points).

f Statistical Quality and Interpretation: Percentage score based on a total maximum score of 4 points. This included reporting of a summary index of test performance and of an index of variability (2 points), and use of multivariate or stratified analyses to adjust for potential confounders (2 points).

Evidence Table 24. Results of studies evaluating computed tomography or magnetic resonance imaging for diagnosis of pulmonary embolism

Author, Year | Most distal arterial level interpreted | Subgroup | N | TP^a^ | FP^b^ | TN^c^ | FN^d^ | Sensitivity % [95% CI] | Specificity % [95% CIY] | Accuracy % [95% CI] | PPV % [95% CI] | NPV % [95% CI] | Prevalence %
Computed tomography
Remy-Jardin, 1992 | Segmental | | 42 | 18 | 1 | 23 | 0 | 100 [81–100] | 96 [79–100] | 98 [87–100] | 95 [74–100] | 100 [85–100] | 43
Blum, 1994 | Segmental | | 10 | 7 | 0 | 3 | 0 | 100 [59–100] | 100 [29–100] | 100 [69–100] | 100 [59–100] | 100 [29–100] | 70
Goodman, 1995 | Segmental | | 20 | 6 | 1 | 12 | 1 | 86 [42–100] | 92 [64–100] | 90 [68–99] | 86 [42–100] | 92 [64–100] | 35
| Subsegmental | | 20 | 7 | 1 | 8 | 4 | 64 [31–89] | 89 [52–100] | 75 [51–91] | 88 [47–100] | 67 [35–90] | 55
Remy-Jardin, 1996 | Segmental | All cases | 75 | 39 | 7 | 25 | 4 | 91 [78–97] | 78 [60–91] | 85 [75–92] | 85 [71–94] | 86 [68–96] | 57
| | Excluding inconclusive cases | 65 | 39 | 0 | 25 | 1 | 98 [87–100] | 100 [86–100] | 98 [92–100] | 100 [91–100] | 96 [80–100] | 62
Christiansen, 1997 | Segmental | | 70 | 17 | 2 | 49 | 2 | 89 [67–99] | 96 [87–100] | 94 [86–98] | 89 [67–99] | 96 [87–100] | 27
Drucker, 1998 | Segmental | Inexperienced readers | 47 | 9 | 6 | 26 | 6 | 60 [32–84] | 81 [64–93] | 74 [60–86] | 60 [32–84] | 81 [64–93] | 32
| | Experienced readers | 47 | 8 | 1 | 31 | 7 | 53 [27–79] | 97 [84–100] | 83 [69–92] | 89 [52–100] | 82 [66–92] | 32
Qanadli, 2000 | Subsegmental | All cases | 157 | 56 | 6 | 89 | 6 | 90 [80–96] | 94 [87–98] | 92 [87–96] | 90 [80–96] | 94 [87–98] | 39
| | Excluding inconclusive cases | 151 | 56 | 3 | 89 | 3 | 95 [86–99] | 97 [91–99] | 96 [92–99] | 95 [86–99] | 97 [91–99] | 39
Velmahos, 2001 | Subsegmental | | 22 | 5 | 2 | 9 | 6 | 45 [17–77] | 82 [48–98] | 64 [41–83] | 71 [29–96] | 60 [32–84] | 50
Magnetic Resonance Imaging
Grist, 1993 | All cases | Referred for PA | 14 | 6 | 3 | 5 | 0 | 100 | 62 | 79 | 67 | 100 | 43
Erdman, 1994 | Segmental | All cases | 63 | 31 | 3 | 26 | 4 | 88 | 90 | 90 | 91 | 87 | 55
Loubeyre, 1994 | Segmental | All cases | 23 | 10 | 0 | 11 | 2 | 83 | 100 | 91 | 100 | 85 | 52
Meaney, 1997 | Segmental | All cases | 30 | 8 | 1 | 21 | 0 | 100 | 95 | 97 | 89 | 100 | 27
Berthezene, 1999 | Segmental | All cases | 24 | | | | | 69 | 91
Gupta, 1999 | Segmental | All cases | 36 | 11 | 2 | 22 | 1 | 85 | 96 | 92 | 85 | 96 | 36
Oudkerk, 2001 | Segmental | All cases | 118 | 27 | 2 | 81 | 8 | 77 | 98 | 92 | 93 | 91 | 30

a TP=true positive

b FP=false positive

c TN=true negative

d FN=false negative