# Bibliography

Agnelli G. Treatment of venous thromboembolism: unfractionated heparin or low molecular weight heparins?. Haematologica. 1995;80(2 Suppl):78-83. [pmid: 7628776].
Agnelli G, Prandoni P, Santamaria M G, et al. Three months versus one year of oral anticoagulant therapy for idiopathic deep venous thrombosis. Warfarin Optimal Duration Italian Trial Investigators. N Engl J Med. 2001;345(3):165-9. [pmid: 11463010].
Anand A C, Jha S K, Saha A, et al. Thrombosis as a complication of extended stay at high altitude. Natl Med J India. 2001;14(4):197-201. [pmid: 11547523].
Anderson D R, Wells P S, Stiell I, et al. Management of patients with suspected deep vein thrombosis in the emergency department: combining use of a clinical diagnosis model with D-dimer testing. J Emerg Med. 2000;19(3):225-30. [pmid: 11033266].
Anderson D R, Wells P S, Stiell I, et al. Thrombosis in the emergency department: use of a clinical diagnosis model to safely avoid the need for urgent radiological investigation. Arch Intern Med. 1999;159(5):477-82. [pmid: 10074956].
Ascani A, Iorio A, Agnelli G. Withdrawal of warfarin after deep vein thrombosis: effects of a low fixed dose on rebound thrombin generation. Blood Coagul Fibrinolysis. 1999;10(5):291-5. [pmid: 10456621].
Aschwanden M, Labs K, Jeanneret C, et al. Can a D-dimer assay, alone or combined with structured clinical risk assessment, rule out deep venous thrombosis in symptomatic patients?. West J Med. 2001;174(4):255-6. [pmid: 11290681].
Aschwanden M, Labs K H, Jeanneret C, et al. The value of rapid D-dimer testing combined with structured clinical evaluation for the diagnosis of deep vein thrombosis. J Vasc Surg. 1999;30(5):929-35. [pmid: 10550192].
Autar R. Calculating patients' risk of deep vein thrombosis. Br J Nurs. 1998;7(1):7-12. [pmid: 9495950].
Autar R. Nursing assessment of clients at risk of deep vein thrombosis (DVT): the Autar DVT scale. J Adv Nurs. 1996;23(4):763-70. [pmid: 8675895].
Baarslag H J, van Beek E J, Koopman M M, et al. Prospective study of color duplex ultrasonography compared with contrast venography in patients suspected of having deep venous thrombosis of the upper extremities. Ann Intern Med. 2002;136(12):865-72. [pmid: 12069560].
Baldt M M, Zontsich T, Stumpflen A, et al. Deep venous thrombosis of the lower extremity: efficacy of spiral CT venography compared with conventional venography in diagnosis. Radiology. 1996;200(2):423-8. [pmid: 8685336].
Bankier A A, Janata K, Fleischmann D, et al. Severity assessment of acute pulmonary embolism with spiral CT: evaluation of two modified angiographic scores and comparison with clinical data. J Thorac Imaging. 1997;12(2):150-8. [pmid: 9179827].
Becker D M, Philbrick J T, Abbitt P L. Real-time ultrasonography for the diagnosis of lower extremity deep venous thrombosis. The wave of the future?. Arch Intern Med. 1989;149(8):1731-4. [pmid: 2669660].
Becker D M, Philbrick J T, Bachhuber T L, et al. D-dimer testing and acute venous thromboembolism. A shortcut to accurate diagnosis?. Arch Intern Med. 1996;156(9):939-46. [pmid: 8624174].
Belcaro G, Nicolaides A N, Cesarone M R, et al. Comparison of low-molecular-weight heparin, administered primarily at home, with unfractionated heparin, administered in hospital, and subcutaneous heparin, administered at home for deep-vein thrombosis. Angiology. 1999;50(10):781-7. [pmid: 10535716].
Berlin J. Does blinding of readers affect the results of meta-analyses?. Lancet. 1997;350:185-6. [pmid: 9250191].
Berthezene Y, Croisille P, Wiart M, et al. Prospective comparison of MR lung perfusion and lung scintigraphy. J Magn Reson Imaging. 1999;9(1):61-8. [pmid: 10030651].
Bettmann M A, Boxt L M, Gomes A S, et al. Acute chest pain--suspected pulmonary embolism. American College of Radiology. ACR Appropriateness Criteria. Radiology. 2000;215(Suppl):15-21. [pmid: 11037399].
Bick R L. Current status of thrombosis: a multidisciplinary medical issue and major American health problem-beyond the year 2000. Clin Appl Thromb Hemost. 2002;3:1-5. [pmid: 11991236].
Birdwell B G, Raskob G E, Whitsett T L, et al. The clinical validity of normal compression ultrasonography in outpatients suspected of having deep venous thrombosis. Ann Intern Med. 1998;128(1):1-7. [pmid: 9424975].
Blachere H, Latrabe V, Montaudon M, et al. Pulmonary embolism revealed on helical CT angiography: comparison with ventilation-perfusion radionuclide lung scanning. AJR Am J Roentgenol. 2000;174(4):1041-7. [pmid: 10749247].
Blum A G, Delfau F, Grignon B, et al. Spiral-computed tomography versus pulmonary angiography in the diagnosis of acute massive pulmonary embolism. Am J Cardiol. 1994;74(1):96-8. [pmid: 8017318].
Boccalon H, Elias A, Chale J J, et al. Clinical outcome and cost of hospital vs home treatment of proximal deep vein thrombosis with a low-molecular-weight heparin: the Vascular Midi-Pyrenees study. Arch Intern Med. 2000;160(12):1769-73. [pmid: 10871969].
Boneu B. Glycosaminoglycans: clinical use. Semin Thromb Hemost. 1996;22(2):209-12. [pmid: 8807719].
Boneu B. Low molecular weight heparin therapy: is monitoring needed?. Thromb Haemost. 1994;72(3):330-4. [pmid: 7855780].
Bounameaux H, de Moerloose P, Perrier A, et al. Plasma measurement of D-dimer as diagnostic aid in suspected venous thromboembolism: an overview. Thromb Haemost. 1994;71(1):1-6. [pmid: 8165626].
Brandjes D P, Heijboer H, Buller H R, et al. Acenocoumarol and heparin compared with acenocoumarol alone in the initial treatment of proximal-vein thrombosis. N Engl J Med. 1992;327(21):1485-9. [pmid: 1406880].
Brewer D. Should low-molecular-weight heparins replace unfractionated heparin as the agent of choice for adults with deep venous thrombosis?. J Fam Pract. 1998;47(3):185-92. [pmid: 9752370].
Brill-Edwards P, Lee A. D-dimer testing in the diagnosis of acute venous thromboembolism. Thromb Haemost. 1999;82(2):688-94. [pmid: 10605769].
Brown J. Assessment of pretest risk for venous thromboembolic disease. Emerg Med Clin North Am. 2001;19(4):861-8. [pmid: 11762275].
Chan W S, Ray J G. Low molecular weight heparin use during pregnancy: issues of safety and practicality. Obstet Gynecol Surv. 1999;54(10):649-54. [pmid: 10511964].
Christiansen F. Diagnostic imaging of acute pulmonary embolism. Acta Radiol Suppl. 1997;410:1-33. [pmid: 9105183].
Clancy C M, Centor R M, Campbell M S, et al. Rational decision making based on history: adult sore throats. J Gen Intern Med. 1988;3(3):213-7. [pmid: 3288726].
Cogo A, Lensing A W, Wells P, et al. Noninvasive objective tests for the diagnosis of clinically suspected deep-vein thrombosis. Haemostasis. 1995;25(12):27-39. [pmid: 7896220].
Constans J, Nelzy M L, Salmi L R, et al. Clinical prediction of lower limb deep vin thrombosis in symptomatic hospitalized patients. Thromb Haemost. 2001;86:985-90. [pmid: 11686356].
Cook D J, Sackett D L, Spitzer W O. Methodologic guidelines for systematic reviews of randomized control trials in health care from the Potsdam Consultation on Meta-Analysis. J Clin Epidemiol. 1995;48(1):167-71. [pmid: 7853043].
Cornuz J, Ghali W A, Hayoz D, et al. Clinical prediction of Deep Venous Thrombosis using two risk assessment methods in combination with rapid quantitative d-dimer testing. Am J Med. 2002;112(3):198-203. [pmid: 11893346].
Criado E, Burnham C B. Predictive value of clinical criteria for the diagnosis of deep vein thrombosis. Surgery. 1997;122(3):578-83. [pmid: 9308616].
Crippa L, D'Angelo S V, Tomassini L, et al. The utility and cost-effectiveness of D-dimer measurements in the diagnosis of deep vein thrombosis. Haematologica. 1997;82(4):446-51. [pmid: 9299859].
Crowther M A, Roberts J, Roberts R, et al. Fibrinolytic variables in patients with recurrent venous thrombosis: a prospective cohort study. Thromb Haemost. 2001;85(3):390-4. [pmid: 11307802].
Cueto S M, Cavanaugh S H, Benenson R S, et al. Computed tomography scan versus ventilation-perfusion lung scan in the detection of pulmonary embolism. J Emerg Med. 2001;21(2):155-64. [pmid: 11489406].
Dauzat M, Laroche J P, Deklunder G, et al. Diagnosis of acute lower limb deep venous thrombosis with ultrasound: trends and controversies. J Clin Ultrasound. 1997;25(7):343-58. [pmid: 9282799].
de Lissovoy G, Yusen R D, Spiro T E, et al. Cost for inpatient care of venous thrombosis: a trial of enoxaparin vs standard heparin. Arch Intern Med. 2000;160(20):3160-5. [pmid: 11074747].
de Maat M P, Meijer P, Nieuwenhuizen W, et al. Performance of semiquantitative and quantitative D-dimer assays in the ECAT external quality assessment program. Semin Thromb Hemost. 2000;26(6):625-30. [pmid: 11140799].
Deitcher S R. Overview of enoxaparin in the treatment of deep vein thrombosis. Am J Manag Care. 2000;6(20 Suppl):S1026-33. [pmid: 11484302].
Dempfle C, Schraml M, Besenthal I, et al. Multicentre evaluation of a new point-of-care test for the quantitative determination of D-dimer. Clin Chim Acta. 2001;307(12):211-8. [pmid: 11369360].
Derksen R H, de Groot P G, Kater L, et al. Patients with antiphospholipid antibodies and venous thrombosis should receive long term anticoagulant treatment. Ann Rheum Dis. 1993;52(9):689-92. [pmid: 8239766].
Diamond P T, Macciocchi S N. Predictive power of clinical symptoms in patients with presumptive deep venous thrombosis. Am J Phys Med Rehabil. 1997;76(1):49-51. [pmid: 9036911].
Dolovich L R, Ginsberg J S, Douketis J D, et al. A meta-analysis comparing low-molecular-weight heparins with unfractionated heparin in the treatment of venous thromboembolism: examining some unanswered questions regarding location of treatment, product type, and dosing frequency. Arch Intern Med. 2000;160(2):181-8. [pmid: 10647756].
Drucker E A, Rivitz S M, Shepard J A, et al. Acute pulmonary embolism: assessment of helical CT for diagnosis. Radiology. 1998;209(1):235-41. [pmid: 9769837].
Dryjski M, O'Brien-Irr M S, Harris L M, et al. Evaluation of a screening protocol to exclude the diagnosis of deep venous thrombosis among emergency department patients. J Vasc Surg. 2001;34(6):1010-5. [pmid: 11743553].
Durieux P, Dhote R, Meyniard O, et al. D-dimer testing as the initial test for suspected pulmonary embolism. Appropriateness of prescription and physician compliance to guidelines. Thromb Res. 2001;101(4):261-6. [pmid: 11248287].
Dyke P C 2nd, Stevermer J J. Can a clinical rule accurately predict whether a patient has strep throat?. J Fam Pract. 2001;50(1):69. [pmid: 11195485].
Egermayer P, Town G I, Turner J G, et al. Usefulness of D-dimer, blood gas, and respiratory rate measurements for excluding pulmonary embolism. Thorax. 1998;53(10):830-4. [pmid: 10193368].
Eisenberg J M. Clinical economics. A guide to the economic analysis of clinical practices. JAMA. 1989;262(20):2879-86. [pmid: 2509745].
Eldor A, Rachmilewitz E A. The hypercoagulable state in thalassemia. Blood. 2002;99(1):36-43. [pmid: 11756150].
Erdman W A, Peshock R M, Redman H C, et al. Pulmonary embolism: comparison of MR images with radionuclide and angiographic studies. Radiology. 1994;190(2):499-508. [pmid: 8284406].
Estrada C A, Mansfield C J, Heudebert G R. Cost-effectiveness of low-molecular-weight heparin in the treatment of proximal deep vein thrombosis. J Gen Intern Med. 2000;15(2):108-15. [pmid: 10672114].
Fennerty A G, Dolben J, Thomas P, et al. A comparison of 3 and 6 weeks' anticoagulation in the treatment of venous thromboembolism. Clin Lab Haematol. 1987;9(1):17-21. [pmid: 3581712].
Ferretti G R, Bosson J L, Buffaz P D, et al. Acute pulmonary embolism: role of helical CT in 164 patients with intermediate probability at ventilation-perfusion scintigraphy and normal results at duplex US of the legs. Radiology. 1997;205(2):453-8. [pmid: 9356628].
Fiessinger J N, Lopez-Fernandez M, Gatterer E, et al. Once-daily subcutaneous dalteparin, a low molecular weight heparin, for the initial treatment of acute deep vein thrombosis. Thromb Haemost. 1996;76(2):195-9. [pmid: 8865530].
Fihn S D, McDonell M, Martin D, et al. Risk factors for complications of chronic anticoagulation. A multicenter study. Warfarin Optimized Outpatient Follow-up Study Group. Ann Intern Med. 1993;118(7):511-20. [pmid: 8280198].
Fowl RJ, Strothman GB, Blebea J, et al. Inappropriate use of venous duplex scans: an analysis of indications and results. J Vasc Surg 1996;23(5):881–5; discussion 885–6.
Fraser D G, Moody A R, Morgan P S, et al. Diagnosis of lower-limb deep venous thrombosis: a prospective blinded study of magnetic resonance direct thrombus imaging. Ann Intern Med. 2002;136(2):89-98. [pmid: 11790060].
Fraser J D, Anderson D R. Deep venous thrombosis: recent advances and optimal investigation with US. Radiology. 1999;211(1):9-24. [pmid: 10189448].
Fric M, Pechan J, Mikulecky M, et al. Evaluation of clinical signs and symptoms in active deep venous thrombosis of the calf. Cor Vasa. 1985;27(5):346-52. [pmid: 4075799].
Funfsinn N, Caliezi C, Biasiutti F D, et al. Rapid D-dimer testing and pre-test clinical probability in the exclusion of deep venous thrombosis in symptomatic outpatients. Blood Coagul Fibrinolysis. 2001;12(3):165-70. [pmid: 11414629].
Galle C, Papazayan J-P, Miron M-J, et al. Prediction of pulmonary embolism extent by clinical findings, d-dimer level and deep vein thrombosis shown by ultrasound. Thromb Haemost. 2001;86:1156-60. [pmid: 11816700].
Galvani M, Ferrini D, Ghezzi F, et al. Cardiac markers and risk stratification: an integrated approach. Clin Chim Acta. 2001;311(1):9-17. [pmid: 11557247].
Garbutt J C, West S L, Carey T S, et al. Pharmacological treatment of alcohol dependence: a review of the evidence. JAMA. 1999;281(14):1318-25. [pmid: 10208148].
Garg K, Welsh C H, Feyerabend A J, et al. Pulmonary embolism: diagnosis with spiral CT and ventilation-perfusion scanning--correlation with pulmonary angiographic results or clinical outcome. Radiology. 1998;208(1):201-8. [pmid: 9646814].
Gebo KA, Jenckes MW, Chander G, Torbenson MS, Ghanem KG, Herlong HF, Sulkowski MS, El-Kamery S, Harris KA, Guedelhoefer OC, and Bass EB. Evidence report on management of chronic hepatitis C. Web Page. Available at: “Health Care: Evidence-based Practice Subdirectory Page”, URL: http://www.ahrq.gov/clinic/epcix.htm.
Geerts W H, Heit J A, Clagett G P, et al. Prevention of venous thromboembolism. Chest. 2001;119(1 Suppl):132S-75S. [pmid: 11157647].
Ghali W A, Cornuz J, Perrier A. New methods for estimating pretest probability in the diagnosis of pulmonary embolism. Curr Opin Pulm Med. 2001;7(5):349-53. [pmid: 11584188].
Ginsberg J S, Kearon C, Douketis J, et al. The use of D-dimer testing and impedance plethysmographic examination in patients with clinical indications of deep vein thrombosis. Arch Intern Med. 1997;157(10):1077-81. [pmid: 9164373].
Gold MR, Siegal JE, Russell LB, Weinstein MD, Eds; Cost-Effectiveness in Health and Medicine. New York: Oxford Press ; 1996.
Goldhaber S Z. Unsolved issues in the treatment of pulmonary embolism. Thromb Res. 2001;103(6):V245-55. [pmid: 11567662].
Goodman L R, Curtin J J, Mewissen M W, et al. Detection of pulmonary embolism in patients with unresolved clinical and scintigraphic diagnosis: helical CT versus angiography. AJR Am J Roentgenol. 1995;164(6):1369-74. [pmid: 7754875].
Gottlieb R H, Widjaja J, Tian L, et al. Calf sonography for detecting deep venous thrombosis in symptomatic patients: experience and review of the literature. J Clin Ultrasound. 1999;27(8):415-20. [pmid: 10477882].
Gottsater A, Berg A, Centergard J, et al. Clinically suspected pulmonary embolism: is it safe to withhold anticoagulation after a negative spiral CT?. Eur Radiol. 2001;11(1):65-72. [pmid: 11194920].
Gould M K, Dembitzer A D, Sanders G D, et al. Low-molecular-weight heparins compared with unfractionated heparin for treatment of acute deep venous thrombosis. A cost-effectiveness analysis. Ann Intern Med. 1999;130(10):789-99. [pmid: 10366368].
Grau E, Tenias J M, Real E, et al. Home treatment of deep venous thrombosis with low molecular weight heparin: Long-term incidence of recurrent venous thromboembolism. Am J Hematol. 2001;67(1):10-4. [pmid: 11279651].
Green D, Hirsh J, Heit J, et al. Low molecular weight heparin: a critical analysis of clinical trials. Pharmacol Rev. 1994;46(1):89-109. [pmid: 8190751].
Grifoni S, Olivotto I, Cecchini P, et al. Utility of an integrated clinical, echocardiographic, and venous ultrasonographic approach for triage of patients with suspected pulmonary embolism. Am J Cardiol. 1998;82(10):1230-5. [pmid: 9832100].
Grist T M, Sostman H D, MacFall J R, et al. Pulmonary angiography with MR imaging: preliminary clinical experience. Radiology. 1993;189(2):523-30. [pmid: 8210385].
Groce JB 3rd. Treatment of deep vein thrombosis using low-molecular-weight heparins. Am J Manag Care 2001;7(17 Suppl):S510–5; discussion S515–23.
Gupta A, Frazer C K, Ferguson J M, et al. Acute pulmonary embolism: diagnosis with MR angiography. Radiology. 1999;210(2):353-9. [pmid: 10207414].
Handoll HHG, Farrar MJ, McBirnie J, et al. Heparin, low molecular weight heparin and physical methods for preventing deep vein thrombosis and pulmonary embolism following surgery for hip fractures (Cochrane Review). The Cochrane Library, Issue 4 2001.
Hanley J A, McNeil B J. The meaning and use of the area under a receiver operating characteristic (ROC) curve. Radiology. 1982;143(1):29-36. [pmid: 7063747].
Hansson P O, Sorbo J, Eriksson H. Recurrent venous thromboembolism after deep vein thrombosis: incidence and risk factors. Arch Intern Med. 2000;160(6):769-74. [pmid: 10737276].
Harrison L, McGinnis J, Crowther M, et al. Assessment of outpatient treatment of deep-vein thrombosis with low-molecular-weight heparin. Arch Intern Med. 1998;158(18):2001-3. [pmid: 9778199].
Harvey R T, Gefter W B, Hrung J M, et al. Accuracy of CT angiography versus pulmonary angiography in the diagnosis of acute pulmonary embolism: evaluation of the literature with summary ROC curve analysis. Acad Radiol. 2000;7(10):786-97. [pmid: 11048876].
Heim S W, Philbrick J T. D-dimer assays for deep venous thrombosis: a systematic review. J Gen Intern Med. 2002;17(Suppl 1):112. [pmid: 11841526].
Heit J A, Mohr D N, Silverstein M D, et al. Predictors of recurrence after deep vein thrombosis and pulmonary embolism: a population-based cohort study. Arch Intern Med. 2000;160(6):761-8. [pmid: 10737275].
Hettiarachchi R J, Prins M H, Lensing A W, et al. Low molecular weight heparin versus unfractionated heparin in the initial treatment of venous thromboembolism. Curr Opin Pulm Med. 1998;4(4):220-5. [pmid: 10813237].
Hirsh J, Siragusa S, Cosmi B, et al. Low molecular weight heparins (LMWH) in the treatment of patients with acute venous thromboembolism. Thromb Haemost. 1995;74(1):360-3. [pmid: 8578485].
Hobson R W 2nd, Mintz B L, Jamil Z, et al. Diagnosis of acute deep venous thrombosis. Surg Clin North Am. 1990;70(1):143-57. [pmid: 2406964].
Holmgren K, Andersson G, Fagrell B, et al. One-month versus six-month therapy with oral anticoagulants after symptomatic deep vein thrombosis. Acta Med Scand. 1985;218:279-84. [pmid: 3907286].
Howard P A. Dalteparin: a low-molecular-weight heparin. Ann Pharmacother. 1997;31(2):192-203. [pmid: 9034422].
Hull R D, Pineo G F, Raskob G E. The economic impact of treating deep vein thrombosis with low-molecular-weight heparin: outcome of therapy and health economy aspects. Haemostasis. 1998;28(Suppl 3):8-16. [pmid: 10069757].
Hull R D, Raskob G E, Brant R F, et al. Low-molecular-weight heparin vs heparin in the treatment of patients with pulmonary embolism. American-Canadian Thrombosis Study Group. Arch Intern Med. 2000;160(2):229-36. [pmid: 10647762].
Hull R D, Raskob G E, Pineo G F, et al. Subcutaneous low-molecular-weight heparin compared with continuous intravenous heparin in the treatment of proximal-vein thrombosis. N Engl J Med. 1992;326(15):975-82. [pmid: 1545850].
Hull R D, Raskob G E, Rosenbloom D, et al. Treatment of proximal vein thrombosis with subcutaneous low-molecular-weight heparin vs intravenous heparin. An economic perspective. Arch Intern Med. 1997;157(3):289-94. [pmid: 9040295].
Hunt D. Low-molecular-weight heparins in clinical practice. South Med J. 1998;91(1):2-10. [pmid: 9438394].
Huse D M, Cummins G, Taylor D C, et al. Outpatient treatment of venous thromboembolism with low-molecular-weight heparin: an economic evaluation. Am J Manag Care. 2002;8(1 Suppl):S10-6. [pmid: 11822346].
Hutten BA, Prins MH. Duration of treatment with vitamin K antagonists in symptomatic venous thromboembolism (Cochrane Review). The Cochrane Library, Issue 4 2001.
Hyers T M. Venous thromboembolism. Am J Respir Crit Care Med. 1999;159(1):1-14. [pmid: 9872811].
Hyers T M, Agnelli G, Hull R D, et al. Antithrombotic therapy for venous thromboembolic disease. Chest. 2001;119(1 Suppl):176S-93S. [pmid: 11157648].
Jadad A R, Moher M, Browman G P, et al. Systematic reviews and meta-analyses on treatment of asthma: critical evaluation. BMJ. 2000;320(7234):537-40. [pmcid: 27295]. [pmid: 10688558].
Janes S, Ashford N. Use of a simplified clinical scoring system and D-dimer testing can reduce the requirement for radiology in the exclusion of deep vein thrombosis by over 20%. Br J Haematol. 2001;112(4):1079-82. [pmid: 11298611].
Janssen M C, Wollersheim H, Verbruggen B, et al. Rapid D-dimer assays to exclude deep venous thrombosis and pulmonary embolism: current status and new developments. Semin Thromb Hemost. 1998;24(4):393-400. [pmid: 9763357].
Kahn S R, Joseph L, Abenhaim L, et al. Clinical prediction of deep vein thrombosis in patients with leg symptoms. Thromb Haemost. 1999;81(3):353-7. [pmid: 10102459].
Kearon C, Gent M, Hirsh J, et al. A comparison of three months of anticoagulation with extended anticoagulation for a first episode of idiopathic venous thromboembolism. N Engl J Med. 1999;340(12):901-7. [pmid: 10089183].
Kearon C, Ginsberg J S, Douketis J, et al. Management of suspected deep venous thrombosis in outpatients by using clinical assessment and a d-dimer testing. Ann Intern Med. 2001;135(2):108-11. [pmid: 11453710].
Kearon C, Julian J A, Newman T E, et al. Noninvasive diagnosis of deep venous thrombosis. McMaster Diagnostic Imaging Practice Guidelines Initiative. Ann Intern Med. 1998;128(8):663-77. [pmid: 9537941].
Khajuria A, Houston D S. Induction of monocyte tissue factor expression by homocysteine: a possible mechanism for thrombosis. Blood. 2000;96(3):966-72. [pmid: 10910911].
Kiil J, Moller J C. Ultrasound and clinical diagnosis of deep vein thrombosis of the leg. Acta Radiol Diagn (Stockh). 1979;20(2):292-8. [pmid: 495179].
Kline J A, Israel E G, Michelson E A, et al. Diagnostic accuracy of a bedside D-dimer assay and alveolar dead-space measurement for rapid exclusion of pulmonary embolism: a multicenter study. JAMA. 2001;285(6):761-8. [pmid: 11176914].
Kline J A, Kubin A K, Patel M M, et al. Alveolar dead space as a predictor of severity of pulmonary embolism. Acad Emerg Med. 2000;7(6):611-7. [pmid: 10905639].
Koopman M M, Prandoni P, Piovella F, et al. Treatment of venous thrombosis with intravenous unfractionated heparin administered in the hospital as compared with subcutaneous low-molecular-weight heparin administered at home. The Tasman Study Group. N Engl J Med. 1996;334(11):682-7. [pmid: 8594426].
Koster T, Rosendaal F R, Briet E, et al. John Hageman's factor and deep-vein thrombosis: Leiden thrombophilia Study. Br J Haematol. 1994;87(2):422-4. [pmid: 7947293].
Kovacs M J, Anderson D, Morrow B, et al. Outpatient treatment of pulmonary embolism with dalteparin. Thromb Haemost. 2000;83(2):209-11. [pmid: 10739374].
Kraaijenhagen R A, Lensing A W, Lijmer J G, et al. Diagnostic strategies for the management of patients with clinically suspected deep-vein thrombosis. Curr Opin Pulm Med. 1997;3(4):268-74. [pmid: 9262112].
Kraaijenhagen R A, Piovella F, Bernardi E, et al. Simplification of the diagnostic management of suspected deep vein thrombosis. Arch Intern Med. 2002;162(8):907-11. [pmid: 11966342].
Kuzo R S, Goodman L R. CT evaluation of pulmonary embolism: technique and interpretation. AJR Am J Roentgenol. 1997;169(4):959-65. [pmid: 9308445].
Labas P, Ohradka B, Cambal M. Could deep vein thrombosis be safely treated at home?. Bratisl Lek Listy. 2001;102(10):458-61. [pmid: 11802292].
Lagerstedt C, Olsson C G, Fagher B, et al. 99mTc plasmin in 394 consecutive patients with suspected deep venous thrombosis. Eur J Nucl Med. 1989;15(12):771-5. [pmid: 2533891].
Lagerstedt C I, Olsson C G, Fagher B O, et al. Need for long-term anticoagulant treatment in symptomatic calf-vein thrombosis. Lancet. 1985;2(8454):515-8. [pmid: 2863541].
Landefeld C S, McGuire E, Cohen A M. Clinical findings associated with acute proximal deep vein thrombosis: a basis for quantifying clinical judgment. Am J Med. 1990;88(4):382-8. [pmid: 2327426].
Leizorovicz A. Comparison of the efficacy and safety of low molecular weight heparins and unfractionated heparin in the initial treatment of deep venous thrombosis. An updated meta-analysis. Drugs. 1996;52(Suppl 7):30-7. [pmid: 9042557].
Leizorovicz A, Simonneau G, Decousus H, et al. Comparison of efficacy and safety of low molecular weight heparins and unfractionated heparin in initial treatment of deep venous thrombosis: a meta-analysis. BMJ. 1994;309(6950):299-304. [pmid: 8086867].
Lennox A F, Delis K T, Serunkuma S, et al. Combination of a clinical risk assessment score and rapid whole blood D-dimer testing in the diagnosis of deep vein thrombosis in symptomatic patients. J Vasc Surg. 1999;30(5):794-803. [pmid: 10550176].
Lensing A W, Prins M H, Davidson B L, et al. Treatment of deep venous thrombosis with low-molecular-weight heparins. A meta-analysis. Arch Intern Med. 1995;155(6):601-7. [pmid: 7887755].
Levine M, Gent M, Hirsh J, et al. A comparison of low-molecular-weight heparin administered primarily at home with unfractionated heparin administered in the hospital for proximal deep-vein thrombosis. N Engl J Med. 1996;334(11):677-81. [pmid: 8594425].
Levine M N, Hirsh J, Gent M, et al. Optimal duration of oral anticoagulant therapy: a randomized trial comparing four weeks with three months of warfarin in patients with proximal deep vein thrombosis. Thromb Haemost. 1995;74(2):606-11. [pmid: 8584992].
Lindmarker P, Holmstrom M. Use of low molecular weight heparin (dalteparin), once daily, for the treatment of deep vein thrombosis. A feasibility and health economic study in an outpatient setting. Swedish Venous Thrombosis Dalteparin Trial Group. J Intern Med. 1996;240(6):395-401. [pmid: 9010387].
Lindmarker P, Schulman S. The risk of ipsilateral versus contralateral recurrent deep vein thrombosis in the leg. The DURAC Trial Study Group. J Intern Med. 2000;247(5):601-6. [pmid: 10810000].
Lloyd A C, Aitken J A, Hoffmeyer U K, et al. Economic evaluation of the use of nadroparin in the treatment of deep-vein thrombosis in Switzerland. Ann Pharmacother. 1997;31(78):842-6. [pmid: 9220041].
Lohr J M, Hasselfeld K A, Byrne M P, et al. Does the asymptomatic limb harbor deep venous thrombosis?. Am J Surg. 1994;168(2):184-7. [pmid: 8053523].
Lorut C, Ghossains M, Horellou M H, et al. A noninvasive diagnostic strategy including spiral computed tomography in patients with suspected pulmonary embolism. Am J Respir Crit Care Med. 2000;162(4 Pt 1):1413-8. [pmid: 11029354].
Loubeyre P, Revel D, Douek P, et al. Dynamic contrast-enhanced MR angiography of pulmonary embolism: comparison with pulmonary angiography. AJR Am J Roentgenol. 1994;162(5):1035-9. [pmid: 8165977].
Low-molecular-weight heparin in the treatment of patients with venous thromboembolism. The Columbus Investigators. N Engl J Med 1997;337(10):657–62.
Mandelli V, Schmid C, Zogno C, et al. “False negatives” and “false positives” in acute pulmonary embolism: a clinical-postmortem comparison. Cardiologia. 1997;42(2):205-10. [pmid: 9090162].
Mant M J, O'Brien B D, Russell D B. Diagnostic leg scanning for deep venous thrombosis in the recently heparinized patient. Arch Intern Med. 1981;141(13):1757-60. [pmid: 7032439].
Marder V J, Zareba W, Horan J T, et al. Automated latex agglutination and ELISA testing yield equivalent D-dimer results in patients with recent myocardial infarction. THROMBO Research Investigators. Thromb Haemost. 1999;82(5):1412-6. [pmid: 10595629].
Martineau P, Tawil N. Low-molecular-weight heparins in the treatment of deep-vein thrombosis. Ann Pharmacother 1998;32(5):588–98, 601.
Mathis G, Bitschnau R, Gehmacher O, et al. Chest ultrasound in diagnosis of pulmonary embolism in comparison to helical CT. Ultraschall Med. 1999;20(2):54-9. [pmid: 10407975].
Mavromatis B H, Kessler C M. D-dimer testing: the role of the clinical laboratory in the diagnosis of pulmonary embolism. J Clin Pathol. 2001;54(9):664-8. [pmid: 11533069].
Meaney J F, Weg J G, Chenevert T L, et al. Diagnosis of pulmonary embolism with magnetic resonance angiography. N Engl J Med. 1997;336(20):1422-7. [pmid: 9145679].
Meyer G, Brenot F, Pacouret G, et al. Subcutaneous low-molecular-weight heparin fragmin versus intravenous unfractionated heparin in the treatment of acute non massive pulmonary embolism: an open randomized pilot study. Thromb Haemost. 1995;74(6):1432-5. [pmid: 8772215].
Michiels J J. Rational diagnosis of deep vein thrombosis (RADIA DVT) in symptomatic outpatients with suspected DVT: simplification and improvement of decision rule analysis for the exclusion and diagnosis of DVT by the combined use of a simple clinical model, a rapid sensitive D-dimer test and compression ultrasonography (CUS). Semin Thromb Hemost. 1998;24(4):401-7. [pmid: 9763358].
Michiels J J, Freyburger G, van der Graaf F, et al. Strategies for the safe and effective exclusion and diagnosis of deep vein thrombosis by the sequential use of clinical score, D-dimer testing, and compression ultrasonography. Semin Thromb Hemost. 2000;26(6):657-67. [pmid: 11140802].
Midgette A S, Stukel T A, Littenberg B. A meta-analytic method for summarizing diagnostic test performances: receiver-operating-characteristic-summary point estimates. Med Decis Making. 1993;13(3):253-7. [pmid: 8412556].
Miniati M. Clinical assessment in the diagnosis of pulmonary embolism. Monaldi Arch Chest Dis. 2000;55(6):491-4. [pmid: 11272638].
Miron M J, Perrier A, Bounameaux H. Clinical assessment of suspected deep vein thrombosis: comparison between a score and empirical assessment. J Intern Med. 2000;247(2):249-54. [pmid: 10692088].
Miron M J, Perrier A, Bounameaux H, et al. Contribution of noninvasive evaluation to the diagnosis of pulmonary embolism in hospitalized patients. Eur Respir J. 1999;13(6):1365-70. [pmid: 10445613].
Moher D, Cook D J, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. QUOROM Group. Br J Surg. 2000;87(11):1448-54. [pmid: 11091231].
Mohr D N, Silverstein M D, Heit J A, et al. The venous stasis syndrome after deep venous thrombosis or pulmonary embolism: a population-based study. Mayo Clin Proc. 2000;75(12):1249-56. [pmid: 11126832].
Monreal M, Moreno V, Martorell A, et al. Predicting pulmonary embolism in postoperative patients with deep venous thrombosis of lower limbs. Ann Vasc Surg. 1987;1(4):421-5. [pmid: 3504355].
Moreira KECS, Castro AA, Atallah AN. Subcutaneous versus intravenous unfractioned heparin for treatment of deep vein thrombosis/pulmonary embolism (Protocol for a Cochrane Review). The Cochrane Library, Issue 4 2001.
Moser K M, Fedullo P F. Imaging of venous thromboemboli with labeled platelets. Semin Nucl Med. 1984;14(3):188-97. [pmid: 6382616].
Moser K M, Fedullo P F, LitteJohn J K, et al. Frequent asymptomatic pulmonary embolism in patients with deep venous thrombosis. JAMA. 1994;271(3):223-5. [pmid: 8277550].
Moses L E, Shapiro D, Littenberg B. Combining independent studies of a diagnostic test into a summary ROC curve: data-analytic approaches and some additional considerations. Stat Med. 1993;12(14):1293-316. [pmid: 8210827].
Mullins M D, Becker D M, Hagspiel K D, et al. The role of spiral volumetric computed tomography in the diagnosis of pulmonary embolism. Arch Intern Med. 2000;160(3):293-8. [pmid: 10668830].
Mustafa B. , Rathbun S. , Whitsett T. , Raskob G. Sensitivity and Specificity of Ultrasonography in the Diagnosis of Upper Extremity Deep Vein Thrombosis. 2002;162:401–404.
Nilsson T, Mare K, Carlsson A. Value of structured clinical and scintigraphic protocols in acute pulmonary embolism. J Intern Med. 2001;250(3):213-8. [pmid: 11555125].
Noble S, Spencer C M. Enoxaparin. A review of its clinical potential in the management of coronary artery disease. Drugs. 1998;56(2):259-72. [pmid: 9711450].
Nypaver T J, Shepard A D, Kiell C S, et al. Outpatient duplex scanning for deep vein thrombosis: parameters predictive of a negative study result. J Vasc Surg. 1993;18(5):821-6. [pmid: 8230569].
O'Brien B, Levine M, Willan A, et al. Economic evaluation of outpatient treatment with low-molecular-weight heparin for proximal vein thrombosis. Arch Intern Med. 1999;159(19):2298-304. [pmid: 10547169].
O'Shaughnessy A M, Fitzgerald D E. An audit of the clinical and sub-clinical changes in the first year following an acute deep vein thrombosis. Int Angiol. 2001;20(2):141-7. [pmid: 11533522].
O'Shaughnessy D F, Tovey C, Miller A L, et al. Outpatient management of deep vein thrombosis. J Accid Emerg Med. 1998;15(5):292-3. [pmid: 9785152].
O'Sullivan E F. Duration of anticoagulant therapy in venous thrombo--embolism. Med J Aust. 1972;2(20):1104-7. [pmid: 4640564].
Oger E, Leroyer C, Le Moigne E, et al. The value of a risk factor analysis in clinically suspected deep venous thrombosis. Respiration. 1997;64(5):326-30. [pmid: 9311047].
Optimum duration of anticoagulation for deep-vein thrombosis and pulmonary embolism. Research Committee of the British Thoracic Society. Lancet 1992;340(8824):873–6.
Ost D, Rozenshtein A, Saffran L, et al. The negative predictive value of spiral computed tomography for the diagnosis of pulmonary embolism in patients with nondiagnostic ventilation-perfusion scans. Am J Med. 2001;110(1):16-21. [pmid: 11152860].
Oudkerk M, van Beek E J R, Wielopolski P, et al. Comparison of contrast-enhanced magnetic resonance angiography and conventional pulmonary angiography for the diagnosis of pulmonary embolism: a prospective study. Lancet. 2002;359:1643-47. [pmid: 12020524].
Oxman A D, Guyatt G H. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44(11):1271-8. [pmid: 1834807].
Patil S, Henry J W, Rubenfire M, et al. Neural network in the clinical diagnosis of acute pulmonary embolism. Chest. 1993;104(6):1685-9. [pmid: 8252942].
Pearson S D, Blair R, Halpert A, et al. An outpatient program to treat deep venous thrombosis with low-molecular-weight heparin. Eff Clin Pract. 1999;2(5):210-7. [pmid: 10623053].
Perrier A, Desmarais S, Miron M J, et al. Non-invasive diagnosis of venous thromboembolism in outpatients. Lancet. 1999;353(9148):190-5. [pmid: 9923874].
Perrier A, Howarth N, Didier D, et al. Performance of helical computed tomography in unselected outpatients with suspected pulmonary embolism. Ann Intern Med. 2001;135:88-97. [pmid: 11453707].
Petitti D B, Strom B L, Melmon K L. Duration of warfarin anticoagulant therapy and the probabilities of recurrent thromboembolism and hemorrhage. Am J Med. 1986;81(2):255-9. [pmid: 3740082].
Petitti DB. Meta-Analysis, Decision-Analysis and Cost-Effectiveness in Health and Medicine. New York: Oxford Press; 1996.
Philbrick J T, Heim S W. Research on D-dimer tests for deep venous thrombosis: the gold standard and bias in negative predictive value. J Gen Intern Med. 2002;17(Suppl 1):117. [pmid: 11841527].
Pinede L, Cucherat M, Duhaut P, et al. Optimal duration of anticoagulant therapy after an episode of venous thromboembolism. Blood Coagul Fibrinolysis. 2000;11(8):701-7. [pmid: 11132647].
Pinede L, Ninet J, Duhaut P, et al. Comparison of 3 and 6 months of oral anticoagulant therapy after a first episode of proximal deep vein thrombosis or pulmonary embolism and comparison of 6 and 12 weeks of therapy after isolated calf deep vein thrombosis. Circulation. 2001;103(20):2453-60. [pmid: 11369685].
Pini M, Marchini L, Giordano A. Diagnostic strategies in venous thromboembolism. Haematologica. 1999;84(6):535-40. [pmid: 10366798].
Piotrowski J J, Alexander J J, Brandt C P, et al. Is deep vein thrombosis surveillance warranted in high-risk trauma patients?. Am J Surg. 1996;172(2):210-3. [pmid: 8795534].
Poulsen S H, Noer I, Moller J E, et al. Clinical outcome of patients with suspected pulmonary embolism. A follow-up study of 588 consecutive patients. J Intern Med. 2001;250(2):137-43. [pmid: 11489063].
Prandoni P, Lensing A W, Buller H R, et al. Comparison of subcutaneous low-molecular-weight heparin with intravenous standard heparin in proximal deep-vein thrombosis. Lancet. 1992;339(8791):441-5. [pmid: 1346817].
Qanadli S D, Hajjam M E, Mesurolle B, et al. Pulmonary embolism detection: prospective evaluation of dual-section helical CT versus selective pulmonary arteriography in 157 patients. Radiology. 2000;217(2):447-55. [pmid: 11058644].
Rathbun S W, Raskob G E, Whitsett T L. Sensitivity and specificity of helical computed tomography in the diagnosis of pulmonary embolism: a systematic review. Ann Intern Med. 2000;132(3):227-32. [pmid: 10651604].
Reber G, Bounameaux H, Perrier A, et al. Performances of a new, automated latex assay for the exclusion of venous thromboembolism. Blood Coagul Fibrinolysis. 2001;12(3):217-20. [pmid: 11414638].
Remy-Jardin M, Remy J, Deschildre F, et al. Diagnosis of pulmonary embolism with spiral CT: comparison with pulmonary angiography and scintigraphy. Radiology. 1996;200(3):699-706. [pmid: 8756918].
Remy-Jardin M, Remy J, Wattinne L, et al. Central pulmonary thromboembolism: diagnosis with spiral volumetric CT with the single-breath-hold technique--comparison with pulmonary angiography. Radiology. 1992;185(2):381-7. [pmid: 1410342].
Reprinted with permission from Elsevier Science. (Lancet 1995, 345:1328).
Ridker P M, Vaughan D E, Stampfer M J, et al. Baseline fibrinolytic state and the risk of future venous thrombosis. A prospective study of endogenous tissue-type plasminogen activator and plasminogen activator inhibitor. Circulation. 1992;85(5):1822-7. [pmid: 1572039].
Rissanen V, Suomalainen O, Karjalainen P, et al. Screening for postoperative pulmonary embolism on the basis of clinical symptomatology, routine electrocardiography and plain chest radiography. Acta Med Scand. 1984;215(1):13-9. [pmid: 6695561].
Roberts H R, Stinchcombe T E, Gabriel D A. The dysfibrinogenaemias. Br J Haematol. 2001;114(2):249-57. [pmid: 11529842].
Robinson K S, Anderson D R, Gross M, et al. Accuracy of screening compression ultrasonography and clinical examination for the diagnosis of deep vein thrombosis after total hip or knee arthroplasty. Can J Surg. 1998;41(5):368-73. [pmid: 9793503].
Rocha E, Martinez-Gonzalez M A, Montes R, et al. Do the low molecular weight heparins improve efficacy and safety of the treatment of deep venous thrombosis? A meta-analysis. Haematologica. 2000;85(9):935-42. [pmid: 10980632].
Rodger M, Bredeson C, Wells P S, et al. Cost-effectiveness of low-molecular-weight heparin and unfractionated heparin in treatment of deep vein thrombosis. CMAJ. 1998;159(8):931-8. [pmid: 9834718].
Rodger M, Makropoulos D, Turek M, et al. Diagnostic value of the electrocardiogram in suspected pulmonary embolism. Am J Cardiol 2000;86(7):807–9, A10.
Rooke T W, Osmundson P J. Heparin and the in-hospital management of deep venous thrombosis: cost considerations. Mayo Clin Proc. 1986;61(3):198-204. [pmid: 3945121].
Rosen M P, Sheiman R G, Weintraub J, et al. Compression sonography in patients with indeterminate or low-probability lung scans: lack of usefulness in the absence of both symptoms of deep-vein thrombosis and thromboembolic risk factors. AJR Am J Roentgenol. 1996;166(2):285-9. [pmid: 8553931].
Rowe B H, Lang E S. Evidence-based emergency medicine/systematic review abstract. Use of low molecular weight heparins in patients with acute venous thromboembolism. Ann Emerg Med. 2002;39(5):555-7. [pmid: 11973565].
Sacks H S, Berrier J, Reitman D, et al. Meta-analyses of randomized controlled trials. N Engl J Med. 1987;316(8):450-5. [pmid: 3807986].
Safriel Y, Zinn H. CT pulmonary angiography in the detection of pulmonary emboli: a meta- analysis of sensitivities and specificities. Clin Imaging. 2002;26(2):101-5. [pmid: 11852216].
Samama M M. [Prevention of venous thromboembolic disease]. Rev Prat. 1996;46(10):1245-53. [pmid: 8763680].
Sanson B J, Lijmer J G, Mac Gillavry M R, et al. Comparison of a clinical probability estimate and two clinical models in patients with suspected pulmonary embolism. ANTELOPE-Study Group. Thromb Haemost. 2000;83(2):199-203. [pmid: 10739372].
Sarasin F P, Bounameaux H. Decision analysis model of prolonged oral anticoagulant treatment in factor V Leiden carriers with first episode of deep vein thrombosis. BMJ. 1998;316(7125):95-9. [pmid: 9462312].
Sarasin F P, Bounameaux H. Duration of oral anticoagulant therapy after proximal deep vein thrombosis: a decision analysis. Thromb Haemost. 1994;71(3):286-91. [pmid: 8029791].
Schein OD, Friedman DS, Fleisher LA, et al. Anesthesia Managment During Cataract Surgery. Evidence Report/Technology Assessment No. 16 (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-097-0006.) AHRQ Publication No. 01-E017. Rockville, MD: Agency for Healthcare Research and Quality; 2001
Schraibman IG, Milne AA, Royle EM. Home versus in-patient treatment for deep vein thrombosis (Cochrane Review). Cochrane Database Syst Rev 2001;2:CD003076.
Schulman S. Quality of oral anticoagulant control and treatment in Sweden. Duration of Anticoagulation (DURAC) Trial Study Group. J Intern Med. 1994;236(2):143-52. [pmid: 8046313].
Schulman S, Granqvist S, Holmstrom M, et al. The duration of oral anticoagulant therapy after a second episode of venous thromboembolism. The Duration of Anticoagulation Trial Study Group. N Engl J Med. 1997;336(6):393-8. [pmid: 9010144].
Schulman S, Lockner D, Juhlin-Dannfelt A. The duration of oral anticoagulation after deep vein thrombosis. A randomized study. Acta Med Scand. 1985;217(5):547-52. [pmid: 3895828].
Schulman S, Rhedin A S, Lindmarker P, et al. A comparison of six weeks with six months of oral anticoagulant therapy after a first episode of venous thromboembolism. Duration of Anticoagulation Trial Study Group. N Engl J Med. 1995;332(25):1661-5. [pmid: 7760866].
Schulman S, Svenungsson E, Granqvist S. Anticardiolipin antibodies predict early recurrence of thromboembolism and death among patients with venous thromboembolism following anticoagulant therapy. Duration of Anticoagulation Study Group. Am J Med. 1998;104(4):332-8. [pmid: 9576405].
Seligsohn U, Lubetsky A. Genetic susceptibility to venous thrombosis. N Engl J Med. 2001;344(16):1222-31. [pmid: 11309638].
Seo P, Locke CF. Current and potential uses of low molecular weight heparin: a review and an economic analysis. Am J Manag Care 2000;6(4):498–506; quiz 507–8.
Shepperd S, Iliffe S. Hospital at home versus in-patient hospital care (Cochrane Review). The Cochrane Library, Issue 4 2001.
Shitrit D, Heyd J, Raveh D, et al. Diagnostic value of the D-dimer test in deep vein thrombosis: improved results by a new assay method and by using discriminate levels. Thromb Res. 2001;102(2):125-31. [pmid: 11323023].
Silverstein M D, Heit J A, Mohr D N, et al. Trends in the incidence of deep vein thrombosis and pulmonary embolism: a 25-year population-based study. Arch Intern Med. 1998;158(6):585-93. [pmid: 9521222].
Simonneau G, Sors H, Charbonnier B, et al. A comparison of low-molecular-weight heparin with unfractionated heparin for acute pulmonary embolism. The THESEE Study Group. Tinzaparine ou Heparine Standard: Evaluations dans l'Embolie Pulmonaire. N Engl J Med. 1997;337(10):663-9. [pmid: 9278462].
Siragusa S, Cosmi B, Piovella F, et al. Low-molecular-weight heparins and unfractionated heparin in the treatment of patients with acute venous thromboembolism: results of a meta-analysis. Am J Med. 1996;100(3):269-77. [pmid: 8629671].
Smith B J, Weekley J S, Pilotto L, et al. Cost comparison of at-home treatment of deep venous thrombosis with low molecular weight heparin to inpatient treatment with unfractionated heparin. Intern Med J. 2002;32(12):29-34. [pmid: 11783670].
Sostman H D, Layish D T, Tapson V F, et al. Prospective comparison of helical CT and MR imaging in clinically suspected acute pulmonary embolism. J Magn Reson Imaging. 1996;6(2):275-81. [pmid: 9132089].
Spinler S A, Nawarskas J J. Low-molecular-weight heparins for acute coronary syndromes. Ann Pharmacother. 1998;32(1):103-10. [pmid: 9475828].
Stein P D, Goldhaber S Z, Henry J W, et al. Arterial blood gas analysis in the assessment of suspected acute pulmonary embolism. Chest. 1996;109(1):78-81. [pmid: 8549223].
Stein P D, Henry J W, Gopalakrishnan D, et al. Asymmetry of the calves in the assessment of patients with suspected acute pulmonary embolism. Chest. 1995;107(4):936-9. [pmid: 7705157].
Stiell I G, Greenberg G H, McKnight R D, et al. A study to develop clinical decision rules for the use of radiography in acute ankle injuries. Ann Emerg Med. 1992;21(4):384-90. [pmid: 1554175].
Stollberger C, Finsterer J, Lutz W, et al. Multivariate analysis-based prediction rule for pulmonary embolism. Thromb Res. 2000;97(5):267-73. [pmid: 10709901].
Sutton A J, Abrams K R, Jones D R, et al. Systematic reviews of trials and other studies. Health Technol Assess. 1998;2(19):1-276. [pmid: 10347832].
Swensen S J, Sheedy P F 2nd, Ryu J H, et al. Outcomes after withholding anticoagulation from patients with suspected acute pulmonary embolism and negative computed tomographic findings: a cohort study. Mayo Clin Proc. 2002;77(2):130-8. [pmid: 11838646].
Tapson V F, Carroll B A, Davidson B L, et al. The diagnostic approach to acute venous thromboembolism. Clinical practice guideline. American Thoracic Society. Am J Respir Crit Care Med. 1999;160(3):1043-66. [pmid: 10471639].
Tarlov A R, Ware J E Jr, Greenfield S, et al. The Medical Outcomes Study. An application of methods for monitoring the results of medical care. JAMA. 1989;262(7):925-30. [pmid: 2754793].
ten Cate J W, Koopman M M, Prins M H, et al. Treatment of venous thromboembolism. Thromb Haemost. 1995;74(1):197-203. [pmid: 8578457].
Thery C, Simonneau G, Meyer G, et al. Randomized trial of subcutaneous low-molecular-weight heparin CY 216 (Fraxiparine) compared with intravenous unfractionated heparin in the curative treatment of submassive pulmonary embolism. A dose-ranging study. Circulation. 1992;85(4):1380-9. [pmid: 1313340].
Tillman D J, Charland S L, Witt D M. Effectiveness and economic impact associated with a program for outpatient management of acute deep vein thrombosis in a group model health maintenance organization. Arch Intern Med. 2000;160(19):2926-32. [pmid: 11041899].
Undas A, Williams E B, Butenas S, et al. Homocysteine inhibits inactivation of factor Va by activated protein C. J Biol Chem. 2001;276(6):4389-97. [pmid: 11083858].
van Beek E J, Brouwers E M, Song B, et al. Lung scintigraphy and helical computed tomography for the diagnosis of pulmonary embolism: a meta-analysis. Clin Appl Thromb Hemost. 2001;7(2):87-92. [pmid: 11292198].
van den Belt A G, Bossuyt P M, Prins M H, et al. Replacing inpatient care by outpatient care in the treatment of deep venous thrombosis--an economic evaluation. TASMAN Study Group. Thromb Haemost. 1998;79(2):259-63. [pmid: 9493572].
van den Belt AGM, Prins MH, Lensing AWA, et al. Fixed dose subcutaneous low molecular weight heparins versus adjusted dose unfractionated heparin for venous thromboembolism (Cochrane Review). The Cochrane Library, Issue 4, 2001 2000.
van der Heijden D, Hutten BA, Buller HR, et al. Vitamin K antagonists or low-molecular-weight heparin for the long term treatment of symptomatic venous thromboembolism (Cochrane Review). Cochrane Database Syst Rev 2002;(1):CD002001.
van Der Heijden JF, Hutten BA, Buller HR, et al. Vitamin K antagonists or low-molecular-weight heparin for the long term treatment of symptomatic venous thromboembolism. Cochrane Database Syst Rev 2000;(4):CD002001.
van der Heijden J F, Prins M H, Buller H R. For the initial treatment of venous thromboembolism: are all low-molecular-weight heparin compounds the same?. Thromb Res. 2000;100(2):V121-30. [pmid: 11053625].
van der Heijden JF, Prins MH, Buller HR. Low-molecular-weight heparins: are they interchangeable? Haemostasis 2000a;30 Suppl 2:148–57; discussion 146–7.
van Dongen CJ, MacGillavry MR, Prins MH. Once versus twice daily LMWH for the initial treatment of venous thromboembolism (Protocol for a Cochrane Review). The Cochrane Library, Issue 4 2001.
van Rossum A B, Pattynama P M, Mallens W M, et al. Can helical CT replace scintigraphy in the diagnostic process in suspected pulmonary embolism? A retrolective-prolective cohort study focusing on total diagnostic yield. Eur Radiol. 1998;8(1):90-6. [pmid: 9442137].
van Rossum A B, Treurniet F E, Kieft G J, et al. Role of spiral volumetric computed tomographic scanning in the assessment of patients with clinical suspicion of pulmonary embolism and an abnormal ventilation/perfusion lung scan. Thorax. 1996;51(1):23-8. [pmid: 8658363].
Velmahos G C, Vassiliu P, Wilcox A, et al. Spiral computed tomography for the diagnosis of pulmonary embolism in critically ill surgical patients: a comparison with pulmonary angiography. Arch Surg. 2001;136(5):505-11. [pmid: 11343539].
Vine H S, Hillman B, Hessel S J. Deep venous thrombosis: predictive value of signs and symptoms. AJR Am J Roentgenol. 1981;136(1):167-71. [pmid: 6779565].
Vinson D R, Berman D A. Outpatient treatment of deep venous thrombosis: a clinical care pathway managed by the emergency department. Ann Emerg Med. 2001;37(3):251-8. [pmid: 11223760].
Warkentin T E. Heparin-induced thrombocytopenia: a clinicopathologic syndrome. Thromb Haemost. 1999;82(2):439-47. [pmid: 10605735].
Welch G N, Loscalzo J. Homocysteine and atherothrombosis. N Engl J Med. 1998;338(15):1042-50. [pmid: 9535670].
Wells P S, Anderson D R, Bormanis J, et al. Application of a diagnostic clinical model for the management of hospitalized patients with suspected deep-vein thrombosis. Thromb Haemost. 1999;81(4):493-7. [pmid: 10235426].
Wells P S, Anderson D R, Rodger M, et al. Derivation of a simple clinical model to categorize patients probability of pulmonary embolism: increasing the models utility with the SimpliRED D-dimer. Thromb Haemost. 2000;83(3):416-20. [pmid: 10744147].
Wells P S, Anderson D R, Rodger M, et al. Excluding pulmonary embolism at the bedside without diagnostic imaging: management of patients with suspected pulmonary embolism presenting to the emergency department by using a simple clinical model and d-dimer. Ann Intern Med. 2001;135(2):98-107. [pmid: 11453709].
Wells P S, Ginsberg J S, Anderson D R, et al. Use of a clinical model for safe management of patients with suspected pulmonary embolism. Ann Intern Med. 1998;129(12):997-1005. [pmid: 9867786].
Wells P S, Hirsh J, Anderson D R, et al. Accuracy of clinical assessment of deep-vein thrombosis. Lancet. 1995;345(8961):1326-30. [pmid: 7752753].
Wells P S, Hirsh J, Anderson D R, et al. A simple clinical model for the diagnosis of deep-vein thrombosis combined with impedance plethysmography: potential for an improvement in the diagnostic process. J Intern Med. 1998;243(1):15-23. [pmid: 9487327].
Wells P S, Kovacs M J, Bormanis J, et al. Expanding eligibility for outpatient treatment of deep venous thrombosis and pulmonary embolism with low-molecular-weight heparin: a comparison of patient self-injection with homecare injection. Arch Intern Med. 1998;158(16):1809-12. [pmid: 9738611].
Wells P S, Lensing A W, Davidson B L, et al. Accuracy of ultrasound for the diagnosis of deep venous thrombosis in asymptomatic patients after orthopedic surgery. A meta-analysis. Ann Intern Med. 1995;122(1):47-53. [pmid: 7985896].
Wells P S, Anderson D R, Bormanis J, et al. Value of assessment of pretest probability of deep-vein thrombosis in clinical management. Lancet. 1997;350:1795-8. [pmid: 9428249].
White R H, McGahan J P, Daschbach M M, et al. Diagnosis of deep-vein thrombosis using duplex ultrasound. Ann Intern Med. 1989;111(4):297-304. [pmid: 2667418].
Wicki J, Perneger T V, Junod A F, et al. Assessing clinical probability of pulmonary embolism in the emergency ward: a simple score. Arch Intern Med. 2001;161(1):92-7. [pmid: 11146703].
Wildberger J E, Niethammer M U, Klotz E, et al. Multi-slice CT for visualization of pulmonary embolism using perfusion weighted color maps. Rofo Fortschr Geb Rontgenstr Neuen Bildgeb Verfahr. 2001;173(4):289-94. [pmid: 11367835].
Worsley D F, Palevsky H I, Alavi A. A detailed evaluation of patients with acute pulmonary embolism and low- or very-low-probability lung scan interpretations. Arch Intern Med. 1994;154(23):2737-41. [pmid: 7993159].
Zacharski L R, Ornstein D L, Mamourian A C. Low-molecular-weight heparin and cancer. Semin Thromb Hemost. 2000;26(Suppl 1):69-77. [pmid: 11011810].