# Appendix C. Literature Search Strategies

## Question 1 and Question 2 — Low molecular weight heparin for deep venous thrombosis and pulmonary embolism (systematic reviews)

### Medline

(quantitative* OR methodolog* OR systematic* OR meta-analysis OR “metaanalysis” OR “meta analysis” OR “meta-analyses” OR “ metaanalyses” OR “meta analyses” OR (MEDLINE AND review[pt]) OR “clinical conference”[pt] OR “consensus development conference”[pt] OR “guideline”[pt] OR “meta analysis”[pt] OR “practice guideline”[pt] OR ( review [pt] AND systematic*)) AND (deep venous thrombosis OR venous thromboembolism OR pulmonary embolism) AND (low molecular weight heparin OR lmwh OR enoxoparin OR Lovenox OR logiparin OR Innohep OR nadroparin OR fraxoparine OR dalteparin OR Fragmin OR reviparin OR clivarin OR CY222 OR tinzaparin OR innohep OR logiparin OR certoparin OR sandoparin OR embolex OR parnaparin OR fluxum OR clexane OR tedelparin OR Tedral)

### Cochrane

((LOW and (MOLECULAR and (WEIGHT and HEPARIN))) AND ((DVT or PE) OR (VENOUS AND THROMBOSIS)))

## Question 3a. Inpatient versus outpatient (primary literature)

(inpatients OR hospital) AND (ambulatory care OR ambulatory care facility OR outpatient) AND (deep venous thrombosis OR venous thromboembolism OR pulmonary embolism) AND (low molecular weight heparin OR lmwh OR enoxoparin OR Lovenox OR logiparin OR Innohep OR nadroparin OR fraxoparine OR dalteparin OR Fragmin OR reviparin OR clivarin OR CY222 OR tinzaparin OR innohep OR logiparin OR certoparin OR sandoparin OR embolex OR parnaparin OR fluxum OR clexane OR tedelparin OR Tedral)

## Question 3b. Low molecular weight heparin costs (primary literature)

(cost OR charge) AND (low molecular weight heparin OR lmwh OR enoxoparin OR Lovenox OR logiparin OR Innohep OR nadroparin OR fraxoparine OR dalteparin OR Fragmin OR reviparin OR clivarin OR CY222 OR tinzaparin OR innohep OR logiparin OR certoparin OR sandoparin OR embolex OR parnaparin OR fluxum OR clexane OR tedelparin OR Tedral) AND (deep venous thrombosis OR pulmonary embolism OR venous thromboembolism)

## Question 4. Duration of treatment (primary literature)

duration of treatment OR (“time factors/adverse effects” [MESH] OR “time factors/standards”[MESH]) AND (deep vein thrombosis OR pulmonary embolism or venous thromboembolism) AND (warfarin OR coumadin OR low molecular weight heparin)

## Question 5. Clinical prediction rules

(sensitivity AND specificity) AND (deep venous thrombosis or pulmonary embolism and venous thromboembolism) AND clinical

## Question 6. Ultrasound (systematic reviews)

(quantitative* OR methodolog* OR systematic* OR meta-analysis OR “metaanalysis” OR “ meta analysis” OR “meta-analyses” OR “ metaanalyses” OR “meta analyses” OR (MEDLINE AND review[pt]) OR “clinical conference”[pt] OR “consensus development conference”[pt] OR “guideline”[pt] OR “meta analysis”[pt] OR “practice guideline”[pt] OR ( review [pt] AND systematic*)) AND (deep vein thrombosis OR venous thromboembolism) AND (ultrasonography OR ultrasound OR Doppler)

## Question 7. Computerized tomography or magnetic resonance imaging (systematic reviews)

(quantitative* OR methodolog* OR systematic* OR meta-analysis OR “metaanalysis” OR “ meta analysis” OR “meta-analyses” OR “ metaanalyses” OR “meta analyses” OR (MEDLINE AND review[pt]) OR “clinical conference”[pt] OR “consensus development conference”[pt] OR “guideline”[pt] OR “meta analysis”[pt] OR “practice guideline”[pt] OR ( review [pt] AND systematic*)) AND (pulmonary embolism) AND (computed tomography OR magnetic resonance imaging)

### (Primary literature)

evaluation AND pulmonary embolism AND (computed tomography OR magnetic resonance imaging)

## Question 8. D-dimer (systematic reviews)

(quantitative* OR methodolog* OR systematic* OR meta-analysis OR “metaanalysis” OR “ meta analysis” OR “meta-analyses” OR “ metaanalyses” OR “meta analyses” OR (MEDLINE AND review[pt]) OR “clinical conference”[pt] OR “consensus development conference”[pt] OR “guideline”[pt] OR “meta analysis”[pt] OR “practice guideline”[pt] OR ( review [pt] AND systematic*)) AND d-dimer AND (deep venous thrombosis OR pulmonary embolism OR venous thromboembolism)