# Appendix B. Priority Journals for Hand Searching^*^ * Tables of Contents reviewed from 1 October 2001 to 31 March 2002.

Priority Journal Titles
American Journal of Respiratory and Clinical Care Medicine
American Journal of Roentgenology (AJR)
Annals of Internal Medicine
Arteriosclerosis, Thrombosis, and Vascular Biology
Blood
British Journal of Haematology
British Medical Journal
Chest
Circulation
Circulation Research
JAMA
Journal of Computer Assisted Tomography
Journal of Nuclear Medicine
Lancet
Magnetic Resonance Medicine
New England Journal of Medicine
Radiology
Seminars in Nuclear Medicine
Thorax
Thrombosis and Haemostasis